# Appendix B: Exact Search Strings

## Question 1 (RCTs)

The literature search was done on MEDLINE (via OVID) using the following combination of MeSH headings, keywords, and publication types (search results were limited to clinical trials, clinical trials phase I, clinical trials phase II, clinical trials phase III, clinical trials phase IV, controlled clinical trials, meta analyses, or randomized controlled trials):

(aortic aneurysm/ OR aortic aneurysm, abdominal/)

AND

((Blood Vessel Prosthesis/ OR Blood Vessel Prosthesis Implantation/ OR (endovascular repair.mp. OR evar.mp. OR Stents/) OR (vascular surgical procedures/ OR open surgery.mp.))

## Question 2 (Volume)

The literature search was done on MEDLINE (via OVID) using the following combination of MeSH headings, keywords, and publication types (search results were limited to humans, English language, and years 2000-2005):

((hospital.tw. AND volume.tw.) AND ((outcome.mp. AND process assessment health care.sh.) OR outcome.tw. OR (mortality.tw. OR risk.tw. OR quality.tw.)))

AND

(Aortic Aneurysm, Abdominal/)

## Question 4 (Cost)

The literature search (taken from Meenan 2005 [AHRQ report])^17^ was done on MEDLINE (via OVID) using the following combination of MeSH headings and keywords (search results were limited to English language, and years 2000-2005):

(aortic aneurysm, abdominal/ OR (aortic and aneurysm$ and abdom$).ti,ab.)

AND

(ECONOMICS/ OR economics, nursing/ OR economics, pharmaceutical/ OR ec.fs. OR (econom$ or cost or costs or costing or pharmacoeconomic$).ti,ab. OR (expenditure$ not energy).ti,ab. OR “costs and cost analysis”/ OR cost allocation/ OR cost-benefit analysis/ OR cost control/ OR cost savings/ OR cost of illness/ OR cost sharing/ OR “deductibles and coinsurance”/ OR medical savings accounts/ OR health care costs/ OR direct service costs/ OR drug costs/ OR employer health costs/ OR hospital costs/ OR health expenditures/ OR capital expenditures/ OR economics, hospital/ OR hospital charges/ OR hospital costs/ OR economics, medical/ OR fees, medical/)