# Appendix A: Technical Expert Panel Members and Areas of Expertise

TEP Member | Area of Expertise
R. Clement Darling, III, MD | Vascular surgery
Russell Harris, MD, MPH | Internal medicine
Wayne Johnston, MD, FRCSC, FACS | Vascular surgery
Jon S. Matsumura, MD | Vascular surgery