# Appendixes

Appendix A: Technical Expert Panel Members and Areas of Expertise

Appendix B: Exact Search Strings

Appendix C: List of Excluded Studies

Appendix D: Data Extraction Forms

Appendix E: Evidence Tables and Figures