# List of Acronyms/Abbreviations

- | without
# | number
# | number
Δ | change
? | unknown, unclear
+ | with
<p | less than a partial resection
1° | primary
18-FDG | 18-fluorodeoxyglucose
95% CIL | lower limit 95% confidence interval
95% CIU | upper limit 95% confidence interval
A | Asian
A | doxorubicin (Adriamycin®)
abstr | abstract
ACCP | American College of Chest Physicians
AHRQ | Agency for Healthcare Research and Quality
ALT | alanine transaminase
Alt | alternating
AP | anterioposterior
ASCO | American Society of Clinical Oncology
AST | aspartate transaminases
ASTRO | American Society for Therapeutic Radiology and Oncology
B | bilobectomy
B | Black
BSC | best supportive care
c | complete
C | cyclophosphamide
CALGB | Cancer and Leukemia Group B
Cb | carboplatin
CCNU | lomustine
CD | cyclophosphamide- and/or doxorubicin-based chemotherapy
chemoTx | chemotherapy
CI | confidence interval
CNS | central nervous system
Conc | concurrent
cont'd | continued
contr | contralateral
Conv | conventional
CPHM | Cox proportional hazard model
CR | complete response
CT | computed tomography
Ctrl | control
CTx | chemotherapy
d | day
DA | diagnostic accuracy
dist | distant
Dx | diagnosis
E Alt | early alternating
E | etoposide
E | etoposide
ea | each
ECOG | Eastern Cooperative Oncology Group
endosc | endoscopic
EORTC LCCG | European Organization for the Research and Treatment of Cancer Lung Cancer Cooperative Group
EPC | Evidence-based Practice Center
EQ-5D | EuroQOL 5-dimension health-related quality of life instrument
ES | extensive stage
ESD | extensive-stage disease
F | female
F | fractions
F/d | fractions per day
F/U | follow-up
FDA | Food and Drug Administration
FE | fixed effects
FEV1 | forced expiratory volume in 1 second
FN | false negative
FNA | fine-needle aspiration
FP | false positive
Frac(s) | fraction(s)
FWHM | full width, half maximum
GQ | good quality
Gy | Gray
H | Hispanic
HL | hilar
HR | hazard ratio
hr | hour
Hyper | hyperfractionated
ips | ipsilateral
IV | intravenous
K-M | Kaplan-Meier
KPS | Karnofsky Performance Status
L Alt | late alternating
L | lobectomy
L | lomustine
L95 | upper limit 95% confidence interval
LCSG | Lung Cancer Study Group
LDH | lactic dehydrogenase
LINAC | linear accelerator
LN | lymph node
LRFS | local recurrence-free survival
LRFS | local recurrence-free survival
LS | limited stage
LSD | limited-stage disease
M | male
M | methotrexate
MBq | megabecquerel
mCi | milliCurie
md | median
MD | mediastinal
mets | metastases
MeV | megaelectron volt
mg | milligram
M-H | Mantel-Haenszel
MI | myocardial infarction
mn | mean
mo(s). | month(s)
MR | meta regression
MRI | magnetic resonance imaging
MS | mediastinal
N | no
n | number
N | pooled number
NCI | National Cancer Institute
NE | not evaluable
NED | no evidence of disease
neg | negative
NNEC | non-neuroendocrine carcinoma
NNT | number needed to treat
nonrandom. | nonrandomized
NOS | not otherwise specified
NR | not reported
NS | nonsignificant
NSCLC | non-small-cell lung cancer
O | other
OR | odds ratio
ORR | overall response rate
OS | overall survival
P | cisplatin
p | partial
P | pneumonectomy
PA | posterioanterior
PCI | prophylactic cranial radiation
PD | progressive disease
PE | platinum/etoposide chemotherapy
PET | positron emission tomography
PFS | progression-free survival
PI | primary investigator
po | oral
P-OR | Peto odds ratio
pos | positive
PR | partial response
PS | performance status
Pt | platinum
pub | publication
PWIFR | percent/proportion with in-field recurrence
Q | heterogeneity statistic
QoL | quality of life
QUADAS | Quality Assessment of Diagnostic Accuracy Studies
R/I | ruled in
R/O | ruled out
radiol | radiologic
RadioTx | radiotherapy
RCT | randomized, controlled trial
RD | risk difference
RE | random effects
reg | regimen
regl | regional
retrospect | retrospective
RFS | recurrence-free survival
rng | range
RNS | radionuclide scan
ROC | receiver operating characteristic
RR | relative risk
RR | risk ratio
SC | supraclavicular
SC/LC | small-cell/large-cell subtype
SCLC | small cell lung cancer
SD | stable disease
SE | standard error
Sens | sensitivity
Seq | sequential
Spec | specificity
STARD | Standards for Reporting of Diagnostic Accuracy
sup-clav | supraclavicular
supraclav | supraclavicular
surg | surgery
SWOG | Southwest Oncology Group
T | thoracotomy only (open and close)
TN | true negative
TNM | Tumor, Node, Metastasis (staging system)
TP | true positive
TRTx | thoracic radiotherapy
TTF | time to failure
Tx | treatment; therapy
U.S. | United States
U95 | upper limit 95% confidence interval
ULN | upper limit of normal
US | ultrasound
V | vincristine
VC | vital capacity
Ve | vindesine
W | White
WBC | white blood cell
WHO | World Health Organization
wk(s) | week(s)
Wt | weight
XRT | radiotherapy
Y | yes
yr | year

Abbreviations of Combination Chemotherapy Regimens

ACO | doxorubicin, cyclophosphamide, and vincristine
ACOM | doxorubicin, lomustine, methotrexate, vincristine
BTOC | vincristine, thiotepa, cyclophosphamide, carmustine
CAE | cyclophosphamide, doxorubicin, etoposide
CAV | cyclophosphamide, doxorubicin, vincristine
CbE | carboplatin, etoposide
CbPE | carboplatin, cisplatin, etoposide
CC | cyclophosphamide, lomustine
CCM | cyclophosphamide, lomustine, methotrexate
CCMV | cyclophosphamide, lomustine, methotrexate, vincristine
CDE | cyclophosphamide, doxorubicin, etoposide
CE-CAP | cyclophosphamide, doxorubicin, cisplatin
COME | cyclophosphamide, vincristine, methotrexate, etoposide
COMF | cyclophosphamide, vincristine, methotrexate, fluorouracil
CVMP | cyclophosphamide, vincristine, methotrexate, cisplatin
EP | etoposide, platinum compound
LCAE | lomustine, cyclophosphamide, doxorubicin, etoposide
M-CAV | methotrexate, cyclophosphamide, doxorubicin, vincristine
MCCC/VI | methotrexate, cyclophosphamide, lomustine, ifosfamide, etoposide
PE | cisplatin, etoposide
PEVe | platinum, epirubicin, etoposide
PMP | cisplatin, methotrexate, procarbazine
VCMV | vincristine, cyclophosphamide, mitomycin, chromomycin
VIC-E/VICE | vincristine, ifosfamide, carboplatin, etoposide
VIMP | vincristine, ifosfamide, mesna, carboplatin
VIP-E | etoposide, ifosfamide, cisplatin, and epirubicin