# References and Included Studies

Agelaki S, Syrigos K, Christophylakis C, et al. A multicenter phase II study of the combination of irinotecan and gemcitabine in previously treated patients with small-cell lung cancer. Oncology. 2004;66(3):192-6. [pmid: 15218309].
Ahles TA, Silberfarb PM, Rundle AC, et al. Quality of life in patients with limited small-cell carcinoma of the lung receiving chemotherapy with or without radiation therapy, for cancer and leukemia group B. Psychother Psychosom. 1994;62(34):193-9. [pmid: 7846263].
Aisner SC, Finkelstein DM, Ettinger DS, et al. The clinical significance of variant-morphology small-cell carcinoma of the lung. J Clin Oncol. 1990;8(3):402-8. [pmid: 2155311].
Albain KS, Crowley JJ, Hutchins L, et al. Predictors of survival following relapse or progression of small cell lung cancer. Southwest Oncology Group Study 8605 report and analysis of recurrent disease data base. Cancer. 1993;72(4):1184-91. [pmid: 8393365].
Alderson P, Green S, Higgins JPT, eds. Cochrane Reviewers' Handbook 4.2.2 [updated March 2004]. Available online at http://www.cochrane.org/resources/handbook/hbook.htm (accessed November 19, 2004).
American Cancer Society. Cancer Facts and Figures 2005. Atlanta, GA: American Cancer Society, 2005. Available online at http://www.cancer.org/docroot/STT/stt_0.asp. 5 Last accessed June 15, 2005.
American Cancer Society. Detailed guide: lung cancer — What is lung cancer? American Cancer Society, 2004. Available online at http://www.cancer.org/docroot/CRI/content/CRI_2_4_1X_What_is_lung_cancer_26.asp. Last accessed June 15, 2005.
Ando M, Kobayashi K, Yoshimura A, et al. Weekly administration of irinotecan (CPT-11) plus cisplatin for refractory or relapsed small cell lung cancer. Lung Cancer. 2004;44(1):121-7. [pmid: 15013590].
Ardizzoni A, Hansen H, Dombernowsky P, et al. Topotecan, a new active drug in the second-line treatment of small-cell lung cancer: a phase II study in patients with refractory and sensitive disease. The European Organization for Research and Treatment of Cancer Early Clinical Studies Group and New Drug Development Office, and the Lung Cancer Cooperative Group. J Clin Oncol. 1997;15(5):2090-6. [pmid: 9164222].
Ardizzoni A, Manegold C, Debruyne C, et al. European organization for research and treatment of cancer (EORTC) 08957 phase II study of topotecan in combination with cisplatin as second-line treatment of refractory and sensitive small cell lung cancer. Clin Cancer Res. 2003;9(1):143-50. [pmid: 12538462].
Aroney RS, Aisner J, Wesley MN, et al. Value of prophylactic cranial irradiation given at complete remission in small cell lung carcinoma. Cancer Treat Rep. 1983;67:675-82. [pmid: 6307516].
Arriagada R, Le Chevalier T, Borie F, et al. Prophylactic cranial irradiation for patients with small-cell lung cancer in complete remission. J Natl Cancer Inst. 1995;87(3):183-90. [pmid: 7707405].
Arriagada R, Le Chevalier T, Riviere A, et al. Patterns of failure after prophylactic cranial irradiation in small-cell lung cancer: analysis of 505 randomized patients. Ann Oncol. 2002;13(5):748-54. [pmid: 12075744].
Auperin A, Arriagada R, Pignon JP, et al. for the Prophylactic Cranial Irradiation Overview Collaborative Group. Prophylactic cranial irradiation for patients with small-cell lung cancer in complete remission. N Engl J Med. 1999;341:476-84. [pmid: 10441603].
Badzio A, Jassem J, Kurowski K, et al. The impact of primary pulmonary resection on local control and survival in limited disease (LD) small cell lung cancer (SCLC) patients (pts): a retrospective comparative study. Lung Cancer. 2005;49(suppl2):S316. Abstract P-750.
Badzio A, Kurowski K, Karnicka-Mlodkowska H, et al. A retrospective comparative study of surgery followed by chemotherapy vs. non-surgical management in limited-disease small cell lung cancer. Eur J Cardiothorac Surg. 2004;26(1):183-8. [pmid: 15200999].
Berkey CS, Hoaglin DC, Mosteller F, et al. A random-effects regression model for meta-analysis. Stat Med. 1995;14:395-411. [pmid: 7746979].
Blackstock AW, Bogart JA, Matthews C, et al. Split-course versus continuous thoracic radiation therapy for limited-stage small-cell lung cancer: final report of a randomized phase III trial. Clin Lung Cancer. 2005;6(5):287-92. [pmid: 15845179].
Blum R, MacManus MP, Rischin D, et al. Impact of positron emission tomography on the management of patients with small-cell lung cancer: preliminary experience. Am J Clin Oncol. 2004;27(2):164-71. [pmid: 15057156].
Bohrer M, Wenz F. Prophylactic cranial irradiation in limited-disease small-cell lung cancer - why, when, how much?. Onkologie. Feb. 2002;25(1):66-8. [pmid: 11928694].
Bonner JA, Sloan JA, Shanahan TG, et al. Phase III comparison of twice-daily split-course irradiation versus once-daily irradiation for patients with limited stage small-cell lung carcinoma. J Clin Oncol. 1999;17(9):2681-91. [pmid: 10561342].
Bradley JD, Dehdashti F, Mintun MA, et al. Positron emission tomography in limited-stage small-cell lung cancer: a prospective study. J Clin Oncol. 2004;22(16):3248-54. [pmid: 15310768].
Brincker H, Hindberg J, Hansen PV. Cyclic alternating polychemotherapy with or without upper and lower half-body irradiation in small cell anaplastic lung cancer. A randomized study. Eur J Cancer Clin Oncol. 1987;23(2):205-11. [pmid: 2832178].
Brink I, Schumacher T, Mix M, et al. Impact of (18F)FDG-PET on the primary staging of small-cell lung cancer. Eur J Nucl Med Mol Imaging. 2004;31(12):1614-20. [pmid: 15258700].
Cameron RB, Schwartz D. Current concepts in the staging of lung cancer. PPO Updates. 2005;19(1):1-16.
Cancer Care Ontario. The role of thoracic radiotherapy as an adjunct to standard chemotherapy in limited-stage small cell lung cancer: update. 2003 Jan. Available online at http://www.cancercare.on.ca/pdf/full7_13_3.pdf. Last accessed December 2005.
Cao K, Huang H, Tu M. [Clinical study of prophylactic cranial irradiation for small-cell lung cancer]. Zhonghua Zhong Liu Za Zhi. 2000;22(4):336-8. [pmid: 11778566].
Carney DN. Prophylactic cranial irradiation and small-cell lung cancer. N Engl J Med. 1999;341(7):524-6. [pmid: 10441611].
Chin R Jr, McCain TW, Miller AA, et al. Whole body FDG-PET for the evaluation and staging of small cell lung cancer: a preliminary study. Lung Cancer. 2002;37(1):1-6. [pmid: 12057859].
Chua YJ, Steer C, Yip D. Recent advances in management of small-cell lung cancer. Cancer Treat Rev. 2004;30(6):521-43. [pmid: 15325033].
Cochran WG. The combination of estimates from different experiments. Biometrics. 1954;10:101-129.
Cochran WG. Problems arising in the analysis of a series of similar experiments. J R Stat Soc. 1937;Suppl 4(1):102-118.
Coy P, Hodson DI, Murray N, et al. Patterns of failure following loco-regional radiotherapy in the treatment of limited stage small cell lung cancer. Int J Radiat Oncol Biol Phys. 1994;28(2):355-62. [pmid: 8276650].
DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7:177-188. [pmid: 3802833].
Egger M, Davey Smith G, Schneider M, et al. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315(7109):629-34. [pmid: 9310563]. [pmcid: 2127453].
Einhorn LH, Loehrer PJ. Hoosier Oncology Group studies in extensive and recurrent small cell lung cancer. Semin Oncol. 1995;22(1 Suppl 2):28-31. [pmid: 7846539].
Einhorn LH, Pennington K, McClean J. Phase II trial of daily oral VP-16 in refractory small cell lung cancer: a Hoosier Oncology Group study. Semin Oncol. 1990;17(1 Suppl 2):32-5. [pmid: 2154857].
Ettinger DS. Overview and state of the art in the management of lung cancer. Oncology (Huntingt). 2004;18(7 Suppl 4):3-9. [pmid: 15255162].
Faylona EA, Loehrer PJ, Ansari R, et al. Phase II study of daily oral etoposide plus ifosfamide plus cisplatin for previously treated recurrent small-cell lung cancer: a Hoosier Oncology Group Trial. J Clin Oncol. 1995;13(5):1209-14. [pmid: 7738623].
Feld R, Payne D, Hodson I, et al. Complications of treatment of small cell carcinoma of the lung. Experience from a recent Canadian trial. Antibiot Chemother. 1988;41:204-9. [pmid: 2854441].
Fried DB, Morris DE, Poole C, et al. Systematic review evaluating the timing of thoracic radiation therapy in combined modality therapy for limited-stage small-cell lung cancer. J Clin Oncol. 2004;22(23):4837-45. [pmid: 15570087].
Friess GG, McCracken JD, Troxell ML, et al. Effect of initial resection of small-cell carcinoma of the lung: a review of Southwest Oncology Group Study 7628. J Clin Oncol. 1985;3(7):964-8. [pmid: 2991477].
George TK, Fitzgerald D, Brown BS, et al. Long-term survival in limited-stage small cell lung carcinoma. Experience in Rochester, New York from 1975 to 1981. Cancer. 1986;58(6):1193-8. [pmid: 3017533].
Girling DJ, Stott H, Stephens RJ, Fox W. Fifteen-year follow-up of all patients in a study of post-operative chemotherapy for bronchial carcinoma. Br J Cancer. 1985;52(6):867-73. [pmid: 3907687].
Goto K, Nishiwaki Y, Takada M, et al. Final results of a phase III study of concurrent versus sequential thoracic radiotherapy in combination with cisplatin and etoposide for limited-stage small cell lung cancer: the Japanese Clinical Oncology Group Study. Proc Am Soc Clin Oncol. 1999;18:468a.
Graziano SL, Lee K, Propert KJ, et al. Phase II trial of etoposide and cisplatin for refractory small cell lung cancer: a Cancer and Leukemia Group B Study. Med Pediatr Oncol. 1990;18(1):22-6. [pmid: 2152956].
Gregor A, Cull A, Stephens RJ, et al. Prophylactic cranial irradiation is indicated following complete response to induction therapy in small cell lung cancer: results of a multicentre randomised trial. United Kingdom Coordinating Committee for Cancer Research (UKCCCR) and the European Organization for Research and Treatment of Cancer (EORTC). Eur J Cancer. 1997b;33(11):1752-8. [pmid: 9470828].
Gregor A, Drings P, Burghouts J, et al. Randomized trial of alternating versus sequential radiotherapy/chemotherapy in limited-disease patients with small-cell lung cancer: a European Organization for Research and Treatment of Cancer Lung Cancer Cooperative Group Study. J Clin Oncol. 1997a;15(8):2840-9. [pmid: 9256127].
Gridelli C, De Marinis F, Rossi A, et al. A phase II study of VM-26 plus lonidamine in pretreated small cell lung cancer. Anticancer Res. 1997;17(2B):1277-9. [pmid: 9137485].
Groen HJ, Fokkema E, Biesma B, et al. Paclitaxel and carboplatin in the treatment of small-cell lung cancer patients resistant to cyclophosphamide, doxorubicin, and etoposide: a non-cross-resistant schedule. J Clin Oncol. 1999;17(3):927-32. [pmid: 10071286].
Hainsworth JD, Burris HA 3rd, Erland JB, et al. Combination chemotherapy with gemcitabine and vinorelbine in the treatment of patients with relapsed or refractory small cell lung cancer: a phase II trial of the Minnie Pearl Cancer Research Network. Cancer Invest. 2003;21(2):193-9. [pmid: 12743984].
Hara N, Ichinose Y, Kuda T, et al. Long-term survivors in resected and nonresected small cell lung cancer. Oncology. 1991a;48(6):441-7. [pmid: 1660999].
Hara N, Ohta M, Ichinose Y, et al. Influence of surgical resection before and after chemotherapy on survival in small cell lung cancer. J Surg Oncol. 1991b;47(1):53-61. [pmid: 1850811].
Harris RP, Helfand M, Woolf SH, et al. (Methods Work Group, Third US Preventive Services Task Force.) Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
Hauber HP, Bohuslavizki KH, Lund CH, et al. Positron emission tomography in the staging of small-cell lung cancer: a preliminary study. Chest. 2001;119(3):950-4. [pmid: 11243980].
Hoang T, Kim K, Jaslowski A, et al. Phase II study of second-line gemcitabine in sensitive or refractory small cell lung cancer. Lung Cancer. 2003;42(1):97-102. [pmid: 14512193].
Huang Q, Muzitansky A, Mark EJ. Pulmonary neuroendocrine carcinomas. A review of 234 cases and a statistical analysis of 50 cases treated at one institution using a simple clinicopathologic classification. Arch Pathol Lab Med. May. 2002;126(5):545-53. [pmid: 11958659].
Huncharek M, McGarry R. A meta-analysis of the timing of chest irradiation in the combined modality treatment of limited-stage small cell lung cancer. Oncologist. 2004;9(6):665-72. [pmid: 15561810].
Inoue M, Miyoshi S, Yasumitsu T, et al. Surgical results for small cell lung cancer based on the new TNM staging system. Thoracic Surgery Study Group of Osaka University, Osaka, Japan. Ann Thorac Surg. 2000;70(5):1615-9. [pmid: 11093496].
Issell BF, Einhorn LH, Comis RL, et al. Multicenter phase II trial of etoposide in refractory small cell lung cancer. Cancer Treat Rep. 1985;69(1):127-8. [pmid: 2981617].
Iyoda A, Hiroshima K, Baba M, et al. Pulmonary large cell carcinomas with neuroendocrine features are high-grade neuroendocrine tumors. Ann Thorac Surg. 2002;73:1049-1054. [pmid: 11996239].
James LE, Spiro S, O'Donnell KM, et al. A randomised study of timing of thoracic irradiation in small cell lung cancer (SCLC) - study 8. Lung Cancer. 2003;41(Suppl 2):S23. Abstract.
Japan Cooperative Oncology Group on Lung Cancer. Phase II study of carboplatin in patients with nonresected lung cancer. Cancer Chemother Pharmacol. 1990;26(2):101-4. [pmid: 2161295].
Janne PA, Freidlin B, Saxman S, et al. Twenty-five years of clinical research for patients with limited-stage small cell lung carcinoma in North America. Cancer. 2002;95(7):1528-38. [pmid: 12237922].
Jassem J, Karnicka-Mlodkowska H, van Pottelsberghe C, et al. Phase II study of vinorelbine (Navelbine) in previously treated small cell lung cancer patients. EORTC Lung Cancer Cooperative Group. Eur J Cancer. 1993;29A(12):1720-2. [pmid: 8398301].
Jeremic B, Shibamoto Y, Acimovic L, et al. Initial versus delayed accelerated hyperfractionated radiation therapy and concurrent chemotherapy in limited small-cell lung cancer: a randomized study. J Clin Oncol. 1997;15(3):893-900. [pmid: 9060525].
Jeremic B, Shibamoto Y, Nikolic N, et al. Role of radiation therapy in the combined-modality treatment of patients with extensive disease small-cell lung cancer: A randomized study. J Clin Oncol. 1999;17(7):2092-9. [pmid: 10561263].
Johnson BE, Ihde DC, Bunn PA, et al. Patients with small-cell lung cancer treated with combination chemotherapy with or without irradiation. Data on potential cures, chronic toxicities, and late relapses after a five- to eleven-year follow-up. Ann Intern Med. 1985;103(3):430-8. [pmid: 2992337].
Kakolyris S, Mavroudis D, Tsavaris N, et al. Paclitaxel in combination with carboplatin as salvage treatment in refractory small-cell lung cancer (SCLC): a multicenter phase II study. Ann Oncol. 2001;12(2):193-7. [pmid: 11300323].
Kamel EM, Zwahlen D, Wyss MT, et al. Whole-body (18)F-FDG PET improves the management of patients with small cell lung cancer. J Nucl Med. 2003;44(12):1911-7. [pmid: 14660716].
Karrer K, Denck H, Drings P, Orel J, Bruno MF. Combination of surgery and chemotherapy for small-cell bronchial carcinoma. Drugs Exp Clin Res. 1986;12(13):191-200. [pmid: 3015543].
Karrer K, Denck H, Karnicka-Mlodkowska H, et al. Surgery for cure followed by combined modality treatment for small cell bronchial carcinoma. ISC Lung Cancer Study Group. Int J Clin Pharmacol Res. 1988;8(6):415-21. [pmid: 2855325].
Karrer K, Denck H, Karnicka-Mlodkowska H, et al. The importance of surgery as the first step in multimodality treatment of small cell bronchial carcinoma. The ISC Lung Cancer Study Group. Int J Clin Pharmacol Res. 1990;10(5):257-63. [pmid: 1964153].
Karrer K, Denck H, Karnicka-Mlodkowska H, et al. The role of ifosfamide and cyclophosphamide in the multi-modality treatment after surgery for cure for small-cell bronchial carcinomas (SCLC). Med Oncol Tumor Pharmacother. 1989;6(2):143-9. [pmid: 2545979].
Karrer K, Shields TW, Denck H, Hrabar B, Vogt-Moykopf I, Salzer GM. The importance of surgical and multimodality treatment for small cell bronchial carcinoma. J Thorac Cardiovasc Surg. 1989;97(2):168-76. [pmid: 2536867].
Karrer K, Ulsperger E. Surgery for cure followed by chemotherapy in small cell carcinoma of the lung. For the ISC-Lung Cancer Study Group. Acta Oncol. 1995;34(7):899-906. [pmid: 7492378].
Karrer K. Surgery in SCLC as first step of multimodality treatment. Anticancer Res. 1994;14(1B):327-31. [pmid: 8166477].
Kosmas C, Tsavaris NB, Malamos NA, et al. Phase II study of paclitaxel, ifosfamide, and cisplatin as second-line treatment in relapsed small-cell lung cancer. J Clin Oncol. 2001;19(1):119-26. [pmid: 11134204].
Lad T, Piantadosi S, Thomas P, et al. A prospective randomized trial to determine the benefit of surgical resection of residual disease following response of small cell lung cancer to combination chemotherapy. Chest. 1994;106(6 Suppl):320S-3S. [pmid: 7988254].
Laplanche A, Monnet I, Santos-Miranda JA, et al. Controlled clinical trial of prophylactic cranial irradiation for patients with small-cell lung cancer in complete remission. Lung Cancer. 1998;21(3):193-201. [pmid: 9857997].
Laplanche A, Monnet I, Santos-Miranda JA, et al. Controlled clinical trial of prophylactic cranial irradiation for patients with small-cell lung cancer in complete remission. Lung Cancer. 1998;21(3):193-201. [pmid: 9857997].
Lebeau B, Chastang C, Brechot JM, et al. A randomized trial of delayed thoracic radiotherapy in complete responder patients with small-cell lung cancer. Petites Cellules Group. Chest. 1993;104(3):726-33. [pmid: 8396000].
Lebeau B, Urban T, Brechot JM, et al. A randomized clinical trial comparing concurrent and alternating thoracic irradiation for patients with limited small cell lung carcinoma. “Petites Cellules” Group. Cancer. 1999;86(8):1480-7. [pmid: 10526276].
Liao M, Zhao J, Zhou Y. [Multimodality therapy of late stage lung cancer]. Zhonghua Zhong Liu Za Zhi. 1995;17(5):384-6. [pmid: 8697983].
Livingston RB, Mira JG, Chen TT, et al. Combined modality treatment of extensive small cell lung cancer: a Southwest Oncology Group study. J Clin Oncol. Jun. 1984;2(6):585-90. [pmid: 6327927].
Livingston RB, Schulman S, Mira JG, et al. Combined alkylators and multiple-site irradiation for extensive small cell lung cancer: a Southwest Oncology Group Study. Cancer Treat Rep. Dec. 1986;70(12):1395-401. [pmid: 3024826].
Masters GA, Declerck L, Blanke C, et al. Phase II trial of gemcitabine in refractory or relapsed small-cell lung cancer: Eastern Cooperative Oncology Group Trial 1597. J Clin Oncol. 2003;21(8):1550-5. [pmid: 12697880].
Murray N, Coy P, Pater JL, et al. Importance of timing for thoracic irradiation in the combined modality treatment of limited-stage small-cell lung cancer. The National Cancer Institute of Canada Clinical Trials Group. J Clin Oncol. 1993;11(2):336-44. [pmid: 8381164].
Murren J, Glatstein E, Pass HI. Small cell lung cancer. In: DeVita VT, Jr, Hellman S, Rosenberg SA, editors. Cancer: principles and practice of oncology. 6th edition. Philadelphia: Lippincott, Williams & Wilkins; 2001. p. 983–1018.
Murren JR, Turrisi AT, Pass HI. Small cell lung cancer. In: DeVita VT, Jr, Hellman S, Rosenberg SA, editors. Cancer: principles and practice of oncology. 7th edition. Philadelphia: Lippincott, Williams & Wilkins; 2005. p. 810–843.
Namikawa S, Den T, Kimura M, et al. The role of surgical resection and the effects of neo-adjuvant therapy in the management of small cell lung cancer. Surg Today. 1994;24(4):342-6. [pmid: 8038511].
Niiranen A, Holsti P, Salmo M. Treatment of small cell lung cancer. Two-drug versus four-drug chemotherapy and loco-regional irradiation with or without prophylactic cranial irradiation. Acta Oncol. 1989;28(4):501-5. [pmid: 2551355].
Nou E, Brodin O, Bergh J. A randomized study of radiation treatment in small cell bronchial carcinoma treated with two types of four-drug chemotherapy regimens. Cancer. 1988;62(6):1079-90. [pmid: 2457422].
O'Brien M, Ciuleanu T, Tsekov H, et al. Survival benefit of oral topotecan plus supportive care versus supportive care alone in relapsed, resistant SCLC. Lung Cancer. 2005;49(suppl 2):S54. Abstract -157.
O'Bryan RM, Crowley JJ, Kim PN, et al. Comparison of etoposide and cisplatin with bis-chloro-ethylnitrosourea, thiotepa, vincristine, and cyclophosphamide for salvage treatment in small cell lung cancer. A Southwest Oncology Group Study. Cancer. 1990;65(4):856-60. [pmid: 2153435].
Ohnoshi T, Hiraki S, Ueda N, et al. Long-term results of combination chemotherapy with or without irradiation in small cell lung cancer: a 5- to 11-year follow-up. Intern Med. 1993;32(3):215-20. [pmid: 8392405].
Ohonoshi T, Ueoka H, Kawahara S, et al. Comparative study of prophylactic cranial irradiation in patients with small cell lung cancer achieving a complete response: a long-term follow-up result. Lung Cancer. 1993;10(12):47-54. [pmid: 8069603].
Osterlind K. Chemotherapy in small cell lung cancer. Eur Respir J. Dec. 2001;18(6):1026-43. [pmid: 11829085].
Osterlind K, Hansen M, Hansen HH, et al. Treatment policy of surgery in small cell carcinoma of the lung: retrospective analysis of a series of 874 consecutive patients. Thorax. 1985;40(4):272-7. [pmid: 2992111]. [pmcid: 460045].
Park SK, Kim GH, Jeong SS, et al. The effects according to the timing of thoracic radiotherapy in limited stage small cell lung cancer. Tuberc Respir Dis. 1996;43:903-15.
Perry MC, Eaton WL, Propert KJ, et al. Chemotherapy with or without radiation therapy in limited small-cell carcinoma of the lung. N Engl J Med. 1987;316(15):912-8. [pmid: 3029592].
Perry MC, Herndon JE 3rd, Eaton WL, et al. Thoracic radiation therapy added to chemotherapy for small-cell lung cancer: an update of Cancer and Leukemia Group B Study 8083. J Clin Oncol. 1998;16(7):2466-7. [pmid: 9667265].
Physicians Data Query (PDQ). Small cell lung cancer treatment (health professional version). U.S. National Cancer Institute, National Institutes of Health; last modified 05/17/2005; accessed on 6/15/2005. Available online at: http://cancernet.nci.nih.gov/cancertopics/pdq/treatment/small-cell-lung/healthprofessional
Pignon JP, Arriagada R, Ihde DC, et al. A meta-analysis of thoracic radiotherapy for small-cell lung cancer. N Engl J Med. Dec 3. 1992;327(23):1618-24. [pmid: 1331787].
Pijls-Johannesma MCG, De Ruysscher D, Lambin P, et al. Early versus late chest radiotherapy for limited stage small cell lung cancer. The Cochrane Database of Systematic Reviews 2004, Issue 4. Art. No.: CD004700. DOI: 10.1002/14651858.CD004700.pub2.
Pirogov AI, Polotskii BE, Al-Ansari N, et al. [Clinical evaluation of the small-cell and poorly differentiated forms of squamous-cell and glandular lung cancers]. Vopr Onkol. 1989;35(2):154-8. [pmid: 2467441].
Postmus PE, Smit EF, Kirkpatrick A, et al. Testing the possible non-cross resistance of two equipotent combination chemotherapy regimens against small-cell lung cancer: a phase II study of the EORTC Lung Cancer Cooperative Group. Eur J Cancer. 1993;29A(2):204-7. [pmid: 8380697].
Prophylactic Cranial Irradiation Overview Collaborative Group. Cranial irradiation for preventing brain metastases of small cell lung cancer in patients in complete remission. Cochrane Database Syst Rev. 2000;(4):CD002805.
Qiao TK, Zhou DA, Xin L, et al. [Concurrent radiotherapy combined with carboplatin and etoposide in limited stage small cell lung cancer]. Zhonghua Jie He He Hu Xi Za Zhi. 2004;27(4):237-9. [pmid: 15144613].
Ronze S, Noel G, Mazeron JJ. [A randomized clinical trial comparing concurrent and alternating thoracic irradiation for patients with limited small cell lung carcinoma]. Cancer Radiother. 2000;4(4):325-6. [pmid: 10994401].
Rosenthal MA, Tattersall MHN, Fox RM, et al. Adjuvant thoracic radiotherapy in small cell lung cancer: Ten-year follow-up of a randomized study. Lung Cancer. 1991;7(4):235-41.
Rostad H, Naalsund A, Jacobsen R, et al. Small cell lung cancer in Norway: should more patients have been offered surgical therapy?. Eur J Cardiothorac Surg. Oct. 2004;26(4):782-6. [pmid: 15450573].
Ruffini E, Rena O, Oliaro A, et al. Lung tumors with mixed histologic pattern. Clinico-pathologic characteristics and prognostic significance. Eur J Cardiothorac Surg. 2002;22(5):701-7. [pmid: 12414033].
Schamanek A, Karrer K. Importance of surgery in the multimodality treatment for small cell lung cancer (SCLC). Radiol Oncol. 1994;28:351-8.
Schild SE, Bonner JA, Shanahan TG, et al. Long-term results of a phase III trial comparing once-daily radiotherapy with twice-daily radiotherapy in limited-stage small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2004;59(4):943-51. [pmid: 15234027].
Schumacher T, Brink I, Mix M, et al. FDG-PET imaging for the staging and follow-up of small cell lung cancer. Eur J Nucl Med. 2001;28(4):483-8. [pmid: 11357499].
Sculier JP, Lafitte JJ, Lecomte J, et al. A phase II randomised trial comparing the cisplatin-etoposide combination chemotherapy with or without carboplatin as second-line therapy for small-cell lung cancer. Ann Oncol. 2002;13(9):1454-9. [pmid: 12196372].
Sculier JP, Thiriaux J, Bureau G, et al. A phase II study testing weekly platinum derivative combination chemotherapy as second-line treatment in patients with advanced small cell lung cancer. Int J Oncol. 1995;6(2):425-9. [pmid: 21556555].
Sessa C, Wanders J, Roelvink M, et al. Second-line treatment of small-cell lung cancer with the camptothecin-derivative GI147211: a study of the EORTC Early Clinical Studies Group (ECSG). Ann Oncol. 2000;11(2):207-10. [pmid: 10761757].
Seydel HG, Creech R, Pagano M, et al. Prophylactic versus no brain irradiation in regional small cell lung carcinoma. Am J Clin Oncol. 1985;8(3):218-23. [pmid: 2996327].
Shen YY, Shiau YC, Wang JJ, et al. Whole-body 18F-2-deoxyglucose positron emission tomography in primary staging small cell lung cancer. Anticancer Res. 2002;22(2B):1257-64. [pmid: 12168935].
Shepherd FA, Ginsberg RJ, Feld R, et al. Surgical treatment for limited small-cell lung cancer. The University of Toronto Lung Oncology Group experience. J Thorac Cardiovasc Surg. 1991;101(3):385-93. [pmid: 1847981].
Shepherd FA, Ginsberg RJ, Haddad R, et al. Importance of clinical staging in limited small-cell lung cancer: a valuable system to separate prognostic subgroups. The University of Toronto Lung Oncology Group. J Clin Oncol. 1993;11(8):1592-7. [pmid: 8393098].
Shepherd FA, Ginsberg RJ, Patterson GA, et al. A prospective study of adjuvant surgical resection after chemotherapy for limited small cell lung cancer. A University of Toronto Lung Oncology Group study. J Thorac Cardiovasc Surg. 1989;97(2):177-86. [pmid: 2536868].
Simon GR, Wagner H. for the American College of Chest Physicians. Small cell lung cancer. Chest. 2003;123(1 Suppl):259S-271S. [pmid: 12527584].
Skarlos DV, Samantas E, Briassoulis E, et al. Randomized comparison of early versus late hyperfractionated thoracic irradiation concurrently with chemotherapy in limited disease small-cell lung cancer: a randomized phase II study of the Hellenic Cooperative Oncology Group (HeCOG). Ann Oncol. 2001;12(9):1231-8. [pmid: 11697833].
Sloan JA, Bonner JA, Hillman SL, et al. A quality-adjusted reanalysis of a Phase III trial comparing once-daily thoracic radiation vs. twice-daily thoracic radiation in patients with limited-stage small-cell lung cancer(1). Int J Radiat Oncol Biol Phys. 2002;52(2):371-81. [pmid: 11872282].
Smyth JF, Smith IE, Sessa C, et al. Activity of docetaxel (Taxotere) in small cell lung cancer. The Early Clinical Trials Group of the EORTC. Eur J Cancer. 1994;30A(8):1058-60. [pmid: 7654428].
Smythe WR, Estrera AL, Swisher SG, et al. Surgical resection of non-small cell carcinoma after treatment for small cell carcinoma. Ann Thorac Surg. 2001;71(3):962-6. [pmid: 11269481].
Sonpavde G, Ansari R, Walker P, et al. Phase II study of doxorubicin and paclitaxel as second-line chemotherapy of small-cell lung cancer: a Hoosier Oncology Group Trial. Am J Clin Oncol. 2000;23(1):68-70. [pmid: 10683082].
Spiro SG, Souhami RL, Geddes DM, et al. Duration of chemotherapy in small cell lung cancer: a Cancer Research Campaign trial. Br J Cancer. Apr. 1989;59(4):578-83. [pmid: 2540788].
Stupp R, Monnerat C, Turrisi AT 3rd, et al. Small cell lung cancer: state of the art and future perspectives. Lung Cancer. 2004;45(1):105-17. [pmid: 15196740].
Sun Y, Zhang XR, Yin WB, et al. Prospective multimodality treatment of SCLC--experience during the past 18 years. Gan To Kagaku Ryoho. 1995;22(Suppl 3):222-5. [pmid: 7661586].
Sutton AJ, Abrams KR, Jones DR, et al. Methods for meta-analysis in medical research. John Wiley & Sons; West Sussex, England, 2000. p. 73–86.
Takada M, Fukuoka M, Kawahara M, et al. Phase III study of concurrent versus sequential thoracic radiotherapy in combination with cisplatin and etoposide for limited-stage small-cell lung cancer: results of the Japan Clinical Oncology Group Study 9104. J Clin Oncol. 2002;20(14):3054-60. [pmid: 12118018].
The Prophylactic Cranial Irradiation Overview Collaborative Group. Cranial irradiation for preventing brain metastases of small cell lung cancer in patients in complete remission. The Cochrane Database of Systematic Reviews 2000, Issue 4. Art. No.: CD002805. DOI: 10.1002/14651858.CD002805.
Theuer W, Selawry O, Karrer K. The impact of surgery on the multidisciplinary treatment of bronchogenic small cell carcinoma (updated review including ongoing studies). Med Oncol Tumor Pharmacother. 1992;9(3):119-37. [pmid: 1341324].
Trillet-Lenoir V, Lasset C, Arpin D, et al. [Comparison of 2 cisplatin and etoposide dosages in relapsing small cell lung cancer]. Bull Cancer. 1992;79(12):1173-81. [pmid: 1339011].
Turrisi AT 3rd. Platinum combined with radiation therapy in small cell lung cancer: focusing like a laser beam on crucial issues. Semin Oncol. Jun. 1994;21(3 Suppl 6):36-42. [pmid: 8052872].
Turrisi AT 3rd, Glover DJ. Thoracic radiotherapy variables: influence on local control in small cell lung cancer limited disease. Int J Radiat Oncol Biol Phys. 1990;19(6):1473-9. [pmid: 2175739].
Turrisi AT 3rd, Kim K, Blum R, et al. Twice-daily compared with once-daily thoracic radiotherapy in limited small-cell lung cancer treated concurrently with cisplatin and etoposide. N Engl J Med. 1999;340(4):265-71. [pmid: 9920950].
van der Lee I, Smit EF, van Putten JW, et al. Single-agent gemcitabine in patients with resistant small-cell lung cancer. Ann Oncol. 2001;12(4):557-61. [pmid: 11398892].
von Pawel J, Gatzemeier U, Pujol JL, et al. Phase ii comparator study of oral versus intravenous topotecan in patients with chemosensitive small-cell lung cancer. J Clin Oncol. 2001;19(6):1743-9. [pmid: 11251005].
von Pawel J, Schiller JH, Shepherd FA, et al. Topotecan versus cyclophosphamide, doxorubicin, and vincristine for the treatment of recurrent small-cell lung cancer. J Clin Oncol. 1999;17(2):658-67. [pmid: 10080612].
Waddell TK, Shepherd FA. Should aggressive surgery ever be part of the management of small cell lung cancer?. Thorac Surg Clin. 2004;14(2):271-81. [pmid: 15382303].
Wagner H, Kim K, Turrisi A, et al. for the Eastern Cooperative Oncology Group, Radiation Therapy Oncology Group. A randomized phase III study of prophylactic cranial irradiation versus observation in patients with small cell lung cancer achieving a complete response: Final report of an incomplete trial. Proceedings of the American Society of Clinical Oncology. 1996;15:376.
Warde P, Payne D. Does thoracic irradiation improve survival and local control in limited-stage small-cell carcinoma of the lung? A meta-analysis. J Clin Oncol. Jun. 1992;10(6):890-5. [pmid: 1316951].
Whiting P, Rutjes AWS, Dinnes J, et al. Development and validation of methods for assessing the quality of diagnostic accuracy studies. Health Technol Assess. 2004;8(25):1-234.
Wolff SN, Birch R, Sarma P, et al. Randomized dose-response evaluation of etoposide in small cell carcinoma of the lung: a Southeastern Cancer Study Group Trial. Cancer Treat Rep. 1986;70(5):583-7. [pmid: 3011257].
Work E, Bentzen SM, Nielsen OS, et al. Prophylactic cranial irradiation in limited stage small cell lung cancer: survival benefit in patients with favourable characteristics. Eur J Cancer. 1996;32A(5):772-8. [pmid: 9081352].
Work E, Nielsen OS, Bentzen SM, et al. Randomized study of initial versus late chest irradiation combined with chemotherapy in limited-stage small-cell lung cancer. Aarhus Lung Cancer Group. J Clin Oncol. 1997;15(9):3030-7. [pmid: 9294465].
Yoshikawa K, Tsubota N, Kodama K, et al. Prospective study of extended segmentectomy for small lung tumors: the final report. Ann Thorac Surg. 2002;73(4):1055-8. [pmid: 11996240].
Yuen AR, Zou G, Turrisi AT, et al. Similar outcome of elderly patients in intergroup trial 0096: Cisplatin, etoposide, and thoracic radiotherapy administered once or twice daily in limited stage small cell lung carcinoma. Cancer. 2000;89(9):1953-60. [pmid: 11064352].