# Executive Summary

## Introduction

Small-cell lung cancer (SCLC) accounts for 13–20 percent of the 172,570 new cases and 163,510 deaths from lung cancer expected in the U.S. in 2005 (American Cancer Society, 2005; Murren, Glatstein, and Pass, 2001; Simon and Wagner, 2003; Physicians Data Query 2005; Chua, Steer, and Yip, 2004; Ettinger, 2004; Stupp, Monnerat, Turrisi, et al., 2004). Untreated SCLC is aggressive, with a median survival of 2 to 4 months after diagnosis (Physicians Data Query, 2005).

The American College of Chest Physicians (ACCP), nominated SCLC as a topic for an evidence report to support updating of its 2003 guideline. Consultation with technical experts, some nominated by ACCP, identified nine key issues in need of systematic review:

1 For limited-stage SCLC, what are the relative benefits and harms (survival, toxicity, and quality of life) of thoracic radiotherapy (TRTx) combined with chemotherapy either in alternating fashion, concurrently or sequentially?
2 For limited-stage SCLC, do outcomes (survival, toxicity, or quality of life) differ if concurrent TRTx is given in early versus late chemotherapy cycles?
3 For limited-stage SCLC, do outcomes (survival, toxicity, quality of life) of primary therapy differ if one varies dose rate, treatment interval, or fractionation scheme for delivering TRTx? Comparisons of interest include:
  - accelerated regimens (>10 Gy per week completed over a short interval) versus standard duration regimens (<10 Gy per week) versus split courses delivered over the standard interval; and
  - single daily fractions versus hyperfractionated (two or more daily fractions or concomitant boost).
4 What are the relative benefits and harms (survival, toxicity, and quality of life) of adding TRTx to chemotherapy for primary treatment of extensive-stage SCLC?
5 What are the benefits and harms (survival, toxicity and quality of life) of prophylactic cranial irradiation (PCI)?
6 Does the addition of positron emission tomography (PET) scanning improve the accuracy of staging for patients diagnosed with SCLC, over the use of other techniques, including computed tomography (CT) and magnetic resonance imaging (MRI), without PET?
7 What are the outcomes (survival, toxicity and quality of life) of treatments used to manage patients with mixed small cell/non-small cell lung cancers?
8 What is the role of surgery and what is its impact on survival in patients with early stage SCLC? How do available studies define early stage SCLC?
9 What are the outcomes of second- or subsequent-line therapy in patients with relapsed or progressive SCLC? Where available data permit, patients with limited- and extensive-stage disease will be addressed separately, as will those with refractory disease (relapse or progression within 3 months of primary treatment).

## Methods

The review methods were defined prospectively in a written protocol. A technical expert group provided consultation. The draft report was also reviewed by other experts and stakeholders.

Primary outcomes include: duration of survival, disease- or progression-free survival; quality of life; brain metastasis; and adverse events. Secondary outcomes include: response rates; response duration; and recurrence. For key question 6 (PET staging) additional outcomes are diagnostic accuracy and changes in patient management.

Electronic database searches of MEDLINE (through 12/21/04), EMBASE (through 3/04/05), and the Cochrane Controlled Trials Register (through 3/11/05).were conducted. The search was not limited to English language, but foreign-language references without abstracts were excluded. Relevant conference proceedings were searched electronically.

We sought randomized, controlled trials (RCTs) that compared the interventions of interest. Where randomized trials were limited or nonexistent, we sought additional studies. For question 8 (surgery), we also sought nonrandomized comparative trials, prospective or retrospective. For question 9 (second- or subsequent line therapy), we also sought phase II multicenter studies reporting on at least 25 patients. For question 6 (PET staging), we sought single-arm trials that permitted computation of specificity and sensitivity in relation to an appropriate reference standard.

A single reviewer screened titles and abstracts for full-text retrieval; citations marked as uncertain were reviewed by a second reviewer. Review of full-text articles was conducted in the same fashion to determine inclusion in the systematic review. One reviewer performed primary data abstraction and a second reviewer reviewed the evidence tables for accuracy. All disagreements were resolved by consensus.

The general approach to assessing quality of evidence from studies of therapeutic interventions developed by the U.S. Preventive Services Task Force (Harris, Helfand, Woolf, et al., 2001) was applied. For diagnostic studies, we used the Quality Assessment of Diagnostic Accuracy Studies (QUADAS) tool.

We performed meta-analysis that combined studies included in key questions 1 and 2. The metrics were 2-year and 3-year mortality relative risks (RRs). Publication bias was tested using Egger's linear regression (Egger, Davey Smith, Schneider, et al., 1997). A standard test for heterogeneity, the Q statistic, was used (Cochran, 1954). If significant, the combined RR point estimate was computed with a random effects (RE) model (DerSimonian and Laird, 1986). If not, a fixed effects (FE) model would be used (Cochran, 1937). Pooled estimates of treatment effects were derived using the inverse variance-weighted method (Cochran, 1937). Subgroup/sensitivity analyses were performed for earliest initiation of TRTx, hyperfractionation; platinum chemotherapy; concurrent TRTx; and study quality. Analyses were performed using STATA 9.0 and Microsoft Excel 2002.

## Results

1. For limited-stage SCLC, what are the relative benefits and harms of TRTx combined with chemotherapy either in alternating fashion, concurrently, or sequentially?

One multicenter trial and one single-center trial (n=307) compared concurrent and sequential TRTx. Results are not conclusive but suggest better outcomes for concurrent TRTx. Overall survival adjusted for confounders significantly favored concurrent TRTx in the Takada, Fukuoka, Kawahara, et al. trial (2002; n=228), although unadjusted results were not significant. Additionally, the Park, Kim, Jeong, et al. (1996) trial found significantly longer response duration for concurrent TRTx. Of 11 types of adverse events reported, only leukopenia occurred significantly more frequently in the concurrent TRTx group in both studies.

No conclusions could be drawn on alternating TRTx. No significant differences in overall or progression-free survival were found in any of four trials: two (n=458) comparisons to sequential TRTx; one (n=156) comparison concurrent TRTx; and one (n=199) comparison of early and late alternating TRTx.

2. For limited-stage SCLC, do outcomes differ if concurrent TRTx is given in early versus late chemotherapy cycles?

The evidence is equivocal, finding no difference or small advantage for early concurrent TRTx. One large multicenter trial of good quality significantly favored concurrent therapy given in an early cycle (Murray, Coy, Pater, et al., 1993/Coy, Hodson, Murray, et al., 1994/Feld, Payne, Hodson, et al., 1988), as did 2 smaller trials. Of the two large multicenter trials that found no significant difference in survival, one did not use platinum chemotherapy (Perry, Eaton, Propert, et al., 1987/Ahles, Silberfarb, Rundle, et al., 1994/Perry, Herndon, Eaton, et al., 1988) and the other is published only in abstract (James, Spiro, O'Donnell, et al., 2003). Leukopenia/neutropenia appeared to be more common with early TRTx.

Meta-analysis was performed in an attempt to obtain clearer results. Studies selected for Key Questions 1 and 2 were viewed as comparing early and late TRTx, and were pooled to give a more robust analysis. We did not find statistically significant reductions in 2- and 3-year mortality for early TRTx over late TRTx. The relative risk (RR) at 2 years was 0.921 (95 percent CI: 0.844–1.005) and the RR at 3 years was 0.991 (95 percent CI: 0.955–1.029).

3. For limited-stage SCLC, do outcomes (survival, toxicity, quality of life) of primary therapy differ if one varies dose rate, treatment interval, or fractionation scheme for delivering TRTx?

Evidence to compare dose rates, treatment intervals, or fractionation schemes is limited. Two RCTs compared one versus two fractions a day for previously untreated SCLC. One compared an accelerated regimen versus the standard duration, while the other compared a split-course regimen versus the standard duration.

Compared to a single daily fraction, two daily fractions delivered concurrently with platinum chemotherapy improved overall survival (23 vs. 19 months, log rank p=0.04) in a large multicenter trial of good quality (Turrisi, Kim, Blum, et al., 1999/Yuen, Zou, Turrisi, et al., 2000; n=417). The second trial is difficult to interpret, since multiple variables were studied simultaneously (Schild, Bonner, Shanahan, et al., 2004/Sloan, Bonner, Hillman, et al., 2002/Bonner, Sloan, Shanahan, et al., 1999; n=161), but there was no difference in survival with one versus two fractions per day.

Esophagitis was more frequent with two fractions daily.

4. What are the relative benefits and harms (survival, toxicity, and quality of life) of adding thoracic radiation therapy to chemotherapy for primary treatment of extensive-stage SCLC?

One single-center RCT (Jeremic, Shibamoto, Nikolic, et al., 1999; n=99) suggests that adding concurrent TRTx improves survival of patients with extensive-stage disease that responds to an initial three cycles of platinum/etoposide chemotherapy with a complete response (CR) outside the thorax and at least a partial response in the thorax. Uncontrolled data from the same trial suggest little to no benefit for other patients. Grades 3/4 esophagitis were more common with TRTx.

5. What are the benefits and harms (survival, toxicity and quality of life) of prophylactic cranial irradiation?

An individual patient data meta-analysis on seven RCTs (N=987) conducted by the Cochrane PCI Overview Collaborative Group shows that PCI improves survival of SCLC patients in CR after primary therapy. PCI increases 3-year survival from 15.3 percent to 20.7 percent (p=0.01), an absolute increase of 5.4 percent. PCI also significantly decreases the risk for brain metastasis and increases the likelihood of disease-free survival. The sole trial reported after the meta-analysis generally agrees with these findings.

Subgroup analyses showed that PCI significantly decreases brain metastases for SCLC patients in CR regardless of age, disease stage or performance status at diagnosis, and whether or not TRTx is part of the induction regimen. Survival benefit does not appear to differ among subgroups.

Additional subgroup analyses suggested that increasing the PCI dose from 8 to 40 Gy and starting PCI within the first 6 months after achieving complete response may reduce the likelihood of brain metastases. However, these hypotheses, derived from subgroup analyses, require formal testing in RCTs.

Although data are scant, acute toxicities of PCI seem tolerable at the doses used in these trials (8–40 Gy in 1.8 to 3 Gy fractions) and neurocognitive deficits no greater than existed prior to PCI.

6. Does the addition of PET scanning improve the accuracy of staging for patients with SCLC over the use of other techniques, including CT and MRI, without PET?

The evidence is limited and of poor quality, thus no conclusions can be drawn. Six studies (N=277) suggest that, except for brain metastases, PET added to conventional staging is more sensitive in detecting disease. However, there is so much uncertainty about the execution and interpretation of the reference standard in all of these studies that confidence is quite low in estimates of diagnostic and staging accuracy. The frequency of incorrect changes in stage attributable to PET is unknown due to incomplete reporting.

7. What are the outcomes (survival, toxicity and quality of life) of treatments used to manage patients with mixed small cell/non-small cell lung cancers?

There are few studies of any design that included patients with mixed histology. No conclusions can be drawn from the available evidence.

8. What is the role of surgery and what is its impact on survival in patients with early stage SCLC? How do available studies define early stage SCLC?

We sought studies that compared surgery to no surgery in patients with very early limited SCLC, defined as no preoperative evidence of involved nodes (clinically NO). Two randomized controlled trials and 8 nonrandomized comparative studies were reviewed. None studied a homogeneous group of patients with respect to nodal status; nor were separate outcomes reported for a subgroup of patients without evidence of nodal involvement. Thus no conclusion can be drawn.

9. What are the outcomes of second- or subsequent-line therapy in patients with relapsed or progressive SCLC?

Nine RCTs address second- or subsequent-line treatment of SCLC, each of which compared different sets of chemotherapy regimens. Two randomized trials directly compared chemotherapy with best supportive care for recurrent SCLC. The first studied second-line methotrexate plus doxorubicin and found an overall response rate of 23 percent for the chemotherapy arm. The second reported that oral topotecan resulted in a statistically significant increase in survival (26 weeks vs. 14 weeks) and slower decline in quality of life. High-grade neutropenia occurred in one-third of patients. Another trial compared oral versus intravenous topotecan; leukopenia and neutropenia were more frequent with the intravenous route, but survival and response were no greater. Other RCTs found higher rates of adverse events for one treatment over another, but no associated survival advantage that would offset increased high grade toxicity.

Five multicenter phase II trials of note published since 2000 have reported overall response rates of 20 percent or more. Only one study, using topotecan plus cisplatin, enrolled more than 50 patients. Approximately one-fourth of both sensitive and refractory patients responded. Three-quarters or more of both patient groups had high-grade leukopenia and neutropenia. A small study of irinotecan plus cisplatin found very high rates of partial response and low hematologic toxicity. The combination of paclitaxel, ifosfamide, and cisplatin achieved a high overall response rate and high-grade leukopenia in nearly all patients. One-quarter of those given paclitaxel plus carboplatin had a response and about half had high-grade neutropenia. In a study of doxorubicin plus carboplatin, nearly half of patients responded; however, 4 out of 5 had grade 3 or 4 granulocytopenia.

### Discussion and Future Research

The strongest evidence available for this report is a patient-level meta-analysis showing that PCI improves survival of SCLC patients who achieved CR following primary therapy. No other question yielded evidence so robust. Our conclusions typically relied on a single trial showing treatment effects that were modest at best, and sometimes equivocal. This was apparent in our review of evidence for the sequence, timing, dosing and fractionation of TRTx. For example, the case for concurrent over sequential delivery rests largely on a single multicenter trial (Takada, Fukuoka, Kawahara, et al., 2002). Support for early concurrent therapy comes from the multicenter trial by Murray-Coy-Field (Murray, Coy, Pater, et al., 1993/Coy, Hodson, Murray, et al., 1994/Feld, Payne, Hodson, et al., 1988); however, two other multicenter trials, (Perry, Eaton, Propert, et al., 1987/Ahles, Silberfarb, Rundle, et al., 1994/Perry, Herndon, Eaton, et al., 1988; James, Spiro, O'Donnell, et al., 2003 [abstract]) found no advantage. However, the meta-analysis of 11 studies did not find significant reductions in 2- and 3-year mortality for early TRTx. For some questions (i.e., management of mixed histology disease; surgery for early limited SCLC) comparative trials were nonexistent.

Results reported by Jeremic, Shibamoto, Nikolic, et al., (1999) on TRTx for extensive-stage disease, need replication in a multicenter setting.

PET may be more sensitive in detecting disease outside the brain than conventional staging modalities. Future studies should fully report the frequency of correct and incorrect staging changes when PET is added to conventional tests and should link diagnostic performance to outcomes such as improvement in survival or reduced morbidity. Studies should be conducted according to standards described by the Quality Assessment of Diagnostic Accuracy Studies (QUADAS) and reported according to the Standards for Reporting of Diagnostic Accuracy (STARD) statement.

Complicating the evaluation of SCLC treatment are overall poor outcomes and small effect sizes, necessitating large numbers of patients in trials. Furthermore, interventions are multimodal with a multiplicity of variables that might contribute to the effectiveness.

Trials that are poorly designed, conducted, or reported waste limited resources. To advance clinical knowledge and practice, the field should adhere to standards of research quality and set an agenda for research priorities. Given modest gains in survival, quality of life assessment should be integral to clinical trials and should adhere to recommended research methods, including handling of missing data.

## Conclusions

PCI improves survival among those with a complete response to primary therapy. A research agenda is needed to optimize the effectiveness of TRTx and its components. PET for staging may be useful, but its role awaits clarification by rigorous studies. No relevant evidence was available to address management of mixed histology disease or surgery for early limited SCLC.