# Acknowledgments

The research team would like to acknowledge the efforts of Maxine A.Gere, M.S., for general editorial assistance and program support; Carol Gold-Boyd for administrative support; Mark D. Grant, M.D., M.P.H., and Thomas A. Ratko, Ph.D., for fact-checking; Tracey Perez, R.N., J.D., for program support; and William F. Lawrence, M.D., M.S., of the Agency for Healthcare Research and Quality for advice as our Task Order Officer.