# Discussion and Future Research

The majority of evidence reviewed for this report addresses treatments added to primary chemotherapy for small cell lung cancer (SCLC). The main objective is to improve survival by increasing the rate and durability of complete response (CR) resulting from primary treatment; and, for those who do not achieve CR, to delay progression. Questions focus on whether outcomes can be optimized by manipulating variables of adjunctive treatments and their combination.

The strongest evidence available for this report shows that prophylactic cranial irradiation (PCI) improves survival of SCLC patients who achieved CR following primary therapy. Although the benefit is modest, an absolute increase of 5.4 percent in 3-year survival, the evidence is robust and convincing. For this knowledge, clinicians and their patients are the beneficiaries of the PCI Overview Cochrane Collaborative Group, which conducted an individual patient-level meta-analysis, a laborious undertaking. Thus seven discrete randomized, controlled trials were transformed into a rich source of data on almost one-thousand patients, adequate to support clinically relevant subgroup analyses. The results are encouraging in that it appears that all subgroups of eligible patients can potentially benefit from PCI, regardless of age, disease stage, performance status at diagnosis, and whether or not thoracic radiotherapy (TRTx) is part of the induction regimen. Two trials comparing alternative doses and schedules for PCI are in progress, one in the U.S. (RTOG-0212) and one in Europe (FRE-IGR-PCI-99). Targeted accrual for the two trials together is over 900 patients. These trials will provide additional data on neurotoxicity and quality of life.

Patient level meta-analysis was not available for any other key question considered in this evidence report. No other question yielded a body of evidence so robust. Where we attempted to draw conclusions, we typically relied on a single trial showing treatment effects that were modest at best, and sometimes equivocal. This was apparent in our review of evidence for the sequence, timing, dosing and fractionation of TRTx. For some questions (i.e., management of mixed-histology disease; surgery for early limited SCLC) comparative trials were nonexistent.

Perhaps the most vexing questions are those regarding the delivery of TRTx. Strategies for sequencing, timing, dosing, and fractionation are not well supported by a strong evidence base; each rests largely on a single study that shows significant findings. The case for concurrent over sequential delivery rests largely on a single multi-center trial (Takada 2002) supplemented by a smaller study judged to be of poor quality (Park 1996). We found the results to be suggestive, but not conclusive, of better outcomes for concurrent over sequential TRTx. No studies show an advantage for alternating TRTx, but none show it to be inferior. Support for early concurrent therapy comes largely from the results of the multicenter trial by Murray-Coy-Feld (Murray, Coy, Pater, et al., 1993/Coy, Hodson, Murray, et al., 1994/Feld, Payne, Hodson, et al., 1988); but two other multicenter trials, one using non-platinum chemotherapy (Perry, Eaton, Propert, et al., 1987/Ahles, Silberfarb, Rundle, et al., 1994/Perry, Herndon, Eaton, et al., 1988) and the other not yet published in full text (James, Spiro, O'Donnell, et al., 2003), found no advantage. We conducted a meta-analysis of 11 studies, which did not find significant reductions in 2- and 3-year mortality for early TRTx over late TRTx.

Compared to a single daily fraction, two fractions per day of accelerated TRTx delivered concurrently with platinum chemotherapy improved overall survival in a large multicenter trial of good quality (Turrisi, Kim, Blum, et al., 1999/Yuen, Zou, Turrisi, et al., 2000). In contrast to a subsequent study comparing single to twice-daily fractionation (Schild, Bonner, Shanahan, et al., 2004/Sloan, Bonner, Hillman, et al., 2002/Bonner, Sloan, Shanahan, et al., 1999), which is difficult to interpret because multiple variables were studied simultaneously, the Turrisi study compared only the variable of fractionation. An approach to comparing early- versus late-concurrent TRTx, would be to reproduce this twice daily fractionation regimen varying only the element of timing. In concept, late-concurrent TRTx could be advantageous if better tolerated, thus permitting more patients to complete their full course and intensity of chemotherapy. In contrast, our meta-analytic sensitivity analysis suggests that an advantage for early TRTx depends on use of hyperfractionation, a finding that is hypothesis-generating only.

With respect to treatment for extensive-stage disease, results reported by Jeremic, Shibamoto, Nikolic et al. (1999) on the addition of TRTx to chemotherapy need replication in a multicenter setting. This applies both to the evidence suggesting benefit from TRTx for those with complete disappearance of extrathoracic lesions after three cycles of platinum/etoposide, and to the uncontrolled evidence suggesting little or no benefit if extra-thoracic lesions only partially respond.

Use of positron emission tomography (PET) as an adjunct to conventional tests is relevant to initial staging and restaging after treatment. Because PET may be more sensitive in detecting disease outside the brain than conventional staging modalities, and has been suggested to correctly upstage or downstage disease, it should be investigated in better quality studies to confirm these results and determine if it improves clinical management of SCLC. Currently available studies are limited primarily by inadequate quality, especially failure to define an adequate reference standard. An informative design would compare the frequency of correct upstaging, correct downstaging, incorrect overstaging and incorrect understaging for PET plus conventional staging tests in relation to conventional staging tests alone. The use of PET/CT is becoming more common and should be addressed in future studies. Future studies should be conducted according to standards described by the Quality Assessment of Diagnostic Accuracy Studies (QUADAS) and reported according to the Standards for Reporting of Diagnostic Accuracy (STARD) statement.

Authors of a systematic review will rarely be proven wrong in calling for more rigorous evidence from well-conducted, randomized, controlled trials. However, it is also fair to acknowledge that some diseases and treatments pose greater difficulties in conducting trials to evaluate the effectiveness of interventions. A central challenge in evaluating treatments for SCLC is that overall disease outcome is poor and, at this time, the potential for an intervention to change the course of disease is limited. Because treatment effect sizes are small, large numbers of patients are needed in trials to test effectiveness. Complicating this is the multimodal nature of interventions and, as exemplified by TRTx, the multiplicity of variables that might contribute to the effectiveness of a single component of a multimodal intervention. And for some populations of interest (i.e., mixed histology disease; early limited disease), the number of affected individuals is small, making prospective study difficult.

The very circumstances that comprise the challenges to research in SCLC highlight the necessity of setting a systematic and rigorous research agenda to accumulate findings that can improve clinical care and outcomes. To this end, we make the following recommendations for future research.

- In assessing strategies for the delivery of multimodality interventions, such as TRTx, design trials to clearly test a single variable (e.g., early concurrent vs. late concurrent). Multi-arm trials could permit testing of more than one variable simultaneously. Given the potential complexity of variables and combinations, there should be a consensus on the priority of strategies and elements to be tested.
- Trials that are poorly designed, conducted, or reported waste limited resources. To advance clinical knowledge and practice, the field should adhere to standards of research quality, as well as setting an agenda for research priorities.
- Quality of life assessment should be an integral to clinical trials. Given modest gains in survival, it is important to assess the quality of the survival. Quality of life research poses intrinsic difficulties, including missing data as disease progresses. Studies should adhere to recommended methods for quality of life research and handling of missing data.
- Future trials should use consensus definitions for patient enrollment criteria, subgroup characteristics and trial endpoints. Adverse events data should be consistently reported and collected. The use of consistent definitions and end-points can produce a more robust body of cumulative evidence improving the ability to compare results among trials and increasing the potential for combined analyses.

Finally, clinicians and investigators would be well-served by improved indexing and search terms so that electronic literature databases would better distinguish records on SCLC from those on non-small cell lung cancer.