# Conclusions

1. For limited-stage SCLC, what are the relative benefits and harms of TRTx combined with chemotherapy either in alternating fashion, concurrently, or sequentially?

One multicenter trial and one single-center trial (n=307) compared concurrent and sequential TRTx. Results are not conclusive but suggest better outcomes for concurrent TRTx. Overall survival adjusted for confounders significantly favored concurrent TRTx in the Takada, Fukuoka, Kawahara, et al. trial (2002; n=228), although unadjusted results were not significant. Additionally, the Park, Kim, Jeong, et al. (1996) trial found significantly longer response duration for concurrent TRTx. Of 11 types of adverse events reported, only leukopenia occurred significantly more frequently in the concurrent TRTx group in both studies.

No conclusions could be drawn on the relative benefits and harms of TRTx combined with chemotherapy in alternating fashion. No significant differences in survival or progression-free survival were found in any of four trials. Two trials (n=458) compared alternating to sequential TRTx; one trial (n=156) compared alternating to concurrent TRTx; and one trial (n=199) compared early alternating and late alternating TRTx.

2. For limited-stage SCLC, do outcomes differ if concurrent TRTx is given in early versus late chemotherapy cycles?

Overall, the evidence is equivocal, either finding no difference or a small advantage for early TRTx. One multi-center trial of good quality significantly favored concurrent therapy given in an early cycle (Murray, Coy, Pater, et al., 1993/Coy, Hodson, Murray, et al., 1994/Feld, Payne, Hodson, et al., 1988), as did 2 smaller trials. Of the two larger multi-center trials that that found no significant difference in survival, one did not use platinum chemotherapy (Perry, Eaton, Propert, et al., 1987/Ahles, Silberfarb, Rundle, et al., 1994/Perry, Herndon, Eaton, et al., 1988) and the other has not been published in full-text (James, Spiro, O'Donnell, et al., 2003).

Leukopenia/neutropenia appeared to be more common with early concurrent TRTx, although differences were statistically significant in only two of six reporting trials. Other events do not appear to be more frequent with either early or late TRTx. However, evidence is limited as adverse events were not reported consistently across all trials

Meta-analysis was performed on survival outcome of early versus late TRTx in an attempt to obtain clearer results. For purposes of the meta-analysis, the studies selected for Key Questions 1 and 2 were viewed as comparing early and late TRTx. Therefore, these studies were pooled to give a more robust analysis of early versus late TRTx. Overall, we did not find significant reductions in 2- and 3-year mortality for early TRTx over late TRTx. The RR at 2 years was 0.921 (95 percent CI: 0.844–1.005) and the RR at 3 years was 0.991 (0.955–1.029). Although the overall analysis was not significant, sensitivity analysis suggests that if there is an advantage favoring early TRTx it would accompany use of hyperfractionation and possibly use of platinum chemotherapy.

3. For limited-stage SCLC, do outcomes (survival, toxicity, quality of life) of primary therapy differ if one varies dose rate, treatment interval, or fractionation scheme for delivering radiotherapy? Comparisons of interest include:

- accelerated regimens (>10 Gy per week completed over a short interval) versus standard duration regimens (<10 Gy per week) versus split courses delivered over the standard interval; and
- single daily fractions versus hyperfractionated (two or more daily fractions or concomitant boost).

Evidence to compare dose rates, treatment intervals, or fractionation schemes is limited. Two RCTs compared one versus two fractions a day for previously untreated SCLC. One compared an accelerated regimen versus the standard duration, while the other compared a split-course regimen versus the standard duration.

Compared to a single daily fraction, two daily fractions delivered concurrently with platinum chemotherapy improved overall survival in a large multicenter trial of good quality (Turrisi, Kim, Blum, et al., 1999/Yuen, Zou, Turrisi, et al., 2000; N=417). More specifically, this trial showed that starting TRTx with the first cycle of cisplatin-etoposide chemotherapy and giving it in two daily fractions over 3 weeks increased overall survival (23 vs. 19 months, log rank p=0.04) when compared with the same dose begun at the same time but given in one daily fraction over 5 weeks.

Evidence from the second trial is difficult to interpret, since multiple variables were studied simultaneously (Schild, Bonner, Shanahan, et al., 2004/Sloan, Bonner, Hillman, et al., 2002/Bonner, Sloan, Shanahan, et al., 1999; N=161). However, it found no difference in overall survival between treatment arms managed with one versus two fractions per day.

Neither trial reported data on quality of life. Esophagitis was the only adverse event reported more frequently with two fractions per day than with one fraction per day in both trials.

4. What are the relative benefits and harms (survival, toxicity, and quality of life) of adding thoracic radiation therapy to chemotherapy for primary treatment of extensive-stage SCLC?

Evidence from one single-center RCT (Jeremic, Shibamoto, Nikolic, et al., 1999; N= 99) suggests that adding concurrent TRTx improves survival of patients with extensive-stage disease that responds to an initial three cycles of platinum/etoposide chemotherapy with a complete response outside the thorax and at least a partial response in the thorax. Uncontrolled data from the same trial suggest little to no benefit for patients who achieve no better than a partial response outside the thorax. With the regimens used in this trial, concurrent TRTx apparently increases grades 3 and 4 esophagitis.

No other trials have reproduced the results reported by Jeremic, Shibamoto, Nikolic, et al. (1999). Four earlier trials (N=129) are limited by small sample sizes and non- platinum chemotherapy regimens; none used concurrent TRTx.

5. What are the benefits and harms (survival, toxicity and quality of life) of prophylactic cranial irradiation?

Evidence from an individual patient data Cochrane review and meta-analysis on seven RCTs (N=987) conducted by the PCI Overview Collaborative Group shows that PCI modestly improves survival of SCLC patients in CR after primary therapy. PCI increases the proportion alive at 3 years from 15.3 percent to 20.7 percent (P=0.01), an absolute increase of 5.4 percent. PCI also significantly decreases the risk for brain metastasis and increases the likelihood of disease-free survival. The sole trial reported after the meta-analysis confirms effects of PCI on brain metastasis, and generally agrees with the modest effect on overall survival.

Subgroup analyses using individual patient data showed that PCI significantly decreases brain metastases for SCLC patients in CR regardless of age, disease stage or performance status at diagnosis, and whether or not TRTx is part of the induction regimen. Although PCI does not have significant effect on survival for most of these subgroups, it does not appear that any of these subgroups benefits more or less than others.

Additional subgroup analyses suggested that increasing the PCI dose from 8 to 40 Gy and starting PCI within the first 6 months after achieving CR may decrease the likelihood of brain metastasis. Patient gender also may interact with effects of PCI on survival. However, these hypotheses, derived from subgroup analyses, require formal testing in RCTs.

Data on acute toxicities of PCI are scant, but those available suggest they are tolerable at the doses used in these trials (8–40 Gy in 1.8 to 3 Gy fractions). Evidence from two trials suggests neuropsychological and cognitive deficits and structural abnormalities on brain CT scans are relatively common among SCLC patients in CR after primary therapy but before PCI. Available evidence on patients who survived 1–2 years, while limited, did not show greater deterioration of existing deficits or more frequent appearance of new abnormalities with PCI than among controls.

6. Does the addition of PET scanning improve the accuracy of staging for patients with SCLC over the use of other techniques, including CT and MRI, without PET?

It is not possible from the limited and poor quality evidence that is available to determine whether the use of PET adds value relative to conventional staging tests for SCLC.

Six studies reporting on a total of 277 patients (range 20–120) provided data on the diagnostic accuracy of PET in SCLC. The evidence suggests that, except for detection of brain metastases, PET added to conventional staging is more sensitive in detecting disease than conventional staging alone. Upstaging was reported in 4–20 percent of patients and downstaging in 4–13 percent of patients. Three studies reported very high occurrence of patient management changes that were attributed to PET (29–58 percent).

However, the quality of these studies is consistently poor and insufficient detail in reporting was the norm. There is such a high degree of uncertainty about the execution and interpretation of the reference standard in all of these studies that confidence is quite low in estimates of diagnostic and staging accuracy. Although these studies report that PET has correctly upstaged or downstaged the extent of disease, the frequency of incorrect changes in stage attributable to PET is unknown due to incomplete reporting. It is not possible to determine the frequency with which management changes based on PET results were actually beneficial or harmful.

7. What are the outcomes (survival, toxicity and quality of life) of treatments used to manage patients with mixed small cell/non-small cell lung cancers?

No studies meet selection criteria for this question. Very few references from the literature search represented studies of any kind that included patients with mixed histology. No conclusions can be drawn on outcomes of treatment for patients with mixed small cell/non-small cell lung cancers.

8. What is the role of surgery and what is its impact on survival in patients with early stage SCLC? How do available studies define early stage SCLC?

For this question, we sought randomized and nonrandomized studies that compared surgery to no surgery in patients with very early limited SCLC, defined as no preoperative evidence of involved nodes (clinically N0). Two randomized controlled trials and 8 nonrandomized comparative studies were included in the review, but none provided evidence that directly addresses the question.

None of these comparisons studied a homogeneous group of patients with respect to nodal status; nor were separate outcomes reported for a subgroup of patients without evidence of nodal involvement by current staging methods. Moreover, the treatment regimens used had limited relevance to contemporary treatment settings; for example, 5 studies did not use platinum-based chemotherapy for any patients, and the remaining 3 used platinum based therapy only for some patients. Thus no conclusion can be drawn on the outcomes of management of very early limited SCLC with versus without surgery.

9. What are the outcomes of second- or subsequent-line therapy in patients with relapsed or progressive SCLC? Where available data permit, patients with limited- and extensive-stage disease will be addressed separately, as will those with refractory disease.

Nine RCTs address second- or subsequent-line treatment of SCLC, each of which compared different sets of chemotherapy regimens. Two randomized trials directly compared chemotherapy with best supportive care for recurrent SCLC. The first studied second-line methotrexate plus doxorubicin and found an overall response rate of 23 percent for the chemotherapy arm. The second reported that oral topotecan resulted in a statistically significant increase in survival (26 weeks vs. 14 weeks) and slower decline in quality of life. High grade neutropenia occurred in one third of patients. Another trial compared oral versus intravenous topotecan; leukopenia and neutropenia were more frequent with the intravenous route, but survival and response were no greater.

A study that addressed the addition of carboplatin to cisplatin and etoposide is of limited use given that it enrolled only those who did not receive first-line cisplatin and etoposide, which is the current standard regimen. One small study comparing 3 doses of monotherapy etoposide did not find significant survival differences, but a trend favored the highest dose, along with increased thrombocytopenia and neutropenia. Other studies found higher rates of adverse events for one treatment over another, but no associated survival advantage that would offset increased high grade toxicity. A study comparing intravenous topotecan and CAV chemotherapy showed that the topotecan group had higher risks of anemia and thrombocytopenia. High-dose platinum/etoposide had more leukopenia than low-dose platinum/etoposide.

Five multicenter phase II trials of note published since 2000 have reported overall response rates of 20% or more. Only one study, using topotecan plus cisplatin, enrolled more than 50 patients. Approximately one fourth of both sensitive and refractory patients responded. Three-quarters or more of both patient groups had high grade leukopenia and neutropenia. A small study of irinotecan plus cisplatin found very high rates of partial response and low hematologic toxicity. The combination of paclitaxel, ifosfamide and cisplatin achieved a high ORR and high grade leukopenia in nearly all patients. One-quarter of those given paclitaxel plus carboplatin had a response and about half had high grade neutropenia. In a study of doxorubicin plus carboplatin, nearly half of patients responded; however, 4 out of 5 had grade 3 or 4 granulocytopenia. The clinical applicability of these regimens awaits the results of randomized trials.