# Results

## Key Question 1

For limited-stage small cell lung cancer (SCLC), what are the relative benefits and harms (survival, toxicity, and quality of life) of thoracic radiotherapy (TRTx) combined with chemotherapy, either in alternating fashion, concurrently or sequentially?

This question concerns how TRTx is given in relation to chemotherapy. Alternating TRTx is administered between chemotherapy cycles. Concurrent TRTx is TRTx given at the same time as chemotherapy. Sequential TRTx is given after completion of chemotherapy.

### Overview

As summarized in Summary Table 2, 6 randomized, controlled trials (RCTs) made comparisons of alternating, concurrent and sequential TRTx for limited stage SCLC. Two trials (n=307) compared concurrent and sequential TRTx (Takada, Fukuoka, Kawahara, et al., 2002; Park, Kim, Jeong, et al., 1996). Two trials compared alternating to sequential TRTx (Gregor, Drings, Burghouts, et al., 1997; Sun, Zhang, Yin, et al., 1995; n=458). One trial compared alternating to concurrent TRTx (Lebeau, Urban, Brechot, et al., 1999, n=156). The Work and colleagues trial (Work, Nielsen, Bentzen, et al., 1997/Work, Bentzen, Nielsen, et al., 1996) compared early alternating and late alternating TRTx (n=199). Collectively, the 6 trials randomized 228 patients to concurrent treatment, 337 patients to alternating treatment, and 385 patients to sequential treatment. It is worth noting that these studies were generally small in size and likely underpowered to find small but clinically significant differences in survival.

Table 2 Overall Summary of Question 1 Trials

Study | Treatment arm | Control arm | Treatment n | Control n | Pt? | CTx | TRTx Dose (Gy) #Fracs/d | TRTx Timing | | PCI? | Quality Rating
| | | | | | | | Tx | Control
Takada, Fukuoka, Kawahara, et al., 2002 Multicenter | concurrent | sequential | 114 | 114 | yes | PE | 45 2/d | wk 1–3 | wk 13–15 | yes | Good
Park, Kim, Jeong, et al., 1996 Single center | concurrent | sequential | 32 | 47 | yes | CAV-CbPE | 40–50 2/d,1/d | wk 1–3 | wk 19–24 | yes | Poor
Sun, Zhang, Yin, et al., 1995 Multicenter | alternating | sequential | 64 | 59 | no/ yes | COME, CE-CAP | 30–60 1/d | wk 4–9 | wk 13–18 | ? | Poor
Gregor, Drings, Burghouts, et al., 1997 Multicenter | alternating | sequential | 170 | 165 | no | CAE | 50 1/d | wk 7,11, 15,19 | wk 15–18 | ? | Good
Lebeau, Urban, Brechot, et al., 1999 Multicenter | alternating | concurrent | 74 | 82 | no | CAE-CVE | 55/50 1/d | wk 6–7, 10–11, 14–16 | wk 5–9 | yes | Good
Work, Nielsen, Bentzen, et al. 1997/Work, Bentzen, Nielsen, et al., 1996 Single center | early alternating | late alternating | 99 | 100 | yes | CAV-PE | 40–45 1/d | wk 1–2, 6–7 | wk 18–19, 23–24 | yes | Fair

Abbreviations table provided at the end of the Report.

Table 6 Adverse Events Reported in Takada and Park Trials

Adverse Event | Takada | Park
Treatment-related Mortality | | NR
Nausea/vomiting | | NR
Esophagitis | | NR
Anemia
Thrombocytopenia
Leukopenia | ▴ | ▴
Kidney | NR
Infection
Fever
Alopecia | | NR
Arrhythmias | | NR
Hepatic | NR

▴=significantly more frequent in concurrent than in sequential arm

▾=significantly less frequent in concurrent than in sequential arm

NR=not reported; blank cell=outcome reported, but arms not significantly different

Study populations and treatment protocols are summarized in Summary Table 3. Additional details are in Appendix Tables 1A–D, 1H.^*^ Information in the tables came exclusively from articles except for the Park, Kim, Jeong, et al. (1996) study. Park, Kim, Jeong, et al. (1996) did not report survival probabilities at yearly intervals, so an author was contacted directly and additional data were sought. The data obtained from the author represented a larger patient sample than described in the article.

* Appendixes cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/lungcansmall/lungcan.pdf

Table 3 Alternating, Concurrent, or Sequential Radiotherapy

Study | n | | Age | % Female | % Performance Status | | | | CTx Regimen | RTx Regimen
Gregor, Drings, Burghouts, et al., 1997 | Total | 335 | md (rng) | | 0 | 1 | 2 | 3 | | Dose | Schedule | PCI?
EORTC LCCG | Seq | 165 | 61 (33–75) | 32.1 | 46.1 | 47.9 | 4.2 | 1.8 | CAE | 50 Gy | wks 15–18, 20 frac, 1/d, 5/wk | possible if CR
Multiple European institutions, 3/89 -1/95 | Alt | 170 | 61 (34–74) | 34.1 | 47.1 | 44.7 | 5.9 | 2.4 | same | 50 Gy | wks 7, 11, 15, 19; 20 frac, 1/d, 5/wk | same
| | | | | ECOG
Lebeau, Urban, Brechot, et al., 1999 | Total | 156 | mn | | 0 | 1 | 2–3 | NR | | Dose | Schedule | PCI?
26 French institutions, 5/88 - 5/94 | Alt | 74 | 58 | 14.9 | 50.0 | 44.6 | 4.1 | 1.4 | CAE-CVE | 55 Gy | wks 6–7, 10–11, 20 Gy, 8 frac, 12 d, wks 14–15, 15 Gy, 6 frac, 10 d | if CR
| Conc | 82 | 57 | 20.7 | 51.2 | 46.3 | 2.4 | 0.0 | same | 50 Gy | wks 5–9, 40 Gy, 16 frac, 7 d | same
| | | | | ECOG
Takada, Fukuoka, Kawahara, et al., 2002 | Total | 228 | md (rng) | | 0 | 1 | 2 | | | Dose | Schedule | PCI?
15 Japanese institutions, 5/91 - 1/95 | Seq | 114 | 64 (30–74) | 18.4 | 28.9 | 65.8 | 5.3 | | PE | 45 Gy | wks 13–15, 30 frac, 2/d, 5/wk | if CR, near-CR
| Conc | 114 | 65 (39–74) | 20.2 | 21.9 | 72.8 | 5.3 | | same | 45 Gy | wks 1–3, 30 frac, 2/d, 5/wk | same
| | | | | ECOG
Sun, Zhang, Yin, et al., 1995 | Total | 123 | | | | | | | | Dose | Schedule | PCI?
15 Chinese institutions, 1983 -1989 | Seq | 59 | | | | | | | COME, CE-CAP | 45–60 Gy | Local dis, after 2 CTx cyc, 6 wks | not specified
| Alt | 64 | | | | | | | Same | 30–45 Gy | MS/SC LNs, 3–4 wks
| | | | | | | | | | 45–60 Gy | Local dis, between 2 CTx cyc, 6 wks
| | | | | | | | | | 30–45 Gy | MS/SC LNs, 3–4 wks
Work, Nielsen, Bentzen, et al. 1997/Work, Bentzen, Nielsen, et al., 1996 | Total | 199 | md (rng) | | 100 | 90–80 | 70–60 | 50–40 | | Dose | Schedule | PCI?
single-center study, 3/81–9/89 | L Alt | 100 | 59(36–69) | 29 | 10.0 | 70.0 | 15.0 | 5.0 | CAPE | 40–45 Gy | wks 18–19, 23–24, 1 frac/d | all
| E Alt | 99 | 61(36–70) | 45 | 13.1 | 68.7 | 14.1 | 4.0 | Same | 40–45 Gy | wks 1–2, 6–7, 1 frac/d | same
| | | | | KPS
Park, Kim, Jeong, et al., 1996 | Total | 51 | mn (sd) | | 0 | 1 | 2 | | | Dose | Schedule | PCI?
Korean Center 5/91 - 5/96 | Seq | 24 | 60.6(8.9) | 20.8 | 25.0 | 45.8 | 29.2 | | CAV-CbPE | 40–50 Gy | wks 19–24, 1 frac/d | if CR maintained
| Conc | 27 | 57.5(8.8) | 14.8 | 14.8 | 63 | 22.2 | | Same | 45 Gy | wks 1–3, 2 frac/d | same

Abbreviations table provided at the end of the Report.

### Concurrent vs. Sequential

Interventions. Two trials compared concurrent and sequential TRTx. Radiation dose in the Takada, Fukuoka, Kawahara, et al. (2002) study was 45 Gy, while it varied between 40 and 50 Gy in the Park, Kim, Jeong, et al. (1996) study. Both studies gave concurrent TRTx in weeks 1–3. Sequential TRTx occurred in weeks 13–15 in the Takada, Fukuoka, Kawahara, et al. (2002) trial and between weeks 19 and 24 in the Park, Kim, Jeong, et al. (1996) study. Takada, Fukuoka, Kawahara, et al. (2002) delivered 2 daily fractions of TRTx in both groups, while Park, Kim, Jeong, et al. (1996) gave it to the concurrent group. Both studies gave prophylactic cranial irradiation (PCI). Platinum-based chemotherapy was used by Park, Kim, Jeong, et al. (1996), but not by Takada, Fukuoka, Kawahara, et al. (2002).

Populations. Groups were well-balanced on age, gender and performance status in the Takada, Fukuoka, Kawahara, et al. (2002) study (n=228). The sample of 51 patients in the Park, Kim, Jeong, et al. (1996) article was also well-balanced on these characteristics, but the survival data represented 79 patients and no comparison of baseline characteristics is available for all.

Quality and Reporting. The Takada, Fukuoka, Kawahara, et al. (2002) trial was rated as being of good quality. The Park, Kim, Jeong, et al. (1996) study was rated as poor due to insufficient information about assembly and maintenance of comparable groups, in addition to uncertainty about full accounting of subjects in data analysis.

Results. Survival outcomes are shown in Summary Table 4 and adverse events in Summary Table 5. More detailed results are in Appendix Tables 1E–1G.^*^ Both studies showed survival results favoring concurrent TRTx, but were generally not statistically significant. Unadjusted overall survival did not differ significantly between concurrent and sequential TRTx, although p values were nearly significant. Overall median survival favored concurrent therapy by 5.1 months (Park, Kim, Jeong, et al., 1996) and 7.5 months (Takada, Fukuoka, Kawahara, et al., 2002). A Cox proportional hazards model regression found that treatment was a significant predictor of survival, producing a hazard ratio of 0.70 (95 percent confidence interval [CI]: 0.52–0.94) for concurrent relative to sequential TRTx. Takada, Fukuoka, Kawahara, et al. (2002) also reported that median progression-free survival favored the concurrent group by 2 months (p=0.084), but Park, Kim, Jeong, et al. (1996) did not report on progression.

Table 4 Survival Outcomes: Alternating, Concurrent and Sequential Radiotherapy

Study | N | | OS | Md (mo) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | PFS | Md (mo) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
Gregor, Drings, Burghouts, et al., 1997 | Seq | 165 | | 15 | 64% | 23% | 15% | ~14% | ~12% | | 12 | 50% | 22% | 17% | 15% | 5%
| Alt | 170 | | 14 | 60% | 26% | 12% | ~10% | ~4% | | 10 | 43% | 16% | 10% | 8% | 8%
| Difference: | | | -1 | -4% | 3% | -3% | -4% | -8% | | -2 | -7% | -6% | -7% | -7% | 3%
| | | (CPHM: RR 0.88, 95% CI 0.68–1.1, p=0.237; p=0.288, log-rank) | | | | | | | (Log-rank p=0.07)
Lebeau, Urban, Brechot, et al., 1999 | Alt | 74 | | 14.0 | 63% | 17% | 11% | 6% | 6%
| Conc | 82 | | 13.5 | 54% | 13% | 6% | 4% | 4%
| Difference | | | -0.5 | -9% | -4% | -5% | -2% | -2%
| | | (p=0.15, log-rank, 66 Alt deaths, 77 Conc deaths)
Takada, Fukuoka, Kawahara, et al., 2002 | Seq | 114 | | 19.7 | ~80% | 35.1% | 20.2% | ~20% | 18.3% | | ~10 | ~38% | ~19% | ~15% | ~14% | ~14%
| Conc | 114 | | 27.2 | ~80% | 54.4% | 29.8% | ~25% | 23.7% | | ~12 | ~50% | ~28% | ~25% | ~20% | ~17%
| Difference | | | 7.5 | 0% | 19.3% | 9.6% | 5% | 5.4% | | 2 | 12% | 9% | 10% | 6% | 3%
| | | (p=0.097 eligible patients, p=0.086 all randomized, log-rank; CPMH: HR 0.70, 95% CI 0.52–0.94, p=0.02) | | | | | | | (p=0.084, log-rank))
Sun, Zhang, Yin, et al., 1995 | Seq | 59 | | | 64.0% | 13.6% | 12.0%
| Alt | 64 | | | 62.5% | 28% | 16.0%
| Difference | | | | -1.5% | 14.4% | 4%
Work, Nielsen, Bentzen, et al. 1997/Work, Bentzen, Nielsen, et al., 1996 | L Alt | 100 | | 12.0 | ~49% | 18.8% | ~12% | ~12% | 12.0% | | NR~15 | ~58% | 31.7% | ~27% | ~27% | 27%
| E Alt | 99 | | 10.5 | ~43% | 20.2% | ~13% | ~12% | 10.8% | | NR ~9 | ~42% | 27.7% | 25% | 23% | 23%
| Difference | | | -1.5 | -6% | 1.4% | 1% | 0% | -1.2% | | | -18% | -4% | 0.2% | 3.2% | 2.8%
| | | (p=0.41, not significant, RR 0.88, 95% CI 0.66–1.08) | | | | | | | (PWIFR, HR 0.79, 95% CI 0.56–1.12)
Park, Kim, Jeong, et al., 1996 | Seq | 47 | | 16.0 | 74.4% | 27.7% | 8.8% | 4.4% | 2.2%
| Conc | 32 | | 18.4 | 81.3% | 29.0% | 13.8% | 10.7% | 7.4%
| Difference | | | 2,4 | 6.9% | 1.3% | 5.0% | 6.3% | 5.2%
| | | (p=0.11)

Abbreviations table provided at the end of the Report.

Table 5 Adverse Events: Alternating, Concurrent, or Sequential Radiotherapy

Toxicity Type | Study | Severity or Grade | Group | n | % | Group | n | % | p | Not Reporting
Treatment-related mortality | Lebeau 1999 | Deaths from aplasia | Alt | 74 | 2.7 | Conc | 82 | 3.7 | 0.67 | Gregor 1997; Sun 1995; Work 1997/1996; Park, 1996
| | Deaths from pulmonary fibrosis | Alt | 74 | 1.4 | Conc | 82 | 7.3 | 0.05
| Takada 2002 | | Seql | 110 | 3.6 | Conc | 112 | 2.7 | 0.72
| Work 1997 | | L Alt | 100 | 0 | E Alt | 99 | 0 | 1.00
Nausea/Vomiting | Gregor 1997 | Or vomiting, acute (WHO grade)
| | 0 | Seql | 165 | 25.5 | Alt | 169 | 36.1 | 0.129 | Lebeau 1999; Sun 1995; Work 1997/1996; Park, 1996
| | 1 | | | 21.8 | | | 21.3
| | 2 | | | 37.6 | | | 25.4
| | 3 | | | 13.3 | | | 15.4
| | 4 | | | 0.6 | | | 1.2
| | NR | | | 1.2 | | | 0.6
| Takada 2002 | Or vomiting (WHO grade ≥3) | Seql | 110 | 19.1 | Conc | 112 | 10.7 | 0.09
Anorexia | | | | | | | | | | Lebeau 1999; Gregor 1997; Takada 2002; Sun 1995; Work 1997/1996; Park, 1996
Lethargy | | | | | | | | | | Lebeau 1999; Gregor 1997; Takada 2002; Sun 1995; Work 1997/1996; Park, 1996
Neurosensory | Work 1997/1996 | Moderate neurotoxicity (grade ≤ 3) | in 11 (of 199); no difference between groups | | | | | | | Lebeau 1999; Gregor 1997; Takada 2002; Sun 1995; Park, 1996
Hearing loss | | | | | | | | | | Lebeau 1999; Gregor 1997; Takada 2002; Sun 1995; Work 1997/1996; Park, 1996
Esophagitis | Gregor 1997 | Acute (WHO grade) | | | | | | | | Lebeau 1999; Sun 1995; Work 1997/1996; Park, 1996
| | 0 | Seql | 165 | 83.0 | Alt | 169 | 75.7 | 0.198
| | 1 | | | 7.9 | | | 11.8
| | 2 | | | 6.1 | | | 9.5
| | 3 | | | 3.0 | | | 3.0
| | Late esophageal stenosis (WHO grade)
| | 0 | Seql | 143 | 82.5 | Alt | 135 | 94.1 | 0.010
| | 1 | | | 11.2 | | | 3.0
| | 2 | | | 2.8 | | | 1.5
| | 3 | | | 2.1 | | | 0.7
| | NR | | | 1.4 | | | 0.7
| Takada 2002 | WHO grade ≥ 3 | Seql | 110 | 3.6 | Conc | 112 | 8.9 | 0.17
Bronchopulmonary | Gregor 1997 | Late Lung fibrosis (RTOG grade) | | | | | | | | Takada 2002; Sun 1995; Work 1997/1996; Park, 1996
| | 0 | Seql | 143 | 19.6 | Alt | 135 | 11.1 | 0.135
| | 1 | | | 19.6 | | | 20.0
| | 2 | | | 21.7 | | | 27.4
| | 3 | | | 18.2 | | | 14.8
| | 4 | | | 18.9 | | | 24.4
| | NR | | | 2.1 | | | 2.2
| Lebeau 1999 | Pulmonary fibrosis | Alt | 74 | 2.7 | Conc | 82 | 8.5 | 0.17
Pneumonitis | | | | | | | | | | Lebeau 1999; Gregor 1997; Takada 2002; Sun 1995; Work 1997/1996; Park 1996
Kidney | Work 1997/1996 | | quantified by chromium-edathamil clearance; did not differ between groups | | | | | | | Lebeau 1999; Gregor 1997; Takada 2002; Sun 1995
| Park 1996 | ECOG grade 3 | Seql | 24 | 0 | Conc | 27 | 0 | 1.00
| | ECOG grade 4 | | | 0 | | | 0
Anemia | Takada 2002 | WHO grade 3 | Seql | 110 | 41.8 | Conc | 112 | 53.6 | 0.08 | Lebeau 1999; Gregor 1997; Sun 1995; Work 1997/1996
| Park 1996 | ECOG grade 3 | Seql | 24 | 0 | Conc | 27 | 3.7 | 1.00
| | ECOG grade 4 | | | 0 | | | 0
Thrombocytopenia | Gregor 1997 | Acute (WHO grade) | | | | | | | | Lebeau 1999; Sun 1995;
| | 0 | Seql | 165 | 55.2 | Alt | 169 | 24.9 | <0.001
| | 1 | | | 13.9 | | | 17.2
| | 2 | | | 10.9 | | | 23.1
| | 3 | | | 12.7 | | | 11.8
| | 4 | | | 6.7 | | | 20.7
| | NR | | | 0.6 | | | 2.4
| Takada 2002 | (WHO grade)
| | 3 | Seql | 110 | 12.7 | Conc | 112 | 29.5 | 0.11
| | 4 | | | 13.6 | | | 7.1
| | ≥ 3 | | | 26.4 | | | 36.6
| Work 1997/1996 | WHO grades 3 & 4 | L Alt | 100 | 13 | E Alt | 99 | 13 | 1.00
| Park 1996 | ECOG grade 3 | Seql | 24 | 0 | Conc | 27 | 0 | 1.00
| | ECOG grade 4 | | | 0 | | | 3.7
Leukopenia or neutropenia | Gregor 1997 | Acute leukopenia (WHO grade) | | | | | | | | Sun 1995
| | 0 | Seql | 165 | 6.7 | Alt | 169 | 4.1 | <0.001
| | 1 | | | 5.5 | | | 1.2
| | 2 | | | 10.9 | | | 3.6
| | 3 | | | 34.5 | | | 17.8
| | 4 | | | 41.8 | | | 71.6
| | NR | | | 0.6 | | | 1.8
| Lebeau 1999 | Neutropenia (grade 3 or 4) | Alt | 74 | 60.8 | Conc | 82 | 58.5 | 0.87
| Takada 2002 | Leukopenia (WHO grade)
| | 3 | Seql | 110 | 44.5 | Conc | 112 | 50.9 | 0.001
| | 4 | | | 9.1 | | | 37.5
| | 3 or 4 | | | 53.6 | | | 88.4
| Work 1997/1996 | WHO grades 3 & 4 leukopenia | L Alt | 100 | 39 | E Alt | 99 | 67 | <0.001
| | WHO grade 4 leukopenia | | | 6 | | | 23 | 0.0006
| Park 1996 | Leukopenia ECOG grade 3 | Seql | 24 | 12.5 | Conc | 27 | 40.7 | 0.0176
| | ECOG grade 4 | | | 4.2 | | | 11.1
Infection | Takada 2002 | WHO grade ≥3 | Seql | 110 | 0.9 | Conc | 112 | 5.4 | 0.12 | Lebeau 1999; Gregor 1997; Sun 1995
| Work 1997/1996 | | neutropenic fever in 8 patients; no difference between groups
| Park 1996 | ECOG grade 3 | Seql | 24 | 0 | Conc | 27 | 3.7 | 1.00
| | ECOG grade 4 | | | 0 | | | 0
Other | Takada 2002 | Alopecia (WHO grade ≥3) | Seql | 109 | 12.7 | Conc | 109 | 11.6 | 0.99
| Takada 2002 | Fever (WHO grade ≥3) | Seql | 110 | 1.8 | Conc | 112 | 1.8 | 0.99
| Takada 2002 | Arrhythmias (WHO grade ≥3) | Seql | 110 | 0.0 | Conc | 112 | 1.8 | 0.50
| Park 1996 | Hepatic ECOG grade 3 | Seql | 24 | 0 | Conc | 27 | 0 | 1.00
| | Hepatic ECOG grade 4 | | 0 | | 0

Abbreviations table provided at the end of the Report.

Neither study reported on quality of life, but both reported tumor response data. Both found nonsignificantly higher overall response rates (ORRs) in the concurrent group, although the Park, Kim, Jeong, et al. (1996) study found a fairly large difference in rates that approached significance. In the Takada, Fukuoka, Kawahara, et al., 2002) study, ORRs were 96.5 percent; for concurrent and 92.1 percent for sequential (p=0.25). The complete responses (CRs) were higher in the concurrent group (39.5 percent) than in the sequential group (27.2 percent, p=0.07). In the Park, Kim, Jeong, et al. (1996) trial, the concurrent group achieved an ORR of 88 percent, versus 63 percent for sequential (p=0.13). Mean response duration was longer in the sequential group than in the concurrent group (395 days vs. 180 days, p=0.03).

Among 12 categories of adverse events, 5 were reported by both studies (Summary Table 6). Significant between-group differences were not found in either trial for anemia, thrombocytopenia, infection and fever. Both studies found significantly higher risks of leukopenia for those in the concurrent arm. In the Takada, Fukuoka, Kawahara, et al. (2002) study, grade 3 or 4 leukopenia was seen in 88.4 percent of concurrent-arm patients and in 53.6 percent of sequential-arm patients (p=0.001). The risk of higher grade leukopenia among concurrent TRTx patients in the Park, Kim, Jeong, et al. (1996) study was 51.8 percent, compared with 16.7 percent of sequential TRTx patients (p=0.02). One study reported data on each of 7 adverse events, none of which was marked by significant differences between concurrent and sequential TRTx: treatment-related mortality, nausea/vomiting, esophagitis, renal toxicity; alopecia, arrhythmias, and hepatic toxicity.

Summary. These 2 studies suggest better efficacy outcomes for concurrent TRTx than for sequential TRTx, with inconsistent statistical significance, along with similar rates of adverse events of all types except leukopenia, which was more common for concurrent TRTx. Unadjusted analyses of overall survival found nearly significant differences favoring concurrent over sequential TRTx in 2 studies. One study using adjustment by Cox regression found a significant treatment effect for concurrent TRTx. One study that analyzed progression-free survival reported a nearly significant difference in favor of concurrent TRTx. CRs were more common with concurrent therapy in both studies, but not significantly so (p values were 0.07 and 0.13). One study found a significantly longer response duration for concurrent TRTx. Only 1 of 11 types of adverse events showed significant between-group differences. Leukopenia was more common for concurrent TRTx in both studies.

### Alternating vs. Sequential

Interventions. Both Sun, Zhang, Yin, et al. (1995) and Gregor, Drings, Burghouts, et al. (1997) delivered TRTx in single fractions per day. There was a wide range of total doses in the Sun, Zhang, Yin, et al. (1995) study (30–60 Gy), while the Gregor, Drings, Burghouts, et al. (1997) study gave 50 Gy to all patients. Alternating TRTx was given between weeks 4 and 9 in the Sun, Zhang, Yin, et al. (1995) study, whereas Gregor, Drings, Burghouts, et al. (1997) administered it every 4 weeks between 7 and 20 weeks. In the Gregor, Drings, Burghouts, et al. (1997) study, 4 weeks of TRTx in the alternating arm was given over a period of 13 weeks wherease sequential TRTx was given over 4 consecutive weeks. Sun, Zhang, Yin, et al. (1995) provided TRTx over 6 consective weeks in both the alternating and sequential arms. That study also used platinum-based chemotherapy in the later period of the trial, but no patients received it in the Gregor, Drings, Burghouts, et al. (1997) study. Neither report made clear whether patients received PCI.

Populations. The Sun, Zhang, Yin, et al. (1995) article did not report any baseline patient characteristics; it simply stated that 123 patients had localized disease. Patient groups in the Gregor, Drings, Burghouts, et al. (1997) study (n=335) were well-matched on the 3 key characteristics: age, gender and performance status.

Quality and Reporting. Gregor, Drings, Burghouts, et al. (1997) received a good study quality rating. Sun, Zhang, Yin, et al. (1995) was rated as poor because details were lacking for all quality domains.

Results. Gregor, Drings, Burghouts, et al. (1997) did not find a statistically significant difference between groups in adjusted survival. Median survival was 15 months in the sequential group and 14 months in the alternating group. The entire survival curve for the sequential TRTx group was slightly higher than that of the alternating group. Between 1 and 4 years, survival probabilities differed by 4 percent or less, while the difference was 8 percent at 5 years. In the Sun, Zhang, Yin, et al. (1995) study, statistical test results for survival were missing. At 1 year, the survival probability was higher in the sequential group by 1.5 percent, whereas at 2 an 3 years, it was higher for the alternating group by 14.4 percent and 4 percent. Relative risks (RR) for death at 2 years and 3 years were computed for purposes of meta-analysis. At 2 years, the RR of 0.831 significantly favors alternating TRTx (95 percent CI: 0.692–0.999). The difference is smaller and in the same direction at 3 years, with an RR of 0.957, but nonsignificant (95 percent CI: 0.831–1.102). The difference in progression-free survival favoring sequential TRTx in the Gregor, Drings, Burghouts, et al. (1997) study approached statistical significance (p=0.07). Neither study reported on tumor response or quality of life.

Sun, Zhang, Yin, et al. (1995) reported no data on adverse events (Summary Table 7), while Gregor, Drings, Burghouts, et al. (1997) gave data on 6 types. There were no between-group differences in the incidence of nausea/vomiting, acute esophagitis, or late pulmonary fibrosis. Late esophagitis was significantly less frequent in the alternating group, compared to the sequential group (p=0.01). Both thrombocytopenia and leukopenia were more common (p<0.001) in the alternating group.

Table 7 Adverse Events Reported in Gregor and Sun Trials

Adverse Event | Gregor | Sun
Nausea/vomiting | | NR
Acute Esophagitis | | NR
Late Esophagitis | ▾ | NR
Late Pulmonary Fibrosis | | NR
Thrombocytopenia | ▴ | NR
Leukopenia | ▴ | NR

▴=significantly more frequent in alternating than in sequential arm

▾=significantly less frequent in alternating than in sequential arm

NR=not reported; blank cell=outcome reported, but arms not significantly different

Summary. Results are mixed on the relative impact on outcomes for alternating and sequential TRTx. One study reported that the survival curve for sequential TRTx was always higher than that for alternating TRTx, but the difference was not significant. The other study showed a significant difference in the RR of death at 2 years favoring alternating TRTx. The study reporting progression-free survival found a nearly significant advantage for sequential TRTx. Late esophagitis was more common for the sequential group, but thrombocytopenia and leukopenia were more frequent in the alternating group. These data do not show a clear advantage for either sequential or alternating TRTx.

### Alternating vs. Concurrent

Interventions. The Lebeau, Urban, Brechot, et al. (1999) study delivered doses of 55 Gy to the alternating TRTx group and 50 Gy to the concurrent TRTx group.^*^ Radiation was given in once daily fractions to both groups. Concurrent TRTx was offered across 5 weeks from week 5 through 9, while alternating TRTx occurred across 11 weeks during weeks 6–7, 10–11 and 14–16. Both groups received PCI. Non-platinum chemotherapy was administered.

* During final preparation of this report, a second comparison was published of concurrent versus alternating TRTx (Blackstock, Bogart, Matthews, et al., 2005). The study compared five weeks of continuous radiation concurrent with chemotherapy cycles 1–2 (n=56) versus split-course alternating radiation given during weeks without chemotherapy in cycles 1–3 (n=54). Overall survival did notfdiffer between the two groups (median, 14 versus 15 months; survival at 2 years, 36% versus 31%; survival at 5 years 18% versus 17%). Since radiation began in week 1 for the continuous arm and in week 2 for the alternating arm, this study did not meet inclusion criteria for meta-analysis of early versus late radiation therapy.

Populations. The 2 groups of patients in this study (n=156) were well-matched on baseline characteristics.

Quality and Reporting. This trial received a good study quality rating.

Results. The entire survival curve for alternating TRTx lies slightly above that for concurrent TRTx, but the difference overall was not significant. Differences in survival probabilities ranged from a high at 1 year of 9 percent to a low of 2 percent at 5 years. Progression-free survival and quality of life was not reported. There was no statistically significant difference between groups in tumor response rates.

Four types of adverse events (Summary Table 8) were noted by Lebeau, Urban, Brechot, et al. (1999). The only outcome that showed a statistically significant between-group difference was deaths from pulmonary fibrosis, which were more common in the concurrent TRTx group (p=0.05).

Table 8 Adverse Events Reported in Lebeau Trial

Adverse Event | Lebeau
Deaths from aplasia
Deaths from Pulmonary Fibrosis | ▴
Pulmonary Fibrosis
Neutropenia

▴=significantly more frequent in concurrent than in alternating arm

▾=significantly less frequent in concurrent than in alternating arm

NR=not reported; blank cell=outcome reported, but arms not significantly different

Summary. The single study comparing alternating and concurrent TRTx does not suggest a meaningful improvement in survival associated with alternating TRTx. Overall survival did not differ significantly, with a difference between medians of only 0.5 months favoring alternating TRTx. Deaths from pulmonary fibrosis were more frequent in the concurrent TRTx group.

### Early Alternating vs. Late Alternating

Interventions. The dose given to both groups in the early phase of the Work and colleagues study (Work, Nielsen, Bentzen, et al., 1997/Work, Bentzen, Nielsen, et al., 1996) was 40 Gy; it was increased later to 45 Gy. Radiation was delivered as a single daily fraction in both treatment arms. TRTx was given during weeks 1–2 and 6–7 in the early-alternating group and in weeks 18–19 and 23–24 in the late-alternating group. Given the somewhat lower total dose in this study compared with other studies addressed above and administration in split-course fashion, TRTx was given at a relatively low dose rate. Both groups received PCI. The chemotherapy regimen for all patients was platinum-based; however the regimen was given in an unusual schedule and the doses of drugs actually delivered is unclear..

Populations. Groups receiving early and late alternating TRTx were well-balanced on baseline patient characteristics.

Quality and Reporting. This study was rated as fair in quality. The key deficiency was an inadequate description of the randomization method.

Results. Work and colleagues (Work, Nielsen, Bentzen, et al., 1997/Work, Bentzen, Nielsen, et al., 1996) reported that median survival was slightly longer in the late-alternating group (1.5 months), while 2- and 3-year survival probabilities were slightly higher in the early-alternating group. Overall, there was no significant difference in survival between groups. There was an 18 percent difference at 1 year in percentage without in-field recurrence (PWIFR) favoring late-alternating TRTx, but differences at later times were much smaller and the groups did not differ significantly. Tumor response rates did not differ for the 2 patient groups. No quality of life data were collected.

Of the 6 categories of adverse events, only leukopenia showed a difference between groups (Summary Table 9). This outcome was significantly more common among those receiving early alternating TRTx.

Table 9 Adverse Events Reported in Work Trial

Adverse Event | Work
Treatment-related Mortality
Neurotoxicity
Kidney
Thrombocytopenia
Leukopenia | ▴
Infection

▴=significantly more frequent in early alternating than in late alternating arm

▾=significantly less frequent in early alternating than in late alternating arm

NR=not reported; blank cell=outcome reported, but arms not significantly different

Summary. The single study comparing early and late alternating is does not support conclusions about the relative effectiveness of these approaches to TRTx. There was no significant difference between groups on overall survival, percentage without in-field recurrence and tumor response. Of 6 types of adverse events reported, groups differed only in the frequency of leukopenia, which was significantly higher among those receiving early alternating TRTx.

### Conclusions

Among 6 studies meeting selection criteria for Key Question 1, two trials (n=307) compared concurrent and sequential TRTx. Two trials compared alternating to sequential TRTx (n=458). One trial compared alternating to concurrent TRTx (n=156). The final trial compared early alternating and late alternating TRTx (n=199). Comparing these trials with others addressing TRTx delivery, survival is generally lower is this set relative to studies assessing the effect of hyperfractionation. Although an explanation is not readily apparent, possible reasons include patient selection, stage drift and the adequacy of chemotherapy.

Concurrent vs. Sequential. Results are not conclusive but suggest better outcomes for concurrent TRTx. Although not statistically significant, unadjusted overall survival and CR rates favored concurrent TRTx in both studies. However, adjusted overall survival in the larger study was significantly in favor of concurrent TRTx. A smaller study found significantly longer response duration for concurrent TRTx in 1 study. Out of 11 types of adverse events, only leukopenia occurred significantly more frequently, in the concurrent TRTx group in both studies.

Alternating vs. Sequential. Inconsistent findings were observed in the 2 studies and no conclusions can be drawn that one is superior to the other. The direction of the advantage on overall survival differed in the 2 studies.

Alternating vs. Concurrent. In the single study comparing alternating and concurrent TRTx, there was no statistically significant effect on survival and no conclusions of differential efficacy could be drawn.

Early Alternating vs. Late Alternating. In the single study comparing early versus late alternating TRTx, there was no statistically significant difference in survival, thus no conclusions of differences in efficacy can be reached.

## Key Question 2

For limited-stage SCLC, do outcomes (survival, toxicity, or quality of life) differ if concurrent TRTx is given in early versus late chemotherapy cycles?

### Overview

Six randomized, controlled trials (RCTs) compared outcomes of alternate times to administer TRTx concurrently in first-line therapy for limited stage SCLC (N=1,177). Summary Table 10 summarizes selected study variables; further details are in Summary Table 11 and Appendix Tables 2A–C, 2H.^*^ Each of the three larger trials randomized from 125 to 166 patients per arm (Murray, Coy, Pater, et al., 1993/Coy, Hodson, Murray, et al., 1994/Feld, Payne, Hodson, et al., 1988 [hereafter referred to as “Murray-Coy-Feld”]; Perry, Eaton, Propert, et al., 1987/Ahles, Silberfarb, Rundle, et al., 1994/Perry, Herndon, Eaton, et al., 1988; [hereafter referred to as “Perry-Ahles-Perry”]; James, Spiro, O'Donnell, et al., 2003). Together, the three smaller trials included less than one-fourth of all patients studied (Jeremic Shibamoto, Acimovic, et al., 1997; Qiao, Zhou, Xin, et al., 2004; Skarlos, Samantas, Briassoulis, et al., 2001).

Table 10 Selected study parameters of RCTs comparing times to give concurrent TRTx

study | N | | Pt? | chemoTx regimen | TRTx dose (Gy) | # fracs | TRTx timing | | PCI? | # centers | pub type | quality rating
| early | late | | | | | early | late
Murray, Coy, Pater, et al., 1993/Coy, Hodson, Murray, et al., 1994/Feld, Payne, Hodson, et al., 1988 | 155 | 153 | yes | CAV/PE | 40 | 1/d | wk 4–6 | wk 16–18 | yes | multi | full | good
Perry, Eaton, Propert, et al., 1987/Ahles, Silberfarb, Rundle, et al., 1994/Perry, Herndon, Eaton, et al., 1988 | 125 | 145 | no | CAVE | 50 | 1/d | wk 1–5 | wk 10–14 | yes | multi | full | fair
Jeremic Shibamoto, Acimovic, et al., 1997 | 52 | 51 | yes | PE/CbE | 54 | 2/d | wk 1–4 | wk 6–9 | yes | one | full | fair
Qiao, Zhou, Xin, et al., 2004 | 45 | 45 | yes | CbE | 50 or 60 | 1/d | wk 1–5/6 | wk 12–16/17 | ? | one | full | fair
Skarlos, Samantas, Briassoulis, et al., 2001 | 42 | 39 | yes | CbE | 45 | 2/d | wk 1–3 | wk 10–12 | yes | multi | full | fair
James, Spiro, O'Donnell, et al., 2003 | 159 | 166 | yes | CAV/PE | 40 | 1/d | wk 4–6 | wk 16–18 | yes | multi | abstr | not rated

Abbreviations table provided at the end of the Report.

Table 11 Sample and Methods: Early Versus Late Radiotherapy

Study | N | | Age | % Female | % Performance Status | | | | CTx Regimen | RTx Regimen
Murray, Coy, Pater, et al., 1993/Coy, Hodson, Murray, et al., 1994/Feld, Payne, Hodson, et al., 1988 | Total | 308 | md | | 0 | 1 | 2 | 3 | | Dose | Schedule | PCI?
22 centers | Early | 155 | 61.8 | 40.6 | 21.9 | 65.2 | 12.3 | 0.6 | CAV-PE | 40 Gy | wks 4–6, 1/d, 5/wk, 15/course | 25 Gy, 10 frac
1/85 - 12/88 | Late | 153 | 61.6 | 34.6 | 22.2 | 68.0 | 9.2 | 0.7 | same | 40 Gy | wks 16–18, 1/d, 5/wk, 15/course | same
| | | | | ECOG
Perry, Eaton, Propert, et al., 1987/Ahles, Silberfarb, Rundle, et al., 1994/Perry, Herndon, Eaton, et al., 1988 | Total | 270 | % < 60 | | 0 | 1 | 2/3 | | | Dose | Schedule | PCI?
22 centers | Early | 125 | 48 | 38 | 38 | 48 | 13 | | CAVE | 50 Gy | wks 1–5, 40 Gy+10 Gy boost | 30 Gy, 10 frac, con current with TRTx
1/81 - 6/84 | Late | 145 | 45 | 37 | 42 | 45 | 9 | | same | 50 Gy | wks 10–14, 40 Gy+10 Gy boost
| | | | | CALGB
Jeremic Shibamoto, Acimovic, et al., 1997 | Total | 103 | mn (rng) | | 90, 100 | | 50–80 | | | Dose | Schedule | PCI?
single center | Early | 52 | 57 (40–67) | 40.4 | 52 | | 48 | | PE/Cb-E | 54 Gy | wks 1–4, 2/d, 5/wk | 25 Gy, 10 frac, wks 16, 17
1/88–12/92 | Late | 51 | 57 (44–66) | 39.2 | 47 | | 53 | | same | 54 Gy | wks 6–9, 2/d, 5/wk
| | | | | KPS
Qiao, Zhou, Xin, et al., 2004 | Total | 90 | md (rng) | | | | | | | Dose | Schedule | PCI?
single center | Early | 45 | 57 (36–58) | 24.3 | all randomized patients had KPS ≥70 (excluded if ≤60) | | | | Cb-E | 50–60 Gy | begun 1^st^ CTx cyc, over 6 wks | Not specified for either arm
3/93-1/98 | Late | 45 | 56 (38–69) | 33.3 | | | | | same | 50–60 Gy | begun after 4^th^ CTx cyc, over 6 wks
Skarlos, Samantas, Briassoulis, et al., 2001 | Total | 81 | md (rng) | | 0 | 1 | 2 | 3 | | Dose | Schedule | PCI?
multicenter | Early | 42 | 61(40–76) | 7 | 26 | 50 | 24 | | Cb-E | 45 Gy | wks 1–3, 2/d, 5/wk | 20 Gy, CR 5 4 Gy frac
12/93 - 11/99 | Late | 39 | 60 (37–76) | 10 | 41 | 44 | 15 | | same | 45 Gy | wks 10–12, 2/d, 5/wk | same
| | | | | ECOG
James, Spiro, O'Donnell, et al., 2003 (abstract only) | Total | 325 | md (rng) | | 0–1 | 2–3 | | | | Dose | Schedule | PCI?
multicenter; | Early | 159 | 62 (34–74) | 40 | 91 | 9 | | | CAV-PE | 40 Gy | wks 4–6, 1/d, 5/wk | 25 Gy, 10 frac, neg brain scan
1/93 -1/02 | Late | 166 | 62 (33–74) | 43 | 89 | 11 | | | same | 40 Gy | wks 16–18, 1/d, 5/wk
| | | | | ECOG

Abbreviations table provided at the end of the Report.

Interventions. Available studies did not uniformly define early and late concurrent therapy, with respect to either the chemotherapy cycle or weeks during which they administered TRTx. Most trials (4 of 6) began TRTx in chemotherapy cycle 1 (i.e., week 1) for those randomized to early concurrent therapy; two waited until cycle 2 (week 4) (Murray-Coy-Feld; James, Spiro, O'Donnell, et al., 2003). Those randomized to late concurrent therapy began TRTx in cycle 3 (week 6) in one trial (Jeremic Shibamoto, Acimovic, et al., 1997), cycle 4 (week 10 or 12) in three trials (Perry-Ahles-Perry; Qiao, Zhou, Xin, et al., 2004; Skarlos, Samantas, Briassoulis, et al., 2001), and cycle 6 (week 16) in the remaining two trials (Murray-Coy-Feld, James, Spiro, O'Donnell, et al., 2003).

Five of six RCTs used platinum-etoposide chemotherapy regimens, including two of three larger trials; Perry-Ahles-Perry was the exception. Total TRTx dose was ≥40 Gy in each RCT, and only two used doses greater than 50 Gy (Jeremic Shibamoto, Acimovic, et al., 1997; Qiao, Zhou, Xin, et al., 2004). Three trials gave TRTx over a 3-week period (Murray-Coy-Feld; Skarlos, Samantas, Briassoulis, et al., 2001; James, Spiro, O'Donnell, et al., 2003 2003), one gave TRTx over four weeks (Jeremic Shibamoto, Acimovic, et al., 1997), and two gave TRTX over five or six weeks (Perry-Ahles-Perry; Qiao, Zhou, Xin, et al., 2004). Thus, weekly doses were 10 Gy in two trials (Perry-Ahles-Perry; Qiao, Zhou, Xin, et al., 2004), 13.35 Gy in two trials (Murray-Coy-Feld; James, Spiro, O'Donnell, et al., 2003), and 15 Gy in two trials (Jeremic Shibamoto, Acimovic, et al., 1997; Skarlos, Samantas, Briassoulis, et al., 2001). Four trials administered single daily fractions (Murray-Coy-Feld; Perry-Ahles-Perry; Qiao, Zhou, Xin, et al., 2004; James, Spiro, O'Donnell, et al., 2003) and two gave two fractions per day (Jeremic Shibamoto, Acimovic, et al., 1997; Skarlos, Samantas, Briassoulis, et al., 2001). Five of six trials included PCI for each arm; Qiao, Zhou, Xin, et al. (2004) did not report PCI use.

Study Populations. Most trials studied patients with relatively favorable baseline characteristics, and were nearly always well-balanced across arms for consistently-reported factors (Summary Table 11). In four of six trials, performance status (PS) was 0–1 at enrollment for 75 percent to 91 percent of patients across arms (Murray-Coy-Feld; Perry Ahles-Perry; Skarlos, Samantas, Briassoulis, et al., 2001; James, Spiro, O'Donnell, et al., 2003). PS also was well balanced across arms in Jeremic Shibamoto, Acimovic, et al. (1997), but many patients (~50 percent) had Karnofsky scores of 50–80. Qiao, Zhou, Xin, et al. (2004) excluded patients with Karnofsky PS <60, but did not report PS distribution by arm. For all six trials, the median or mean age ranged from approximately 55 to 62 years, and was balanced across arms. Each trial enrolled mostly men (8.6 percent women in one trial, 33 percent to 43 percent across five others), and had similar proportions of women in each arm.

Other prognostic factors and baseline characteristics were reported inconsistently (Appendix Table 2B *). Only three trials reported the proportion with weight loss at entry (Perry-Ahles-Perry; Jeremic Shibamoto, Acimovic, et al., 1997; Skarlos, Samantas, Briassoulis, et al., 2001). Only three trials reported the proportion with disease outside the lung (Murray-Coy-Feld, Qiao, Zhou, Xin, et al., 2004; Skarlos, Samantas, Briassoulis, et al., 2001). Only one trial reported the proportion of former smokers (Skarlos, Samantas, Briassoulis, et al., 2001). No trials reported racial distributions.

Study Quality and Reporting. The larger studies included one good-quality and one fair-quality multicenter trial, each published in full. The third large trial also was multicenter, but was reported only in abstract and information to rate quality was lacking. Two of three small trials were single-center and one was multicenter; each was of fair quality and published in full.

### Results

In one large and two smaller trials, results significantly favored the early TRTx arms for overall (OS), progression-free (PFS), or local recurrence-free (LRFS) survival (Summary Table 12). Murray-Coy-Feld (n=308) reported significantly longer median OS (21.2 versus 16.0 months; p=0.008) and greater 2- and 3-year survival (40 percent versus 33.7 percent and 29.7 percent versus 21.5 percent, respectively) with early TRTx. Murray-Coy-Feld also reported significantly greater PFS with early TRTx (median, 15.4 versus 11.8 months; 26 percent versus 19 percent at 3 years; p=0.036). Qiao, Zhou, Xin, et al. (2004; n=90) reported longer median OS (26 versus 19 months; p<0.05) and greater 3-year survival (33 percent versus 22 percent) with early TRTx, but did not report an outcome related to progression or recurrence. Jeremic Shibamoto, Acimovic, et al. (1997; n=103) reported significantly greater 2- and 3-year LRFS with early TRTx (90 percent versus 69 percent and 73 percent versus 61 percent, respectively; p=0.011). While median OS (34 versus 26 months) and 2- and 3-year survival also favored early TRTx in the Jeremic Shibamoto, Acimovic, et al. (1997) trial, these results were just barely statistically nonsignificant (p=0.052).

Table 12 Survival Outcomes: Early Versus Late Radiotherapy

Study | N | | Overall Survival | | | | | | Other Outcomes (progression, failure, relapse, etc.)
| | | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
Murray, Coy, Pater, et al., 1993/Coy, Hodson, Murray, et al., 1994/Feld, Payne, Hodson, et al., 1988 | Early | 155 | 21.2 | ~77% | 40% | 29.7% | 23.7% | 20% | 15.4 | ~65% | ~28% | 26%
| Late | 153 | 16.0 | ~63% | 33.7% | 21.5% | 15.1% | 11% | 11.8 | ~48% | ~24% | 19%
| Difference | | 5.2 | 14% | 6.3% | 8.2% | 8.6% | 9% | 3.6 | 17% | 4% | 7%
| | | (p=0.008, log-rank; 0.005 Wilcoxon) | | | | | | (PFS, p=0.036, log-rank; 0.014 Wilcoxon)
Perry, Eaton, Propert, et al., 1987/Ahles, Silberfarb, Rundle, et al., 1994/Perry, Herndon, Eaton, et al., 1988 | Early | 125 | 13.0 | ~53% | ~24% | ~10% | | | 11.0 | ~45% | 15% | ~8%
| Late | 145 | 14.5 | ~62% | ~30% | ~20% | | | 11.2 | ~50% | 25% | ~15%
| Difference | | -1.5 | -9% | -6% | -10% | | | -0.2 | -5% | -10% | -7%
| | | (p=0.144; not significant) | | | | | | (TTF, p=0.238; not significant)
Jeremic Shibamoto, Acimovic, et al., 1997 | Early | 52 | 34 | 90% | 71% | 48% | 35% | 30% | 52 | 94% | 90% | 73% | 63% | 58%
| Late | 51 | 26 | 71% | 53% | 39% | 25% | 15% | 51 | 74% | 69% | 61% | 46% | 37%
| Difference | | 8 | 19% | 18% | 9% | 10% | 15% | 1 | 20% | 21% | 12% | 17% | 21%
| | | (p=0.052) | | | | | | (LRFS, p=0.011)
Qiao, Zhou, Xin, et al., 2004 | Early | 45 | 26 | 78% | | 33% | | 27%
| Late | 45 | 19 | 53% | | 22% | | 16%
| Difference | | 7 | 25% | | 11% | | 11%
| | | (log-rank, p<0.05)
Skarlos, Samantas, Briassoulis, et al., 2001 | Early | 42 | 17.5 | ~65% | 36% | 22% | | | 9.5 | ~40% | ~25% | ~20%
| Late | 39 | 17 | ~80% | 29% | 13% | | | 10.5 | ~35% | ~15% | ~15%
| Difference | | 0.5 | -15% | 7% | 9% | | | -1.0 | 5% | 10% | 5%
| | | (p=0.65, not significant) | | | | | | (TTF, p=0.6, not significant)
James, Spiro, O'Donnell, et al., 2003 | Early | 159 | 13.5 | | | 16%
(abstract only) | Late | 166 | 15.1 | | | 20%
| Difference | | -1.6 | | | -4%
| | | (HR = 1.18; 95% CI: 0.93, 1.51; p=0.18)

Abbreviations table available at the end of the Report.

Between-arm differences in response rates were not statistically significant in any trial (Appendix Table 2F).

In two large and one smaller RCTs, OS and time to treatment failure (TTF) did not differ significantly between arms randomized to early or late TRTx (Summary Table 12). Perry-Ahles-Perry (n=270), the only trial that did not use platinum, reported non-significant differences in OS (P=0.144) and TTF (p=0.238). James, Spiro, O'Donnell, et al. (2003; n=325), the sole trial published as an abstract, only reported OS and also found no significant difference (p=0.18). Skarlos, Samantas, Briassoulis, et al. (2001; n=81) reported nonsignificant differences for median OS (p=0.65) and median TTF (p=0.6).

A small pilot sub-study from one RCT reported the only data comparing quality of life outcomes after early versus late TRTx. Ahles et al. (1994) scored responses to measures of mood, psychosocial function, and cognitive function for 14–17 patients (of n=121) given early TRTx and 10–12 (of n=141) given late TRTx in the Perry-Ahles-Perry trial (Appendix Table 2F).^*^

They compared these with scores for another group randomized to chemotherapy without TRTx (not abstracted). Results suggested larger decrements of mood and psychosocial function after chemotherapy plus TRTx than after chemotherapy alone. However, they found no meaningful differences in magnitude of decrement between early and late TRTx groups.

Table 13 shows that leukopenia/neutropenia and esophagitis were the only adverse events consistently reported by all six trials. Although leukopenia/neutropenia was more common in the early arm of five RCTs, only Qiao, Zhou, Xin, et al. (2004; p<0.05) and James, Spiro, O'Donnell, et al. (2003; p=0.006) reported that differences were statistically significant (Summary Table 14). Of four reporting RCTs, only Murray-Coy-Feld reported significantly more anemia in the early treatment arm (49 percent versus 37 percent, p=0.03). Skarlos, Samantas, Briassoulis, et al. (2001) reported significantly more grade 3 esophagitis with late than with early TRTx. However, the arms did not differ significantly when grades 1–3 were pooled, and the other five trials reported no significant differences in grade 3 or 3+4 combined.

Table 13 Adverse Events, Early versus Late Concurrent TRTx

Adverse Event | Murray/Coy/Feld | Perry/Ahles/Perry | Jeremic 1997 | Qiao 2004 | Skarlos 2001 | James 2003
leukopenia/ neutropenia | | | | ▴ | | ▴
anemia | ▴ | NR | | NR
esophagitis | | | | | ▾

▴=significantly more frequent in early than in late arm

▾=significantly less frequent in early than in late arm

NR=not reported; blank cell=outcome reported, but arms not significantly different

Table 14 Adverse Events: Early Versus Late Radiotherapy

Toxicity Type | Study | Severity or Grade | Early n | % | Late n | % | p | Not Reporting
Treatment-related mortality | Murray 1993 | | 155 | 1.3 | 153 | 1.3 | NS | Jeremic 1997; Qiao 2004; James 2003
| Coy 1994
| Feld 1988
| Perry 1987 | | 125 | 4 | 145 | 1 | NS
| Ahles 1994
| Perry 1998
| Skarlos 2001 | | 42 | 0 | 39 | 0 | NS
Nausea/Vomiting | Murray 1993 | required IV fluids | 155 | 11.6 | 153 | 15.8 | NS | Qiao 2004
| Coy 1994
| Feld 1988
| Perry 1987 | nausea and vomiting, NOS | 122 | 18 | 140 | 10 | NS
| Ahles 1994
| Perry 1998
| Jeremic 1997 | nausea and vomiting, grades 3 & 4 | 52 | 9.6 | 51 | 7.8 | NS
| Skarlos 2001 | grade 3 nausea and vomiting | 42 | 2.5 | 39 | 2.5 | NS
| James 2003 | nausea and vomiting, grades 3 & 4 | 159 | 2 | 166 | 3 | NS
Anorexia | Perry 1987 | >10% weight loss | ? | 14 | NR | NR | | Murray 1993/Coy 1994/Feld 1988; Jeremic 1997; Skarlos 2001; James, 2003
| Ahles 1994
| Perry 1998
| Qiao 2004 | weight loss (% not specified) | 45 | 20 | 45 | 33.3 | NS
Lethargy | | | | | | | | Murray 1993/Coy 1994/Feld 1988; Perry 1987/Ahles 1994/Perry 1998; Jeremic 1997; Qiao 2004; Skarlos 2001; James, 2003
Neurosensory | Murray 1993 | severe | 155 | 0.6 | 153 | 3.3 | NS for all 3 levels combined | Jeremic 1997; Qiao 2004; James, 2003
| Coy 1994 | life-threatening | | 0 | | 1.3
| Feld 1988 | lethal | | 0.6 | | 0
| Perry 1987 | “neuromuscular effects” | 124 | 17 | 144 | 16 | NS
| Ahles 1994
| Perry 1998
| Skarlos 2001 | grade 2 & 3 neurotoxicity | 42 | 0 | 39 | 0 | NS
Hearing loss | | | | | | | | Murray 1993/Coy 1994/Feld 1988; Perry 1987/Ahles 1994/Perry 1998; Jeremic 1997; Qiao 2004; Skarlos 2001; James, 2003
Esophagitis | Murray 1993 | fluids only | 149 | 11.4 | 133 | 6.8 | NS for both levels combined
| Coy 1994 | IV fluids | | 3.4 | | 0.8
| Feld 1988
| Perry 1987 | not specified | ? | 10 | ? | 8
| Ahles 1994
| Perry 1998
| Jeremic 1997 | grades 3 & 4 | 52 | 28.9 | 51 | 25.5 | NS
| Qiao 2004 | | 45 | 42.2 | 45 | 28.9 | NS
| Skarlos 2001 | grade 3 | 42 | 2.5 | 39 | 18 | 0.026
| | | | | (p=0.82 for overall incidence)
| James 2003 | grades 3 & 4 | 159 | 7 | 166 | 4 | NS
Bronchopulmonary | Perry 1987 | not specified | 122 | 9 | 133 | 6 | NS | Murray 1993/Coy 1994/Feld 1988; Qiao 2004; James 2003
| Ahles 1994
| Perry 1998
| Jeremic 1997 | grades 3 & 4 | 52 | 1.9 | 51 | 0 | NS
| Skarlos 2001 | Grade 3 | 42 | 5.0 | 39 | 7.5 | NS
Pneumonitis | Murray 1993 | any | 149 | 3.2 | 133 | 0.7 | NS | Jeremic 1997; Skarlos 2001; James, 2003
| Coy 1994 | lethal | | 0 | | 0
| Feld 1988
| Perry 1987 | not specified | 122 | 9 | 133 | 4.5 | NS
| Ahles 1994
| Perry 1998
| Qiao 2004 | radio-pneumonia | 45 | 8.9 | 45 | 6.7 | NS
Kidney | Murray 1993 | creatinine > 354 μmol/L | 155 | 0 | 153 | 0.7 | NS | Perry 1987/Ahles 1994/Perry 1998; Jeremic 1997; Qiao 2004; James, 2003
| Coy 1994
| Feld 1988
| Skarlos 2001 | grade 2 or 3 | 42 | 0 | 39 | 0 | NS
Anemia | Murray 1993 | Hb <80 g/L | 155 | 49 | 153 | 36.8 | 0.0275 | Perry 1987/Ahles 1994/Perry 1998; Qiao 2004
| Coy 1994
| Feld 1988
| Jeremic 1997 | grades 3 & 4 | 52 | 13.5 | 51 | 7.8 | NS
| Skarlos 2001 | grades 3 & 4 | 42 | 19 | 39 | 12.5 | NS
| James, 2003 | grades 3 & 4 | 159 | 9 | 166 | 5 | NS
Thrombocytopenia | Murray 1993 | <25 × 10^9^/L | 155 | 3.9 | 153 | 2.6 | NS | Qiao 2004
| Coy 1994
| Feld 1988
| Perry 1987 | <25 × 10^9^/L | 122 | 1 | 140 | 2 | NS
| Ahles 1994
| Perry 1998
| Jeremic 1997 | grades 3 & 4 | 52 | 38.5 | 51 | 21.6 | NS
| Skarlos 2001 | grades 3 & 4 | 42 | 21.5 | 39 | 23 | NS
| James, 2003 | grades 3 & 4 | 159 | 9 | 166 | 9 | NS
Leukopenia or neutropenia | Murray 1993 | neutrophils<0.5 × 10^9^/L | 155 | 70.3 | 153 | 61.4 | NS
| Coy 1994
| Feld 1988
| Perry 1987 | WBC<1 × 10^9^/L | 117 | 35 | 118 | 25 | NS
| Ahles 1994
| Perry 1998
| Jeremic 1997 | leukopenia, grades 3 & 4 | 52 | 32.7 | 51 | 41.2 | NS
| Qiao 2004 | grade 2 | 45 | 6.7 | 45 | 24.4
| | grade 3 | | 71.1 | | 57.8 | 0.02 (for 3+4)
| | grade 4 | | 22.2 | | 17.8
| Skarlos 2001 | grades 3 & 4 leukopenia | 42 | 35.5 | 39 | 20.5 | NS
| James, 2003 | grades 3–4 leucopenia | 159 | 74 | 166 | 55 | 0.006
Infection | Murray 1993 | neutropenic fever | 155 | 4.5 | 153 | 3.3 | NS (for all 3 combined) | Qiao 2004; James, 2003
| Coy 1994 | septic shock | | 0.6 | | 0.7
| Feld 1988 | lethal | | 0 | | 1.3
| Perry 1987 | sepsis | 125 | 20 | 140 | 15 | NS
| Ahles 1994
| Perry 1998
| Jeremeic 1997 | grades 3 & 4 | 52 | 13.5 | 51 | 13.7 | NS
| Skarlos 2001 | neutropenic fever | 42 | 5 | 39 | 2.5 | NS
Other | Murray 1993 | severe dermatitis | 149 | 2.0 | 133 | 1.5 | NS (for both combined)
| Coy 1994 | blisters | | 4.0 | | 0.7
| Feld 1988
| Qiao 2004 | mild digestive tract reaction | 45 | 73.3 | 45 | 55.6 | NS

Abbreviations table provided at the end of the Report.

Between-arm differences in treatment-related mortality (3 reporting trials), nausea/ vomiting (5 reporting trials), neurosensory effects (3 reporting trials), bronchopulmonary effects or pneumonitis (3 reporting trials each), thrombocytopenia (5 reporting trials), and infections (4 reporting trials) were not statistically significant.

### Conclusions

Overall, the evidence is equivocal, either finding no difference or a small advantage for early TRTx. One larger trial of good quality significantly favored concurrent therapy given in an early cycle (Murray-Coy-Feld; median OS 21.2 versus 16.0 months; p=0.008), as did 2 smaller trials. Of the two larger trials that that found no significant difference, one did not use platinum chemotherapy and the other has not been published in full text. Meta-analysis on the question of early versus late TRTx was performed to attempt to obtain clearer results.

Leukopenia/neutropenia appeared to be more common with early concurrent TRTx, although differences were statistically significant in only two of six reporting trials. Other events do not appear to be more frequent with either early or late TRTx. However, evidence is limited as adverse events were not reported consistently across all trials.

## Meta-Analysis/Meta-Regression

### Overview

All but one of the studies selected for Key Questions 1 and 2 can be viewed as comparing early and late TRTx. Key Question 2 is limited to studies in which both early and late TRTx were given concurrently with chemotherapy, while Key Question 1 included those with arms defined by TRTx given either concurrently, sequentially or in alternating fashion. Only the study by Lebeau, Urban, Brechot, et al. (1999) is excluded because only 1 week separated the start of TRTx in the study's 2 arms. Four previous meta-analyses have compared the impact of early and late TRTx, but none have included all 11 studies reviewed here. Three meta-analyses are summarized in Summary Table 25; a meta-analysis by Cancer Care Ontario (2003) is omitted because it used much more restrictive study selection criteria, including only 4 studies. The meta-analysis of 8 studies by Fried, Morris, Poole, et al. (2004) used the most rigorous methods and comprised the largest pool of the previous meta-analyses. The present meta-analysis addresses whether the findings of Fried, Morris, Poole, et al. (2004) can be reproduced in light of a larger study pool and different meta-analytic techniques.

Table 25 Summary of Published Meta-Analyses on Early Versus Late Thoracic Radiation Therapy for Limited-Stage Small-Cell Lung Cancer

Study/ Meta-Analysis | Takada 2002 | Murray 1993 | Perry 1998 | Jeremic 1997 | Skarlos 2001 | Work 1997 | James 2003 | Gregor 1997 | Lebeau 1999 | Goto 1999 | Sun 1995 | Qiao 2004 | Park 1996 | Method/ Measures | Handling of Heterogeneity | Results(ratios compare early to late)
Fried, Morris, Poole, et al. (2004) | X | X | X | X | X | X | * | X | | | | | | Fixed effects | M-H χ^2^, subgroup analysis, sensitivity analysis, random effects meta-regression | All studies: 2 yr: OS RR 1.17 (1.02, 1.35); 3 yr OS RR 1.13 (0.92, 1.39)
| | | | | | | | | | | | | | (M-H) | | M-H χ^2^ p=.17, 2 yr, p=.18, 3 yr
| | | | | | | | | | | | | | 2 yr OS | | Excluding Takada had large impact
| | | | | | | | | | | | | | 3 yr OS | | Subgroups: | | 2 yr p | 3 yr p
| | | | | | | | | | | | | | RR | | Hyperfractionation | Y | .001 | .04
| | | | | | | | | | | | | | RD | | | N | NS | NS
| | | | | | | | | | | | | | NNT | | Platinum | Y | .002 | .01
| | | | | | | | | | | | | | | | | N | NS | NS
| | | | | | | | | | | | | | | | Concurrent RTx | Y | NS | NS
| | | | | | | | | | | | | | | | | N | NS | NS
| | | | | | | | | | | | | | | | M-R: hyperfractionation, platinum predicted significant difference between RDs
Pijls-Johannesma, De Ruysscher, Lambin, et al. (2005) | X | X | X | X | X | X | X | | | | | | | Random effects | χ^2^, subgroup analysis, random effects meta-regression | All studies: 2–3 yr OS OR: 0.84 (0.56, 1.28); 5 yr OS OR 0.80 (0.47, 1.38)
| | | | | | | | | | | | | | 2–3 yr OS | | χ^2^ p=.006, 2–3 yr; p=05, 5 yr
| | | | | | | | | | | | | | 5 yr OS | | Subgroups: | | 2–3 yr p | 5 yr p
| | | | | | | | | | | | | | OR, RR | | Platinum | Y | .01 | .01
| | | | | | | | | | | | | | | | | N | .02 | NS
| | | | | | | | | | | | | | | | RTx < 30 d | Y | NS | .006
| | | | | | | | | | | | | | | | M-R: significant association between RTx < 30 d and survival, 5 yr
Huncharek & McGarry (2004) | X | | X | X | X | X | | | X | X | | | | Fixed effects (Peto) | Q, sensitivity analysis | All studies: 1 yr OS P-OR: 1.11 (0.88, 1.40);
| | | | | | | | | | | | | | 1 yr OS | | 2 yr OS P-OR: 1.60 (1.29, 1.99);
| | | | | | | | | | | | | | 2 yr OS | | 3 yr OS P-OR: 1.49 (1.15, 1.93)
| | | | | | | | | | | | | | 3 yr OS | | Q, p<.001, 1 yr; p=.24, 2 yr; p=.81, 3 yr
| | | | | | | | | | | | | | Peto OR | | Subgroups: | 1 yr p | 2 yr p | 3 yr p
| | | | | | | | | | | | | | | | -Work, -Lebeau | <.05 | <.05 | <.05
| | | | | | | | | | | | | | | | Platinum-Y | <.05 | <.05 | <.05
| | | | | | | | | | | | | | | | Double-counted data at 2 yr, 3 yr (Goto is preliminary report of Takada)

* James, Spiro, O'Donnell, et al. (2003) study included by Fried, Morris, Poole, et al. (2004) only in informal post-hoc analysis; M-H: Mantel-Haenszel stratified-adjusted analysis; M-R: meta-regression; N: no; NS: not significant; OR: odds ratio; OS: overall survival; P-OR: Peto odds ratio; Q: heterogeneity statistic; RD: risk difference; RR: risk ratio; RTx: radiation therapy; X: included; Y: yes.

Fried, Morris, Poole, et al. (2004) used the Mantel-Haenszel pooling method and found no significant heterogeneity at either 2 or 3 years; thus, fixed-effects models were employed. A significant increase in 2-year survival was found for early TRTx over late TRTx (RR: 1.17, 95 percent CI: 1.02–1.35). The effect was not significant at 3 years (RR: 1.13, 95 percent CI: 0.92–1.39). Subgroups of studies using hyperfractionation and platinum regimens had significant increases in 2- and 3-year survival favoring early TRTx, nonsignificant results were found for subgroups that did not use hyperfraction and platinum. Random effects meta-regression of risk differences (RDs) found that higher RDs were seen at both 2 and 3 years when studies used both hyperfractionation and platinum chemotherapy. Thus, larger effects of early over late TRTx were associated with combining hyperfractionation and platinum chemotherapy.

The present meta-analysis differs from that of Fried, Morris, Poole, et al. (2004) in the following ways: it included 3 additional studies; it used inverse variance weighting rather than the Mantel-Haenszel pooling method; and random effects meta-regression was carried out using RRs for this analysis and RDs by Fried, Morris, Poole, et al. (2004). In addition, Fried, Morris, Poole, et al. (2004) created 3 subgroups from the combination of hyperfractionation and platinum and used indicator variables for them in the meta-regression. This Review kept these variables separate. It could be argued that the hetereogeneity of comparisons across studies is too great to warrant pooling them. Like previous meta-analyses on this topic, we address this concern by using influence analysis, subgroup/sensitivity analysis, and meta-regression to investigate whether potential sources of hetereogeneity are associated with different results.

2-Year Mortality. The funnel plot in Figure 2 shows asymmetry in the lower right portion, suggestive of publication bias. The Egger regression test (Summary Table 15) reveals that the intercept differs significantly from zero. These results suggest the presence of publication bias.

Table 15 Egger Linear Regression Test for Publication Bias, 2-Year Mortality

| Coefficient | Standard Error | L95 | U95 | t | p value
Intercept | -2.444 | 0.936 | -4.658 | -0.230 | -2.61 | 0.035

Figure 2. Two-Year Mortality Funnel Plot, Early vs. Late Thoracic Radiotherapy for Limited Stage Small-Cell Lung Cancer

Summary Table 16 and Figure 3 show 2-year RRs for each individual trial, along with 95 percent confidence intervals (CIs). It should be noted that all RRs were computed based on data from articles for all studies except Park, Kim, Jeong, et al. (1996). The Park, Kim, Jeong, et al. (1996) article did not give survival probabilities at yearly periods so an author was contacted who provided data for a larger sample than was described in the original articles. The Sun, Zhang, Yin, et al. (1995) and Takada, Fukuoka, Kawahara, et al. (2002) trials both obtained 2-year RRs showing a significant reduction in the risk of mortality for early TRTx. One study (Perry, Herndon, Eaton, et al. 1998) found a slight nonsignificant increase in mortality for early TRTx and the remaining 6 studies yielded nonsignificant decreases in mortality for early TRTx.

Table 16 Individual Trial 2-Year Mortality Relative Risks, Confidence Intervals and Covariate Matrix

Study | Early Deaths | Early n | Late Deaths | Late n | RR | L95 | U95 | Earliest | Hyper | Plat | Conc | GQ
Murray | 93 | 155 | 101 | 153 | 0.909 | 0.766 | 1.079 | 0 | 0 | 1 | 1 | 1
Sun | 46 | 64 | 51 | 59 | 0.831 | 0.692 | 0.999 | 0 | 0 | 0 | 0 | 0
Park | 23 | 32 | 34 | 47 | 0.994 | 0.751 | 1.314 | 1 | 1 | 1 | 0 | 0
Gregor | 126 | 170 | 127 | 165 | 0.963 | 0.852 | 1.088 | 0 | 0 | 0 | 0 | 1
Jeremic | 15 | 52 | 24 | 51 | 0.613 | 0.366 | 1.028 | 1 | 1 | 1 | 1 | 0
Work | 79 | 99 | 81 | 100 | 0.985 | 0.859 | 1.130 | 1 | 0 | 1 | 0 | 0
Perry | 104 | 125 | 113 | 145 | 1.068 | 0.950 | 1.200 | 1 | 0 | 0 | 1 | 0
Skarlos | 27 | 42 | 28 | 39 | 0.895 | 0.664 | 1.208 | 1 | 1 | 1 | 1 | 0
Takada | 52 | 114 | 74 | 114 | 0.703 | 0.552 | 0.895 | 1 | 1 | 1 | 0 | 1

Figure 3. Two-Year Mortality Random Effects Forest Plot, Early vs. Late Thoracic Radiotherapy for Limited Stage Small-Cell Lung Cancer, All Trials

The Q statistic value obtained here (Summary Table 17) exceeds the threshold for concluding that significant heterogeneity of treatment effects exists, therefore a random effects pooled estimate was computed (see forest plot in Figure 3). The pooled RR is 0.921 and the 95 percent CI overlaps the null value of 1.0 (0.844, 1.005). Figure 4 presents the results of influence analysis, in which each individual study is excluded from the random effects pooled estimate. This graph can be interpreted by finding the studies that depart to the greatest extent from the vertical line for the full pooled estimate RR of 0.92. When the Perry study is excluded, the lowest RR estimate, 0.898, is obtained. So Perry exerts the greatest influence of pulling the pooled estimate toward the null or an advantage for late TRTx. Exclusion of the Takada, Fukuoka, Kawahara, et al. (2002) study results in the highest RR estimate, 0.955. Takada, Fukuoka, Kawahara, et al. (2002) is the most influential study in drawing the pooled estimate in the direction favoring early TRTx. Exclusion of the Perry study was the only instance in which a significant pooled result was obtained. However, as a whole, excluding any individual study has little influence on the estimate of the pooled RR.

Table 17 Results from Heterogeneity Tests and Random Effects Meta-Analysis

| Study n | Subject n | Q | pvalue | RE RR | L95 | U95 | Z | P Value
2-Year Mortality | 9 | 1726 | 15.393 | 0.052 | 0.921 | 0.844 | 1.005 | -1.852 | 0.064

Figure 4. Two-Year Mortality Random Effects Influence Plot, Early vs. Late Thoracic Radiotherapy for Limited Stage Small-Cell Lung Cancer

Summary Table 18 gives the results of subgroup/sensitivity analysis. Selection of variables defining subgroups was constrained by the relatively small pool of studies. Fine gradations of variables dilute the power to detect differences between early and late TRTx. Two concerns guide interpretation of subgroup results: the magnitude of differences in RR point estimates for different levels of a variable and whether statistical significance is achieved in any subgroup. Q statistic values exceeded the threshold for significant heterogeneity in 4 instances: among those studies that delivered the early TRTx at the earliest time (beginning in the first week of chemotherapy), those that did not use platinum chemotherapy, those that gave TRTx and chemotherapy concurrently, and those studies rated as being of good quality. These subgroups were pooled using random-effects models, while all other subgroups were pooled with fixed-effects.

Table 18 Results of Subgroup/Sensitivity Analyses, Two-Year Mortality

2-Year Mortality | Study n | Subject n | Q | P value | Model | RR | L95 | U95 | Z | P value
Earliest-Yes | 6 | 960 | 12.796 | 0.025 | RE | 0.914 | 0.792 | 1.054 | -1.241 | 0.215
Earliest-No | 3 | 766 | 1.720 | 0.423 | FE | 0.918 | 0.841 | 1.001 | -1.929 | 0.054
Hyperfractionation-Yes | 4 | 491 | 4.921 | 0.178 | FE | 0.815 | 0.702 | 0.946 | -2.691 | 0.007
Hyperfractionation-No | 5 | 1235 | 5.893 | 0.207 | FE | 0.972 | 0.913 | 1.035 | -0.890 | 0.373
Platinum-Yes | 6 | 998 | 8.300 | 0.140 | FE | 0.905 | 0.829 | 0.987 | -2.258 | 0.024
Platinum-No | 3 | 728 | 5.212 | 0.074 | RE | 0.964 | 0.848 | 1.096 | -0.563 | 0.573
Concurrent RTx-Yes | 4 | 762 | 6.285 | 0.099 | RE | 0.938 | 0.799 | 1.100 | -0.790 | 0.430
Concurrent RTx-No | 5 | 964 | 7.726 | 0.102 | FE | 0.920 | 0.854 | 0.992 | -2.182 | 0.029
Good Quality-Yes | 3 | 871 | 5.209 | 0.074 | RE | 0.874 | 0.744 | 1.027 | -1.638 | 0.101
Good Quality-No | 6 | 855 | 8.647 | 0.124 | FE | 0.975 | 0.906 | 1.050 | -0.672 | 0.501

Use of hyperfractionation was the variable with the greatest difference in point estimates of RR between subgroups of studies. Inclusion of studies using hyperfractionation produced a significant pooled RR of 0.815 (95 percent CI: 0.702–0.946). Studies that used once daily fractionation had a pooled RR much closer to the null, 0.972 (95 percent CI: 0.913–1.035). There was a moderate difference between point estimates of those studies that did and did not use platinum. Studies using platinum in chemotherapy regimens obtained a greater reduction in mortality, with a significant RR of 0.905 (95 percent CI: 0.829–0.987). Those not using platinum yielded an RR close to the null, 0.964 (95 percent CI: 0.848–1.096). The set of studies that offered the earliest early TRTx did not result in a statistically significant reduction in mortality at 2 years for early TRTx (RR=0.914, 95 percent CI: 0.792–1.054). The point estimate for those studies not among the earliest was nearly identical and also nonsignificant (RR=0.918, 95 percent CI: 0.841–1.001). Those using concurrent TRTx had a nonsignificant RR of 0.938 (95 percent CI: 0.799–1.100) and those not using concurrent TRTx had a significant RR of 0.920 (95 percent CI: 0.854–0.992). There was a considerable difference between studies of good quality and lesser quality, but pooled results were nonsignificant for both. Good quality studies produced a RR of 0.874 (95 percent CI: 0.744–1.027). Lesser quality studies had a RR of 0.975 (95 CI: 0.906–1.050). A random effects meta-regression (Table 19) found that no variables was a significant predict of differences in treatment effect at 2 years, but hyperfractionation was nearly significant (p=0.07).

Table 19 Results of Meta-Regression

2 Year Mortality
Model | Z | p value | Initial tau squared | Model tau squared
Earliest | 0.26 | 0.797 | 0.0077 | 0.0086
Hyperfractionation | -1.81 | 0.070 | | 0.0034
Platinum | -0.98 | 0.327 | | 0.0070
Concurrent | 0.57 | 0.571 | | 0.0074
Good Quality | -0.82 | 0.414 | | 0.0073

3-Year Mortality. The funnel plot (Figure 5) suggests the presence of publication bias. Point estimates appear to be missing in the lower right region of the plot. Linear regression (Egger test, Table 20) shows that the intercept differs significantly from zero, confirming that publication bias may be present.

Table 20 Egger Linear Regression Test for Publication Bias, 3Year Mortality

| Coefficient | Standard Error | L95 | U95 | t | p value
Intercept | -2.351 | 0.540 | -3.573 | -1.130 | -4.35 | 0.002

Figure 5. Three-Year Mortality Funnel Plot, Early vs. Late Thoracic Radiotherapy for Limited Stage Small-Cell Lung Cancer

Three-year mortality RRs for individual trials are given in Table 21. Three trials obtained RR estimates favoring late TRTx, while the other 8 favor early TRTx. The 95 percent CIs all overlap the null value RR of 1.0.

Table 21 Individual Trial 3-Year Mortality Relative Risks, Confidence Intervals and Covariate Matrix

Study | Early Deaths | Early N | Late Deaths | Late n | RR | L95 | U95 | Earliest | Hyper | Plat | Conc | GQ
Murray | 109 | 155 | 120 | 153 | 0.897 | 0.786 | 1.023 | 0 | 0 | 1 | 1 | 1
Sun | 54 | 64 | 52 | 59 | 0.957 | 0.831 | 1.102 | 0 | 0 | 0 | 0 | 0
Park | 28 | 32 | 43 | 47 | 0.956 | 0.817 | 1.119 | 1 | 1 | 1 | 0 | 0
Gregor | 150 | 170 | 140 | 165 | 1.040 | 0.955 | 1.132 | 0 | 0 | 0 | 0 | 1
Jeremic | 27 | 52 | 31 | 51 | 0.854 | 0.607 | 1.203 | 1 | 1 | 1 | 1 | 0
Work | 86 | 99 | 88 | 100 | 0.987 | 0.888 | 1.097 | 1 | 0 | 1 | 0 | 0
Perry | 115 | 125 | 128 | 145 | 1.042 | 0.963 | 1.128 | 1 | 0 | 0 | 1 | 0
Skarlos | 33 | 42 | 34 | 39 | 0.901 | 0.739 | 1.099 | 1 | 1 | 1 | 1 | 0
Takada | 80 | 114 | 91 | 114 | 0.879 | 0.756 | 1.023 | 1 | 1 | 1 | 0 | 1
James | 134 | 159 | 133 | 166 | 1.052 | 0.951 | 1.164 | 1 | 0 | 1 | 1 | 0
Qiao | 30 | 45 | 35 | 45 | 0.857 | 0.662 | 1.111 | 0 | 0 | 1 | 1 | 0

Table 22 shows that the Q statistic value does not exceed the level for concluding that significant heterogeneity of effects is present. Thus, a fixed effects model was used to compute a pooled 3-year RR (see forest plot in Figure 6). The obtained estimate was 0.991 (95 percent CI: 0.955–1.029). Based on these results, it cannot be concluded that use of early TRTx significant reduces the risk of mortality at 3 years.

Table 22 Results from Heterogeneity Tests and Fixed Effects Meta-Analysis

| Study n | Subject n | Q | P value | FE RR | L95 | U95 | Z | P Value
3-Year Mortality | 11 | 2141 | 12.019 | 0.284 | 0.991 | 0.955 | 1.029 | -0.457 | 0.648

Figure 6. Three-Year Mortality Fixed Effects Forest Plot, Early vs. Late Thoracic Radiotherapy for Limited Stage Small-Cell Lung Cancer, All Trials

The influence analysis plot in Figure 7 shows only extremely small changes in the pooled RR estimate when individual studies are excluded. When the Perry study is excluded, the lowest pooled RR estimate is produced: 0.977. This study has the greatest impact on drawing the pooled RR toward the null or effects favoring late TRTx. The largest pooled RR is derived when the Murray study is excluded: 1.000. Murray has the strongest influence on pulling the pooled RR away from the null, favoring early TRTx. Point estimates changed very little when individual studies were excluded.

Figure 7. Three-Year Mortality Fixed Effects Influence Plot, Early vs. Late Thoracic Radiotherapy for Limited Stage Small-Cell Lung Cancer

Results of subgroup/sensitivity analysis are presented in Summary Table 23. The subset of studies using hyperfractionation yielded a significant pooled RR of 0.908 (95 percent CI: 0.828–0.995). Those that used once daily fractionation had a nonsignificant pooled RR of 1.008 (95 percent CI: 0.968–1.050). No other subgroup produced a significant result. Studies in which platinum was part of chemotherapy regimens had an RR of 0.958 (95 percent CI: 0.910–1.009). Non-platinum studies produced an RR of 1.029 (95 percent CI: 0.975–1.085). The group of studies in which early TRTx was begun at the earliest time produced a nearly null-value RR (0.998, 95 percent CI: 0.953–1.045). Those studies that began early TRTx after the first week of chemotherapy produced a similar RR (0.980, 95 percent CI: 0.921–1.042). Studies that offered concurrent RTx had a similar pooled RR (0.997, 95 percent CI: 0.947–1.051) compared with those that did not (RR: 0.985, 95 percent CI: 0.935–1.038). There was a modest difference between studies of good quality versus lesser quality. Good quality studies had an RR of 0.948 (95 percent CI: 0.843–1.064), while fair and poor quality studies had an RR of 1.000 (95 CI: 0.956, 1.047). Results of random effects meta-regression are shown in Summary Table 24. Use of hyperfractionation (p=0.04) was the only significant predictor, while use of platinum (p=0.06) was nearly a significant predictor of differences in treatment effects.

Table 23 Results of Subgroup/Sensitivity Analyses, Three-Year Mortality

3-Year Mortality | Study n | Subject n | Q | P value | Model | RR | L95 | U95 | Z | P value
Earliest-Yes | 7 | 1285 | 7.037 | 0.317 | FE | 0.998 | 0.953 | 1.045 | -0.089 | 0.929
Earliest-No | 4 | 856 | 4.770 | 0.189 | FE | 0.980 | 0.921 | 1.042 | -0.644 | 0.520
Hyperfractionation-Yes | 4 | 491 | 0.722 | 0.868 | FE | 0.908 | 0.828 | 0.995 | -2.061 | 0.039
Hyperfractionation-No | 7 | 1650 | 7.095 | 0.312 | FE | 1.008 | 0.968 | 1.050 | 0.406 | 0.685
Platinum-Yes | 8 | 1413 | 7.302 | 0.398 | FE | 0.958 | 0.910 | 1.009 | -1.637 | 0.102
Platinum-No | 3 | 728 | 1.167 | 0.558 | FE | 1.029 | 0.975 | 1.085 | 1.039 | 0.299
Concurrent RTx-Yes | 6 | 1177 | 7.872 | 0.163 | FE | 0.997 | 0.947 | 1.051 | -0.098 | 0.922
Concurrent RTx-No | 5 | 964 | 4.045 | 0.400 | FE | 0.985 | 0.935 | 1.038 | -0.549 | 0.583
Good Quality-Yes | 3 | 871 | 5.580 | 0.061 | RE | 0.948 | 0.843 | 1.064 | -0.908 | 0.364
Good Quality-No | 8 | 1270 | 5.981 | 0.542 | FE | 1.000 | 0.956 | 1.047 | 0.015 | 0.988

Table 24 Results of Meta-Regression

3 Year Mortality
Model | Z | p value | Initial tau squared | Model tau squared
Earliest | 0.40 | 0.688 | 0.0008 | 0.0016
Hyperfractionation | -2.05 | 0.040 | | <0.0001
Platinum | -1.88 | 0.060 | | <0.0001
Concurrent | 0.12 | 0.906 | | 0.0016
Good Quality | -0.61 | 0.540 | | 0.0015

Summary. This meta-analysis indicates that the findings of Fried, Morris, Poole, et al. (2004) are not reproducible when different pooling methods are used and 3 additional studies are included. We found evidence of publication bias at both 2 and 3 years, while Fried, Morris, Poole, et al. (2004) found it at neither time. Significant heterogeneity was observed at 2 years here but not at 3 years. Thus, we used a random effects model at 2 years and a fixed effects model at 3 years, but Fried, Morris, Poole, et al. (2004) did not find significant heterogeneity at either period and used only fixed effects models. While Fried, Morris, Poole, et al. (2004) reported a significant advantage for early TRTx at 2 years and nonsignificance at 3 years, nonsignificant results were obtained here at both periods.

Subgroups including studies using hyperfractionation or platinum yielded significant advantages for early TRTx at 2 years in both Fried, Morris, Poole, et al. (2004) and this meta-analysis. At 3 years, Fried, Morris, Poole, et al. (2004) reported that both subgroups retained significance, while here only hyperfractionation was significant. The current meta-regression found hyperfractionation to be nearly significant (p=0.07) at 2 years; hyperfractionation was significant at 3 years (p=0.04) and platinum was nearly significant at 3 years (p=0.06). Fried, Morris, Poole, et al. found that hyperfractionation and platinum predicted heterogeneity in risk differences.

As an exercise, we ran multiple variable meta-regression models, but none were significant at either period. In particular, hyperfractionation and platinum were not significant independent predictors here in multiple variable models. In contrast, Fried, Morris, Poole, et al. (2004) found larger effects when the variables were combined. Any meta-gresssion with multiple variables models is limited by the risk of overfitting when the pool of studies is small.

### Conclusions

All but one of the studies selected for Key Questions 1 and 2 can be viewed as comparing early and late TRTx. Therefore, these studies were pooled to give a more robust analysis of early versus late TRTx. Overall, we did not find significant reductions in 2- and 3-year mortality for early TRTx over late TRTx. The RR at 2 years was 0.921 (95 percent CI: 0.844–1.005) and the RR at 3 years was 0.991 (0.955, 1.029). Although the overall analysis was nonsignificant, sensitivity analysis suggests that if there is an advantage favoring early TRTx it would seem to depend on use of hyperfractionation and possibly use of platinum chemotherapy.

## Key Question 3

For limited-stage SCLC, do outcomes (survival, toxicity, quality of life) of primary therapy differ if one varies dose rate, treatment interval, or fractionation scheme for delivering TRTx? Comparisons of interest include:

- accelerated regimens (>10 Gy per week completed over a short interval) versus standard duration regimens (≤10 Gy per week) versus split courses delivered over the standard interval; and
- single daily fractions versus hyperfractionated (two or more daily fractions or concomitant boost).

### Overview

Two randomized controlled trials (RCTs) compared one versus two fractions per day for previously-untreated limited stage SCLC (Turrisi, Kim, Blum, et al., 1999/Yuen, Zou, Turrisi, et al., 2000 [hereafter referred to as “Turrisi/Yuen”]; Schild, Bonner, Shanahan, et al., 2004/Sloan, Bonner, Hillman, et al., 2002/Bonner, Sloan, Shanahan, et al., 1999 [hereafter referred to as “Schild/Sloan/Bonner”]; N=678). No other randomized trials directly compared dose rates, treatment intervals or fractionation schemes. Summary Table 26 summarizes selected characteristics; further details are in Appendix Tables 3A–C, 3H.^*^

Table 26 Selected study characteristics of RCTs comparing one versus two fractions per day

study | N | | chemoTx regimen | TRTx dose, Gy | | # fractions × size; TRTx duration | | TRTx started | PCI?
| 2/d | 1/d | | 2/d | 1/d | 2/day | 1/day
Turrisi, Kim, Blum, et al., 1999/Yuen, Zou, Turrisi, et al., 2000 | 211 | 206 | PE | 45 | 45 | 30 × 1.5 Gy; 3 wks | 25 × 1.8 Gy; 5 wks | week 1 | yes
Schild, Bonner, Shanahan, et al., 2004/Sloan, Bonner, Hillman, et al., 2002/Bonner, Sloan, Shanahan, et al., 1999 | 130 | 131 | PE | 48 | 50.4 | 32 × 1.5 Gy; 6 wks^*^ | 28 × 1.8 Gy; 6 wks | week 13 | yes

* Split course: 16 fractions over 1.5 weeks, 2.5 weeks rest, then final 16 fractions over 1.5 weeks

Abbreviations table provided at the end of the Report.

Interventions. While total radiation doses were similar (45–50 Gy), and each trial compared one versus two fractions per day, they differed with respect to TRTx timing relative to chemotherapy cycles and other regimen features. The Turrisi/Yuen trial began TRTx in week one of cycle one, used the same total dose (45 Gy) in each arm, and gave radiation continuously (5 days/week for 3 or 5 weeks) in each arm. Thus, patients randomized to two fractions per day received 3 Gy daily and 15 Gy weekly, while those randomized to one fraction per day received 1.8 Gy daily and 9 Gy weekly.

The Schild/Sloan/Bonner trial administered three chemotherapy cycles, then restaged and randomized patients and began TRTx at week 13. Patients whose tumor had progressed during the initial three cycles were excluded if a single radiation field no longer encompassed the full extent of disease. Those randomized to two fractions per day received two split courses, each 24 Gy over 1.5 weeks, separated by 2.5 weeks' rest. Those randomized to one fraction per day received 50.4 Gy over 6 weeks, as 5 days/week of continuous TRTx. Thus, patients in the two-per-day arm received 3 Gy each treatment day, and 16 Gy/week in each of two 1.5 week courses. Those in the one-per-day arm received 1.8 Gy daily and 9 Gy weekly for 5 weeks and 3 days.

Both RCTs used cisplatin-etoposide chemotherapy (Summary Table 26). However, cisplatin dose in the Turrisi/Yuen trial was 60 mg/m^2^ each 21-day cycle, but was 30 mg/m^2^ each 28 day cycle in the Schild/Sloan/ Bonner trial (Appendix Table 3C).^*^

Study Populations. Each trial's study population had relatively good prognosis, and was well-balanced across arms for consistently reported baseline characteristics (Summary Table 27, Appendix Table 3B).^*^ More than 90 percent of patients had good performance status (PS) of 0–1 at enrollment. Median or mean age ranged from 61 to 63 years across arms. Each trial enrolled mostly men (41 percent to 43 percent women across arms). Each reported the proportion of patients with weight loss at entry, and few (1–5 percent) had lost more than 10 percent.

Table 27 Sample and Methods: Alternative Fractionations Schemes (once versus twice daily)

Study | N | | Age | % Female | % Performance Status | | | | CTx Regimen | RTx Regimen
Turrisi, Kim, Blum, et al., 1999/Yuen, Zou, Turrisi, et al., 2000 | Total | 417 | md (rng) | | 0 | 1 | 2 | 3 | PE (4 × 21 day cycles; 1 or 2 during, 2 or 3 after TRTx) | Dose | Schedule | PCI?
multicenter trial | 1 F/d | 206 | 63 (34–80) | 41 | 43 | 51 | 5 | | | 1 F/d:
5/89–7/92 | 2 F/d | 211 | 61 (30–82) | 42 | 39 | 55 | 5 | | | 45 Gy | 1.8 Gy/frac, 5 d/wk, 5 wks, begun in 1^st^ wk of CTx | 10 × 2.5 Gy, if CR
| | | | | | | | | | 2 F/d
| | | | | | | | | | 45 Gy | 1.5 Gy/frac, 5 d/wk, 3 wks, begun in 1^st^ wk of CTx | same
Schild, Bonner, Shanahan, et al., 2004/Sloan, Bonner, Hillman, et al., 2002/Bonner, Sloan, Shanahan, et al., 1999 | Total | 261 | mn (rng) | | 0–1 | 2 | | | PE (6 × 28 day cycles; 3 before, 2 during, 1 after TRTx) | Dose | Schedule | PCI?
multicenter trial | 1 F/d | 131 | 61.8 (38–81) | 42.0 | 97.7 | 5.3 | | | | 1 F/d:
9/90 –11/96 | 2 F/d | 130 | 62.1 (37–79) | 43.1 | 93.1 | 6.9 | | | | 50.4 Gy | 28 × 1.8 Gy fracs, 38 d, 1^st^ 39.6 Gy in AP-PA fields, last 10.8 Gy in oblique fields excluding spine, wks 13–16 | 15 × 2 Gy if CR
| | | | | | | | | | 2 F/d
| | | | | | | | | | 48 Gy | 32 × 1.5 Gy fracs; ≥ 4 hours apart; split course (16 fracs in 1.5 weeks; 2.5 weeks rest; then 16 fracs in 1.5 weeks) | same

Abbreviations table provided at the end of the Report.

The two trials did not consistently report other prognostic factors or baseline characteristics (Appendix Table 3B).^*^ One trial reported both the proportion with disease outside the lung and the patients' racial distribution (Turrisi/Yuen). The other trial stratified patients by response to initial chemotherapy (Schild/ Sloan/Bonner). Neither trial reported the proportion of former or current smokers.

Study Quality and Reporting. Both trials were multicenter studies, published in full, and rated as good quality.

### Results

The Turrisi/Yuen trial, using immediate concurrent TRTx, found that overall survival (OS) significantly favored the 2/day arm (Summary Table 28). The trial (n=211 2/day arm, 206 1/day arm) reported significantly longer median OS (23 versus 19 months; HR=1.2, 95 percent CI: 1.0–1.6; p=0.04) and greater 2- and 5-year survival (47 percent versus 41 percent, and 26 percent versus 16 percent, respectively) with two fractions per day (Turrisi/Yuen). However, the difference in failure-free survival at 2 years (29 percent versus 24 percent) was not statistically significant (p=0.10). Between-arm differences in response rates also were not statistically significant (Appendix Table 3F).^*^

Table 28 Survival Outcomes: Alternative Fractionations Schemes (once versus twice daily)

| | | Overall Survival | | | | | | Failure- or Progression-Free Survival
Study | N | | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Med | | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
Turrisi, Kim, Blum, et al., 1999/Yuen, Zou, Turrisi, et al., 2000 | 1 F/d | 206 | 19 | ~75% | 41% | ~32% | ~29% | 16% | FFS: | | | 24%
| 2 F/d | 211 | 23 | ~70% | 47% | ~28% | ~20% | 26% | | | | 29%
| Difference | | 4 | ~5% | 6% | ~4% | ~9% | 10% | | | | 5%
| | | (log-rank p=0.04; HR 1.2, 95% CI: 1.0, 1.6) | | | | | | | | | (p=0.10)
Schild, Bonner, Shanahan, et al., 2004/Sloan, Bonner, Hillman, et al., 2002/Bonner, Sloan, Shanahan, et al., 1999 | 1 F/d | 131 | 20.6 | ~74% | 44% | ~33% | ~23% | 20.40% | PFS: ~14 | ~14 | ~57% | 31.30% | ~25% | ~23% | 19.80%
multicenter trial | 2 F/d | 130 | 20.6 | ~74% | 44% | ~31% | ~26% | 22% | | ~14 | ~58% | 30.80% | ~27% | ~21% | 21%
9/90 –11/96 | Difference | | 0 | 0% | 0% | -2% | 3% | 1.6% | | 0 | 1% | -0.5% | 2% | -2% | 1.2%
| | | (p=0.68, log-rank) | | | | | | (p=0.68, log-rank)

Abbreviations table provided at the end of the Report.

Using late TRTx and split course therapy in the 2/day arm, Schild/Sloan/Bonner reported no significant difference between arms in overall (p=0.68) or progression-free (p=0.68) survival. Since this trial stratified patients by responses to three cycles of chemotherapy given before randomization, excluded any whose disease progressed substantially, and used an extended split-course rather than accelerated schedule in the 2/day arm, response rates could not be compared across arms or trials in a meaningful way.

Neither trial reported quality of life outcomes (Appendix Table 3F).^*^

The trials differed with respect to the frequency and/or between-arm comparisons of some adverse events, but were similar for others (Summary Table 29). Schild/Sloan/Bonner reported 3 percent treatment-related deaths in the 2/day arm and none in the 1/day arm (p=0.04), while Turrisi/Yuen reported similar rates in each arm (2–3 percent). Turrisi/Yuen reported no significant differences between arms in the proportion of patients experiencing one or more grade 3 (25 percent versus 23 percent), or grade 4 (62 percent versus 63 percent) toxicities. In contrast, Schild/Sloan/ Bonner reported significantly more patients in the 2/day arm than the 1/day arm with a non-hematologic toxicity of grade ≥3 (54.6 percent versus 38.9 percent, p=0.01) or grade 5 (3 percent versus zero, p=0.04).

Table 29 Adverse Events: Alternative Fractionations Schemes (once versus twice daily)

Toxicity Type | Study | Severity or Grade | 1 F/d n | % | 2 F/d n | % | p | Not Reporting
Treatment-related mortality | Turrisi 1999 | | 203 | 2 | 206 | 3 | NS
| Yuen 2000
| Bonner 1999 | | 131 | 0 | 130 | 4 | 0.04
| Sloan 2002
| Schild 2004
Nausea/Vomiting | Turrisi 1999 | grade 3 vomiting | 203 | 8 | 206 | 8
| Yuen 2000 | grade 4 vomiting | | 2 | | 1 | NS (3+4)
| Bonner 1999 | ≥ grade 3 nausea | 132 | 16.7 | 130 | 16.9 | NS
| Sloan 2002 | ≥ grade 3 vomiting | | 12.1 | | 14.6 | NS
| Schild 2004
Anorexia | Turrisi 1999 | grade 3 weight loss | 203 | 3 | 206 | 2
| Yuen 2000 | grade 4 weight loss | | 0 | | 0 | NS (3+4)
| Bonner 1999 | ≥ grade 3 | 132 | 3 | 130 | 2.3 | NS
| Sloan 2002
| Schild 2004
Lethargy | Bonner 1999 | ≥ grade 3 | 132 | 3 | 130 | 7.7 | NS | Turrisi 1999/Yuen 2000
| Sloan 2002
| Schild 2004
Neurosensory | Bonner 1999 | ≥ grade 3 | 132 | 7.6 | 130 | 11.5 | NS | Turrisi 1999/Yuen 2000
| Sloan 2002
| Schild 2004
Hearing loss | Bonner 1999 | ≥ grade 3 | 132 | 1.5 | 130 | 3.8 | NS | Turrisi 1999/Yuen 2000
| Sloan 2002
| Schild 2004
Esophagitis | Turrisi 1999 | grade 3 | 203 | 11 | 206 | 27 | <0.001
| Yuen 2000 | grade 4 | | 5 | | 5
| Bonner 1999 | ≥ grade 3 | 132 | 5.3 | 130 | 12.3 | 0.05 (per investigators; 0.074 by corrected χ^2^)
| Sloan 2002
| Schild 2004
Bronchopulmonary | Turrisi 1999 | grade 3 | 203 | 3 | 206 | 4
| Yuen 2000 | grade 4 & 5 | | 1 | | 2 | NS (3–5)
| Bonner 1999 | ≥ grade 3 | 132 | 4.5 | 130 | 6.2 | NS
| Sloan 2002
| Schild 2004
Pneumonitis | Bonner 1999 | ≥ grade 3 | 132 | 4.5 | 130 | 6.2 | NS | Turrisi 1999/Yuen 2000
| Sloan 2002
| Schild 2004
Kidney | | | | | | | | Turrisi 1999/Yuen 2000; Bonner 1999/Sloan 2002/Schild 2004
Anemia | Turrisi 1999 | grade 3 | 203 | 23 | 206 | 23
| Yuen 2000 | grade 4 | | 3 | | 5 | NS (3+4)
| Bonner 1999 | ≥ grade 3 | 132 | 3 | 130 | 2.3 | NS
| Sloan 2002
| Schild 2004
Thrombocytopenia | Turrisi 1999 | grade 3 | 203 | 16 | 206 | 13
| Yuen 2000 | grade 4 | | 8 | | 8 | NS (3+4)
| Bonner 1999 | ≥ grade 3 | 128 | 60.9 | 127 | 45.7 | 0.0145
| Sloan 2002 | grade 4 | | 24.2 | | 20.5 | NS
| Schild 2004
Leukopenia or neutropenia | Turrisi 1999 | grade 3 | 203 | 41 | 206 | 38 | NS (3+4)
| Yuen 2000 | grade 4 | | 39 | | 44 | NS
| Bonner 1999 | ≥ grade 3 | 128 | 88.3 | 127 | 89.8 | NS
| Sloan 2002 | grade 4 | | 37.5 | | 36.2 | NS
| Schild 2004
Hemoglobin | Bonner 1999 | ≥ grade 3 | 128 | 5.3 | 127 | 3.8 | NS | Turrisi 1999/Yuen 2000
| Sloan 2002
| Schild 2004
Infection | Turrisi 1999 | grade 3 | 203 | 6 | 206 | 6
| Yuen 2000 | grades 4 & 5 | | 2 | | 3 | NS (3–5)
| Bonner 1999 | ≥ grade 3 | 132 | 2.3 | 130 | 3.8 | NS
| Sloan 2002
| Schild 2004
Other | Turrisi 1999 | one or more grade 3, no grade 4 | 203 | 23 | 206 | 25 | NS
| Yuen 2000 | one or more grade 4, no grade 5 | | 63 | | 62 | NS
| Bonner 1999 | any hematologic, ≥ grade 3 | 131 | 90.1 | 130 | 89.2 | NS
| Sloan 2002 | any hematologic, ≥ grade 4 | | 43.5 | | 42.3 | NS
| Schild 2004 | any nonhematologic, ≥ grade 3 | | 38.9 | | 54.6 | 0.01
| | any nonhematologic, ≥ grade 4 | | 9.2 | | 13.8 | NS
| | any nonhematologic, grade 5 | | 0 | | 3.1 | 0.04
| | any toxicity, ≥ grade 3 | | 91.6 | | 92.3 | NS
| | any toxicity, ≥ grade 4 | | 46.6 | | 46.9 | NS
| | any toxicity, grade 5 | | 0 | | 3.1 | 0.04

With respect to hematologic toxicities, Schild/ Sloan/Bonner reported substantially more grade ≥3 thrombocytopenia (46 percent and 61 percent for 2/day and 1/day, respectively) than did Turrisi/Yuen (21 percent and 24 percent for 2/day and 1/day, respectively). The difference significantly favored the 2/day arm in Schild/Sloan/Bonner. However, grade 4 thrombocytopenia did not differ significantly between arms in either trial. Neither trial reported a significant difference between arms in incidence of grade ≥3 anemia, but it was substantially more common with early TRTx and larger cisplatin doses (Turrisi/Yuen; 26 percent and 28 percent) than with late TRTx and smaller cisplatin doses (Schild/Sloan/Bonner; 3 percent and 2.3 percent). Grade ≥3 leukopenia/ neutropenia was common in both trials, and did not differ across arms in either (≥80 percent in each).

With respect to non-hematologic toxicities, esophagitis was more common with twice daily than with once daily TRTx in each trial. Esophagitis also appeared more common in the Turrisi/Yuen trial, which used an accelerated schedule in the hyperfractionated arm, than in the other study, which used a split-course schedule. Both trials reported no significant differences between arms in incidence of vomiting, anorexia, bronchopulmonary effects, and infections. Grade ≥3 vomiting was not uncommon (9–15 percent). The other grade ≥3 adverse events reported by both trials each occurred in ≤10 percent of patients. Only Schild/Sloan/Bonner reported on lethargy, neurosensory effects, hearing loss, and pneumonitis. Between-arm differences were not statistically significant for any of these adverse events.

### Conclusions

Evidence to compare dose rates, treatment intervals, or fractionation schemes is limited. One RCT suggests that starting TRTx with the first cycle of cisplatin-etoposide chemotherapy and giving it in two daily fractions over 3 weeks increases overall survival when compared with the same dose begun at the same time but given in one daily fraction over 5 weeks. Evidence from a second trial is difficult to interpret, since multiple variables were studied simultaneously. However, it found no difference in overall survival between treatment arms managed with one versus two fractions per day. Neither trial reported data on quality of life. Esophagitis was the only adverse event reported more frequently with two fractions per day than with one fraction per day in both trials.

## Key Question 4

What are the relative benefits and harms (survival, toxicity, and quality of life) of adding TRTx to chemotherapy for primary treatment of extensive-stage SCLC?

### Overview

Five small RCTs compared outcomes of chemotherapy with versus without TRTx for previously-untreated extensive stage SCLC (N=238; 110–135 randomized to +TRTx, 103–128 to -TRTx). Summary Table 30 summarizes selected characteristics of these trials; more complete details are in Summary Table 31 and Appendix Tables 4A–C, 4H.^*^ The Jeremic, Shibamoto, Nikolic, et al. (1999) trial randomized 109 patients; other trials were smaller, ranging from 18 to 54 patients.

Table 30 Selected Characteristics of RCTs Comparing Chemotherapy with versus without TRTx

study | N | | Pt? | chemoTx regimen | TRTx timing* | TRTx dose | TRTx schedule; fractionation | PCI? | # centers | quality rating
| +TRTx | -TRTx
Jeremic, Shibamoto, Nikolic, et al., 1999 | 55 | 54 | yes | PE/CbE | concurrent | 54 Gy | wks 10–13; 36 × 1.5Gy, 2/d | yes | one | fair
Nou, Brodin, and Bergh, 1988 | 28 | 26 | no | CAVML | alternating | 40 Gy | wks 10–13; 20 × 2 Gy, 1/d | no | one | good
Lebeau, Chastang, Brechot, et al., 1993 | 10 | 8 | yes | LCAE/PEVe | sequential | 32–65 Gy | wks 36–39; 2 Gy fracs, 1/d | some | multi | poor
Rosenthal, Tattersall, Fox, et al., 1991 | 27 total; N/arm NR | | no | M-CAV | alternating | 40 Gy | wks 10-?; 20 × 2 Gy, ?/d | ? | multi | poor
Brincker, Hindberg, Hansen, et al., 1987 | 16 | 14 | no | CAV/LME | alternating | 12 Gy | days 60 and 100; 6 Gy each | ? | one | poor

* Timing relative to chemotherapy administration

Abbreviations table provided at the end of the Report.

Table 31 Sample and Methods: Chemotherapy with versus without Thoracic Radiation Therapy, Extensive Stage Disease (ESD)

Study | N | | Age | % Female | % Performance Status | | | | CTx Regimen | RTx Regimen
Jeremic, Shibamoto, Nikolic, et al., 1999 ^1^ | Total | 109 | md (rng) | | 100 | 90 | 80 | 70 | PE/Cb-E | Dose | Schedule | PCI?
single center: | +TRTx | 55 | 59 (38–70 | 40 | 31 | 36 | 18 | 15 | | 54 Gy | 24 × 1.5 Gy fracs; 2 frac/d, over 2.5 wks, | 25 Gy, 10 fracs
01/88 – 06/93 | -TRTx | 54 | 59 (39–71) | 41 | 24 | 43 | 18 | 15 | | | then 12 × 1.5 Gy fracs, 2 frac/d over 6 d
| nonrandomized | | | | KPS
| CR/PR: | 34
| PR/PR: | 28
| SD/PD | 35
Nou, Brodin, and Bergh, 1988 ^2^ | Total | 54 | md (rng) | | med (rng) | | | | cytoxan, vincristine, doxorubicin, methotrexate, lomustine | Dose | Schedule | PCI?
single center | +TRTx | 28 | 65 (55–78) | 25 | 60 (30–90) | | | | | 40 Gy | 1 frac/d, 2 Gy each, 5 d/wk, over 4 wks | No
01/80 – 12/83 | -TRTx | 26 | 60 (41–81) | 31 | 60 (30–90)
(ESD only) | | | | | KPS
Lebeau, Chastang, Brechot, et al., 1993 ^3^ | Total | 18 | ≥ 60 | | 90–100 | | 70–80 | 60 | CCNU, cytoxan, doxorubicin, etoposide, cisplatin, vindesine | Dose | Schedule | PCI?
27 centers | +TRTx | 10 | 48 | 4 | 63 | | 22 | 15 | | mn 46.5 Gy (rng: 32–65 Gy) | begun 4 wks after last CTx cyc; varied schedules: 32 Gy in 9 frac over 11–18 d to 65 Gy in 33 frac over 64 d vincristine, | some, but N/arm uncertain for ESD
10/85 – 04/88 | -TRTx | 8 | 38.5 | 8 | 46 | | 50 | 4
| | | | | KPS
Rosenthal, Tattersall, Fox, et al., 1991 ^3^ | Total | 27 | md (rng) | | 0 | 1 | 2 | ? | cytoxan, vincristine, doxorubicin; + methotrexate (IV or intra-thecal) | Dose | Schedule | PCI?
3 centers | +TRTx | ? | 60 (26–77) | 24 | 1 | 88 | 3 | 8 | | 40 Gy | 20 fracs between CTx cycs 3, 4 | not specified
01/77 – 07/79 | -TRTx | ?
Brincker, Hindberg, Hansen, et al., 1987 ^3^ | Total | 30 | md (rng) | | 0 | 1 | 2 | 3 | cytoxan, vincristine, doxorubicin, methotrexate, lomustine, etoposide | Dose | Schedule | PCI?
single center | +TRTx | 16 | 60 (42–69) | 27 | 34 | 51 | 15 | | | 12 Gy | 2 fracs, 6 Gy each, day 60 to upper hemi-body and day 100 to lower hemi-body | not specified
03/81 – 01/84 | -TRTx | 14 | 63 (46–69) | 27 | 24 | 57 | 19

Abbreviations table provided at the end of the Report.

1 enrollment limited to ESD patients

2 enrolled ESD & LSD patients, and reported characteristics of each separately;

3 enrolled ESD & LSD patients, but only reported characteristics for the two groups pooled

Interventions. Of the five available trials, only Jeremic, Shibamoto, Nikolic, et al. (1999). (1999) tested effects of TRTx in the context of current treatment strategies (regimens, doses, and schedules). Although both Jeremic, Shibamoto, Nikolic, et al. (1999) and Lebeau, Chastang, Brechot, et al. (1993) used platinum-etoposide chemotherapy regimens, only Jeremic, Shibamoto, Nikolic, et al. (1999) administered chemotherapy and radiation concurrently. Lebeau, Chastang, Brechot, et al. (1993) gave radiation therapy after all chemotherapy was completed (sequential administration), while the other three trials alternated chemotherapy and radiation and did not use platinum-based chemotherapy. Also noteworthy are the wide range of radiation doses used by Lebeau, Chastang, Brechot, et al. (1993), and the low dose and unusual schedule of TRTx used by Brincker, Hindberg, Hansen, et al. (1987).

Another study design feature, unique to Jeremic, Shibamoto, Nikolic, et al. (1999) (Appendix Table 4A),^*^ permits outcomes of randomized (chemotherapy-responsive) patients to be compared with those of nonrandomized patients who responded less completely outside the chest. All patients registered for this trial received 3 cycles of cisplatin/etoposide (PE) before randomization. To be eligible for the RCT, patients had to achieve a complete response (CR) outside the thorax and respond at least partially (PR) in the thorax after three PE cycles. Those who achieved only a PR outside the thorax, and those with less than PR in either site, were not randomized, but were treated with chemotherapy plus TRTx and followed.

Study Populations. Only Jeremic, Shibamoto, Nikolic, et al. (1999) limited enrollment to extensive-stage disease (ESD) patients. The others included both stages (Appendix Table 4A),^*^ but reported at least one outcome separately by arm for those with ESD. Rosenthal, Tattersall, Fox, et al. (1991) did not report the number of ESD patients per treatment arm. Data on baseline characteristics showed that ESD patients enrolled in each arm of Jeremic, Shibamoto, Nikolic, et al. (1999) and Nou, Brodin, and Bergh (1998) were similar (Summary Table 31, Appendix Table 4B).^*^ The other RCTs pooled baseline characteristics for extensive- and limited-stage patients (Lebeau, Chastang, Brechot, et al., 1993; Brincker, Hindberg, Hansen, et al., 1987) or for all participants (Rosenthal, Tattersall, Fox, et al., 1991), thus similarity of ESD patients was uncertain.

Most patients in Jeremic, Shibamoto, Nikolic, et al. (1999) had good performance at enrollment (67 percent with Karnofsky scores 90–100, excluded if ≤60), while Nou, Brodin, and Bergh (1998) included many with poorer performance (median Karnofsky score 60, range 30–90). Median age ranged from 59 to 65 years across study arms. Both trials enrolled mostly men (25 percent to 41 percent women across arms). Just over half of patients in each trial had ≥2 metastatic sites (50 percent to 58 percent across arms; Appendix Table 4B). ^†^ Less than half of patients in Jeremic, Shibamoto, Nikolic, et al. (1999) had lost ≥5 percent of body weight at enrollment, but Nou, Brodin, and Bergh (1998) did not report this potential marker of poor prognosis. Neither trial reported distributions by race.

† Appendixes cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/lungcansmall/lungcan.pdf.

Study Quality and Reporting. All five trials were published in full, but only two were multicenter studies (Lebeau, Chastang, Brechot, et al., (1993); Rosenthal, Tattersall, Fox, et al., 1991) and only Nou, Brodin, and Bergh (1998) was a good-quality trial. Jeremic, Shibamoto, Nikolic, et al. (1999) was of fair quality since it did not report on methods used for randomizing patients. The other three were of poor quality to evaluate the role of TRTx for ESD patients (Appendix Table 4H).^*^ Data were unavailable for each of the poor quality trials to evaluate the comparability of randomized ESD patients; two had excessive loss to follow-up (Rosenthal, Tattersall, Fox, et al. 1991; Brincker, Hindberg, Hansen, et al., 1987), and each failed to analyze and report all important outcomes separately for ESD patients.

### Results

Jeremic, Shibamoto, Nikolic, et al. (1999) reported that adding concurrent TRTx to platinum-based chemotherapy for good-performance patients selected by their response to an initial 3 cycles of platinum-etoposide (PE) significantly improved overall survival (median OS, 17 versus 11 months; 2- and 3-year OS, 38 percent versus 28 percent and 22 percent versus 13 percent respectively; p=0.041) and relapse-free survival (median RFS, 13 versus 9 months; 2- and 3-year RFS, 35 percent versus 22 percent and 20 percent versus 9 percent, respectively; p=0.045) (Summary Table 32). Jeremic, Shibamoto, Nikolic, et al. (1999) also reported that adding TRTx to chemotherapy for these selected patients significantly increased CR rates in the thorax at week 21 (96 percent versus 66 percent; p=0.00005) (Appendix Table 4F). However, the improvement in duration of CRs in the thorax did not achieve statistical significance (mean, 22±26 versus 14±16 months; p=0.055).

Table 32 Survival Outcomes: Chemotherapy with versus without Thoracic Radiation Therapy, Extensive Stage Disease (ESD)

Study | N | | OS Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | RFS Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
Jeremic,1999 ^1^ | +TRTx | 55 | 17 | 65% | 38% | 22% | 13% | 9.1% | 13 | 56% | 35% | 20% | 13% | 9.1%
| -TRTx | 54 | 11 | 46% | 28% | 13% | 5.6% | 3.7% | 9 | 41% | 22% | 9.3% | 5.6% | 1.9%
| Difference | | 6 | 19% | 10% | 9% | 7.4% | 5.4% | 4 | 15% | 13% | 10.7% | 7.4% | 7.2%
| | | (p=0.041 by log-rank test) unrandomized groups by post-3^rd^ cycle response (thorax/ elsewhere):
| CR/PR: | 34 | 8 | 35% | 8.8% | 2.9% | 0% | 0% | 6 | 26% | 5.9% | 0% | 0% | 0%
| PR/PR: | 28 | 6 | 21% | 3.6% | 0% | 0% | 0% | 5 | 18% | 0% | 0% | 0% | 0%
| SD/PD | 35 | 3 | 0% | 0% | 0% | 0% | 0% | NR | 0% | 0% | 0% | 0% | 0%
Nou 1988 ^2^ | +TRTx | 28 | 9.2 | 32% | 0% | 0% | 0%
| -TRTx | 26 | 7.6 | 26% | 0% | 0% | 0%
| Difference | | 1.6 | 6% | 0% | 0% | 0%
| | | (chi-square 0.045, 0.8<p<0.9, by life-table analysis)
Lebeau 1993 ^3^ | +TRTx | 10 | ~6.3 | ~10% | ~10% | 0% | 0% | 0%
| -TRTx | 8 | ~7.0 | ~25% | ~12% | ~12% | 0% | 0%
| Difference | | -0.7 | -15% | -2% | -12% | 0% | 0%
| | | (p = 0.43 by log-rank test)
Rosenthal 1991 ^3^ | Total | 27
| +TRTx | ? | 5 (95% CI: 2–8)
| -TRTx | ? | 7 (95% CI: 3–10)
| Difference | | -2
| | | (p=0.796)
Brincker 1987 ^3^ | +TRTx | 16 | 7 | ~25% | 0% | 0% | 0% | 0% | 7 | ~23 | 0% | 0% | 0% | 0%
| -TRTx | 14 | 10 | ~30% | 0% | 0% | 0% | 0% | 8.5 | ~26 | 0% | 0% | 0% | 0%
| Difference | | -3 | -5% | 0% | 0% | 0% | 0% | -1.5 | -3% | 0% | 0% | 0% | 0%
| | | (p = 0.44) | | | | | | (p = 0.45)

1 enrollment limited to ESD patients

2 enrolled ESD & LSD patients, and reported characteristics of each separately;

3 enrolled ESD & LSD patients, but only reported characteristics for the two groups pooled

Only 3% of non-randomized patients who achieved PR outside the thorax and CR in the thorax after three cycles of PE survived at 3 years, despite TRTx and additional chemotherapy (Summary Table 32). Furthermore, no patients who achieved only PR at each site survived at three years. However, data are unavailable to compare these outcomes with similar patients managed without TRTx.

No other trial reported a statistically significant effect of TRTx on survival of ESD patients (Summary Table 32). This includes Lebeau, Chastang, Brechot, et al. (1993), which only randomized patients in CR after eight cycles of chemotherapy (Appendix Tables 4A, F)^*^and used a chemotherapy regimen with cisplatin (Summary Table 31). Whether the absence of a significant effect reflects the small size and inadequate statistical power of these trials, or is attributable to their use of chemotherapy regimens, timing and sequencing of TRTx, or radiation doses and schedules that differed from those used in Jeremic, Shibamoto, Nikolic, et al. (1999) is uncertain, since available data are insufficient.

None of the trials reported data on quality of life (Appendix Table 4F).^*^ Jeremic, Shibamoto, Nikolic, et al. (1999) reported significantly more grade 3 and 4 esophagitis (27 percent versus zero, p=0.0002), but significantly less grade 3 and 4 nausea and vomiting (9 percent versus 34 percent, p=0.0038) and renal toxicity (zero versus 22 percent, p=0.001) in the arm given TRTx (Summary Table 33). No other statistically significant differences between arms were reported for adverse events.

Table 33 Adverse Events: Chemotherapy with versus without Thoracic Radiation Therapy, Extensive Stage Disease (ESD)

Toxicity Type | Study | Severity or Grade | +TRTx | | -TRTx | | | Not Reporting
| | | n | % | n | % | p
Treatment-related mortality | Nou 1988 | | 28 | 4 | 26 | 4 | NS | Jeremic 1999; Lebeau 1993; Rosenthal 1991; Brincker 1987
Nausea/Vomiting | Jeremic 1999 | acute grades 3/4 nausea and vomiting | 55 | 9 | 54 | 34 | 0.0038 | Nou 1988; Lebeau 1993; Rosenthal 1991
| Brincker 1987 | | “no significant differences between the two treatment groups”
Anorexia | | | | | | | | Jeremic 1999; Nou 1988; Lebeau 1993; Rosenthal 1991; Brincker 1987
Lethargy | | | | | | | | Jeremic 1999; Nou 1988; Lebeau 1993; Rosenthal 1991; Brincker 1987
Neurosensory | Brincker 1987 | | “no significant differences between the two treatment groups” | | | | | Jeremic 1999; Nou 1988; Lebeau 1993; Rosenthal 1991
Hearing loss | | | | | | | | Jeremic 1999; Nou 1988; Lebeau 1993; Rosenthal 1991; Brincker 1987
Esophagitis | Jeremic 1999 | acute grades 3/4 esophageal | 55 | 27 | 54 | 0 | 0.0002 | Nou 1988; Lebeau 1993; Rosenthal 1991; Brincker 1987
Bronchopulmonary | Jeremic 1999 | acute grade 3 (no grade 4, either arm) | 55 | 5 | 54 | 0 | 0.082 | Nou 1988; Lebeau 1993; Rosenthal 1991; Brincker 1987
Pneumonitis | Brincker 1987 | | no cases observed | | | | | Jeremic 1999; Nou 1988; Lebeau 1993; Rosenthal 1991
Kidney | Jeremic 1999 | acute grades 3 or 4 | 55 | 0 | 54 | 22 | 0.001 | Nou 1988; Lebeau 1993; Rosenthal 1991; Brincker 1987
Anemia | Jeremic 1999 | acute grades 3 or 4 | 55 | 11 | 54 | 20 | 0.39 | Lebeau 1993; Rosenthal 1991
| Nou 1988 | hemoglobin nadir | Similar medians and ranges between groups
| Brincker 1987 | hemoglobin <6 mmol/L | 41 | ~50 | 37 | ~27
| | | (LSD+ESD) | | (LSD+ESD)
Thrombocytopenia | Jeremic 1999 | acute grades 3/4 | 55 | 27 | 54 | 42 | 0.23 | Lebeau 1993; Rosenthal 1991
| Nou 1988 | thrombocyte count nadir (10^9^/L) | Similar medians between groups
| Brincker 1987 | platelets <75×10^3^/μl | 41 | ~65 | 37 | ~10
| | | (LSD+ESD) | | (LSD+ESD)
Leukopenia or neutropenia | Jeremic 1999 | acute grade 3/4 leukopenia | 55 | 44 | 54 | 61 | 0.18 | Lebeau 1993; Rosenthal 1991
| Nou 1988 | leukocyte count nadir (10^9^/L) | Similar medians and ranges between groups
| Brincker 1987 | leukocytes < 2.5×10^3^/μl | 41 | ~37 | 37 | ~18
| | | (LSD+ESD) | | (LSD+ESD)
Infection | Jeremic 1999 | acute grades 3–5 | 55 | 23 | 54 | 33 | 0.64 | Lebeau 1993; Rosenthal 1991
| Nou 1988 | septicemia | Similar medians and ranges between groups
| Brincker 1987 | febrile episodes | No significant differences between arms
Other | Jeremic 1999 | combined late grades 3/4 toxicities | 55 | 5 | 54 | 0 | 0.082 | Lebeau 1993; Rosenthal 1991
| Nou 1988 | “other serious side effects” | 28 | 29 | 26 | 8 | NS
| Brincker 1987 | tolerated 75–100% of CTx doses in cycles after hemibody RTx completed | 28 | 25 | 32 | 91
| | | (LSD+ESD) | | (LSD+ESD)

### Conclusions

Evidence from one small single-center randomized trial suggests adding concurrent TRTx to chemotherapy may improve survival of ESD patients who respond to an initial three cycles of PE chemotherapy with a CR outside the thorax and at least a PR in the thorax. Uncontrolled data from the same trial suggest that there is little to no benefit from adding TRTx to chemotherapy for ESD patients who achieve no better than a PR outside the thorax after three cycles of PE. With the regimens used in Jeremic, Shibamoto, Nikolic, et al. (1999), concurrent TRTx apparently increases grades 3 and 4 esophagitis.

No other trials were able to reproduce the results reported by Jeremic, Shibamoto, Nikolic, et al. (1999). Limitations of these trials include small sample sizes lack of a platinum-containing drug in their chemotherapy regimens, and use of nonconcurrent TRTx.

## Key Question 5

What are the benefits and harms (survival, toxicity and quality of life) of prophylactic cranial irradiation (PCI) for patients with SCLC in complete remission (CR) after primary therapy?

### Overview

The literature search identified seven RCTs comparing primary therapy for SCLC with versus without PCI (Summary Table 34). One of these was excluded because randomization and PCI preceded completion of primary therapy and evaluation of response (n=51; Niiranen, Holsti, and Salmo, 1989). Thus, each arm included some patients with less than CR. A second was excluded because it also randomized patients to PCI or no PCI before response was known, and because an initial randomization assigned half the patients to radiotherapy without chemotherapy (n=104 in 4 groups; Seydel, Creech, Pagano, et al., 1985). The remaining five trials onlyrandomized patients who achieved CR after primary chemotherapy with or without TRTx (pooled N=922; Arriagada, Le Chevalier, Borie, et al., 1995/Arriagada, Le Chevalier, Riviere, et al., 2002; Laplanche, Monnet, Santos-Miranda, et al., 1998; Gregor, Cull, Stephens, et al., 1997; Ohonoshi, Ueoka, Kawahara, et al., 1993; Cao, Huang, and Tu, 2000).

Table 34 RCTs of PCI versus no PCI for SCLC in CR

Study | N Randomized | | all in CR? | Pt? | chemoTx regimen | TRTx | PCI Regimen | | | publication type
| + PCI | no PCI | | | | | dose | fractions | duration
Arriagada, Le Chevalier, Borie, et al., 1995 | 149 | 151 | yes | some | various; # type NR | 91%–93% each arm; reg. NR | 24 Gy | 8 × 3 Gy | 12 days (4 d/wk) | full
Laplanche, Monnet, Santos-Miranda, et al., 1998 | 100 | 111 | yes | ?? | various; # type NR | not reported | 24–30 Gy | ≤3 Gy each | ≤ 3 weeks | full
Gregor, Cull, Stephens, et al., 1997 | 194 | 120 | yes | some | various; # NR | 84% each arm; reg. NR | 8–40 Gy | 2 Gy each | 1–3+ weeks | full
Ohonoshi, Ueoka, Kawahara, et al., 1993 | 23 | 23 | yes | no | same for all | all LS; 20 × 2 Gy/d | 40 Gy | 20 × 2 Gy | 4 weeks | full
Aroney, Aisner, Wesley, et al., 1983 | 15 | 14 | yes | no | same for all | not reported | 30 Gy | 10 × 3 Gy | 2 weeks | full
Wagner, Kim, Turrisi, et al., 1996 | 17 | 15 | yes | NR | not reported | 57%; reg. NR | 24 Gy | 8 × 3 Gy | not reported | abstract
Danish/NCI | 28 | 27 | yes | NR | not reported | 42%; reg. NR | 24 Gy | 8 × 3 Gy | not reported | none
Cao, Huang, and Tu, 2000 | 26 | 25 | yes | some | two; # NR | all; 40–64 Gy 1.8–2 Gy/d | 25–30 Gy | 1.8–2 Gy ea. | 2–3 weeks | full
Seydel, Creech, Pagano, et al., 1985 | 52 | 51 | ?? | no | one; half only | all; 45 Gy 1.8–2 Gy/d | 30 Gy | 10 × 3 Gy | 2 weeks | full
Niiranen, Holsti, and Salmo, 1989 | 25 | 26 | no | no | two; half each | all; 25 × 2.2 Gy/d | 40 Gy | 20 × 2 Gy | 4 weeks | full

Four of these five studies were included in a Cochrane review and meta-analysis that collected updated individual patient data from each RCT (Prophylactic Cranial Irradiation Overview Collaborative Group 2000; Auperin, Arriagada, Pignon, et al. 1999). Cao, Huang, and Tu (2000; n=51) was the exception. The Cochrane review also included one study published before 1985 (Aroney, Aisner, Wesley, et al., 1983; n=29) and two unpublished trials (Wagner, Kim, Turrisi, et al., 1996; Danish/NCI trial; pooled N=87) that were not identified by our literature search. Additionally, the Cochrane review collected data on randomized patients excluded from investigators' published analyses, permitting intent-to-treat analysis of results for 987 patients in CR from seven RCTs (526 randomized to PCI, 461 to no PCI). Finally, the Cochrane review collected individual patient data on duration of follow-up and on covariates at randomization including age, gender, extent of disease, performance status, induction regimen (chemotherapy with versus without TRTx), and time since initial therapy, to permit analyses that tested whether these covariates influenced the magnitude of benefit from PCI. The Cochrane review excluded Niiranen, Holsti, and Salmo (1989) and Seydel, Creech, Pagano, et al. (1985) (as does this review), plus eight other RCTs published before 1985, for similar reasons (some randomized patients not in CR; pooled N=929).

Since individual patient data submitted for the Cochrane review included longer follow up and permitted analyses not possible with abstracted data from a literature-based systematic review, and since only one eligible study was published subsequently (Cao, Huang, and Tu, 2000; N=51), the Results section below summarizes and highlights the principal findings of the Cochrane review, and also summarizes results of the Cao, Huang, and Tu (2000) study.

### Results

#### Cochrane Review and Meta-Analysis

Study Characteristics. At the time of analysis, median follow-up for the control and PCI groups was 5.3 and 5.9 years, respectively; 846 of 987 randomized patients had died (PCI Overview Collaborative Group 2000; Auperin, Arriagada, Pignon, et al., 1999). Of seven included trials, three enrolled 84 percent of patients (Arriagada, Le Chevalier, Borie, et al., 1995/Arriagada, Le Chevalier, Riviere, et al., 2002; Laplanche, Monnet, Santos-Miranda, et al., 1998; Gregor, Cull, Stephens, et al., 1997) while the other four contributed 29 to 55 each (Aroney, Aisner, Wesley, et al., 1983; Wagner, Kim, Turrisi, et al., 1996; Ohonoshi, Ueoka, Kawahara, et al., 1993; Danish/NCI trial). The control (N=461) and PCI (n=526) groups were well balanced for gender (76–77 percent male), age (median 59 years, ranges 26–80 and 21–79), performance status (66–67 percent PS 0, 30–32 percent PS 1) and other covariates. Reviewers judged each trial to be methodologically sound, including adequate randomization and allocation concealment.

For most patients in these trials, the specific chemotherapy regimens used to induce CR were not reported but it is likely platinum-based regimens were used only for a minority. The large trials did not mandate a uniform chemotherapy regimen (Arriagada, Le Chevalier, Borie, et al., 1995/Arriagada, Le Chevalier, Riviere, et al., 2002; Laplanche, Monnet, Santos-Miranda, et al., 1998; Gregor, Cull, Stephens, et al., 1997). Only Gregor, Cull, Stephens, et al. (1997) reported the variety of regimens used, but since they did not report the proportion given each regimen, an unknown number of patients received cisplatin or carboplatin. Of the four smaller trials, Aroney, Aisner, Wesley, et al. (1983) and Ohonoshi, Ueoka, Kawahara, et al. (1993) each used a uniform regimen, but neither included a platinum drug. While Cochrane reviewers collected individual patient data on whether they received TRTx, information was unavailable (either in the review or in the original publications) on doses, fractionation schemes, or timing relative to chemotherapy. Summary Table 35 summarizes the review's pooled estimates of efficacy outcomes.

Table 35 Meta-analytic Results for Efficacy Outcomes Reported in the Cochrane Review

Outcome | N evaluated | | Hazard Ratio | 95% CI | | p | event-free at 3 yrs (by K-M)
| +PCI | -PCI | | lower | upper | | +PCI | -PCI | difference
mortality | 526 | 461 | 0.84 | 0.73 | 0.97 | 0.01 | 20.7% | 15.3% | 5.4%
disease-free survival | 526 | 461 | 0.75 | 0.65 | 0.86 | <0.00003
brain metastasis | 524 | 457 | 0.46 | 0.38 | 0.57 | <0.00001 | 33.3% | 58.6% | 25.3%
non-brain metastasis | 325 | 332 | 0.89 | 0.69 | 1.15 | 0.4
loco-regional recurrence | 323 | 334 | 0.97 | 0.75 | 1.26 | 0.8

Mortality and Survival. Although six of seven included trials observed proportionally more deaths in the control arms, the hazard ratio (HR) for mortality did not significantly favor the PCI arm in any single trial. However, meta-analysis showed that PCI significantly decreased the likelihood of death (HR=0.84; 95 percent CI: 0.73–0.97; p = 0.01). Cox modeling to adjust for extent of disease, gender and age did not appreciably change the relative likelihood (HR=0.83; p=0.009). The HR remained constant despite further adjustment for performance status, induction regimen (with versus without TRTx), and time from induction to randomization. Kaplan-Meier actuarial analysis estimated an absolute increase of 5.4 percent in the proportion of patients alive at 3 years (from 15.3 percent without PCI to 20.7 percent with PCI). The survival benefit persisted beyond 3 years, and there was no evidence of statistical heterogeneity among the seven included trials.

Other Efficacy Endpoints. The HR for brain metastasis significantly favored the PCI arm in five of seven trials; the Danish/NCI and Laplanche, Monnet, Santos-Miranda, et al. (1998) trials were the exceptions. Meta-analysis showed reduced likelihood of brain metastasis among those randomized to PCI (HR = 0.46; 95 percent CI: 0.38–0.57; p <0.001). Kaplan-Meier analysis estimated an absolute decrease of 25.3% in the cumulative rate of brain metastasis at 3 years (from 58.6 percent without PCI to 33.3 percent with PCI).

Additional analyses demonstrated that PCI increased the likelihood of disease-free survival (HR=0.75; 95 percent CI: 0.65–0.86; p < 0.001), but did not reduce extra-cerebral metastases (HR=0.89; 95% CI: 0.69–1.15; p=0.4) or locoregional recurrence (HR=0.97; 95% CI: 0.75–1.26; p=0.8). However, data on non-brain metastases and locoregional recurrence were available for only 67% of randomized patients.

PCI Dose-Response. Trials (and subgroups from different centers in Gregor, Cull, Stephens, et al., 1997) were divided by total radiation dose used for PCI: 8 Gy delivered in one fraction, 24–25 Gy delivered in 8–12 fractions, 30 Gy delivered in 10 fractions, and 36 or 40 Gy delivered in 18 or 20 fractions. Summary Table 36 summarizes results of this and other subgroup analyses.

Table 36 Cochrane Review Subgroup Analyses for Mortality and Brain Metastasis

covariate | subgroups | mortality | | | | | | brain metastasis
| | N evaluated | | hazard ratio | 95% CI | | p | N evaluated | | hazard ratio | 95% CI | | p
| | +PCI | -PCI | | lower | upper | | +PCI | -PCI | | lower | upper
PCI dose | 8 Gy | 26 | 16 | 0.69 | 0.35 | 1.37 | 0.3 | 26 | 16 | 0.76 | 0.28 | 2.10 | 0.6
| 24–25 Gy | 330 | 340 | 0.88 | 0.75 | 1.04 | 0.12 | 329 | 338 | 0.52 | 0.41 | 0.67 | <0.00001
| 30 Gy | 119 | 82 | 0.81 | 0.59 | 1.12 | 0.2 | 118 | 80 | 0.34 | 0.19 | 0.59 | 0.0002
| 36–40 Gy | 51 | 59 | 0.81 | 0.54 | 1.20 | 0.3 | 51 | 59 | 0.27 | 0.14 | 0.51 | 0.00001
age | ≤ 54 yrs | 147 | 158 | 0.84 | 0.65 | 1.08 | 0.18 | 147 | 157 | 0.55 | 0.39 | 0.77 | 0.0005
| 55–64 yrs | 250 | 185 | 0.90 | 0.73 | 1.11 | 0.3 | 248 | 184 | 0.49 | 0.35 | 0.68 | <0.00002
| ≥ 65 yrs | 129 | 118 | 0.79 | 0.60 | 1.03 | 0.09 | 129 | 116 | 0.37 | 0.24 | 0.59 | <0.0001
disease stage | limited | 464 | 383 | 0.85 | 0.73 | 0.99 | 0.04 | 462 | 382 | 0.48 | 0.38 | 0.61 | <0.00001
| extensive | 62 | 78 | 0.77 | 0.54 | 1.11 | 0.16 | 62 | 75 | 0.38 | 0.23 | 0.64 | 0.0002
performance status | 0 | 212 | 215 | 0.85 | 0.69 | 1.05 | 0.13 | 211 | 214 | 0.47 | 0.35 | 0.63 | <0.00001
| 1–3 | 103 | 111 | 0.78 | 0.58 | 1.04 | 0.09 | 103 | 110 | 0.50 | 0.32 | 0.78 | 0.003
induction therapy | +TRTx | 314 | 248 | 0.86 | 0.71 | 1.03 | 0.10 | 314 | 248 | 0.43 | 0.33 | 0.57 | <0.00001
| -TRTx | 94 | 86 | 0.88 | 0.64 | 1.21 | 0.4 | 92 | 82 | 0.40 | 0.23 | 0.67 | 0.0005
gender | male | 403 | 352 | 0.77 | 0.66 | 0.90 | 0.0009 | 401 | 348 | 0.47 | 0.37 | 0.60 | <0.00001
| female | 123 | 109 | 1.05 | 0.78 | 1.42 | 0.7 | 123 | 109 | 0.50 | 0.32 | 0.78 | 0.002
time from induction to randomization | <4 mos. | 84 | 77 | 0.92 | 0.66 | 1.29 | 0.6 | 83 | 75 | 0.27 | 0.16 | 0.46 | <0.00001
| 4–6 mos. | 127 | 152 | 0.79 | 0.61 | 1.02 | 0.07 | 126 | 150 | 0.50 | 0.35 | 0.72 | 0.0002
| >6 mos. | 102 | 91 | 1.01 | 0.74 | 1.38 | 0.9 | 102 | 91 | 0.69 | 0.44 | 1.08 | 0.1

Evidence was lacking for a trend towards smaller HR (greater impact on survival) with larger PCI dose (p = 0.89), but few patients were treated at the lowest and highest doses. In contrast, the HR to develop brain metastasis decreased significantly as PCI dose increased (p = 0.02), suggesting larger doses had a greater magnitude of beneficial effect.

Subgroup Analyses. Patient subgroups were evaluated for differences in magnitude of benefit from PCI. Subgroups were defined by individual patient data on age (≤54 versus 55–64 versus ≥65 years), gender, disease stage at diagnosis (limited versus extensive), performance status (0 versus 1–3), induction regimen (with versus without TRTx), and time from beginning induction to randomization (<4 versus 4–6 versus >6 months). Only two subgroup comparisons suggested significant differences in benefit from PCI for overall survival or brain metastasis.

Results for males (n =755) showed statistically significant decreases in mortality (HR=0.77; 95 percent CI: 0.66–0.90; p = 0.0009) and brain metastasis (HR=0.47; 95 percent CI: 0.37–0.60; p<0.0001) among those randomized to PCI. However, results for females (n=232) showed no significant effect of PCI on survival (HR=1.05; 95 percent CI: 0.78–1.42; p=0.7) despite a significant effect on brain metastasis (HR=0.50; 95 percent CI: 0.32–0.78; p=0.0002). A statistical test for interaction of gender with treatment effect on survival was of borderline significance (p=0.07).

PCI delayed by <4 months from start of induction therapy (HR=0.27; 95 percent CI: 0.16–0.46; p<0.0001) or by 4 to 6 months (HR=0.50; 95 percent CI: 0.35–0.72; p=0.0002) significantly reduced the likelihood of brain metastasis. In contrast, PCI delayed >6 months (HR=0.69; 95 percent CI: 0.44–1.08; p=0.10) did not significantly decrease the likelihood of brain metastasis. Note that each fully published trial with some patients given PCI later than 6 months after induction (3 of 4 trials, with 95 percent of 193 patients in this subgroup) specified that patients were randomized to PCI or no PCI within 14 days of achieving CR. This trend (smaller effect on likelihood of brain metastasis as delay lengthened) was statistically significant (p=0.01). However, the relationship between time from induction therapy to PCI and hazard ratio for death did not show a similar statistically significant trend.

Adverse Events. The Cochrane review did not abstract and report data on adverse events. Of five fully-published studies, only Arriagada et al. (1995) reported acute events during PCI; these included fever or asthenia (24 percent), headache (24 percent), vomiting (10 percent), skin erythema (9 percent), and altered mood (6 percent). Adverse event data were unavailable from the two unpublished trials (Wagner, Kim, Turrisi, et al., 1996; Danish/NCI trial).

Two trials prospectively studied neuropsychological or cognitive sequelae of PCI in patients who survived ≥6 months from treatment (Arriagada, Le Chevalier, Borie, et al. 1995; Gregor, Cull, Stephens, et al., 1997; Table 37). The Gregor, Cull, Stephens, et al. (1997) trial also reported data on symptoms that affect quality of life (QoL). Each compared measurements at baseline with measurements at times after PCI. Information was unavailable on ages and other baseline characteristics of those tested for late neuropsychological or cognitive effects. Additionally, available evidence did not permit testing of the hypothesis that the likelihood of neuropsychological deficits may increase with increasing PCI dose.

Table 37 Adverse Effects Reported from RCTs of PCI versus no PCI

Study | acute toxicities reported? | most common events | type of assessment | N randomized | N evaluated at baseline | # w no or only mild baseline deficits | #, time of reassessments | principal findings
Arriagada, Le Chevalier, Borie, et al., 1995 | yes | fever 24% | neuropsychological; brain CT | total: 300 | 229 | 94 | 33 of 58 @ 18 mos. | groups did not differ in # of new changes or abnormalities
| | headache 24% | | +PCI: 149 | 114 | 44 | 23 of 35 @ 30 mos.
| | vomiting 10% | | -PCI: 151 | 115 | 50
Gregor, Cull, Stephens, et al., 1997 | no | | cognitive | total: 314 | 125 | diff. tests: | 59 of 106 @ 6 mos. | groups did not differ in # of new deficits
| | | | +PCI: 194 | 76 | 44–58 | 32 of 54 @ 1 yr
| | | | -PCI: 120 | 49 | 29–37 | 9 of 20 @ 2 yr
| | | symptoms affecting QoL | total: 314 | not reported | diff tests: | re-assessed @ 6 mos., 1 & 2 yr; #'s not reported; | larger proportion of -PCI than of +PCI showed deterioration
| | | | +PCI: 194 | | 11–21
| | | | -PCI: 120 | | 7–14

In Arriagada, Le Chevalier, Borie, et al. (1995), neuropsychological assessments (made by a neurologist at baseline and late after PCI) included evaluation of higher brain function, mood, sensation, walking, cerebellar function, tendon reflexes, and sensibility. Additionally, blinded assessors reviewed pre- and post-PCI brain computed tomography (CT) scans for evidence of structural abnormalities (e.g., cortical atrophy or ventricular dilatation).

Of 300 randomized patients, baseline assessments were available for only 229 (115 controls and 114 randomized to PCI). Only 50 control patients (43 percent) and 44 randomized to PCI (39 percent) were free of neuropsychological abnormalities at baseline assessment. Investigators re-assessed 33 of 58 patients alive at 18 months and 23 of 35 alive at 30 months. They reported no statistically significant differences between treatment groups with respect to appearance of further neuropsychological changes or CT scan abnormalities over two years from PCI. However, only 11 percent or less of all randomized patients contributed to these observations, and the report did not explain why some patients alive at 18 and 30 months were not re-assessed.

Gregor, Cull, Stephens, et al. (1997) assessed cognitive function at baseline, 6 months, and 1 and 2 years with a battery of optional measures including the National Adult Reading Test, Paced Auditory Serial Addition Task, Rey-Osterrieth Complex Figure Test, and Auditory Verbal Learning Test. Of 314 randomized patients, at least one test result was submitted for N=136 (52 controls, 84 PCI). Of these, baseline data were available for N=125, 6-month data for N=59 (of 106 assessable), one-year data for N=32 (of 54 assessable), and two-year data for N=9 (of 20 assessable). Each test showed evidence of new impairments at 6 months and 1 year in some patients free of impairments at baseline. However, investigators reported no evidence of sustained deterioration with time, and no notable differences between the PCI and control groups with respect to new cognitive deficits.

Gregor, Cull, Stephens, et al. (1997) also measured symptoms that affect QoL at the same intervals used for cognitive function, with the Rotterdam Symptom Checklist and the Hospital Anxiety and Depression Scale. Symptoms that showed the greatest deterioration from baseline to 6 months included tiredness, lack of energy, irritability, decreased sexual interest, shortness of breath, and cough. For each symptom, of those who reported themselves with no or mild symptoms at baseline, a larger proportion of controls than of those given PCI reported moderate or severe symptoms at 6 months. Based on these data, investigators concluded deterioration was worse in controls than in the PCI group.

Ohonoshi, Ueoka, Kawahara, et al. (1993) did not formally assess neuropsychological function or measure cognitive function or quality life. However, they reported that one of seven patients who survived more than two years after PCI developed symptoms of late central nervous system toxicity. These included memory impairment and gait ataxia at 30 months, with CT scan evidence of cortical atrophy. Ohonoshi, Ueoka, Kawahara, et al. (1993) did not report on late toxicity in the 4 control patients alive at 2 years.

Subsequent Study. Cao, Huang, and Tu (2000) reported the only eligible RCT of PCI versus no PCI omitted from the Cochrane review and meta-analysis (N = 47; 24 to PCI, 23 to control). Study arms were well-balanced and most patients had relatively favorable baseline characteristics: mean age, 55–56 (range 39–65), Karnofsky score ≥70, two females in each arm, all patients initially diagnosed with limited stage disease and in CR after chemotherapy plus TRTx. Chemotherapy regimens were either cyclophosphamide/doxorubicin/vincristine or etoposide plus carboplatin or cisplatin, with most patients also given lomustine. All patients received 40–66 Gy TRTx in 1.8–2 Gy fractions, given sequentially for most (17 controls, 18 PCI) and in alternating fashion for the rest (6 from each group). PCI began 11 to 58 days after achieving CR (mean, 33 days) at a mean dosage of 28.8 Gy (range, 25.2 to 30.6 Gy) in single daily fractions of 1.8 to 2 Gy, 5 days/week.

Cao, Huang, and Tu (2000) reported fewer cranial metastases at 3 years after irradiation in the arm given PCI (3.8 percent versus 28 percent, p<0.05). However, differences in survival at one (85 percent versus 72 percent), two (73 percent versus 40 percent) or three (42 percent versus 32 percent) years were not statistically significant (median, 20 versus 8.3 months; log rank p>0.05). Acute reactions to PCI included mild nausea and dizziness, but frequencies were not reported. Late effects in 11 patients who survived ≥3 years included two with memory deficits and three with dizziness and lack of strength. Brain CT scans on 7 of the 11 survivors showed no structural abnormalities.

### Conclusions

Evidence from an individual patient data Cochrane review and meta-analysis on seven RCTs (N=987) conducted by the PCI Overview Collaborative Group shows that PCI modestly but significantly improves survival of SCLC patients in CR after primary therapy. PCI increases the proportion alive at 3 years from 15.3 percent of controls to 20.7 percent of those randomized to PCI, an absolute increase of 5.4 percent. PCI also significantly decreases the risk for brain metastasis and increases the likelihood of disease-free survival. The sole trial reported after the meta-analysis confirms effects of PCI on brain metastasis, and generally agrees with the modest effect on overall survival.

Subgroup analyses using individual patient data showed that PCI significantly decreases brain metastases for SCLC patients in CR regardless of age, disease stage or performance status at diagnosis, and whether or not TRTx is part of the induction regimen. Although effects of PCI on survival lacks statistical significance for nearly all these subgroups, it does not appear that any subgroup benefits more or less than others with respect to each of these covariates.

Additional subgroup analyses suggested that increasing the PCI dose from 8 to 40 Gy and starting PCI within the first 6 months after achieving CR may decrease the likelihood of brain metastasis. Patient gender also may interact with effects of PCI on survival. However, these hypotheses, derived from subgroup analyses, require formal testing in randomized, controlled trials.

Data on acute toxicities of PCI are scant, but those available suggest they are tolerable at the doses used in these trials (8–40 Gy in 1.8 to 3 Gy fractions). Evidence from two trials suggests neuropsychological and cognitive deficits and structural abnormalities on brain CT scans are relatively common among SCLC patients in CR after primary therapy. However, available evidence did not show greater deterioration of existing deficits or more frequent appearance of new abnormalities among the minority randomized to PCI who survive 1–2 years or more, than among the fewer controls with equivalent survival duration.

## Key Question 6

Does the addition of positron emission tomography (PET) scanning improve the accuracy of staging for patients diagnosed with SCLC, over the use of other techniques, including CT and MRI, without PET?

### Overview

Evidence of the effect of PET on health outcomes, such as overall survival or avoidance of unnecessary procedures, is of greatest interest to this review. RCTs were sought that compared outcomes of staging tests that included PET versus the same tests without PET in patients who had a confirmed diagnosis of SCLC. No such studies were found.

Single-arm studies with the following characteristics were sought: prospective design; reported on at least 20 patients undergoing imaging to stage SCLC; correlated 18-fluorodeoxyglucose (FDG) PET findings with findings from other imaging modalities and an appropriate reference standard; applied the reference standard to patients with and without metastasis to a given anatomic site (to permit computation of sensitivity and specificity); and reported at least one outcome of interest. Outcomes included: diagnostic and staging accuracy; patient management decisions, which may be altered by imaging results, duration of survival; disease-free survival and/or progression-free survival; quality of life; palliation of measurable symptoms; treatment-related adverse effects; objective response rates; and response durations. Studies were excluded if they did not report data needed to calculate diagnostic accuracy; or if they did not report separate diagnostic accuracy results for SCLC and NSCLC patients. Since the question posed here concerned the incremental value of PET relative to staging tests, the comparison of greatest interest is between results of conventional staging tests alone and conventional staging tests plus PET.

Due to the limited evidence available, the study selection criteria on prospective design and on appropriate reference standard were relaxed. Six studies reporting on a total of 277 patients (range: 20–120) are included in this review. Data from these studies primarily concerned diagnostic and staging accuracy. Characteristics of these studies are summarized in Summary Table 38 (sample selection) and Summary Table 39 (tests and reference standards). Four of the six studies were clearly prospective in design (Bradley, Dehdashti, Mintun et al., 2004; Brink, Schumacher, Mix et al., 2004; Kamel, Zwahlen, Wyss, et al., 2003; Shen, Shiau, Wang, et al., 2002), while 1 study produced a mix of data collected prospectively and retrospectively (Blum, MacManus, Rischin, et al., 2004) and 1 study was of uncertain design (Schumacher, Brink, Mix, et al., 2001). Three studies enrolled consecutive series of patients (Blum, MacManus, Rischin, et al., 2004; Brink, Schumacher, Mix et al., 2004; Kamel, Zwahlen, Wyss, et al., 2003). Three of the 6 studies provide staging accuracy data based on comparisons of conventional staging tests alone and conventional staging plus PET (Blum, MacManus, Rischin, et al., 2004; Bradley, Dehdashti, Mintun et al., 2004; Kamel, Zwahlen, Wyss, et al., 2003). Three studies compared staging results of conventional tests alone and PET alone (Brink, Schumacher, Mix et al., 2004; Shen, Shiau, Wang, et al., 2002; Schumacher, Brink, Mix, et al., 2001).

Table 38 Sample Selection: Positron Emission Tomography for Staging of Small-Cell Lung Cancer

Study | Design | Patient Selection | n | Age (yr) | | Gender (%) | | Stage | | Representative Sample?
| | | | | | | | Limited % | Extensive %
Blum, MacManus, Rischin, et al., 2004 | partially prospective, partially retrospective | proven SCLC underwent PET; consecutive patients; newly diagnosed- initial staging in 15, restaging in 21; PET based on review of all clinical data and was performed to guide clinical management; | 36 | med | 64 | M | 66 | | | Unclear
| | | | | | F | 33
Bradley, Dehdashti, Mintun et al., 2004 | prospective | newly diagnosed confirmed limited stage SCLC, completed standard staging procedures | 24 | mn | 60 | M | 44 | 87.5 | 12.5 | Yes
| | | | rng | 33–90 | F | 56
Brink, Schumacher, Mix et al., 2004 | prospective | consecutive patients with histologically confirmed SCLC examined with FDG-PET during primary staging | 120 | mn | 60.8 | M | 75 | 37 | 63 | Unclear
| | | | sd | 8.9 | F | 25
Kamel, Zwahlen, Wyss, et al., 2003 | prospective | consecutive patients with SCLC referred for whole-body FDG-PET; initial staging in 24 patients and restaging after therapy in 20 patients (both in 2) | 42 | mn | 62 | M 64 | | 62.5 | 37.5 | Unclear
| | | | rng | 45–83 | F 36
Shen, Shiau, Wang, et al., 2002 | retrospective | histologically confirmed SCLC; KPS ≥ 60%; total serum bilirubin ≤ 2.0 mng/dL; serum creatinine ≤ 2.5 mg/dL; fasting blood sugar ≤ 150 mg/dL | 25 | mn | 56 | M | 72 | 40 | 60 | Unclear
| | | | sd | 7 | F | 28
| | | | rng | 45–68
Schumacher, Brink, Mix, et al., 2001 | unclear | histologically proven SCLC, primary staging in 24, therapy follow-up in 4, both in 2; therapy was surgery, RTx and CTx (ACO, EPI-CO, VIP-E, VIC-E); all treatment stopped ≥ 1 mo before PET | 30 | mn | 57 | M | 77 | 30 | 70 | Unclear
| | | | sd | 13 | F | 23
| | | | rng | 34–78

Abbreviations table provided at the end of the Report.

Table 39 Test/Reference Standard Procedure and Interpretation: Positron Emission Tomography for Staging of Small-Cell Lung Cancer

Study | PET | Conventional Staging Tests | Reference Standard | PET: Ref Stand Blind? | Ref Stand: PET Blind? | Avoided Verification Bias
Blum, MacManus, Rischin, et al., 2004 | ≥ 4 hr fast; ± attenuation correction, qualitative interpretation, access to results of the previous imaging and clinical information | initial staging - high-quality CT of chest, upper abdomen, brain, usually bone scan; restaging after initial treatment - CT, bone scan, X-ray; | if discordant results, TP = site biopsy+; or site + only on PET with other progression < 6 mos of PET, no treatment; TN = site biopsy-; or conventional equivocal/negative site with no progression for ≥ 6 mos, no treatment | Unclear | Unclear | Unclear
Bradley, Dehdashti, Mintun et al., 2004 | 4-hr fast, 10–15 mCi FDG, 50 min delay ± attenuation correction, visual interpretation; 2 experienced nuclear physicians; first, independent, blinded to conventional, then observers reread with conventional, final consensus of blinded readings; also semiquantitative maximum standardized uptake value | history, physical exam, chest X-ray, chest CT, upper abdominal CT, bone scan, contrast-enhanced CT/MRI of brain; all conventional staging procedures completed ≤ 4 wk of PET | protocol-defined approaches for further evaluation or biopsy: PET+ intrapulmonary parenchymal metastases outside RTx portal, do biopsy; thin-cut CT- or US-guided FNA where feasible; liver PET+, do biopsy/FNA cytology; adrenal PET+, do biopsy; bone PET+, evaluate by appropriate imaging studies (X-ray, CT, MRI, repeat bone scan) or biopsy or bone scan/MRI if multiple bone metastases suspected | Unclear | Unclear | Unclear
Brink, Schumacher, Mix et al., 2004 | 12 hr fast, 5 MBq/kg FDG, 90 min delay; data corrected for dead time, decay, photon attenuation; whole-body PET performed after CT (mean 12 d, range 1–26 d), hard copy and computer workstation, 2 independent investigators blinded to other data; hot spot evaluation, consensus | conventional staging by history, physical exam, bronchoscopy, thoracic/abdominal contrast-enhanced CT, cranial CT/MRI in 91, bone biopsy in 84 (refused in 36) | histology in ~20%; available data; follow-up, committee of physicians (2 clinicians, 2 nuclear specialists) achieved reference standard diagnosis by consensus; when histologic results were unavailable, consensus based on sum of available data, including follow-up, non-validated results excluded from data analysis | Yes | Unclear | No
Kamel, Zwahlen, Wyss, et al., 2003 | ≥ 4 hr fast, 300–400 MBq FDG; 40–50 min delay; segmented or PET/CT fusion attenuation correction, pre-PET staging and post-PET staging were always performed independently; clinical information available, including CT | history, physical exam, blood tests, bronchoscopy, contrast-enhanced CT of chest, upper abdomen, bone scan, CT/MRI of brain in 9 | when possible, biopsies or other imaging studies were performed to resolve discrepancies between modalities | Unclear | Unclear | Unclear
Shen, Shiau, Wang, et al., 2002 | 6 hr fast; 10 mCi (370 MBq) FDG; 40–50 min delay, agreement of at least 2 of 3 experienced nuclear medicine specialists blind to clinical stage | within 2 wk of PET: history, physical exam, blood chemistry, chest X-ray ± chest CT/MRI, brain CT/MRI, abdominal CT/MRI ± hepatic US, pelvic CT/MRI, bone scan, bone marrow biopsy | final stage was verified by pathologic findings from thoracotomyy/mediastinoscopy. other imaging results, follow-up ≥ 1 yr | Unclear | Unclear | No
Schumacher, Brink, Mix, et al., 2001 | 12 hr fast; 5 MBq FDG/kg; 90 min delay attenuation correction, hard copy and computer workstation; visual interpretation, 2 experienced independent blinded investigators; consensus; standardized uptake value > 4 | within 2 wk before or after PET: CT/MRI of brain, thorax, abdomen carried out according to standard protocols, thin-section or contrast enhancement used if needed | if discrepancies between PET and other staging procedures found, selective additional examinations performed or existing images reevaluated; in some cases, clinical follow-up proved/disproved inconsistent findings; confirmation necessary within 4 wk | Unclear | Unclear | No

Abbreviations table provided at the end of the Report.

Study quality was assessed as described in the Methods chapter, using the QUADAS tool (Whiting, Rutjes, Dinnes, et al., 2004). A major weakness of the included evidence is the uniformly poor quality of information reported about the reference standard. None of the 6 studies adequately described the execution of the reference standard and whether the reference standard correctly classifies the target condition. Without these details, the definition of a positive reference standard result is unclear. Thus the poor quality of information reported on reference standards undermines confidence in the estimates of sensitivity, specificity and staging accuracy that can be drawn from this literature.

### Study Populations

The proportion of patients enrolled who had limited stage disease ranged from 30 percent to 87.5 percent in 5 studies; it could not be determined in the study by Blum, MacManus, Rischin, et al., (2004). Three studies (Blum, MacManus, Rischin, et al., 2004; Kamel, Zwahlen, Wyss, et al., 2003; Schumacher, Brink, Mix, et al., 2001) included samples mixed with those undergoing initial staging and other being restaged. In only one study was it clear that selection of patients was not based on referral for PET scanning (Bradley, Dehdashti, Mintun et al., 2004).

### Diagnostic Accuracy

Three studies (Blum, MacManus, Rischin, et al., 2004; Brink, Schumacher, Mix et al., 2004; Shen, Shiau, Wang, et al., 2002; total N=181) reported diagnostic accuracy data (Summary Table 40). Results are presented below according to stage or site of disease.

Table 40 Diagnostic Accuracy Results: Positron Emission Tomography for Staging of Small-Cell Lung Cancer

Study | Test | Focus | n | TP | FN | FP | TN | Prev | Sens | Sens 95% CIL | Sens 95% CIU | Spec | Spec 95% CIL | Spec 95% CIU | PPV | NPV | DA
Blum, MacManus, Rischin, et al., 2004 | PET | any disease | 36 | 36 | 0 | | | | 100% | 90.3% | 100%
Bradley, Dehdashti, Mintun et al., 2004 | PET | Any disease | 24 | 24 | 0 | 1 | 0 | | 100% | 85.5% | 100%
Bradley, Dehdashti, Mintun et al., 2004 | PET | LNs | 118 | 53 | 0 | 1 | 64 | 44.9% | 100% | 93.3% | 100% | 98.5% | 91.7% | 100% | 98.1% | 100% | 99.2%
| Conv | | 118 | 37 | 16 | 4 | 61 | 44.9% | 69.8% | 55.7% | 81.7% | 93.8% | 85.0% | 98.3% | 90.2% | 79.2% | 83.1%
| PET | dist, non-brain | 70 | 45 | 1 | 2 | 22 | 65.7% | 97.8% | 88.5% | 99.9% | 91.7% | 73.0% | 99.0% | 95.7% | 95.7% | 95.7%
| Conv | | 70 | 38 | 8 | 5 | 19 | 65.7% | 82.6% | 68.6% | 92.2% | 79.2% | 57.8% | 92.9% | 88.4% | 70.4% | 81.4%
| PET | brain | 91 | 6 | 7 | 2 | 76 | 14.3% | 46.2% | 19.2% | 74.9% | 97.4% | 91.0% | 99.7% | 75.0% | 91.6% | 90.1%
| Conv | | 91 | 13 | 0 | 0 | 78 | 14.3% | 100% | 75.3% | 100% | 100% | 95.4% | 100% | 100% | 100% | 100%
Kamel, Zwahlen, Wyss, et al., 2003
Shen, Shiau, Wang, et al., 2002 | PET | regl mets | 18 | 20 | 0 | 2 | 0 | | 100% | 83.2% | 100%
| | MD/HL LNs | 9 | 9 | 0 | 2 | 0 | | 100% | 66.4% | 100%
| | ips SC LNs | 7 | 7 | 0 | 0 | 0 | | 100% | 59.0% | 100%
| | ips lung | 2 | 2 | 0 | 0 | 0 | | 100% | 15.8% | 100%
| | distant | 24 | 23 | 1 | 1 | 0 | | 95.8% | 78.9% | 100%
| | contr SC LNs | 5 | 5 | 0 | 0 | 0 | | 100% | 47.8% | 100%
| | contr lung | 3 | 3 | 0 | 1 | 0 | | 100% | 29.2% | 100%
| | liver | 3 | 3 | 0 | 0 | 0 | | 100% | 29.2% | 100%
| | bone/marrow | 6 | 6 | 0 | 0 | 0 | | 100% | 54.1% | 100%
| | brain | 2 | 1 | 1 | 0 | 0 | | 50.0% | 1.3% | 99%
| | adrenal | 2 | 2 | 0 | 0 | 0 | | 100% | 15.8% | 100%
| | other extrathoracic | 3 | 3 | 0 | 0 | 0 | | 100% | 29.2% | 100%
Schumacher, Brink, Mix, et al., 2001

Abbreviations table available at the end of the Report.

Any Disease. The study by Blum, MacManus, Rischin, et al. (2004) was the only one that reported diagnostic accuracy with reference to any disease. These investigators only included data on sensitivity in 36 patients, which they estimated at 100 percent for PET. This study does not address whether there was additional value to adding PET to staging, information about extent of disease was not reported.

Lymph Nodes. Using the patient (n=118) as the unit of analysis, Brink, Schumacher, Mix et al. (2004) found that PET had a sensitivity of 100 percent for detecting lymph node metastasis, compared with 69.8 percent for conventional staging. PET specificity was 98.5 percent, while it was 93.8 percent for conventional staging. The study by Shen, Shiau, Wang, et al. (2002) also used a patient-based analysis, but grouped lymph nodes into regions. Few patients provided data on negative nodes, so specificity was not reported. Shen, Shiau, Wang, et al. (2002) did not provide separate sensitivity data for PET and conventional imaging. PET was found to be 100 percent sensitive in each of 3 lymph regions: in 9 patients with mediastinal or hilar lymph metastases; in 7 patients with ipsilateral supraclavicular lymph metastases; and in 5 patients with contralateral supraclavicular lymph metastases. There were 2 PET false positives in mediastinal/hilar lymph nodes.

Other Regional Sites. Shen, Shiau, Wang, et al. (2002) reported that sensitivity for ipsilateral lung foci was 100 percent in 2 patients.

Distant Sites, Non-Brain. Among 70 patients, Brink, Schumacher, Mix et al. (2004) found that PET's sensitivity for distant non-brain sites was 97.8 percent, compared with 82.6 percent for conventional staging. Specificity was 91.7 percent for PET and 79.2 percent for conventional staging. In the Shen, Shiau, Wang, et al. (2002) study, PET had 100 percent sensitivity in 19 patients. Sites in this study included contralateral lung (1 false positive), liver, bone/marrow, adrenal and other extrathoracic.

Brain Metastases. In the Brink, Schumacher, Mix et al. (2004) study, PET's sensitivity was 46.2 percent, compared with 100 percent for conventional staging, among 13 patients. Specificities were 97.4 percent for PET and 100 percent for conventional staging. Shen, Shiau, Wang, et al. (2002) included 2 patients with brain metastases and PET detected 1 (50 percent sensitivity).

### Staging Accuracy

All 6 studies reported on instances in which PET correctly upstaged disease among those undergoing initial staging (Table 41). The proportions were: 3 of 15 (20 percent) in Blum, MacManus, Rischin, et al. (2004); 1 of 24 (4.2 percent) in Bradley, Dehdashti, Mintun et al. (2004); 10 of 120 (8.3 percent) in Brink, Schumacher, Mix et al. (2004); 3 of 24 (12.5 percent) in Kamel, Zwahlen, Wyss, et al. (2003); 1 of 25 (4 percent) in Shen, Shiau, Wang, et al. (2002); and 5 of 30 (19.2 percent) in Schumacher, Brink, Mix, et al. (2001). Three studies mentioned examples of PET correctly downstaging disease. Brink, Schumacher, Mix et al. (2004) found 3 cases in 24 (12.5 percent), Kamel, Zwahlen, Wyss, et al. (2003) observed 1 in 24 (4.2 percent) and Shen, Shiau, Wang, et al. (2002) saw 1 in 25 (4 percent). Among patients being restaged, Schumacher, Brink, Mix, et al. (2001) reported that PET correctly upstaged disease in 1 of 6 patients (16.7 percent).

Table 41 Staging Accuracy Results/Changes in Patient Management: Positron Emission Tomography for Staging of Small-Cell Lung Cancer

Study | Test | Use | PET Correctly Changed Stage | | | PET Ruled-in (R/I) or Ruled-out (R/O) Metastases | | | | PET Missed Metastases | | | PET Changed Patient Management
| | | | # | % | | Site | # | % | Site | # | % | # | % | Changes
Blum, MacManus, Rischin, et al., 2004 | PET | staging | up | 3 | 20 | | | | | | | | 4 | 26.7 | forgone RTx for ED
| | | | | | | | | | | | | 1 | 6.7 | ED, received palliative
| | | | | | | | | | | | | | CTx/RTx
| | | | | | | | | | | | | 2 | 13.3 | RTx target volume changed
| | | | | | | | | | | | | 3 | 12 | PCI omitted
| | | | | | | | | | | | | 3 | 12 | PCI selected
| | | | | | | | | | | | | 2 | 8 | forgone CTx, observation for NED
Bradley, Dehdashti, Mintun et al., 2004 | PET | staging | up | 1 | 4.2 | R/I | lung | 1 | 4.2 | | | | 7 | 29.2 | RTx target volume changed
| | | | | | R/I | regl LNs | 6 | 25
Brink, Schumacher, Mix et al., 2004 | PET | staging | up | 10 | 8.3 | | | | | brain | 1 | 0.8 | 10 | 8.3 | forgone RTx for ED
| | | down | 3 | 2.5 | | | | | | | | 3 | 2.5 | selected CTx/RTx
| | | | | | | | | | | | | 1 | 0.8 | missed brain metastasis, affected treatment
Kamel, Zwahlen, Wyss, et al., 2003 | PET | staging | up | 3 | 12.5 | R/I | visceral/ soft tissue | 1 | 4.2 | brain | 2 | 8.3 | 12 | 29
| | | down | 1 | 4.2 | R/O | adrenal | 1 | 4.2 | LN | 1 | 5 | 9 | 37 | forgone RTx for ED (3)
| | | | | | R/I | lung | 1 | 5 | | | | | | altered radiation field (5)
| | restaging | | | | R/I | breast/axilla | 1 | 5 | | | | | | selected surgery (1)
| | | | | | R/O | LN | 2 | 10 | | | | 3 | 15 | CTx reinstituted (1)
| | | | | | R/O | bone | 1 | 5 | | | | | | CTx discontinued (2)
Shen, Shiau, Wang, et al., 2002 | PET | staging | up | 1 | 4
| | | down | 1 | 4
Schumacher, Brink, Mix, et al., 2001 | PET | staging | up | 5 | 19.2
| | restaging | up | 1 | 16.7

In two studies, PET was found to correctly rule in disease at various sites. In the Bradley, Dehdashti, Mintun et al. (2004) study the site was lung in 1 patient (4.2 percent) and regional lymph nodes in 6 (25 percent). In the Kamel, Zwahlen, Wyss, et al. (2003) study, the sites were: visceral/soft tissue in 1 patient undergoing initial staging (4.2 percent); lung in 1 restaged patient (5 percent); and breast/axilla in 1 restaged patient. PET was shown to correctly rule out disease in selected sites in the Kamel, Zwahlen, Wyss, et al. (2003) study, including: adrenal gland in 1 patient who was initially staged (4.2 percent); bone in 1 who was restaged (5 percent); and lymph node in 2 restaged patients (10 percent).

Only Kamel, Zwahlen, Wyss, et al. (2003) and Shen, Shiau, Wang, et al. (2002) reported the frequency of incorrect staging by PET; it is unclear from the other studies how often restaging by PET was incorrect. Both Kamel, Zwahlen, Wyss, et al. (2003) and Shen, Shiau, Wang, et al. (2002) found no cases incorrectly upstaged or downstaged by PET at initial staging, but Kamel, Zwahlen, Wyss, et al. (2003) reported 1 case being restaged that was incorrectly upstaged.

### Changes in Patient Management

Four studies reported on instances in which patient management was changed based on PET results. The total proportions were: 41.7 percent in Blum, MacManus, Rischin, et al. (2004); 58.3 percent in Brink, Schumacher, Mix et al. (2004); 29.2 percent in Bradley, Dehdashti, Mintun, et al. (2004) and 28.6 percent in Kamel, Zwahlen, Wyss, et al. (2003). Specific changes included the following: forgoing of RTx for extensive disease; palliative CTx/RTx selected for extensive disease; change in RTx target volume; PCI selected; PCI omitted; forgoing of CTx for no evidence of disease; CTx/RTx selected for limited disease; surgery selected; CTx reinstituted; and CTx discontinued.

Study Quality. The quality assessment tool used for Key Question 6 includes 14 items, 8 of which focus on the reference standard (Appendix Table 4G).^*^ A reference standard is the basis for estimating sensitivity and specificity. As noted, the quality of information about the reference standard was uniformly poor, undermining confidence in estimates of sensitivity and specificity. The ratings of study quality can be seen in Summary Table 42.

Table 42 Ratings of Study Quality for Key Question 6

Item | Blum | Bradley | Brink | Kamel | Shen | Schumacher
Representative sample? | ? | + | ? | ? | ? | ?
Clear patient selection criteria? | ? | + | ? | ? | ? | ?
Correct reference standard classification of target? | ? | ? | ? | ? | ? | ?
Short period between test and reference standard? | ? | ? | ? | ? | ? | ?
Random/whole sample received reference standard? | + | + | + | + | + | +
Received reference standard regardless of test results? | ? | ? | - | ? | - | -
Reference standard independent of test? | ? | + | + | ? | ? | ?
Test execution sufficiently described? | + | + | + | + | - | +
Reference standard execution sufficiently described? | - | - | - | - | - | -
Test interpreted blind to reference standard? | ? | ? | + | ? | ? | ?
Reference standard interpreted blind to test? | ? | ? | ? | ? | ? | ?
Clinical data available? | + | +/- | - | + | - | -
Uninterpretable/indeterminate results? | - | - | - | - | - | +
Withdrawals explained? | + | + | + | + | + | +

Given 14 items in the instrument and 6 studies, there were 84 data points, among which 51 percent were rated as unclear, underlining the prevalence of poor reporting in these articles.

In only 1 study (Bradley, Dehdashti, Mintun et al., 2004) was it clear if the sample was representative of population of interest. Conventional staging suggested that patients in the Bradley, Dehdashti, Mintun et al. (2004) study had limited disease, so PET was used to determine if any patients were understaged. In all of the other 5 studies, it is unclear why patients were referred for PET and no study clearly stated that an intact group of patients newly diagnosed with SCLC were enrolled. Selection criteria were clear only in the Bradley, Dehdashti, Mintun et al. (2004) study. For all other studies, criteria were unclear. Articles by Brink, Schumacher, Mix et al. (2004) and Shen, Shiau, Wang, et al. (2002) suggest that PET results influenced performance of the reference standard. In the other 4 studies, it is unclear if PET results influenced performance of the reference standard. The Bradley, Dehdashti, Mintun et al. (2004) study did not incorporate PET into the reference standard, while in all other studies, it was unclear whether PET and the reference standard were independent. Only the Bradley, Dehdashti, Mintun et al. (2004) study stated that PET was interpreted blind to the reference standard; all others were unclear.

### Conclusions

Six studies reporting on a total of 277 patients (range 20–120) provided data on the diagnostic accuracy of PET in SCLC. The evidence suggests that, except for detection of brain metastases, the PET added to conventional staging is more sensitive in detecting disease than conventional staging alone. Upstaging was reported in 4–20 percent of patients and downstaging in 4–13 percent of patients. Three studies reported very high occurrence of patient management changes that were attributed to PET (29–58 percent).

However, the quality of these studies is consistently poor and insufficient detail in reporting was the norm. There is such a high degree of uncertainty about the execution and interpretation of the reference standard in all of these studies that confidence is quite low in estimates of diagnostic and staging accuracy. Although these studies report that PET has correctly upstaged or downstaged the extent of disease, the frequency of incorrect changes in stage attributable to PET is unknown due to incomplete reporting. It is not possible to determine the frequency with which management changes, based on PET results, were actually beneficial or harmful.

Thus it is not possible from the limited and poor quality evidence that is available to determine whether the use of PET adds value relative to conventional staging tests for SCLC.

## Key Question 7

What are the outcomes (survival, toxicity and quality of life) of treatments used to manage patients with mixed small cell/non-small cell lung cancers?

### Overview

Two types of studies were sought: RCTs that compared alternative chemotherapy regimens for mixed small cell/non-small cell cancers; and phase II prospective trials reporting on at least 25 patients treated with a single regimen that reported at least one health outcome of interest. Health outcomes included: duration of survival; disease-free survival and/or progression-free survival; quality of life; treatment-related adverse effects; objective tumor response rates; and response durations.

### Results

No studies meet selection criteria for this question. Very few references from the literature search represented studies of any kind that included patients with mixed histology. Several studies are described below, along with reasons for exclusion.

- The single-arm study by Ruffini, Rena, Oliaro, et al. (2002) was excluded because it could not be confirmed as a prospective phase II multicenter trial. It was clearly conducted as a single-center case series of patients with mixed histologic pattern who underwent surgery. The article does not mention that it was prospective and is likely to be retrospective. Between 1993 and 1999, 1158 patients underwent surgery for lung tumors. Among these were 59 patients with a mixed histologic pattern, separated into 3 main subgroups: 1) adenosquamous carcinoma, n=33, 2) combined neuroendocrine + non-neuroendocrine carcinoma (NNEC), n=21, and 3) biphasic tumors, n=5. The second subgroup included 14 patients with SCLC: 10 who had SCLC + squamous cell carcinoma and 4 who had SCLC + adenocarcinoma. The article provides survival data for 19 of the patients in the second subgroup.
- Smythe Estrera, Swisher, et al. (2001) was excluded because it was not prospective or multicenter and it did not enroll the minimum of 25 patients. These authors reported a single-center retrospective study of 11 patients who underwent surgery for NSCLC after treatment for SCLC. The study period spanned 1978 to 1998. Survival results for the mixed histology patients were compared with 3 control groups: 1) 23 patients with stage I NSCLC undergoing any resection; 2) 46 patients with stage I NSCLC undergoing wedge resection; and 3) 17 patients undergoing wedge resection who had NSCLC and a prior malignancy.
- A subset of patients with mixed histology from an RCT is discussed by Aisner, Finkelstein, Ettinger, et al. (1990). This study is excluded because outcomes are not presented according to treatment group. Patients with extensive stage SCLC received one of 2 induction chemotherapy regimens and complete responders were further randomized to maintenance chemotherapy or observation after whole brain irradiation. A pathologist reviewed the tumor specimens according to a revised classification scheme that includes a variant-morphology category characterized as the small-cell/large-cell (SC/LC) subtype. An initial review of 577 patients identified 24 with the SC/LC subtype. Subsequent review with a second pathologist confirmed only 11 patients in this category. Of these 11 patients, 3 achieved a complete response and 4 achieved a partial response.
- The paper by Johnson, Ihde, Bunn, et al. (1985) is excluded because it presents outcome data for only a single patient with mixed histology. This article summarized data from a series of intramural NCI clinical trials that included 252 patients with newly diagnosed SCLC. Of these, 19 patients were of SC/LC subtype. The article focuses on 19 patients who achieved long-term survival (≥30 months). Only 1 SC/LC patient was a member of this group.

### Conclusions

No studies meet selection criteria for this question. Very few references from the literature search represented studies of any kind that included patients with mixed histology. No conclusions can be drawn on outcomes of treatment for patients with mixed small cell/non-small cell lung cancers.

## Key Question 8

What is the role of surgery and what is its impact on survival in patients with very early stage SCLC? How do available studies define very early stage SCLC?

### Overview

Very early limited SCLC is defined as no preoperative evidence of involved nodes (clinically N0). In a retrospective analysis of 264 limited stage SCLC patients treated with chemotherapy and radiation from 1976 through 1985, Shepherd, Ginsberg, Haddad et al. (1993) found significantly (p=0.02) better survival for patients clinically staged with negative mediastinal nodes, compared to those with positive mediastinal nodes and also to those with pneumonic consolidation, pleural effusion, atelectasis, or supraclavicular adenopathy. About half the patients classified node negative underwent mediastinoscopy and half were staged by thoracic CT or X-ray only. Unfortunately, retrospective analyses of resected SCLC patients show that clinical (preoperative) staging frequently underestimates pathologic stage (Shepherd, Ginsberg, Patterson et al. 1989; Shepherd, Ginsberg, Feld et al. 1991; Inoue, Miyoshi, Yasumitsu et al. 2000) and inadequately separates limited stage patients by prognosis (Waddell and Shepherd, 2004). Moreover, detection of involved nodes depends on the methods used for staging.

For this question, randomized, controlled trials that compared surgery to no surgery in patients with very early limited SCLC were sought. Two randomized, controlled trials were identified (Lad, Piantadosi, Thomas, et al., 1994; Liao, Zhao, Zhou, et al., 1995), but each had serious limitations for purposes of this review (Summary Table 43). First, neither used platinum based chemotherapy, and thus had limited relevance to contemporary treatment settings. Second, neither RCT studied a homogeneous group with respect to nodal status at randomization (Summary Table 44). The larger RCT (Lad, Piantadosi, Thomas, et al., 1994; N=146) included patients with involved mediastinal nodes, and it is uncertain whether Liao, Zhao, Zhou, et al. (1995; N=40) excluded such patients. Neither study reported outcomes separately for a subgroup without nodal involvement. Since relevant RCT data were lacking, we also sought data from non-randomized comparative studies, both prospective and retrospective (see Summary Table 43 and Appendix Tables 8A–D).^*^

Table 43 Studies Comparing Surgery versus No Surgery for Early Limited Stage SCLC

Study | N evaluated | | Pt? | ChemoTx regimen | TRTx? | PCI? | resections | | response status^3^ | study | # centers | quality rating
| +surg | -surg | | | | | types^1^ | timing^2^ | | type
Lad, Piantadosi, Thomas, et al., 1994 | 70 | 76 | no | CAV | all | all | 54 c, 4 p, 12 T | after | 40% CR | RCT | multi | fair
| | | | | | | | | 60% PR
Liao, Zhao, Zhou, et al., 1995 | 20 | 20 | no | IMAV | -surg only | NR | NR | Mid | 70–80% CR | RCT | one | poor
Badzio, Kurowski, Karnicka-Mlodkowska, et al., 2004/Badzio, Jassem, Kurowski, et al., 2005 | 67 | 67 | some^4^ | various | 58% of -surg | 34% of +surg | 30 P 37 L | before | not relevant | case-control | one | poor
Shepherd, Ginsberg, Patterson et al. 1989 | 38 | 19 | ~5% | various | all | all | 8 P, 25 L 5 T | after | 45% CR | non-random. | multi | fair
| | | | | | | | | 50% PR
Namikawa, Den, Kimura, et al., 1994 | 58 | 43 | NR | NR | NR | NR | NR | NR | ? | retrospect. | one | poor
Hara, Ohta, Ichinose, et al., 1991/Hara, Ichinose, Kuda et al., 1991 | 36 | 45 | ~33% | various | all | NR | 4 P, 27 L 5 B | 19 before 17 after | 24% CR | retrospect. | one | poor
| | | | | | | | | 59% CR
Friess, McCracken, Troxell, et al., 1985 | 15 | 246 | no | COMF or CAV | all | all | 3 P 12L | before | not relevant | retrospect. | multi | fair
Osterlind, Hansen, Hansen, et al., 1985 | 33 | 46 | no | CCM ± V ± A ± E | 33% each | 7–12% | 11c, 13p 9<p | before | not relevant | retrospect. | two | fair
Rostad, Naalsund, Jacobsen, et al., 2004 | 29 | 96 | NR | NR | NR | NR | 3P, 15L 3B, 5<p | before | not relevant | registry | multi | poor
George, Fitzgerald, Brown, et al., 1986 | 13 | 88 | no | various | NR | NR | NR | before | not relevant | registry | multi | poor

1 resection types: c=complete; p=partial; <p=less than a partial resection; T=thoracotomy only (open and close); P=pneumonectomy; L=lobectomy; B=bilobectomy

2 resection timing: after = after all chemotherapy cycles; before = before any chemotherapy; mid = between cycles

3 at the time of randomization or resection

4 proportion treated with platinum not reported.

Table 44 Sample and Methods: Surgery versus No Surgery for Very Early Limited Stage Disease

Study | N | | Age | % Female | % Performance Status | | | | +Surg: Type of Resections | CTX Regimen | RTx Regimen
Lad et al. 1994 RCT multi-center late 1983 - 10/1989 | Total | 146 | md (rng) 59 (35–72); arms pooled but “well, matched” | 35 arms pooled but “well matched” | 82% with KPS ≥ 90 | | | | 54 complete 4 partial 12 open & close | CAV | Dose | Schedule | PCI?
| +surg | 70 | | | arms pooled but “well matched” | | | | | same | 50 Gy | 25 x 2 Gy | 30 Gy 15 x 2 Gy
| -surg | 76
Liao et al. 1995 single center RCT (Shanghai) 1/90–12/91 | Total | 40 | mn (rng) | | NOT REPORTED | | | | not reported | same for all: ifosfamide, Mesna, doxorubicin, vincristine | Dose | Schedule | PCI?
| +surg | 20 | 50 (33–74) | 10 | | | | | | | only for -surg arm; dose, schedule not reported | | not reported
| -surg | 20 | 54 (31–66) | 10
Badzio et al. 2004, 2005; pair-matched case/control one center1984-96 | Total | 134 | mn (rng) | | 0 | 1 | 2 | 3 | 30 pneumonectomy; 37 lobectomy | CAV, CDE, PE or MCCC/CAV/VI CCMV or ACOM | Dose | Schedule | PCI?
| +surg | 67 | 57 (29–70) | 15 | 60 | 36 | 4 | | | | 30–50 Gy | 10, 20, or25 fracs; n=39 -surg only | n=23, +surg only; dose, fractionation not reported
| -surg | 67 | 54 (36–71) | 22 | 58 | 33 | 9
| in CR | 23 | (p=0.03) | (p=0.27) | WHO
Shepherd et al. 1989; adjuv. surgery post chemoTx; non-randomized multi-center | Total | 57 | md (rng) | | NOT REPORTED | | | | 8 pneumonectomy; 25 lobectomy; 5 thoracotomy only | CAV ± etoposide or PE | Dose | Schedule | PCI?
| +surg | 38 | 60 (39–77) | 32 | | | | | | | 25–35 Gy same | 10–20 fracs | 20 Gy in 5 fracs
| -surg | 19 | 59 (44–75) | 47
Namikawa et al. 1994 retrospective series; single center 1960-86 | Total | 101 | NOT REPORTED | NOT REPORTED | NOT REPORTED | | | | NOT REPORTED | NOT REPORTED | Dose | Schedule | PCI?
| +surg | 58 | | | | | | | | | NOT REPORTED
| -surg | 43
Hara et al. 1991 retrospective series; single center 1972-89 | Total | 81 | mn (rng) | | 0 | 1 | 2 | 3 | 4 pneumonectomy; 27 lobectomy; 5 bilobectomy | various regimens | Dose | Schedule | PCI?
| +surg | 36 | 64 (44–76) | 17 | 50 | 44 | 6 | | | same | 30–70 Gy (mn 46 Gy) | 1.4–2 Gy, 25–36 fracs, 1/d | NOT REPORTED
| -surg | 45 | 63 (45–83) | 16 | 18 | 78 | 4
| | | | | ECOG
Friess et al. 1985 retrospective analysis of SWOG 7628 patients; 1977-9 | Total | 261 | NOT REPORTED | NOT REPORTED | NOT REPORTED | | | | 3 pneumonectomy; 12 lobectomy | 4 different regimens | Dose | Schedule | PCI?
| +surg | 15 | | | | | | | | | 2 × 30 Gy ± 15 Gy boost | NOT REPORTED | dose, fracs not reported
| -surg | 246
Osterlind et al. 1985; retrospective analysis of patients from 6 trials, 2 Danish institutions, 3/73–9/81 | Total | 79 | mn (sd) | | AJC^1^ | [underlined: 0–1] | [underlined: 2] | [underlined: 3–4] | 11 complete, 13 partial, 9 <partial resections | CCM ± vincristine ± (doxorubicin + etoposide) | Dose | Schedule | PCI?
| +surg | 33 | 55 (± 8) | 18 | | 83 | 17 | 0 | | | 33% of each group, but dose, schedule not reported | | 12%
| -surg | 46 | 60 (± 6) | 28 | | 91 | 6 | 3 | | | | | 7% but regimen details not reported
Rostad et al. 2004 registry analysis all cases in Norway, 1993-9 | Total | 125 | “no age difference” between groups | NOT REPORTED | NOT REPORTED | | | | 3 pneumonectomy; 15 lobectomy; 3 bilobectomy; 5 minor resection | NOT REPORTED | Dose | Schedule | PCI?
| +surg | 29 | | | | | | | | | no details provided | | not specified
| -surg | 96
George et al.1986 registry analysis all cases in Rochester, NY 1975-81 | Total | 101 | 14% 31–50 29% 51–60 38% 61–70 19% ≥71 (groups pooled) | 35 (groups pooled) | NOT REPORTED | | | | NOT REPORTED | CCM, CMVP, CC, or CAV | Dose | Schedule | PCI?
| +surg | 13 | | | | | | | | same | no details provided | | not specified
| -surg | 88

1 American Joint Committee for Cancer Staging, 1979

Abbreviations table provided at the end of this Report.

Eight studies were identified:

- one case-control study (Badzio, Kurowski, Karnicka-Mlodkowska, et al., 2004/Badzio, Jassem, Kurowski, et al., 2005);
- a prospective study of surgery with a comparison group of surgical candidates who did not undergo thoracotomy (Shepherd, Ginsberg, Patterson, et al. 1989);
- four retrospective analyses (Namikawa, Den, Kimura, et al., 1994; Hara, Ohta, Ichinose, et al., 1991/Hara, Ichinose, Kuda et al., 1991; Friess, McCracken, Troxell, et al., 1985; Osterlind, Hansen, Hansen, et al., 1985); and
- two registry analyses (Rostad, Naalsund, Jacobsen, et al., 2004; George, Fitzgerald, Brown, et al., 1986).

These studies had similar limitations with respect to treatment regimens and included patients (Summary Tables 43 and 45). Three studies used platinum-based regimens (Badzio, Kurowski, Karnicka-Mlodkowska, et al., 2004/Badzio, Jassem, Kurowski, et al., 2005; Shepherd, Ginsberg, Patterson, et al. 1989; Hara, Ohta, Ichinose, et al., 1991/Hara, Ichinose, Kuda et al., 1991), but not for all included patients. Only the Rostad, Naalsund, Jacobsen, et al. (2004) registry analysis restricted their study population to patients with very early limited stage disease (N0 patients clinically staged Ia or Ib).

Table 45 Eligibility criteria and staging procedures used in studies of surgery for very early limited stage SCLC

Study | diagnosis before thoracotomy? | eligibility criteria for inclusion by clinical staging evaluation | | | | | | | | | | | staging procedures utilized
| | solitary peripheral nodules? | T2 tumors | T3 tumors | involved mediastinal nodes | involved supraclavicular nodes | involved hilar nodes | pleural effusion | pericardial effusion | superior vena cava syndrome | stage II disease | stage III disease | chest imaging | abdominal imaging | brain imaging | bone imaging | bone marrow evaluation | bronchoscopy | medistinoscopy
Lad et al., 1994 | yes | no | yes | yes | yes | ? | ? | ? | no | no | yes | yes | ? | yes; method unknown | CT | yes; method unknown | yes | yes | ?
Liao et al., 1995 | yes | no | yes | yes | ? | ? | ? | ? | ? | ? | yes | yes | CT | CT & US | CT | RNS | yes | ? | ?
Badzio et al., 2004 | no | ? | yes | no | yes | no | ? | no | ? | ? | yes | yes | CT | CT or US | CT | RNS | no | yes | not routinely
Shepherd et al., 1989 | yes | no | yes | yes if N0 | yes | ? | ? | ? | ? | ? | yes | yes | some CT | RNS | CT or RNS | RNS | yes | ? | yes if no CT
Namikawa et al., 1994 | most | ? | ? | ? | ? | ? | ? | ? | ? | ? | ? | ? | ? | ? | ? | ? | ? | ? | ?
Hara et al., 1991 | yes | ? | yes | ? | yes | ? | ? | ? | ? | ? | yes | yes | CT | CT or RNS | CT or RNS | CT or RNS | yes | yes | ?
Friess et al., 1985 | yes | ? | ? | ? | yes | yes | ? | ? | ? | ? | ? | ? | X ray | RNS | RNS | RNS | yes | ? | ?
Osterlind et al., 1985 | yes | ? | ? | ? | no | no | no | ? | ? | ? | no | no | ? | ? | ? | ? | yes | in most | in most
Rostad et al., 2004 | ? | ? | yes | no | no | no | no | ? | ? | ? | no | no | CT for some | ? | ? | ? | ? | ? | ?
George et al., 1986 | ? | ? | yes | yes | yes | yes | yes | no | ? | ? | yes | yes | CT for some | CT, US or RNS in 75% | CT or RNS in 77% | ? | yes in 58% | ? | ?

yes=eligible for inclusion, or procedure was used for staging; no=not eligible for inclusion or not used or evaluated for staging ; ?= cannot be determined from information in published report;

Abbreviations table provided at the end of this Report.

### Randomized, Controlled Trials

Interventions. Although two RCTs compared outcomes for limited stage SCLC patients managed with versus without surgery, neither trial fully adhered to a contemporary management strategy (Lad, Piantadosi, Thomas, et al., 1994; Liao, Zhao, Zhou, et al., 1995; see Table 43, Table 44, Appendix Tables 8A–D Only the Lad, Piantadosi, Thomas, et al., (1994) trial used TRTx (and PCI) for all patients, while the Liao, Zhao, Zhou, et al. (1995) trial only gave TRTx to those randomized to no surgery. Patients in the Lad, Piantadosi, Thomas, et al. (1994) trial received TRTx sequentially after completing chemotherapy (and post-operative recovery if randomized to surgery). The Liao, Zhao, Zhou, et al. (1995) trial scheduled operations (and TRTx for the other arm) after chemotherapy cycles 2 or 3 (of up to 7). Each treatment regimen lacked platinum.

Study Populations. Published information suggests that neither RCT studied a homogeneous group of patients with respect to nodal status at randomization (Table 44). Lad, Piantadosi, Thomas, et al. (1994) randomized limited stage patients in CR or PR after five cycles of induction (neoadjuvant) chemotherapy. They did not report nodal status by clinical staging after chemotherapy for either arm. However, of 70 patients randomized to surgery, 15 were clinically N0 at registration (before induction), and 16 were pathologically N0 after resection. Ninety to 95 percent of those Liao, Zhao, Zhou, et al. (1995) randomized were in stage III. They reported 70–80 percent in CR, but it is uncertain when in the course of therapy these remissions were achieved. Liao, Zhao, Zhou, et al. (1995) also did not report nodal status before chemotherapy or after cycles 2–3, when surgery or radiation therapy took place.

Neither trial required mediastinoscopy or other invasive staging. Noninvasive staging was inadequately described in both RCTs.

Results. By log rank analysis, neither RCT found a statistically significant difference between Kaplan-Meier survival curves for those managed with versus without surgery (Lad, Piantadosi, Thomas, et al., 1994, p=0.78; Liao, Zhao, Zhou, et al., 1995, p=0.12; see Table 46, Appendix Table 8E). However, Liao, Zhao, Zhou, et al. (1995) reported a significant difference in percent survival at two years that favored the arm randomized to surgery (52 percent versus 18 percent; p<0.05 by t-test). Neither RCT reported time to relapse or progression, disease-free survival, or quality of life outcomes.

Table 46 Survival Outcomes: Surgery versus No Surgery for Very Early Limited Stage Disease

Study | N | | OS Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr (%) | TTP Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr (%)
Lad et al., 1994 | +surg | 70 | 15.4 | ~60 | 20 | ~20 | ~20 | ~20 | NOT REPORTED
multi-center RCT | -surg | 76 | 18.6 | ~65 | 20 | ~20 | ~20 | ~20
| Difference | | -3.2 | -5 | 0
| | | log rank p=0.78
Liao et al., 1995 | +surg | 20 | | 79 | 52 | 24 | | | NOT REPORTED
single-center RCT (Shanghai) 1/90–12/91 | -surg | 20 | | 63 | 18 | 18
| Difference | | | 16 | 34 | 6
| | | (log rank p=0.12; t-test at 2 yr, p<0.05)
Badzio et al., 2004, 2005 | +surg | 67 | 22.3 | 70 | 43 | ~35 | ~30 | 27 | 20.9
single center case-control | -surg | 67 | 11.2 | 45 | 17 | ~12 | ~4 | 4 | (time to relapse or progression)
| (in CR 23) | | | (22) | (36) | | | (26) | 7
| Difference | | 11.1 | 25 | 26 | ~23 | ~26 | 23 | 13.9
| | | p < 0.001; HR = 0.42; 95% CI: 0.28, 0.61 | | | | | | p < 0.001
Shepherd et al., 1989 | +surg | 38 | 22.8 | ~63 | ~47 | ~36 | ~36 | 36 | NOT REPORTED
non-randomized multi-center | -surg | 19 | 11.8 | ~48 | ~10 | ~10 | ~10
| Difference | | 10 | ~15 | ~37 | ~26 | ~26
| | | p = 0.049
Namikawa et al., 1994 | resected | 43 | 8.1 | | | | | | NOT REPORTED
single center case series | explored^1^ | 15 | 5.1
| -surg | 43 | 5.2
| Difference | | 2.9 | (statistical test result not reported)
Hara et al., 1991 | +surg | 36 | 33 | | | | | 38 | NOT REPORTED
single center case series | -surg^2^: CR | 19 | 24.5
| PR | 20 | 12.5 | | | | | 21
| Difference | | 8.5 (+surg - CR) | | | | | 0
| | | 20.5 (+surg - PR) | (statistical test result not reported)
Friess et al., 1985 | +surg | 15 | 25 | | 44 | | | | NOT REPORTED
4-arm RCT subgroup analysis | -surg | 246 | 10.5 (p=0.0037) | | 13.7 (p<0.05)
| | 33^3^ | 10 (range, 1–46+; p=0.03)
| Difference | | 15 | | 30.3
Osterlind et al., 1985; retrospective analysis, patients from 6 trials, 2 Danish institutions, 3/73–9/81 | +surg | 33 | | ~37 | ~16 | ~14 | ~14 | | DFS: | 15% at 1.5 yr, 12% at 2 yr
| -surg | 46 | | ~50 | ~16 | ~10 | ~8 | | | 15% at 1.5 yr, 13% at 2 yr
| Difference | | | ~(-13) | 0 | ~4 | ~6 | | | none
| | | | (p=0.35 by life table analysis)
Rostad et al., 2004 | +surg | 29 | | | | | | 44.9 (95% CI: 23.9, 65.9)
registry analysis | -surg | 96
| | | | | | | | 11.3 (95% CI: 4.2, 18.4) | NOT REPORTED
| Difference | | | | | | | 33.6
George et al., 1986 | +surg | 13 | 30.8 | ~70 | ~56 | ~46 | ~40 | ~40 | NOT REPORTED
registry analysis | -surg (all) | 88 | 12.4
| CTx | 43 | 11.9 | ~43 | ~15 | ~10 | ~4 | 0
| RTx | 20 | 13.4 | ~58 | ~20 | ~20 | ~20 | 18
| both | 25 | 14.1
| Difference | | 18.4 [+surg - (all -surg)]; (p=0.009 versus all -surg)

1 patients found intra-operatively to have unresectable disease

2 results for unresected patients reported separately for complete (CR) and partial (PR) responders to chemotherapy ± TRTx

3 subgroup of unresected patients selected for “similar initial presentation” as those resected

### Nonrandomized Comparisons

Interventions. Only three of the eight studies reported that all patients received TRTx (Shepherd, Ginsberg, Patterson, et al., 1989; Hara, Ohta, Ichinose, et al., 1991/Hara, Ichinose, Kuda et al., 1991; Friess, McCracken, Troxell, et al., 1985), and only two used PCI (Shepherd, Ginsberg, Patterson, et al. 1989; Friess, McCracken, Troxell, et al., 1985). Only the Shepherd, Ginsberg, Patterson, et al. (1989) study resected patients after chemotherapy was completed. Three studies used platinum-based regimens (Badzio, Kurowski, Karnicka-Mlodkowska, et al., 2004/Badzio, Jassem, Kurowski, et al., 2005; Shepherd, Ginsberg, Patterson, et al., 1989; Hara, Ohta, Ichinose, et al., 1991/Hara, Ichinose, Kuda et al., 1991), but not for all included patients.

Study Populations. Inclusion and exclusion criteria (Summary Table 43, Appendix Table 8A)^*^ showed that only the Rostad, Naalsund, Jacobsen, et al. (2004) registry analysis restricted their study population to patients with very early limited stage disease (N0 patients clinically staged Ia or Ib). However, Rostad, Naalsund, Jacobsen, et al. (2004) did not report TRTx or PCI use, and excluded 18 patients who received adjuvant chemotherapy after surgery from their analysis. Thus, none of the eight non-randomized comparisons addressed the population of interest given contemporary treatment with versus without surgery.

Results. Four of eight nonrandomized studies reported significantly longer survival for the group given surgery than for the comparison group managed without surgery (Badzio, Kurowski, Karnicka-Mlodkowska, et al., 2004/Badzio, Jassem, Kurowski, et al., 2005; Shepherd, Ginsberg, Patterson, et al., 1989; Friess, McCracken, Troxell, et al., 1985; George, Fitzgerald, Brown, et al., 1986; see Summary Table 8B, Appendix Table 8E). The Badzio case-control study (Badzio, Kurowski, Karnicka-Mlodkowska, et al., 2004/Badzio, Jassem, Kurowski, et al., 2005) also reported a statistically significant increase in time to relapse or progression for those given surgery. No non-randomized comparison evaluated quality of life outcomes.

One cannot exclude the influence of patient selection and other biases in the survival results from non-randomized studies. Most did not report adequate details to evaluate the similarity of study groups with respect to baseline characteristics and prognostic factors (Table 44, Appendix Tables 8b and 8H). Information also was inadequate to determine whether patients in each group were managed similarly with respect to chemotherapy and radiation therapy regimens (Table 44, Appendix Table 8C).

### Adverse Events

Perioperative mortality was 2.9 percent in the Lad, Piantadosi, Thomas, et al. (1994) RCT (Table 47, Appendix Table 8G).^*^ It was zero in the Liao, Zhao, Zhou, et al. (1995) RCT and in three reporting non-randomized comparisons. Only two of these five studies reported treatment-related mortality in the comparison groups managed without surgery (Liao, Zhao, Zhou, et al., 1995; George, Fitzgerald, Brown, et al., 1986). Only the Shepherd, Ginsberg, Patterson, et al. (1989) study reported other adverse events, but did not report their rates in the comparison group.

Table 47 Adverse Events: Surgery versus No Surgery for Very Early Limited Stage Disease

Toxicity Type | Study | Severity or Grade | Early n | % | Late n | % | p | Not Reporting
Treatment-related or operative mortality | Lad 1994 | | 70 | 2.9 | 76 | NR | | Badzio 2004; Namikawa 1994; Friess 1985; Osterlind 1985; Rostad 2004
| Liao 1995 | | 20 | 0 | 20 | 0
| Shepherd^1^ 1989 | | 38 | 0 | 19 | NR^1^
| Hara 1991 | | 36 | 0 | 45 | NR
| George 1986 | | 13 | 0 | 88 | 1^2^

1 2 of 72 patients (3%) died after the first course of chemotherapy.

2 given chemotherapy plus TRTx

Only Shepherd, Ginsberg, Patterson, et al. (1989) reported post-operative complications other than mortality. Among 38 resected patients, they observed:

1 severe bronchospasm (2.6%)

1 prolonged atelectasis (2.6%)

1 pulmonary edema (2.6%)

2 transient arrhythmias (5.3%)

1 assisted ventilation for 6 weeks (2.6%)

### Conclusions

For this question, we sought randomized and nonrandomized studies that compared surgery to no surgery in patients with very early limited SCLC, defined as no preoperative evidence of involved nodes (clinically N0). Two randomized controlled trials and 8 nonrandomized comparative studies were included in the review, but none provided evidence that directly address the question.

None of these comparisons studied a homogeneous group of patients with respect to nodal status; nor were separate outcomes reported for the subgroup of patients without nodal involvement. Moreover, the treatment regimens used had limited relevance to contemporary treatment settings; for example, 5 studies did not use platinum based chemotherapy for any patients, and the remaining 3 used platinum based therapy only for some patients. Thus no conclusion can be drawn on the outcomes of management of very early limited SCLC with versus without surgery.

## Key Question 9

What are the outcomes of second- or subsequent-line therapy in patients with relapsed or progressive SCLC? Where available data permit, patients with limited- and extensive-stage disease will be addressed separately, as will those with refractory disease (relapse or progression within 3 months of primary treatment).

### Overview

Two types of studies were sought: randomized, controlled trials (RCTs) that compared alternative chemotherapy regimens for relapsed, progressive, or extensive-stage SCLC; and phase II multicenter, prospective trials reporting on at least 25 patients treated with a single regimen that reported at least one health outcome of interest. Health outcomes included: duration of survival; disease-free survival and/or progression-free survival; quality of life; treatment-related adverse effects; objective tumor response rates; and response durations.

The primary focus here is on RCTs (Summary Tables 48–51; Appendix Tables 9A–9G).^*^ The main purpose of single-arm phase II trials is to assess responsiveness to a chemotherapy regimen and select treatments for further testing in RCTs. Phase II trials in Appendix Tables 9H–9M * are presented mainly to illustrate the regimens that have been tried on relapsed or progressive SCLC. The lack of comparisons between regimens within such trials limits their usefulness to this Review. Several recent studies that reported encouraging response data will be noted.

Table 48 RCTs Comparing Alternative Chemotherapy Regimens for Relapsed, Progressive, or Extensive-Stage SCLC

| N Grp1 | N Grp2 | N Grp3 | Regimen 1 | Regimen 2 | Regimen 3 | Previous Regimens | pub type | quality rating
O'Brien, Ciuleanu, Tsekov, et al., 2005 | 70 | 71 | | po T | BSC | | | Abstr | ?
Sculier, Lafitte, Lecomte, et al., 2002 | 31 | 34 | | PE | CbPE | | No PE; EVI, VAC, RTx, Surgery | Full | Fair
von Pawel, Gatzemeier, Pujol, et al., 2001 | 52 | 54 | | po T | iv T | | | Full | Fair
von Pawel, Schiller, Shepherd, et al., 1999 | 107 | 104 | | iv T | CAV | | Platinum, CAV, PE+CAV, RTx, Immuno-therapy, Surgery | Full | Fair
Postmus, Smit, Kirkpatrick, et al., 1993 | 43 | 25 | | VIMP | CDE | | | Full | Fair
Trillet-Lenoir, Lasset, Arpin, et al., 1992 | 15 | 17 | | Low PE | High PE | | | Full | Poor
O'Bryan, Crowley, Kim, et al., 1990 | 45 | 58 | | BTOC | PE | | CAV, E, other | Full | Poor
Spiro, Souhami, Geddes, et al., 1989 | 294 | 290 | | MA | BSC | | CV | Full | Poor
Wolff, Birch, Sarma, et al., 1986 | 26 | 27 | 26 | E100 | E200 | E300 | 1–3 CTx regimens, RTx, Surgery | Full | Poor

Abbreviations table provided at the end of the Report.

Table 49 Sample and Treatments: Treatment of Recurrent/Progressive Disease

Study | Inclusion | Chemotherapy Agents | | Age (yr) | | | | Gender (%) | | | | Performance Status (%)
O'Brien, Ciuleanu, Tsekov, et al., 2005 | relapsed SCLC ineligible for further IV CTx | po T | topotecan | | [underlined: po T] | [underlined: BSC] | | | [underlined: All] | | | [underlined: PS] | [underlined: po T] | | [underlined: BSC]
| | BSC | best supportive care | mn | | | | M | 73 | | | 0/1 | 73 | | 67
| | | | md | 60 | 59 | | F | 27
| | | | rng
| | | | sd
Sculier, Lafitte, Lecomte, et al., 2002 | proven SCLC prior CTx did not include PE | PE | cisplatin | | [underlined: PE] | [underlined: CbPE] | | | [underlined: PE] | [underlined: CbPE] | | [underlined: KPS] | [underlined: PE] | | [underlined: CbPE]
| | | etoposide | mn | | | | M | 84 | 76 | | 60–70 | 45 | | 32
| | CbPE | carboplatin | md | 58 | 59 | | F | 16 | 24 | | 80–100 | 55 | | 68
| | | cisplatin | rng | 41–73 | 39–70
| | | etoposide | sd
von Pawel, Gatzemeier, Pujol, et al., 2001 | limited or extensive SCLC recurrence ≥ 3 mo after CR/PR to 1^st^-line CTx | po T | topotecan | | [underlined: po T] | [underlined: iv T] | | | [underlined: po T] | [underlined: iv T] | | [underlined: PS] | [underlined: po T] | | [underlined: iv T]
| | iv T | topotecan | mn | 59.9 | 58.2 | | M | 75.0 | 79.6 | | 0 | 19.2 | | 33.3
| | | | md | | | | F | 25.0 | 20.4 | | 1 | 65.4 | | 38.9
| | | | rng | 38–79 | 35–74 | | | | | | 2 | 15.4 | | 27.8
| | | | sd
von Pawel, Schiller, Shepherd, et al., 1999 | progressive, limited or extensive SCLC PD ≥ 60 d after 1^st^- line CTx | iv T | topotecan | | | | | | | | | [underlined: ECOG] | [underlined: iv T] | | [underlined: CAV]
| | CAV | cytoxan | | | | | | | | | 0 | 16.8 | | 19.2
| | | doxorubin | | | | | | | | | 1 | 59.8 | | 61.5
| | | vincristine | | | | | | | | | 2 | 23.4 | | 19.2
Postmus, Smit, Kirkpatrick, et al., 1993 | proven SCLC PD ≤ 3 mo of last CTx | VIMP | vincristine | | [underlined: IMP] | [underlined: VP] | [underlined: CDE] | | [underlined: MP] | [underlined: VP] | [underlined: CDE] | [underlined: ECOG] | [underlined: IMP] | [underlined: VP] | [underlined: CDE]
| 1^st^-line CTx: IMP, VP or CDE; PD after IMP/VP has 2^nd^-line CDE; PD after CDE had VIMP | | ifosfamide | mn | | | | M | 71 | 86 | 88 | 0 | 24 | 18 | 20
| | | mesna | md | 57 | 58 | 55 | F | 29 | 14 | 12 | 1 | 43 | 45 | 40
| | | carboplatin | rng | 38- | 39- | 43- | | | | | 2 | 24 | 32 | 20
| | CDE | cytoxan | | 69 | 73 | 67 | | | | | 3 | 10 | 5 | 20
| | | doxorubicin | sd
| | | etoposide
Trillet-Lenoir, Lasset, Arpin, et al., 1992 | relapsed SCLC after 1^st^-line CTx | PE1 | cisplatin 20 | | [underlined: PE1] | [underlined: PE2] | | | [underlined: PE1] | [underlined: PE2] | | [underlined: KPS] | [underlined: PE1] | | [underlined: PE2]
| | | etoposide 60 | mn | 56.73 | 52.47 | | M | 100 | 88 | | mn | 79.17 | | 74.71
| | PE2 | cisplatin 40 | md | | | | F | 0 | 12 | | sd | 13.82 | | 10.06
| | | etoposide 100 | rng
| | | | sd | 8.7 | 5.95
O'Bryan, Crowley, Kim, et al., 1990 | failed or relapsed SCLC after 1^st^-line CTx | BTOC | vincristine | | [underlined: BTOC] | [underlined: PE] | | | [underlined: BTOC] | [underlined: PE] | | [underlined: KPS] | [underlined: BTOC] | | [underlined: PE]
| | | thiotepa | mn | | | | M | 80 | 64 | | 0–1 | 53 | | 39
| | | cytoxan | md | 58 | 61 | | F | 20 | 36 | | 2–3 | 47 | | 61
| | | carmustine | rng | 41–75 | 38–76
| | PE | cisplatin | sd
| | | etoposide
Spiro, Souhami, Geddes, et al., 1989 | histologically, cytologically proven SCLC; < 75; | MA | methotrexate
| | | doxorubicin
| | BSC | best supportive care
Wolff, Birch, Sarma, et al., 1986 | recurrent SCLC, prior CTx did not include E | E100 | etoposide 100 | | [underlined: 100] | [underlined: 200] | [underlined: 300] | | [underlined: 100] | [underlined: 200] | [underlined: 300] | [underlined: KPS] | [underlined: 100] | [underlined: 200] | [underlined: 300]
| | E200 | etoposide 200 | < 50 | 19 | 11 | 15 | M | 58 | 93 | 81 | 60 | 0 | 15 | 0
| | E300 | etoposide 300 | 50–60 | 38 | 56 | 46 | F | 42 | 7 | 19 | 70 | 46 | 33 | 46
| | | | > 60 | 42 | 33 | 31 | | | | | 80 | 27 | 41 | 31
| | | | | | | | | | | | 90 | 19 | 7 | 12
| | | | | | | | | | | | 100 | 8 | 4 | 12

Abbreviations table provided at the end of the Report.

Table 50 Efficacy Outcomes: Treatment of Recurrent/Progressive Disease

Study | Overall Survival (%) | | | | | Tumor Response (%) | | | | | | | | Med Dur (wks)
| | N | Med | 1 yr | Test | | N | CR | PR | SD | PD | NE | Test
O'Brien, Ciuleanu, Tsekov, et al., 2005 | | N | Med | 1 yr | | po T | 71 | 7 | | 44
| po T | 71 | 26 wks | 49 | (6 mo) | BSC | 70
| BSC | 70 | 14 wks | 26
| HR=0.64 (95% CI: 0.45, 0.90, p=0.0104)
Sculier, Lafitte, Lecomte, et al., 2002 | PE | 31 | 18.9 wks | 18 | Log-rank, | PE | 31 | 0 | 29 | | | | | 22.6
| CbPE | 34 | 33.0 wks | 19 | p=0.11 | CbPE | 34 | 9 | 38 | | | | | 33.9
von Pawel, Gatzemeier, Pujol, et al., 2001 | po T | 52 | 32.3 wks | ~25 | adjusted | po T | 52 | 1.9 | 21.2 | 19.2 | 30.8 | 26.9 | Difference in ORR = 8.3% (95% CI -6.6%, 23.1%, NS) | 18.1
| iv T | 54 | 25.1 wks | ~8 | RR=0.90 (95% CI 0.55, 1.47) | iv T | 54 | 3.7 | 11.1 | 29.6 | 42.6 | 13.0 | | 13.9
von Pawel, Schiller, Shepherd, et al., 1999 | iv T | 107 | 25.0 wks | 14.2 | Log-rank, p=0.772, | iv T | 107 | 0.0 | 24.3 | 19.6 | 45.8 | 10.3 | Difference in ORR, P=0.285 | 14.4
| CAV | 104 | 24.7 wks | 14.4 | Adjusted RR=1.17 | CAV | 104 | 1.0 | 17.3 | 11.5 | 52.9 | 17.3 | | 15.3
| | | | | (p=0.322) | | | | | | | | | (p=0.300)
Postmus, Smit, Kirkpatrick, et al., 1993 | VIMP | 43 | 19 wks | | | VIMP | 25 | 4 | 56 | 8 | 24 | 8 | | 16
| CDE | 25 | 22 wks | | | CDE | 43 | 14 | 37 | 19 | 23 | 7 | | 19
Trillet-Lenoir, Lasset, Arpin, et al., 1992 | PE1 | 15 | 13 wks | | | PE1 | 15 | 6.6 | 20 | 13.3 | 60
| PE2 | 17 | 16.5 wks | | | PE2 | 17 | 11.8 | 23.5 | 11.8 | 52.9
O'Bryan, Crowley, Kim, et al., 1990 | BTOC | 45 | 13 wks | | RR 1.3 (95%CI 0.9, 2.0) | BTOC | 45 | 0 | 13
| PE | 58 | 16 wks | | | PE | 58 | 2 | 10 | | | | (p=0.91)
| BTOCgood | 11 | 10 wks | | RR 3.3 (95%CI 0.2, 9.1) | BTOCgood | 11 | 27
| PEgood | 16 | 35 wks | | | PEgood | 16 | 27
| BTOCpoor | 34 | 14 wks | | RR1.1 (95%CI 0.7, 1.8) | BTOCpoor | 34 | 9
| PEpoor | 68 | 12 wks | | | PEpoor | 68 | 9
Spiro, Souhami, Geddes, et al., 1989 | MA | | | | | MA | 170 | 4 | 19 | 4532 | 1
Wolff, Birch, Sarma, et al., 1986 | E100 | 26 | 12.6 wks | ~4 | Log-rank, Gehan-Wilcoxon (p=NS) | E100 | 26 | | 4
| E200 | 27 | 20.0 wks | ~12 | | E200 | 27 | | 7
| E300 | 26 | 22.5 wks | ~24 | | E300 | 26 | | 4

Table 51 Adverse Events: Treatment of Recurrent/Progressive Disease

Toxicity Type | Study | Description | Group | n | Gr 3 % | Gr 4 % | p value^18^
Treatment-related mortality | O'Bryan 1990 | Drug-related deaths | BTOC | 45 | 4 | 0.28
| | | PE | 84 | 1
Alopecia | Sculier 2002 | | PE | 28 | 21 (3/4) | 0.15
| | | CbPE | 31 | 39
| von Pawel 2001 | | po T | 52 | 1.9 | 0.0 | 0.06
| | | iv T | 54 | 13.0 | 0.0
| von Pawel 1999 | | iv T | 107 | 0.0 (3/4) | 1.0
| | | CAV | 104 | 0.0
Fatigue | von Pawel 2001 | | po T | 52 | 5.8 | 0.0 | 0.36
| | | iv T | 54 | 1.9 | 0.0
| von Pawel 1999 | | iv T | 107 | 4.7 (3/4) | 0.28
| | | CAV | 104 | 8.7
Diarrhea | von Pawel 2001 | | po T | 52 | 7.7 | 0.0 | 0.054
| | | iv T | 54 | 0.0 | 0.0
| von Pawel 1999 | | iv T | 107 | 0.9 (3/4) | 1.0
| | | CAV | 104 | 0.0
Nausea | O'Brien 2005 | | po T | 71 | 1 | 1.0
| | | BSC | 70 | 0
| von Pawel 1999 | | iv T | 107 | 39.3 (3/4) | 0.89
| | | CAV | 104 | 40.4
Vomiting | O'Brien 2005 | | po T | 71 | 3 | 0.50
| | | BSC | 70 | 0
| Sculier 2002 | Nausea/vomiting | PE | 30 | 7 (3/4) | 0.23
| | | | 32 | 0
| von Pawel 2001 | | po T | 52 | 11.5 | 0.0 | 0.16
| | | iv T | 54 | 3.7 | 0.0
| von Pawel 1999 | | iv T | 107 | 2.9 (3/4) | 1.0
| | | CAV | 104 | 1.9
| Wolf 1986 | Nausea/vomiting/bloody diarrhea/stomatitis | E100 | 26 | 5 | 0 | 0.44
| | | E200 | 27 | 4 | 0
| | | E300 | 26 | 10 | 0
Anorexia | von Pawel 1999 | | iv T | 107 | 0.9 (3/4) | 1.0
| | | CAV | 104 | 0.0
Diarrhea | O'Brien 2005 | | po T | 71 | 6 | 0.12
| | | BSC | 70 | 0
Lethargy | O'Brien 2005 | Fatigue | po T | 71 | 4 | 1.0
| | | BSC | 70 | 4
Neurosensory | O'Brien 2005 | Pain | po T | 71 | 3 | 0.44
| | | BSC | 70 | 6
Neuromotor
Hearing loss
Esophagitis
Bronchopulmonary | O'Brien 2005 | Dyspnea | po T | 71 | 3 | | 0.32
| | | BSC | 70 | 9
| von Pawel 2001 | Dyspnea | po T | 52 | 9.6 | 0 | 1.0
| | | iv T | 54 | 9.3 | 0 (5:1.9)
| | Pulmonary embolism | po T | 52 | 1.9 | 0 (5: 3.8) | 0.36
| | | iv T | 54 | 0 | 0 (5: 1.9)
Pneumonitis | von Pawel 2001 | Pneumonia | po T | 52 | 5.8 | 1.9 | 0.054
| | | iv T | 54 | 0.0 | 0.0
Hepatic
Kidney
Hemorrhage
Anemia | O'Brien 2005 | | po T | 71 | 25 (3/4)
| von Pawel 2001 | | po T | 52 | 27.5 | 3.9 | 1.0
| | | iv T | 54 | 26.4 | 3.8
| von Pawel 1999 | | iv T | 104 | 39.4 | 2.9 | 0.001
| | | CAV | 101 | 17.8 | 2.0
Thrombocytopenia | O'Brien 2005 | | po T | 71 | | 7
| Sculier 2002 | | PE | 30 | 17 (3/4) | | 0.07
| | | CbPE | 32 | 38
| von Pawel 2001 | | po T | 52 | 25.5 | 27.5 | 0.85
| | | iv T | 54 | 24.5 | 24.5
| von Pawel 1999 | | iv T | 104 | 28.8 | 28.8 | <0.001
| | | CAV | 101 | 9.9 | 5.0
| Postmus 1993 | | VIMP | 25 | 8 | 45 | <0.001
| | | CDE | 43 | 6 | 3
| Trillet-Lenoir 1992 | | PE1 | 15 | 0 | 7 | 0.041
| | | PE2 | 17 | 18 | 24
| Wolff 1986 | Neutropenia | E100 | 26 | 0 | 15 | <0.001
| | | E200 | 27 | 0 | 13
| | | E300 | 26 | 24 | 33
Leukopenia or neutropenia | O'Brien 2005 | Neutropenia | po T | 71 | | 33
| Sculier 2002 | Leukopenia | PE | 30 | 60 (3/4) | | 0.76
| | | CbPE | 32 | 56
| von Pawel 2001 | Leukopenia | po T | 52 | 27.5 | 17.6 | 0.006
| | | iv T | 54 | 45.3 | 28.3
| | Neutropenia | po T | 52 | 21.6 | 35.3 | <0.001
| | | iv T | 54 | 25.9 | 67.3
Leukopenia or neutropenia | von Pawel 1999 | Leukopenia | iv T | 104 | 54.8 | 31.7 | 0.34
| | | CAV | 101 | 37.6 | 43.6
| | Neutropenia | iv T | 104 | 18.3 | 70.2 | 0.83
| | | CAV | 99 | 15.2 | 71.7
| Postmus 1993 | Leukopenia | VIMP | 25 | 26 | 40 | 1.0
| | | CDE | 43 | 38 | 25
| Trillet-Lenoir 1992 | Leukopenia | PE1 | 15 | 33 | 13 | 0.021
| | | PE2 | 17 | 12 | 76
| Wolff 1986 | | E100 | 26 | 5 | 0 | <0.001
| | | E200 | 27 | 25 | 54
| | | E300 | 26 | 0 | 86
Infection | O'Brien 2005 | Febrile neutropenia | po T | 71 | | 3
| | Neutropenic infections | po T | 71 | | 1
| | Sepsis | po T | 71 | | 4
| Sculier 2002 | | PE | 30 | 3 (3/4) | | 0.96
| | | CbPE | 33 | 3
| von Pawel 2001 | Fever | po T | 52 | 3.8 | 1.9 (5:1.9) | 0.20
| | | iv T | 54 | 1.9 | 0.0
Other

18 Comparison of grade 3 and above versus others Fisher's exact test.

19 Comparison of grade 3 and above versus others Fisher's exact test.

### Randomized, Controlled Trials

Among 9 RCTs meeting selection criteria, sample sizes ranged from 32 to 610 and they collectively included 1,415 patients. As shown in Table 48, each of the 9 trials compared different sets of chemotherapy regimens. Seven trials compared 2 regimens and the Wolff, Birch, Sarma, et al. (1986) trial compared 3. Six studies specifically noted that second-line regimens were compared (von Pawel, Gatzemeier, Pujol, et al., 2001,; von Pawel, Schiller, Shepherd, et al., 1999; Postmus, Smit, Kirkpatrick, et al., 1993; Trillet-Lenoir, Lasset, Arpin, et al., 1992; O'Bryan, Crowley, Kim, et al., 1990; Spiro, Souhami, Geddes, et al. 1989). The study by Sculier, Lafitte, Lecomte, et al. (2002) stated that patients had previously undergone chemotherapy that did not include cisplatin and etoposide, but did not specify the distribution of number of previous regimens. It was also unspecified by O'Brien, Ciuleanu, Tsekov, et al. (2005). Wolff, Birch, Sarma, et al. (1986) described this distribution: 80 percent had previously had 1 chemotherapy regimen, 14 percent had 2; and 6 percent had 3.

Data on age, gender and performance status were reported by all studies except von Pawel, Schiller, Shepherd, et al. (1999), which only give performance status. O'Brien, Ciuleanu, Tsekov, et al. (2005) did not provide separate gender distributions for the two groups. The study by Spiro, Souhami, Geddes, et al. (1989) was a 2-stage randomized trial. In the first stage, patients were randomized to either 4 or 8 cycles of primary chemotherapy consisting of cyclophosphamide, vincristine and etoposide. The second stage randomized patients at relapse to either methotrexate plus doxorubicin or supportive care. Two pairs of first stage groups were compared at the second stage and shown to be similar on age, gender, performance status and stage. Where information was available, groups appeared comparable on these characteristics.

Study Quality. Of the nine RCTs meeting selection criteria, four were rated as being of fair quality (Sculier, Lafitte, Lecomte, et al., 2002; von Pawel, Gatzemeier, Pujol, et al., 2001; von Pawel, Schiller, Shepherd, et al., 1999; Postmus, Smit, Kirkpatrick, et al., 1993, 4 were rated as poor (Trillet-Lenoir, Lasset, Arpin, et al., 1992; O'Bryan, Crowley, Kim, et al., 1990; Spiro, Souhami, Geddes et al. 1989; Wolff, Birch, Sarma, et al. 1986), and one could not be rated because it has only been reported as a conference abstract (O'Brien, Ciuleanu, Tsekov, et al., 2005). The fair trials had moderate flaws mainly in the initial assembly of comparable groups: either the randomization method was inadequately described or insufficient information was available about group baseline characteristics. The 4 poor trials had multiple problems, but 3 failed to define interventions clearly enough. Specifically, the number of intended cycles of chemotherapy was unspecified in these articles.

### Overview of Outcomes

Overall Survival. Eight of nine trials reported data on overall survival, but only the study by O'Brien, Ciuleanu, Tsekov, et al. (2005) found a statistically significant difference between groups, in this case favoring oral topotecan over best supportive care.

Time to Progression. Neither of the two studies reporting on time to progression (von Pawel, Gatzemeier, Pujol, et al., 2001; von Pawel, Schiller, Shepherd, et al., 1999) found statistically significant differences between groups.

Quality of Life. The two studies by von Pawel et al. both reported data from a symptom scale that includes 9 domains. Only the earlier study, comparing intravenous topotecan and CAV, mentioned statistically significant differences between treatment groups.

Adverse Events. Specific risks of adverse events varied as expected given that these studies used a variety of treatments. Higher risks of grade 3 and 4 toxicity may be acceptable if a treatment yields a substantial survival advantage. O'Brien, Ciuleanu, Tsekov, et al. (2005) found significantly greater survival for oral topotecan over best supportive care, while toxicities were low. The 2001 trial by von Pawel, Gatzemeier, Pujol, et al. found no difference in survival between oral and intravenous topotecan, but the intravenous route was associated with higher rates of leukopenia and neutropenia. The 1999 study by von Pawel, Schiller, Shepherd, et al. reported no survival difference between intravenous topotecan and CAV, but the topotecan group had higher risks of anemia and thrombocytopenia. Trillet-Lenoir, Lasset, Arpin, et al. (1992) observed similar survival for low and high dose PE, but the high dose group experienced more leukopenia. The small study conducted by Wolf did not find significant differences in survival for 3 doses of etoposide, but there was a trend toward better survival with higher dose, as well as more thrombocytopenia and neutropenia.

Tumor Response. Excluding the O'Brien, Ciuleanu, Tsekov, et al. (2005) and Spiro, Souhami, Geddes, et al. (1989) studies that did not actively treat the control group, none of the other 7 studies found significant differences in tumor response or duration between treatment groups.

O'Brien, Ciuleanu, Tsekov, et al. (2005). Oral Topotecan (po T) vs. Best Supportive Care (BSC).

Study Quality. Since there is insufficient information about this study's methods, study quality could not be rated.

Overall Survival. This study, available only as a conference abstract, randomized 71 patients to oral topotecan and 70 patients to best supportive care. There was a 36 percent reduction in the risk of death for those receiving topotecan (hazard ratio=0.64, 95 percent CI: 0.45–0.90, p=0.0104). Median survival was longer for the topotecan patients (26 weeks vs. 14 wks) and 6-month survival was increased (49 percent vs. 26 percent).

Time to Progression. No data.

Quality of Life. This study administered the EQ-5D health-related quality of life questionnaire and found a significantly faster rate of deterioration in the BSC group.

Adverse Events. No significant differences were found in the incidence of these adverse events: vomiting, diarrhea, fatigue, pain and dyspnea. No hematologic toxicity was noted in the abstract for the BSC group, but in the topotecan group 7 percent had grade 3 or 4 anemia, 7 percent had grade 4 thrombocytopenia and 33 percent had grade 4 neutropenia. In the topotecan group, the risk of febrile neutropenia was 3 percent, while 1 percent had neutropenic infections and 4 percent developed sepsis.

Tumor Response. The abstract noted that the response rate for topotecan was 7 percent, but it was unclear what proportions had complete or partial responses. A further 44 percent experienced a stable disease after topotecan.

Summary . Compared with best supportive care, oral topotecan significantly improves survival in patients with relapsed SCLC. The decline in quality of life is faster in patients receiving best supportive care. Neutropenia is the most common major adverse event. Careful assessment of the methodologic quality of this study awaits full publication beyond a conference abstract.

Sculier, Lafitte, Lecomte, et al. (2002). Cisplatin/Etoposide (PE) vs. Carboplatin/Cisplatin/Etoposide (CbPE).

Study Quality. This study was rated as fair, its main shortcoming concerned its lack of detail about the randomization method and lack of blinded interpretation of tumor response, which was the primary outcome.

Overall Survival. This trial reported on 31 patients who received cisplatin and etoposide and 34 patients who received that regimen plus carboplatin. These investigators found a median survival advantage of 14.1 weeks for the CbPE group relative to the PE group, although the difference was not statistically significant (p=0.11).

Time to Progression. No data.

Quality of Life. No data.

Adverse Events. Although nearly twice as CbPE patients as PE patients had grade 3 or 4 alopecia (39 percent vs. 20 percent), the difference was not statistically significant. The authors reported that 19 percent of patients receiving PE experienced grade 3 or 4 thrombocytopenia, compared with 12 percent receiving CbPE, a nonsignificant difference. Grade 3 or 4 leukopenia occurred in 60 percent given PE and 56 percent given CbPE (p=0.97). The same percentage of patients (3 percent) in both groups developed infections.

Tumor Response. Thie trial found an ORR of 47 percent for CbPE and an ORR of 29 percent for PE. Median response duration was 33.9 weeks for CbPE and 22.6 weeks for PE. No statistical test results for these outcomes were provided.

Summary. The data from this trial suggested slightly improved survival and tumor response in adding carboplatin to the combination of cisplatin and etoposide. This small underpowered study did not find significant differences between groups on any outcome. It is important to remember that this trial enrolled only patients who did not have previous therapy with platinum and etoposide.

von Pawel, Gatzemeier, Pujol, et al. (2001). Oral Topotecan (po T) vs. Intravenous Topotecan (iv T).

Study Quality. This trial was rated as fair; the principal problem was lack of detail about the randomization method.

Overall Survival. These authors randomized 52 patients to oral topotecan and 54 patients to intravenous topotecan. They reported that median survival using oral topotecan was 32.3 weeks, compared with 25.1 weeks for intravenous topotecan. The difference was not statistically significant.

Time to Progression. These authors found that median time to disease progression was similar in the oral (14.9 weeks) and intravenous (13.1 weeks) topotecan groups. The difference was not statistically significant.

Quality of Life. This article stated that both oral and intravenous topotecan were associated with symptom improvement, but specific results of statistical tests were not given.

Adverse Events. Significant differences were not observed between groups on the following grade 3 and grade 4 outcomes: alopecia, vomiting, dyspnea, pulmonary embolism, pneumonia, anemia, thrombocytopenia and fever. Grade 3 diarrhea was significantly more common in the group receiving oral topotecan (7.7 percent vs. 0 percent). Grade 3 leukopenia was significantly more frequent in the intravenous group (45.3 percent vs. 27.5 percent). Grade 4 neutropenia occurred significantly more often among intravenous topotecan patients (67.3 percent vs. 35.3 percent).

Tumor Response. The ORR for oral topotecan was 23.1 percent and the proportion for intravenous topotecan was 14.8 percent. The difference was not statistically significant.

Summary. This study observed no significant difference in survival between those give oral or intravenous topotecan. The difference in overall response was not significant, but favored the oral route. Some hematologic toxicities were more common for intravenous, but most other adverse events occurred at similar rates.

von Pawel, Schiller, Shepherd, et al. (1999). Intravenous Topotecan (iv T) vs. Cyclophosphamide/Doxorubin/Vincristine (CAV).

Study Quality. This study was rated as fair. While the randomization method was sufficiently described and seemed adequate, age and gender distributions were not specified, co it could not be established if groups were comparable on these characteristics at baseline.

Overall Survival. The total assigned to intravenous topotecan was 107, while 104 received CAV. Median survival was nearly identical for intravenous topotecan (25 weeks) and CAV (24.7 weeks). The analysis that adjusted for covariates was not statistically significant.

Time to Progression. Median progression-free survival differed by only 1 week between the iv T and CAV groups in this trial.

Quality of Life. The percentage of patients improved on symptoms was greater for intravenous topotecan than CAV for all domains except hemoptysis, which showed a nonsignificant difference of 6.6 percent. Five domains significantly favored intravenous topotecan: dyspnea, anorexia, hoarseness, fatigue and impaired activities of daily living.

Adverse Events. Significant differences were not found between groups for these grade 3 or 4 outcomes: fatigue, nausea, vomiting and anorexia. The group receiving intravenous topotecan had a risk of grade 3 or 4 anemia that was twice that of the CAV group: 42.3 percent versus 19.8 percent (p<0.001). The rates of both grade 3 and grade 4 thrombocytopenia were significantly higher for the intravenous topotecan group, compared with the CAV group (grade 3: 28.8 percent vs. 9.9 percent; grade 4: 28.89 percent vs. 5 percent). Risks of grade 3 or 4 leukopenia were similar for intravenous topotecan (76.5 percent) and CAV (81.2 percent), as were grade 3 or 4 neutropenia (78.5 percent) and CAV (76.9 percent).

Tumor Response. Intravenous topotecan had an ORR of 24.3 percent, while CAV had an ORR of 18.3 percent, a difference that was not statistically significant.

Summary. Intravenous topotecan and CAV produced similar overall and progression-free survival. Five symptom domains showed significantly greater improvement in the intravenous topotecan group. Anemia and thrombocytopenia was more common among those receiving intravenous topotecan.

Postmus, Smit, Kirkpatrick, et al. (1993). Vincristine/Ifosfamide/Mesna/Carboplatin (VIMP) vs. Cyclophosphamide/Doxorubicin/Etoposide (CDE).

Study Quality. This study was rated as fair, due to missing information about the method of randomization.

Overall Survival. This study did not include the results of a statistical test on survival duration, but median survival differed between groups by only 3 weeks and given the small sample (n=68; 43 had VIMP and 25 had CDE), this is probably not statistically significant.

Time to Progression. No data.

Quality of Life. No data.

Adverse Events. In this study, there was a significantly higher incidence of grade 3 or 4 thrombocytopenia in the VIMP group (53 percent) compared with the CDE group (9 percent). Incidence of grade 3 or 4 leukopenia was similar for VIMP (66 percent) and CDE (63 percent).

Tumor Response. This study did not mention statistical test results. The ORR for the VIMP group was 60 percent and the figure for the CDE group was 51 percent.

Summary. The VIMP and CDE groups did not differ significantly on survival or tumor response. The only outcome that differed was the incidence of grade 3 or 4 thrombocytopenia, which was significantly more frequent in the VIMP group.

Trillet-Lenoir, Lasset, Arpin, et al. (1992). Cisplatin 20/Etoposide 60 (PE1) vs. Cisplatin 40/Etoposide 100 (PE2).

Study Quality. This study was rated as poor because the randomization method was not sufficiently described, no primary outcome was identified, interventions were incompletely described and it was unclear if outcome measurement was valid, reliable and equal.

Overall Survival. This study found that the high-dose PE2 group (n=15) had a longer median survival than the low-dose group (n=17) by 3.5 weeks. There was no mention of statistical test results on survival, but this trial was very small and the difference is unlikely to be statistically significant.

Time to Progression. No data.

Quality of Life. No data.

Adverse Events. This study showed that high-dose PE was associated with a significantly higher risk of grade 3 or 4 thrombocytopenia than low-dose PE (42 percent vs. 7 percent). Grade 4 leukopenia was much more frequent (76 percent vs. 13 percent) in the high-dose PE group.

Tumor Response. The high-dose PE group had an ORR of 26.6 percent while the low-dose group achieved an ORR of 35.3 percent. No statistical test findings were noted by the authors, but the small sample size of 32 patients would require a large difference to achieve statistical significance.

Summary. Survival and tumor response were roughly similar in the low-dose and high-dose PE groups, while there were higher rates of thrombocytopenia and leukopenia in the high-dose group.

O'Bryan, Crowley, Kim, et al. (1990). Vincristine/Thiotepa/Cyclophosphamide/Carmustine (BTOC) vs. Cisplatin/Etoposide (PE).

Study Quality. This study's quality was rated as poor owing to lack of information about the randomization technique, lack of blinding for the primary outcome (tumor response), and lack of details about treatment.

Overall Survival. There were 45 patients in the BTOC group and 58 in the PE group. The authors presented 3 sets of results: all patients; good prognosis patients; and poor prognosis patients. None of the analyses demonstrated a statistically significant difference between BTOC and PE. Median survival nonsignificantly favored PE among all patients and good prognosis patients. The difference was large for good prognosis patients (25 weeks), but only 27 patients were in this subset. The relation between treatments was reversed for bad prognosis patients: median survival was better by 2 weeks for BTOC over PE.

Time to Progression. No data.

Quality of Life. No data.

Adverse Events. The trial reported that 4 percent of patients in the BTOC group experienced drug-related death, compared with 1 percent for PE, a difference that was not statistically significant.

Tumor Response. The trial found no statistically significant difference between the ORR for BTOC (13 percent) and PE (12 percent). Identical ORRs were obtained for treatment groups with both good and poor prognoses.

Summary. This trial found no significant differences between BTOC and PE in survival, tumor response or drug-related death.

Spiro, Souhami, Geddes, et al. (1989). Methotrexate/Doxorubicin vs. Supportive Care

Study Quality. Quality was rated as poor due to lack of details about the randomization technique and a high loss of patients in the second stage of the study (42 percent).

Overall Survival. This outcome was not reported on the basis of the second randomization (to second-line chemotherapy or supportive care), rather it was based on the first randomization to either 4 or 8 cycles of primary chemotherapy. Therefore, it is unclear how patients given chemotherapy or supportive care upon relapse compare in terms of survival.

Time to Progression. As above, this outcome was not presented based on treatment approach given at relapse.

Quality of Life. This outcome was not reported.

Adverse Events. Toxicity data were not provided for second-line chemotherapy.

Tumor Response. Of the 294 patients randomized to receive chemotherapy at relapse, 170 received it and were assessed for response. Complete response was achieved in 4 percent and partial response was observed in 19 percent.

Summary. Results were presented from this study mainly based on randomization for first-line chemotherapy. An overall response rate of 23 percent to second-line chemotherapy was observed, but other data are lacking on outcomes after randomization at relapse, comparing chemotherapy and supportive care.

Wolff, Birch, Sarma, et al. (1986). Etoposide 100 (E100) vs. Etoposide 200 (E200) vs. Etoposide 300 (E300).

Study Quality. The Wolff, Birch, Sarma, et al. (1986) trial received a poor quality rating due to uncertainty on the comparability of groups at baseline, lack of blinded assessment of tumor response, the primary outcome, lack of detail about treatments and inappropriate analysis of results.

Overall Survival. There were 26, 27 and 26 patients in the groups receiving 100 mg, 200 mg and 300 mg of etoposide, respectively. No statistically significant differences were found between etoposide dose groups. The 200 mg and 300 mg groups were similar in median survival (20 weeks and 22.5 weeks, respectively), while the median for 100 mg group was 12.6 weeks.

Time to Progression. No data.

Quality of Life. No data.

Adverse Events. There was a significant dose gradient for higher grade thrombocytopenia in 3 groups given single agent etoposide therapy: 5 percent for 100 mg; 79 percent for 200 mg; and 86 percent for 300 mg. The trial found that grade 3 or 4 neutropenia was much more likely in the etoposide 300 mg group (57 percent), compared with those receiving 100 mg (15 percent) or 200 mg (13 percent).

Tumor Response. Only PRs were achieved in each of the 3 etoposide groups: 4 percent for 100 mg; 7 percent for 200 mg; and 4 percent for 300 mg.

Summary. Significant differences in survival and tumor response were not observed between 3 different doses of single-agent etoposide. Thrombocytopenia and leukopenia were more common for higher dose etoposide

### Phase II Trial Evidence

Among multicenter phase II trials published since 2000 (Summary Table 52; see Appendix Tables 9H–9M), ^20^ 5 deserve brief mention due to encouraging response data. While overall response rates of 20 percent or higher were reported by these trials, high rates of hematologic toxicity were observed. Each used a different treatment regimen. The largest study was Ardizzoni, Manegold, Debruyne, et al. (2003, n=116); all others enrolled fewer than 50 patients.

20 Appendixes cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/lungcansmall/lungcan.pdf.

Table 52 Multicenter Phase II Trials of Note for Key Question 9

Study | Patient Selection | N | Regimen | Previous Treatment (%)
Ando, Kobayashi, Yoshimura, et al., 2004 | refractory (off CTx < 2 mo) or relapsed (off CTx > 2 mo) after initial etoposide regimen | 25 | irinotecan+cisplatin | PE | | 16
| | | | CbP | | 84
| | | | TRTx | | 20
| | | | Surgery | | 4
Ardizzoni, Manegold, Debruyne, et al., 2003 | relapsed after 1^st^ -line CTX (except camptothecin analogues; cisplatin allowable if responsive, CTx ≥ 6 mo before | 116 | topotecan+cisplatin | | Sen | Ref
| | | | TRTx med # | 69 | 31
| | | | CTX | 3 | 3
| | | | Cisplatin | 22 | 5
| | | | Carbopl | 24 | 36
| | | | Etopos | 90 | 83
Kosmas, Tsavaris, Malamos, et al. et al., 2001 | relapsed after CbE CTx ± TRTx; not curable by other 2^nd^ -line CTx or RTx | 33 | paclitaxel+ifosfamide+cis platin | CTx | | 100
| | | | TRTx | | 42
Kakolyris, Mavroudis, Tsavaris, et al., 2001 | refractory; had failed 1 prior 1^st^ -line CTx | 32 | paclitaxel+carboplatin | EP | | 84
| | | | CAB | | 16
| | | | RTx | | 47
| | | | Surgery | | 6
Sonpavde, Ansari, Walker, et al., 2000 | recurrent; 1 prior combination CTx regimen | 46 | doxorubicin+paclitaxel | Platinum-E
| | | | ± VIP | | 100
| | | | RTx | | 59

Ando, Kobayashi, Yoshimura, et al. (2004) reported data for 25 patients who were given irinotecan plus cisplatin for refractory or relapsed SCLC after first-line etoposide therapy. Partial responses were observed in 81 percent of 16 relapsed patients and 78 percent of 9 refractory patients. Grade 3 thrombocytopenia was seen in 12 percent and 24 percent had grade 3 or 4 neutropenia.

Ardizzoni, Manegold, Debruyne, et al. (2003) collected outcomes for 110 patients who received topotecan plus cisplatin for either sensitive (n=68) or refractory (n=42) SCLC. Among sensitive patients, a CR was seen in 1.5 percent and PR in 27.9 percent. The incidence of grade 3 or 4 leukopenia was 80.9 percent and neutropenia occurred in 76.5 percent. At least 1 episode of febrile neutropenia happened in 19 percent. There was a PR rate of 23.8 percent in refractory patients. Grade 3 or 4 leukopenia was observed in 75.6 percent and the risk of neutropenia was the same. At least 1 instance of febrile neutropenia occurred in 15 percent.

Kosmas, Tsavaris, Malamos, et al. (2001) enrolled 33 patients who relapsed after initial treatment with carboplatin plus etoposide. Second-line therapy was paclitaxel, ifosfamide and cisplatin. The CR rate was 24.2 percent and the PR rate was 48.5 percent. Grade 3 anemia was seen in 18 percent. Grade 3 thrombocytopenia affected 36 percent. Grade 3 or 4 leukopenia occurred in 73 percent, the rate of neutropenia was 91 percent. Grade 3 febrile neutropenia was found in 18 percent.

Kakolyris, Mavroudis, Tsavaris, et al. (2001) gave data for 29 patients who were refractory after first-line chemotherapy and then were offered paclitaxel plus carboplatin. CR was achieved in 3 percent and PR in 22 percent. Grade 3 or 4 neutropenia was observed in 48 percent.

Sonpavde, Ansari, Walker, et al. (2000) recruited 46 patients who recurred after first-line therapy and were given doxorubicin plus carboplatin. CRs were measured in 7 percent and PRs in 35 percent. Grade 3 or 4 granulocytopenia occurred in 80 percent.

### Conclusions

Nine randomized trials have made 9 different comparisons for second- or subsequent-line treatment of SCLC. Two randomized trials have directly compared chemotherapy with best supportive care for recurrent SCLC. The first studied second-line methotrexate plus doxorubicin and found an overall response rate of 23 percent for the chemotherapy arm. The second reported that oral topotecan resulted in a modest but significant improvement in survival, slower decline in quality of life and high grade neutropenia in one third. In another trial, oral topotecan had nonsignificantly higher median survival and overall response rate than intravenous topotecan, which had higher risks of leukopenia and neutropenia. A study that addressed the addition of carboplatin to cisplatin and etoposide is of limited use given that it in enrolled only those who did not receive first-line cisplatin and etoposide, which is the current standard regimen. One small study comparing 3 doses of monotherapy etoposide did not find significant survival differences, but a trend favored the highest dose, along with increased thrombocytopenia and neutropenia. Other studies found higher rates of adverse events for one treatment over another, but no associated survival advantage that would offset increased high grade toxicity. One example is a comparison of oral and intravenous topotecan which reported that the intravenous route was associated with higher rates of leukopenia and neutropenia. A study comparing intravenous topotecan and CAV showed that the topotecan group had higher risks of anemia and thrombocytopenia. High dose PE had more leukopenia than low dose PE.

Five multicenter phase II trials of note published since 2000 have reported overall response rates of 20 percent or more. Only one study, using topotecan plus cisplatin, enrolled more than 50 patients. Approximately one-fourth of both sensitive and refractory patients responded. Three-quarters or more of both patient groups had high grade leukopenia and neutropenia. A small study of irinotecan plus cisplatin found very high rates of partial response and low hematologic toxicity. The combination of paclitaxel, ifosfamide and cisplatin achieved a high ORR and high grade leukopenia in nearly all patients. One quarter of those given paclitaxel plus carboplatin had a response and about half had high grade neutropenia. In a study of doxorubicin plus carboplatin, nearly half responded, but 4 out of 5 had grade 3 or 4 granulocytopenia. Whether these regimens should be used in practice awaits randomized trials.