# Appendix E.Technical Expert Panel (TEP) and Reviewers

Technical Expert Panel (TEP)

- Kemp H. Kernstine, M.D., Ph.D.
- Lung Cancer Program
- City of Hope National Medical Center and Beckman Research Institute
- Duarte, CA

- William F. Lawrence, M.D., M.S.
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, MD

- Sandra Zelman Lewis, Ph.D.
- Research Specialist
- American College of Chest Physicians
- Northbrook, IL

- Douglas C. McCrory, M.D., M.H.S.
- Center for Clinical Health Policy Research
- Duke University Medical Center
- Durham, NC

- David Eric Morris, M.D.
- Department of Radiation Oncology
- University of North Carolina Hospitals
- Chapel Hill, NC

- Alan Sandler, M.D.
- Division of Hematology/Oncology
- Vanderbilt University
- Nashville, TN

- George R. Simon, M.D., F.C.C.P.
- Thoracic Oncology Program
- H. Lee Moffitt Cancer Center
- Tampa, FL

- Stephen J. Swensen, M.D., M.M.M.
- Department of Radiology
- Mayo Clinic
- Rochester, MN

- Andrew T. Turrisi, III, M.D.
- Gershenson Radiation Oncology Center
- Wayne State University
- Detroit, MI

Peer Reviewers

- Richard K.J. Brown, M.D.
- Clinical Associate Professor
- University of Michigan
- Department of Radiology
- Division of Nuclear Medicine
- Ann Arbor, MI
- (Nominated by the American College of Radiology)

- Paul Bunn, M.D.
- University of Colorado Cancer Center
- Aurora, CO

- Norman Edelman, M.D.
- Chief Medical Officer
- American Lung Association
- (Nominated by the American Lung Association)

- Fergus Macbeth, D.M.
- Director National Collaborating Centre for Cancer
- Cardiff
- UK

- John McArdle, M.D.
- Yale University School of Medicine
- Section of Pulmonary and Critical Care Medicine
- New Haven, CT
- (Nominated by the American Thoracic Society)

- Mary A. Simmonds, M.D., FA.C.P.
- Clinical Professor of Medicine
- Penn State University College of Medicine
- University Park, PA
- (Nominated by the American Cancer Society)