# Appendix D. Listing of Excluded Studies

Exclusion Codes

UNR study unrelated to treatment/staging of SCLC (citation review)

FNA foreign language, no abstract

INV investigational therapy

NPD no primary data

NRA narrative review article

NRD non-relevant disease

NSP not correct study population

NRQ non-relevant study question

NSD not correct study design

SCS single center phase II single arm study

FEW too few subjects

<50 for single-arm studies, XRT, PCI (Qs 1–4)

<25 for diagnostic accuracy studies (Q5); single-arm studies, mixed SCLC/NSCLC, surgery, 2nd+-line therapy (Qs 6–8)

(no lower limit for RCTs)

## References

Controlled trial of twelve versus six courses of chemotherapy in the treatment of small-cell lung cancer. Report to the Medical Research Council by its Lung Cancer Working Party. Br J Cancer. 1989 Apr;59(4):584–90. Notes: NRQ
Randomised trial of four-drug vs less intensive two-drug chemotherapy in the palliative treatment of patients with small-cell lung cancer (SCLC) and poor prognosis. Medical Research Council Lung Cancer Working Party. Br J Cancer 1996; 73(3):406–13. Notes: NRQ
Survival, adverse reactions and quality of life during combination chemotherapy compared with selective palliative treatment for small-cell lung cancer. Report to the Medical Research Council by its Lung Cancer Working Party. Respir Med 1989; 83(1):51–8. Notes: NRQ
Abner A. Prophylactic cranial irradiation in the treatment of small-cell carcinoma of the lung. Chest. 1993;103(4 Suppl):445S-8S. Notes: NRA. [pmid: 8384977].
Abratt RP. Commentary on “Novel doublets in extensive-stage small cell lung cancer: A randomised phase II study of topotecan plus cisplatin or paclitaxel (CALGB 9430).” Clin Lung Cancer 3:211–212 Notes: NPD NRQ
Agelaki S, Veslemes M, Syrigos K, et al. A multicenter phase II study of the combination of gemcitabine and docetaxel in previously treated patients with small cell lung cancer. Lung Cancer. 2004;43(3):329-33. Notes: FEW. [pmid: 15165092].
Agra Y, Pelayo M, Sacristan M, Chemotherapy versus best supportive care for extensive small cell lung cancer. Cochrane Database Syst Rev 2003; (4):CD001990. Notes: NRQ
Aisner SC, Finkelstein DM, Ettinger DS, et al. The clinical significance of variant-morphology small-cell carcinoma of the lung. J Clin Oncol. 1990;8(3):402-8. Notes: NRQ; may inform Q7. [pmid: 2155311].
Akbiyik N, Alexander LL. Cure rates in small cell and non-small cell carcinoma of the lung utilizing high-dose radiotherapy and chemotherapy. J Natl Med Assoc. 1986;78(3):219-23. Notes: NSD. [pmid: 3012100]. [pmcid: 2571268].
Albain KS, Crowley JJ, LeBlanc M, Livingston RB. Determinants of improved outcome in small-cell lung cancer: an analysis of the 2,580-patient Southwest Oncology Group data base. J Clin Oncol. 1990;8(9):1563-74. Notes: NRQ. [pmid: 2167954].
Ali MA, Kraut MJ, Valdivieso M, et al. Phase II study of hyperfractionated radiotherapy and concurrent weekly alternating chemotherapy in limited-stage small cell lung cancer. Lung Cancer. 1998;22(1):39-44. Notes: FEW, NSD. [pmid: 9869106].
Ardizzoni A, Antonelli G, Ricci S, et al. Ambamustine in the second-line treatment of patients with small-cell lung cancer: a phase II Fonicap study. Am J Clin Oncol. 2000;23(1):22-5. Notes: INV. [pmid: 10683068].
Ardizzonin A, Tjan-Heijnen VC, Postmus PE, et al. Standard versus intensified chemotherapy with granulocyte colony-stimulating factor support in small-cell lung cancer: a prospective European Organization for Research and Treatment of Cancer-Lung Cancer Group Phase III Trial-08923. J Clin Oncol. 2002;20(19):3947-55. Notes: NRQ. [pmid: 12351591].
Ariyoshi Y, Fukuoka M, Furuse K, et al. Concurrent cisplatin-etoposide chemotherapy plus thoracic radiotherapy for limited-stage small cell lung cancer. Japanese Lung Cancer Chemotherapy Group in Japanese Clinical Oncology Group. Jpn J Clin Oncol. 1994;24(5):275-81. Notes: NSD. [pmid: 7967106].
Armstrong JG. Long-term outcome of small cell lung cancer. Cancer Treat Rev. 1990;17(1):1-13. Notes: NRA. [pmid: 2171763].
Armstrong JG, Rosenstein MM, Kris MG, et al. Twice daily thoracic irradiation for limited small cell lung cancer. Int J Radiat Oncol Biol Phys. 1991;21(5):1269-74. Notes: NSD. [pmid: 1657842].
Armstrong JG, Rosenstein MM, Scher HI, et al. Limited small cell lung cancer: prognostic significance of a complete response to the induction phase of chemotherapy followed by thoracic irradiation. Radiology. 1991;178(3):875-8. Notes: NRQ. [pmid: 1847240].
Arriagada R. Re: Prophylactic cranial irradiation for patients with small-cell lung cancer. J Natl Cancer Inst. 1995;87(10):766. author reply 767. Notes: NPD. [pmid: 7563156].
Arriagada R, Le Chevalier T. Local control and lethal toxicity in limited small cell lung cancer. Int J Radiat Oncol Biol Phys. 1990;19(5):1333. Notes: NPD. [pmid: 2174843].
Arriagadan R, Le Chevalier T, Baldeyrou P, et al. Alternating radiotherapy and chemotherapy schedules in small cell lung cancer, limited disease. Int J Radiat Oncol Biol Phys. 1985;11(8):1461-7. Notes: NSD. [pmid: 2991175].
Arriagadan R, Le Chevalier T, Pignon JP, et al. Initial chemotherapeutic doses and survival in patients with limited small-cell lung cancer. N Engl J Med. 1993;329(25):1848-52. Notes: NRQ. [pmid: 8247036].
Arriagadan R, le Chevalier T, Ruffie P, et al. Alternating radiotherapy and chemotherapy in 173 consecutive patients with limited small cell lung carcinoma. GROP and the French Cancer Center's Lung Group. Int J Radiat Oncol Biol Phys. 1990;19(5):1135-8. Notes: NSD. [pmid: 2174838].
Arriagadan R, Le Chevalier T, Ruffie P, et al. Alternating radiotherapy and chemotherapy in limited small cell lung cancer: the IGR protocols. French FNCLCC Lung Cancer Study Group. Lung Cancer. 1994;10(Suppl 1):S289-98. Notes: NRQ. [pmid: 8087522].
Arriagada R, Pignon JP, Ihde DC, et al. Effect of thoracic radiotherapy on mortality in limited small cell lung cancer. A meta-analysis of 13 randomized trials among 2,140 patients. Anticancer Res. 1994;14(1B):333-5. Notes: NPD. [pmid: 8166478].
Arriagada R, Pignon JP, Le Chevalier T. Initial chemotherapeutic doses and long-term survival in limited small-cell lung cancer. N Engl J Med. 2001;345(17):1281-2. Notes: NRQ. [pmid: 11680466].
Artel-Cortesn A, Gomez-Codina J, Gonzalez-Larriba JL, et al. Prospective randomized phase III trial of etoposide/cisplatin versus high-dose epirubicin/cisplatin in small-cell lung cancer. Clin Lung Cancer. Nov. 2004;6(3):175-83. Notes: NRQ. [pmid: 15555219].
Asamoto H, Kawahara M, Iwami F, et al. Cisplatin plus oral etoposide in the treatment of patients with advanced small cell lung cancer. Japan Clinical Oncology Group. Jpn J Clin Oncol. 1998;28(12):745-8. Notes: NSD. [pmid: 9879292].
Auchter RM. Early versus late irradiation in small-cell lung cancer (3) (multiple letters). J Clin Oncol. 1998;16(3):1235-7. Notes: NPD; but maybe cite in write-up for Q1. [pmid: 9508215].
Auperin A, Arriagada R, Pignon JP, et al. Prophylactic cranial irradiation for patients with small-cell lung cancer in complete remission. Prophylactic Cranial Irradiation Overview Collaborative Group. N Engl J Med. 1999;341(7):476-84. Notes: NPD. [pmid: 10441603].
Baker RR, Ettinger DS, Ruckdeschel JD, et al. The role of surgery in the management of selected patients with small-cell carcinoma of the lung. J Clin Oncol. 1987;5(5):697-702. Notes: FEW. [pmid: 3033160].
Ball DL, Bishop JF. Failure of a short course of prophylactic cranial irradiation to reduce the incidence of cerebral relapse in small cell lung cancer. Australas Radiol. 1987;31(4):361-4. Notes: NSD. [pmid: 2839139].
Bamberga M, Michetti G, Bamberga P, et al. Cyclophosphamide, epirubicin, etoposide, cis platinum (CEVP) in combination with radiotherapy: evaluation of a protocol adopted for 6 years in 148 cases of small cell lung cancer. Tumori. 1992;78(5):333-7. Notes: SCS NSD (retrospective). [pmid: 1337390].
Beith JM, Clarke SJ, Woods RL, et al. Long-term follow-up of a randomised trial of combined chemoradiotherapy induction treatment, with and without maintenance chemotherapy in patients with small cell carcinoma of the lung. Eur J Cancer. 1996;32A(3):438-43. Notes: NRQ. [pmid: 8814688].
Belani CP, Bonomi P, Dobbs TW, et al. Docetaxel and cisplatin in patients with advanced non small-cell lung cancer (NSCLC): a multicenter phase II trial. Clin Lung Cancer. 1999;1(2):144-50. Notes: NSP. [pmid: 14733666].
Berberich W, Schnabel K, Scharding B, et al. [Hyperfractionated irradiation of bronchial cancer. Results of a pilot study]. Strahlenther Onkol. 1987;163(2):74-8. Notes: NSD. [pmid: 3031838].
Berghmans T, Paesmans M, Lafitte JJ, Mascaux C, Meert AP, Sculier JP. Role of granulocyte and granulocyte-macrophage colony-stimulating factors in the treatment of small-cell lung cancer: a systematic review of the literature with methodological assessment and meta-analysis. Lung Cancer. 2002;37(2):115-23. Notes: NRQ. [pmid: 12140132].
Bergman B, Aaronson NK. Quality-of-life and cost-effectiveness assessment in lung cancer. Curr Opin Oncol. 1995;7(2):138-43. Notes: NRA. [pmid: 7756378].
Bergman B, Sullivan M, Sorenson S. Quality of life during chemotherapy for small cell lung cancer. II. A longitudinal study of the EORTC Core Quality of Life Questionnaire and comparison with the Sickness Impact Profile. Acta Oncol. 1992;31(1):19-28. Notes: NRQ. [pmid: 1316770].
Birch R, Omura GA, Greco FA, Perez CA. Patterns of failure in combined chemotherapy and radiotherapy for limited small cell lung cancer: Southeastern Cancer Study Group experience. NCI Monogr 1988; (6):265–70. Notes: NRQ
Birch R, Weaver, CH, Hainsworth JD, Bobo C, Greco FA. A randomized study of etoposide and carboplatin with or without paclitaxel in the treatment of small cell lung cancer. Semin Oncol 1997; 24(4 Suppl 12):S12-135-S12-137. Notes: NRQ
Bishop JF. Scheduling of chemotherapy and radiotherapy in locally advanced non-small cell lung cancer. Lung Cancer. 1995;12(Suppl 2):S53-61. Notes: NRA. [pmid: 7551950].
Bleehen NM, Girling DJ, Gregor A, et al. Can long-term survival be improved in patients with small-cell lung cancer (SCLC) and good performance status? Medical Research Council Lung Cancer Working Party. Br J Cancer. 1994;70(1):142-4. Notes: FEW. [pmid: 8018526].
Bleyer WA. Hobson's choice in the CNS radioprophylaxis of small cell lung cancer. Int J Radiat Oncol Biol Phys. 1988;15(3):783-5. Notes: NPD. [pmid: 2843491].
Bonnefoi H, Zulian GB, Mirimanoff RO, Mermillod B, Alberto P. Priming low-dose chest radiotherapy followed by chemotherapy for limited small-cell lung cancer. Ann Oncol. 1994;5(8):771-2. Notes: NSD. [pmid: 7826914].
Bonomi P. New approaches to symptom improvements in lung cancer patients. Lung Cancer. 2003;41(Suppl 4):S32-6. Notes: NRA. [pmid: 14565513].
Bowen EF, Anderson JR, Roddie ME. Improving surgical resection rates in lung cancer without a two stop service. Thorax. Apr. 2003;58(4):368. Notes: NSP. [pmid: 12668811].
Bremnes RM, Sundstrom S, Aasebo U, et al. The value of prognostic factors in small cell lung cancer: results from a randomised multicenter study with minimum 5 year follow-up. Lung Cancer. 2003;39(3):303-13. Notes: NRQ. [pmid: 12609569].
Bremnes RM, Sundstrom S, Vilsvik J, et al. Multicenter phase II trial of paclitaxel, cisplatin, and etoposide with concurrent radiation for limited-stage small-cell lung cancer. J Clin Oncol. 2001;19(15):3532-8. Notes: NSD. [pmid: 11481360].
Brewster AE, Hopwood P, Stout R, et al. Single fraction prophylactic cranial irradiation for small cell carcinoma of the lung. Radiother Oncol. 1995;34(2):132-6. Notes: NSD. [pmid: 7597211].
Brock MV, Hooker CM, Syphard JE, et al. Surgical resection of limited disease small cell lung cancer in the new era of platinum chemotherapy: Its time has come. J Thorac Cardiovasc Surg. Jan. 2005;129(1):64-72. Notes: SCS. [pmid: 15632826].
Brodin O, Rikner G, Steinholtz L, Nou E. Local failure in patients treated with radiotherapy and multidrug chemotherapy for small cell lung cancer. Acta Oncol. 1990;29(6):739-46. Notes: NSD. [pmid: 2171595].
Brown PD, Bonner JA, Foote RL, et al. Long-term results of a phase I/II study of high-dose thoracic radiotherapy with concomitant cisplatin and etoposide in limited stage small-cell lung cancer. Am J Clin Oncol. 2001;24(6):556-61. Notes: NSD. [pmid: 11801753].
Buck AK, Halter G, Schirrmeister H, et al. Imaging proliferation in lung tumors with PET: 18F-FLT versus 18F-FDG. J Nucl Med. 2003;44(9):1426-31. Notes: NSD. [pmid: 12960187].
Buck, AK, Hetzel, M, Schirrmeister H, Clinical relevance of imaging proliferative activity in lung nodules. Eur J Nucl Med Mol Imaging 2004. Notes: NRQ; excluded
Bulzebruck H, Holle R, Havemann K, et al. [Analysis of the effect of selection in a therapy study]. Onkologie. 1986;9(5):274-80. Notes: NRQ. [pmid: 3027639].
Bunn P, Arriagada R, Choi N, et al. Combined modality therapy in small cell lung cancer. Lung Cancer. 1994;10(Suppl 1):S25-8. Notes: NPD; but maybe cite in write-up. [pmid: 8087517].
Bunn PA Jr, Kelly K. New treatment agents for advanced small cell and non-small cell lung cancer. Semin Oncol. 1995;22(3 Suppl 6):53-63. Notes: NRA. [pmid: 7597434].
Bunn PA Jr, Kelly K. Prophylactic cranial irradiation for patients with small-cell lung cancer. J Natl Cancer Inst. 1995;87(3):161-2. Notes: NPD. [pmid: 7707398].
Bunn PA Jr, Shepherd FA, Sandler A, et al. Ongoing and future trials of biologic therapies in lung cancer. Lung Cancer. 2003;41(Suppl 1):S175-86. Notes: NRA. [pmid: 12867076].
Burgers JA, Arance A, Ashcroft L, et al. Identical chemotherapy schedules given on and off trial protocol in small cell lung cancer: response and survival results. Br J Cancer. 2002;87(5):562-6. Notes: NRQ. [pmid: 12189557].
Bychko MB, Ol'khovskaia IG. [The results of the conservative treatment of patients with small-cell lung cancer]. Vopr Onkol. 1989;35(2):180-4. Notes: SCS. [pmid: 2538963].
Bynhardt R, Komaki R, Ettinger D, et al. Radiation Therapy Oncology Group. Research Plan 2002-2006. Lung Cancer Committee. Int J Radiat Oncol Biol Phys. 2001;51(3 Suppl 2):44-52. Notes: NPD. [pmid: 11641014].
Byrnen MJ, van Hazel G, Trotter J, et al. Maintenance chemotherapy in limited small cell lung cancer: a randomised controlled clinical trial. Br J Cancer. 1989;60(3):413-8. Notes: NRQ. [pmid: 2551359].
Campling B. Topotecan in small cell lung cancer: first or second line?. Cancer Biol Ther. 2004;3(1):94-5. Notes: NPD; exclude, but cite in write-up. [pmid: 14739785].
Canetta R, Bragman K, Smaldone L, et al. Carboplatin: current status and future prospects. Cancer Treat Rev. 1988;15(Suppl B):17-32. Notes: NRA. [pmid: 2841021].
Carlson RW, Sikic BI, Gandara DR, et al. Late consolidative radiation therapy in the treatment of limited-stage small cell lung cancer. Cancer. 1991;68(5):948-58. Notes: NRQ. [pmid: 1655219].
Carney DN. Carboplatin/etoposide combination chemotherapy in the treatment of poor prognosis patients with small cell lung cancer. Lung Cancer. 1995;12(Suppl 3):S77-83. Notes: NRQ. [pmid: 7551960].
Carney DN. Lung cancer--time to move on from chemotherapy. N Engl J Med. 2002;346(2):126-8. Notes: NPD. [pmid: 11784881].
Chanarin N. Chemotherapy plus surgery versus surgery alone in non-small-cell lung cancer. N Engl J Med. 1994;330(24):1756. author reply 1757. Notes: NRD NSP. [pmid: 8190142].
Chatani M, Matayoshi Y, Masaki N, et al. [Radiation therapy for brain metastases from lung carcinoma: the second prospective randomized trial]. Nippon Igaku Hoshasen Gakkai Zasshi. 1994;54(14):1380-7. Notes: NRQ. [pmid: 7596767].
Chatani M, Teshima T, Hata K, et al. Whole brain irradiation for metastases from lung carcinoma. A clinical investigation. Acta Radiol Oncol. 1985;24(4):311-4. Notes: NRQ. [pmid: 2994386].
Chen TT, Chute JP, Feigal E, et al. A model to select chemotherapy regimens for phase III trials for extensive-stage small-cell lung cancer. J Natl Cancer Inst. 2000;92(19):1601-7. Notes: NRQ NPD. [pmid: 11018096].
Cherann SK, Herndon JE 2nd, Patz EF Jr. Comparison of whole-body FDG-PET to bone scan for detection of bone metastases in patients with a new diagnosis of lung cancer. Lung Cancer. 2004;44(3):317-25. Notes: NSD NSP. [pmid: 15140545].
Cheson BD. Clinical trials referral resource. NCI-Navy: small cell lung cancer. Oncology (Huntingt). 1990;4(9):129-30. Notes: NRQ. [pmid: 2169844].
Cheson BD. Clinical trials referral resource. Small-cell lung cancer. Oncology (Huntingt). 1990;4(1):43-56. Notes: NPD. [pmid: 2168198].
Cheson BD, Feigal EG, Phillips PH. Clinical trials referral resource. Extensive-stage small-cell lung cancer. Oncology (Huntingt) 1993; 7(11):60, 63–4. Notes: NPD
Cheson BD, Feigal EG, Phillips PH. Clinical trials referral resource. Small-cell lung cancer. Oncology (Huntingt). 1993;7(10):43-7. Notes: NPD.
Chin R Jr, McCain TW, Miller AA, et al. Whole body FDG-PET for the evaluation and staging of small cell lung cancer: a preliminary study. Lung Cancer. 2002;37(1):1-6. Notes: FEW. [pmid: 12057859].
Chiuten DF, Carr DT, Dhingra HM, et al. Combination chemotherapy with vindesine and cisplatin for refractory small cell bronchogenic carcinoma. Cancer Treat Rep. 1986;70(6):795-6. Notes: FEW. [pmid: 3015403].
Choi NC, Carey RW, Kaufman SD, Grillo HC, Younger J, Wilkins EW Jr. Small cell carcinoma of the lung. A progress report of 15 years' experience. Cancer. 1987;59(1):6-14. Notes: SCS. [pmid: 3024801].
Choi NC, Propert K, Carey R, et al. Accelerated radiotherapy followed by chemotherapy for locally recurrent small-cell carcinoma of the lung. A phase II study of Cancer and Leukemia Group B. Int J Radiat Oncol Biol Phys. 1987;13(2):263-6. Notes: FEW. [pmid: 3028996].
Clark PI, Slevin ML, Joel SP, et al. A randomized trial of two etoposide schedules in small-cell lung cancer: the influence of pharmacokinetics on efficacy and toxicity. J Clin Oncol. 1994;12(7):1427-35. Notes: NRQ. [pmid: 8021734].
Clerici M. Second line treatment (2 LT) in small cell lung cancer (SC). Anticancer Res. 1994;14(1B):337-9. Notes: NRA. [pmid: 8166479].
Cocquytn V, De Neve W, Van Belle SJ. Chemotherapy plus surgery versus surgery alone in non-small-cell lung cancer. N Engl J Med. 1994;330(24):1756. author reply 1757. Notes: NRD NSP.
Coleman RE. Value of FDG-PET scanning in management of lung cancer. Lancet. 2002;359(9315):1361-2. Notes: NPD. [pmid: 11978328].
Collins C, Higano CS, Livingston RB, et al. Cyclophosphamide, vincristine, cisplatin, VP-16 and radiation therapy in extensive small-cell lung cancer. A Southwest Oncology Group Study. Cancer Chemother Pharmacol. 1989;24(2):128-32. Notes: NRQ. [pmid: 2543513].
Coy P, Hodson I, Payne DG, et al. The effect of dose of thoracic irradiation on recurrence in patients with limited stage small cell lung cancer. Initial results of a Canadian Multicenter Randomized Trial. Int J Radiat Oncol Biol Phys. 1988;14(2):219-26. Notes: NSD. [pmid: 2828289].
Crawford J, Kreisman H, Garewal H, et al. The impact of Filgrastim schedule variation on hematopoietic recovery post-chemotherapy. Ann Oncol. 1997;8(11):1117-24. Notes: NRQ. [pmid: 9426331].
Cull A, Gregor A, Hopwood P, et al. Neurological and cognitive impairment in long-term survivors of small cell lung cancer. Eur J Cancer. 1994;30A(8):1067-74. Notes: NSD. [pmid: 7654431].
Dales RE, Stark RM, Raman S. Computed tomography to stage lung cancer. Approaching a controversy using meta-analysis. Am Rev Respir Dis. 1990;141(5 Pt 1):1096-101. Notes: NPD; no separate data for SCLC; systematic review and meta-analysis of CT for staging. [pmid: 2160211].
Davies AM, Evans WK, Mackay JA, Shepherd FA. Treatment of recurrent small cell lung cancer. Hematol Oncol Clin North Am. 2004;18(2):387-416. Notes: NPD; exclude but cite in write-up. [pmid: 15094178].
Davis S, Crino L, Tonato M, Darwish S, Pelicci PG, Grignani F. A prospective analysis of chemotherapy following surgical resection of clinical stage I-II small-cell lung cancer. Am J Clin Oncol. 1993;16(2):93-5. Notes: SCS. [pmid: 8383917].
De Marinis F, Migliorino MR, Paoluzzi L, et al. Phase I/II trial of gemcitabine plus cisplatin and etoposide in patients with small-cell lung cancer. Lung Cancer. 2003;39(3):331-8. Notes: NRQ. [pmid: 12609572].
De MF, Nelli F, Lombardo M, et al. A multicenter, randomized, phase II study of cisplatin, etoposide, and gemcitabine or cisplatin plus gemcitabine as first-line treatment inpatients with poor-prognosis small cell lung carcinoma. Cancer. 2005;103(4):772-9. Notes: NRQ. [pmid: 15641037].
Dearing MP, Steinberg SM, Phelps R, et al. Outcome of patients with small-cell lung cancer: effect of changes in staging procedures and imaging technology on prognostic factors over 14 years. J Clin Oncol. 1990;8(6):1042-9. Notes: NRQ. [pmid: 2161447].
Debevec M, Orel J. Treatment of small cell lung cancer by surgery, chemotherapy, and irradiation. Lung Cancer ( LUNG CANCER ) 1991. Notes: SCS
Del Valle ML, Rubiales AS, Garavis M, Rey P, Lopez-Lara F. Radioterapia en el carcinoma microcítico de pulmón: ¿cuanto antes mejor?. Oncologia. 2000;23(3):29-37. Notes: NPD.
Delbaldon C, Le Pechoux C, Le Chevalier T. Combined modality treatment of lung cancer (NSCLC and SCLC). Cancer Chemother Biol Response Modif. 2002;20:677-95. Notes: NRA; exclude, maybe cite in write-up. [pmid: 12703230].
Dodwell D, Gildersleve JQ. Adjuvant thoracic radiation in small cell lung cancer. Clin Oncol (R Coll Radiol). 1993;5(6):384-5. Notes: NRA. [pmid: 8305361].
Dowlati A, Crosby L, Remick SC, et al. Paclitaxel added to the cisplatin/etoposide regimen in extensive-stage small cell lung cancer — the use of complete response rate as the primary endpoint in phase II trials. Lung Cancer. 2001;32(2):155-62. Notes: NRQ. [pmid: 11325486].
Doyle JJ, Dezii CM, Sadana A. A pharmacoeconomic evaluation of cisplatin in combination with either etoposide or etoposide phosphate in small cell lung cancer. Semin Oncol. 1996;23(6 Suppl 13):51-60. Notes: NRQ. [pmid: 8996576].
Eagan RT, Frytak S, Lee RE, Therneau TM, Richardson RL, Creagan ET. No routine role for vincristine, adriamycin, and cyclophosphamide (VAC) or thoracic radiation therapy in extensive stage small cell lung cancer. Am J Clin Oncol. 1987;10(2):141-5. Notes: NRQ. [pmid: 3031976].
Eberhardt K, Hartmann W, Habermalz H, et al. ACE vs alternating PVB/ACE: Results of a controlled randomised therapy study in small-cell bronchial carcinoma in Bremen hospitals. Pneumologie. 1991;45(4):173-4. Notes: NRQ, exclude.
Eberhardt W, Stamatis G, Stuschke M, et al. Prognostically orientated multimodality treatment including surgery for selected patients of small-cell lung cancer patients stages IB to IIIB: long-term results of a phase II trial. Br J Cancer. 1999;81(7):1206-12. Notes: SCS. [pmid: 10584883].
Ebi N, Kubota K, Nishiwaki Y, et al. Second-line chemotherapy for relapsed small cell lung cancer. Jpn J Clin Oncol. 1997;27(3):166-9. Notes: SCS. [pmid: 9255271].
Eckardt JR. Feasibility of oral topotecan in previously untreated patients with small-cell lung cancer ineligible for standard therapy. Oncology. 2001;61(Suppl 1):42-6. Notes: NRQ. [pmid: 11598414].
Edelman MJ, Chansky K, Gaspar LE, et al. Phase II trial of cisplatin/etoposide and concurrent radiotherapy followed by paclitaxel/carboplatin consolidation for limited small-cell lung cancer: Southwest Oncology Group 9713. J Clin Oncol. 2004;22(1):127-32. Notes: NSD, NRQ. [pmid: 14701775].
Eckardt JR. Second-line treatment of small-cell lung cancer. The case for systemic chemotherapy. Oncology (Huntingt) 2003; 17(2):181–8, 191; discussion 191–2, passim. Notes: NRA
Elias AD. Dose-intensive therapy for small cell lung cancer. Chest. 1995;107(6 Suppl):261S-6S. Notes: NRA. [pmid: 7781403].
Elias AD, Skarin AT, Richardson P, et al. Dose-intensive therapy for extensive-stage small cell lung cancer and extrapulmonary small cell carcinoma: long-term outcome. Biol Blood Marrow Transplant. 2002;8(6):326-33. Notes: NRQ. [pmid: 12108918].
Erkisi M, Unsal M, Tunali C, et al. A randomized study comparing cyclophosphamide, doxorubicin, vincristine (CAV) with cyclophosphamide, etoposide, vincristine, methotrexate (CEVM) in patients with small cell lung cancer. J Chemother. 1993;5(1):56-9. Notes: NRQ. [pmid: 8384659].
Erridge SC, Murray N. Thoracic radiotherapy for limited-stage small cell lung cancer: issues of timing, volumes, dose, and fractionation. Semin Oncol. 2003;30(1):26-37. Notes: NRA. [pmid: 12635087].
Ettinger DS. Ifosfamide in the treatment of small cell lung cancer. Semin Oncol. 1996;23(3 Suppl 6):2-6. Notes: NRA, NRQ. [pmid: 8677443].
Ettinger DS. New drugs for treating small cell lung cancer. Lung Cancer. 1995;12(Suppl 3):S53-61. Notes: NRA. [pmid: 7551957].
Ettinger DS. The place of ifosfamide in chemotherapy of small cell lung cancer: the Eastern Cooperative Oncology Group experience and a selected literature update. Semin Oncol. 1995;22(1 Suppl 2):23-7. Notes: NRQ. [pmid: 7846538].
Ettinger DS, Finkelstein DM, Abeloff MD, et al. Phase II study of n-methylformamide (NSC 3051) and spirogermanium (NSC 192965) in the treatment of advanced small cell lung cancer. Invest New Drugs. 1990;8(2):183-5. Notes: INV. [pmid: 2166720].
Ettinger DS, Finkelstein DM, Ritch PS, et al. Study of either ifosfamide or teniposide compared to a standard chemotherapy for extensive disease small cell lung cancer: an Eastern Cooperative Oncology Group randomized study (E1588). Lung Cancer. 2002;37(3):311-8. Notes: NRQ. [pmid: 12234701].
Evans WK, Radwi A, Tomiak E, et al. Oral etoposide and carboplatin. Effective therapy for elderly patients with small cell lung cancer. Am J Clin Oncol. 1995;18(2):149-55. Notes: NRQ. [pmid: 7534977].
Falk SJ, Maughan TS, Laurence VM, et al. Phase II study of carboplatin and adriamycin as second line chemotherapy in small cell lung cancer. Clin Oncol (R Coll Radiol). 1993;5(2):85-8. Notes: SCS. [pmid: 8386937].
Fayers P. Quality-of-life assessment in small cell lung cancer. Pharmacoeconomics. 1992;2(3):181-8. Notes: NRA; but maybe cite in write-up. [pmid: 10147008].
Feld R, Clamon GH, Blum R, et al. Short course prophylactic cranial irradiation for small cell lung cancer. Am J Clin Oncol. 1985;8(5):371-6. Notes: NSD. [pmid: 2998177].
Feld R, Evans WK, Coy P, et al. Canadian multicenter randomized trial comparing sequential and alternating administration of two non-cross-resistant chemotherapy combinations in patients with limited small-cell carcinoma of the lung. J Clin Oncol. 1987;5(9):1401-9. Notes: NRQ. [pmid: 3040923].
Felip E, Rosell R, Domine M, et al. Sequential dose-dense paclitaxel followed by topotecan in untreated extensive-stage small-cell lung cancer: a Spanish Lung Cancer Group phase II study. Ann Oncol. 2003;14(10):1549-54. Notes: NRQ. [pmid: 14504057].
Ferry DR, Cullen MH. Chemotherapy in advanced small lung cell cancer. BMJ. 1994;308(6933):920. Notes: NSP NRD. [pmid: 8173389].
Fetscher S, Brugger W, Engelhardt R, et al. Standard- and high-dose etoposide, ifosfamide, carboplatin, and epirubicin in 100 patients with small-cell lung cancer: a mature follow-up report. Ann Oncol. 1999;10(5):561-7. Notes: NRQ. [pmid: 10416006].
Fiedler R, Neef H, Hennig H, Rosendahl W, Lautenschlager C. [Quality of life after pneumonectomy for bronchial carcinoma]. Zentralbl Chir. 1997;122(5):327-31. Notes: SCS. [pmid: 9334092].
Filipazzi V, Piazza E, Cattaneo MT, et al. Ifosfamide, carboplatin and etoposide (ICE) in the treatment of small cell lung cancer: A cooperative multicentre study. Eur J Oncol. 2004;9(2):107-10. Notes: NRQ NSD.
Finley RS. Lung cancer: detection, prevention, and therapeutic. Am Pharm. 1989;NS29(11):39-46. Notes: NPD. [pmid: 2554707].
Foley JF, Peterson WC, Mailliard JA. Treatment of small cell carcinoma of the lung. Nebr Med J. 1989;74(11):330-2. Notes: SCS.
Fried DB, Morris DE, Poole C, et al. Systematic review evaluating the timing of thoracic radiation therapy in combined modality therapy for limited-stage small-cell lung cancer. J Clin Oncol. 2004;22(23):4785-93. Notes: NPD.
Frytak S, Shaw EG, Jett JR, et al. Infusion cisplatin chemotherapy and hyperfractionated thoracic radiotherapy for small-cell lung cancer. Am J Clin Oncol. 1996;19(2):193-8. Notes: NSD. [pmid: 8610649].
Fu Q, Gai X, Ji Z. [Clinical analysis of surgical treatment for 86 patients with localized small-cell lung cancer]. Zhonghua Zhong Liu Za Zhi. 1996;18(5):382-4. Notes: NSD. [pmid: 9387282].
Fukuchi K, Yamaguchi M, Hayashida K, Ishida Y. Discrepancy between Tc-99m HMDP bone scan and F-18 FDG positron emission tomographic images in a patient with small cell lung cancer. Clin Nucl Med. 2003;28(3):232-3. Notes: FEW. [pmid: 12592136].
Fukuoka M, Masuda N, Matsui K, et al. Combination chemotherapy with or without radiation therapy in small cell lung cancer. An analysis of a 5-year follow-up. Cancer. 1990;65(8):1678-84. Notes: SCS NSD (retrospective). [pmid: 2156596].
Fukuoka M, Masuda N, Negoro S, et al. CODE chemotherapy with and without granulocyte colony-stimulating factor in small-cell lung cancer. Br J Cancer. 1997;75(2):306-9. Notes: NRQ. [pmid: 9010043].
Furuse K, Fukuoka M, Nishiwaki Y, et al. Phase III study of intensive weekly chemotherapy with recombinant human granulocyte colony-stimulating factor versus standard chemotherapy in extensive-disease small-cell lung cancer. The Japan Clinical Oncology Group. J Clin Oncol. 1998;16(6):2126-32. Notes: NRQ. [pmid: 9626212].
Furuse K, Kawahara M, Arai R, et al. [Combined radiotherapy and chemotherapy modalities in the treatment of lung cancer]. Gan To Kagaku Ryoho. 1988;15(4 Pt 23):1628-33. Notes: NRQ. [pmid: 2837998].
Gasparn LE, Rogers LR. Prophylactic cranial irradiation for small-cell lung cancer: to do or not to do?. Support Oncol. 2004;2:7-9. Notes: NPD.
Gatzemeier U, Achterrath W, Heckmayr M, et al. [Chemotherapy of small cell bronchial cancer with a combination of carboplatin, vincristine and etoposide]. Pneumologie. 1990;44(Suppl 1):584-5. Notes: NRQ. [pmid: 2164203].
Gatzemeier U, Kleisbauer JP, Drings P, et al. Lenograstim as support for ACE chemotherapy of small-cell lung cancer: a phase III, multicenter, randomized study. Am J Clin Oncol. 2000;23(4):393-400. Notes: NRQ. [pmid: 10955871].
Gatzemeiern U, Radenbach D. Chemotherapy (CAV) and surgical resection as combined modality in the therapy of small-cell lung cancer. Panminerva Med. 1986;28(2):63-6. Notes: SCS.
Gatzemeiern U, von Pawel J, Laumen R, et al. Carboplatin/etoposide/vincristine therapy in small cell lung cancer. Oncology. 1992;49(Suppl 1):25-33. Notes: NSD. [pmid: 1323809].
Geara FB, Komaki R, Tucker SL, Travis EL, Cox JD. Factors influencing the development of lung fibrosis after chemoradiation for small cell carcinoma of the lung: evidence for inherent interindividual variation. Int J Radiat Oncol Biol Phys. 1998;41(2):279-86. Notes: NRQ. [pmid: 9607342].
Geddes DM, Dones L, Hill E, et al. Quality of life during chemotherapy for small cell lung cancer: assessment and use of a daily diary card in a randomized trial. Eur J Cancer. 1990;26(4):484-92. Notes: NRQ. [pmid: 2162692].
Gennatas CS, Balafouta MJ, Panayotopoulos PP, et al. A pilot study of an alternating chemotherapy regime and sequential radiation therapy in limited stage small cell carcinoma of the lung. Eur J Cancer. 1993;29A(12):1792-3. Notes: NSD. [pmid: 8398313].
Georgiadis MS, Steinberg SM, Hankins LA, Ihde DC, Johnson BE. Obesity and therapy-related toxicity in patients treated for small-cell lung cancer. J Natl Cancer Inst. 1995;87(5):361-6. Notes: NSD. [pmid: 7853417].
Giaccone G. Identification of new drugs in pretreated patients with small cell lung cancer. Eur J Cancer Clin Oncol. 1989;25(3):411-3. Notes: NPD. [pmid: 2539296].
Giaccone G. Second line chemotherapy in small cell lung cancer. Lung Cancer 1989; 207–13. Notes: NPD
Ginsberg RJ. Small cell lung cancer: how should we treat it? What is it?. Ann Thorac Surg. Nov. 2000;70(5):1453-4. Notes: NPD. [pmid: 11093468].
Girling DJ, Stott H, Stephens RJ, et al. Fifteen-year follow-up of all patients in a study of post-operative chemotherapy for bronchial carcinoma. Br J Cancer. 1985;52(6):867-73. Notes: NRQ. [pmid: 3907687].
Glatstein E, Ihde D, Bunn P, et al. Radiotherapy in management of limited small cell lung carcinoma: a randomized prospective study. Cancer Treat Symp. 1985;2:97-100. Notes: NRQ, exclude.
Glisson B, Lee JS, Palmer J, et al. Cisplatin, ifosfamide, and prolonged oral etoposide in the treatment of patients with extensive small cell lung carcinoma. Cancer. 1998;82(2):301-8. Notes: NRQ, NSD. [pmid: 9445186].
Glisson B, Scott C, Komaki R, et al. Cisplatin, ifosfamide, oral etoposide, and concurrent accelerated hyperfractionated thoracic radiation for patients with limited small-cell lung carcinoma: results of radiation therapy oncology group trial 93–12. J Clin Oncol. 2000;18(16):2990-5. Notes: NSD. [pmid: 10944132].
Glisson BS. Recurrent small cell lung cancer: update. Semin Oncol. 2003;30(1):72-8. Notes: NPD. [pmid: 12635091].
Glissonn BS, Kurie JM, Perez-Soler R, et al. Cisplatin, etoposide, and paclitaxel in the treatment of patients with extensive small-cell lung carcinoma. J Clin Oncol. 1999;17(8):2309-15. Notes: NRQ. [pmid: 10561292].
Gogas H, Lofts FJ, Evans TR, et al. Outpatient treatment with epirubicin and oral etoposide in patients with small-cell lung cancer. Br J Cancer. 1997;76(5):639-42. Notes: NRQ. [pmid: 9303364].
Goodman GE, Crowley JJ, Blasko JC, et al. Treatment of limited small-cell lung cancer with etoposide and cisplatin alternating with vincristine, doxorubicin, and cyclophosphamide versus concurrent etoposide, vincristine, doxorubicin, and cyclophosphamide and chest radiotherapy: a Southwest Oncology Group Study. J Clin Oncol. 1990;8(1):39-47. Notes: NSD. [pmid: 2153194].
Gower NH, Rudd RM, Ruiz de, Elviran MC, et al. Assessment of ‘quality of life’ using a daily diary card in a randomised trial of chemotherapy in small-cell lung cancer. Ann Oncol. 1995;6(6):575-80. Notes: NRQ. [pmid: 8573537].
Grantn SC, Kris MG. Phase II trials in small-cell lung cancer: shouldn't we be doing better?. J Natl Cancer Inst. 1992;84(14):1058-9. Notes: NPD. [pmid: 1320130].
Grecon FA, Hainsworth JD. Clinical studies with etoposide phosphate. Semin Oncol. 1996;23(6 Suppl 13):45-50. Notes: NRQ. [pmid: 8996575].
Grecon FA, Hainsworth JD. Emerging role of topotecan in first-line therapy of small-cell lung cancer. Clin Lung Cancer. 2003;4(5):279-87. Notes: NRA. [pmid: 14609445].
Grecon FA, Hainsworth JD. Paclitaxel, carboplatin, and oral etoposide in the treatment of small cell lung cancer. Semin Oncol. 1996;23(6 Suppl 16):7-10. Notes: NSD.
Gregor A. Combined modality treatment in small cell lung cancer (SCLC). Eur J Cancer. 1995;31A(5):816-8. Notes: NPD. [pmid: 7640065].
Gregor A. Cranial irradiation in small cell lung cancer. Br J Cancer. 1991;63(1):13-4. Notes: NPD. [pmid: 1846550].
Gregor A. Factors influencing use of alternating chemotherapy and radiation schedules in small cell lung cancer. Lung Cancer. 1994;10(Suppl 1):S299-305. Notes: NPD NRA. [pmid: 8087523].
Gregor A, Drings P, Rinaldi M, et al. Acute toxicity of alternating schedule of chemotherapy and irradiation in limited small-cell lung cancer in a pilot study (08877) of the EORTC Lung Cancer Cooperative Group. Ann Oncol. 1995;6(4):403-5. Notes: NPD. [pmid: 7619758].
Gridelli C, Curcio C, Iaffaioli RV, et al. Carboplatin + epirubicin +VP-16 + lenograstim followed by radiotherapy + carboplatin as radiosensitizer in limited small cell lung cancer. A multicenter phase II study. Anticancer Res. 2001;21(6A):4179-83. Notes: NRQ. [pmid: 11911315].
Gridellin C, D'Aprile M, Curcio C, et al. Carboplatin plus epirubicin plus VP-16, concurrent ‘split course’ radiotherapy and adjuvant surgery for limited small cell lung cancer. Gruppo Oncologico Centro-Sud-Isole (GOCSI). Lung Cancer. 1994;11(12):83-91. Notes: NSD. [pmid: 8081707].
Gridelli C, Manzione L, Perrone F, et al. Carboplatin plus paclitaxel in extensive small cell lung cancer: a multicentre phase 2 study. Br J Cancer. 2001;84(1):38-41. Notes: NRQ. [pmid: 11139310].
Gridellin C, Perrone F, D'Aprile M, et al. Phase II study of intensive CEV (carboplatin, epirubicin and VP-16) plus G-CSF (granulocyte-colony stimulating factor) in extensive small cell lung cancer. Eur J Cancer. 1995;31A(1314):2424-6. Notes: NRQ. [pmid: 8652288].
Gridelli C, Perrone F, Ianniello GP, et al. Carboplatin plus vinorelbine, a new well-tolerated and active regimen for the treatment of extensive-stage small-cell lung cancer: a phase II study. Gruppo Oncologico Centro-Sud-Isole. J Clin Oncol. 1998;16(4):1414-9. Notes: NRQ. [pmid: 9552045].
Gridelli C, Rossi A, Barletta E, et al. Carboplatin plus vinorelbine plus G-CSF in elderly patients with extensive-stage small-cell lung cancer: a poorly tolerated regimen. Results of a multicentre phase II study. Lung Cancer. 2002;36(3):327-32. Notes: NRQ, NSD. [pmid: 12009246].
Grozea PN, Crowley JJ, Canfield VA, et al. Teniposide (VM-26) as a single drug treatment for patients with extensive small cell lung carcinoma: a Phase II study of the Southwest Oncology Group. Cancer. 1997;80(6):1029-33. Notes: NRQ. [pmid: 9305702].
Gupta NC, Graeber GM, Bishop HA. Comparative efficacy of positron emission tomography with fluorodeoxyglucose in evaluation of small (<1 cm), intermediate (1 to 3cm), and large (> 3 cm) lymph node lesions. Chest. Mar. 2000;117(3):773-8. Notes: NSP exclude. [pmid: 10713005].
Hainsworth JD, Gray JR, Stroup SL, et al. Paclitaxel, carboplatin, and extended-schedule etoposide in the treatment of small-cell lung cancer: comparison of sequential phase II trials using different dose-intensities. J Clin Oncol. 1997;15(12):3464-70. Notes: NRQ. [pmid: 9396399].
Hainsworth JD, Hopkins LG, Thomas M, et al. Paclitaxel, carboplatin, and extended-schedule oral etoposide for small-cell lung cancer. Oncology (Huntingt). 1998;12(1 Suppl 2):31-5. Notes: NSD. [pmid: 9516609].
Hainsworth JD, Morrissey LH, Scullin DC Jr, et al. Paclitaxel, carboplatin, and topotecan in the treatment of patients with small cell lung cancer: a phase II trial of the Minnie Pearl Cancer Research Network. Cancer. 2002;94(9):2426-33. Notes: NRQ, NSD. [pmid: 12033195].
Hainsworth JD, Stroup SL, Greco FA. Paclitaxel, carboplatin, and extended schedule etoposide in the treatment of small cell lung carcinoma. Cancer. 1996;77(12):2458-63. Notes: NRQ, NSD. [pmid: 8640693].
Halme M, Hallman M, Ruotsalainen T, et al. Tumour response and radiation-induced lung injury in patients with recurrent small cell lung cancer treated with radiotherapy and concomitant interferon-alpha. Lung Cancer. 1999;23(1):39-52. Notes: FEW. [pmid: 10100145].
Hand S, Baker J, Smith AP, Macbeth FR. Outpatient intensive chemotherapy for small cell lung cancer: five years experience of modified ‘ICE’ ifosfamide carboplatin and etoposide. Clin Oncol (R Coll Radiol). 2002;14(5):367-71. Notes: NSD. [pmid: 12555875].
Hanna N, Ansari R, Fisher W, et al. Etoposide, ifosfamide and cisplatin (VIP) plus concurrent radiation therapy for previously untreated limited small cell lung cancer (SCLC): a Hoosier Oncology Group (HOG) phase II study. Lung Cancer. 2002;35(3):293-7. Notes: NSD. [pmid: 11844604].
Hanna NH, Sandier AB, Loehrer PJ Sr, et al. Maintenance daily oral etoposide versus no further therapy following induction chemotherapy with etoposide plus ifosfamide plus cisplatin in extensive small-cell lung cancer: a Hoosier Oncology Group randomized study. Ann Oncol. 2002;13(1):95-102. Notes: NRQ. [pmid: 11863118].
Hara N, Ohta M, Ichinose Y, et al. Multimodality therapy for small cell carcinoma of the lung--the role of surgical treatment. Jpn J Surg. 1989;19(6):699-707. Notes: SCS. [pmid: 2558245].
Hardy J, Smith I, Cherryman G, et al. The value of computed tomographic (CT) scan surveillance in the detection and management of brain metastases in patients with small cell lung cancer. Br J Cancer. 1990;62(4):684-6. Notes: NRQ. [pmid: 2171623].
Harrigan P. Lung cancer tackled at Tokyo conference. Lancet. 2000;356(9236):1173. Notes: NPD. [pmid: 11030306].
Hauber HP, Bohuslavizki KH, Lund CH, et al. Positron emission tomography in the staging of small-cell lung cancer: a preliminary study. Chest. 2001;119(3):950-4. Notes: FEW. [pmid: 11243980].
Havemann K, Wolf M, Drings P, et al. Experience of a German multicenter study group with ifosfamide in small cell lung cancer. Semin Oncol. 1989;16(1 Suppl 3):9-18. Notes: NRQ. [pmid: 2539648].
Hazukan MB, Turrisi AT 3rd. The evolving role of radiation therapy in the treatment of locally advanced lung cancer. Semin Oncol. 1993;20(2):173-84. Notes: NRA. [pmid: 8386856].
Healey EA, Abner A. Thoracic and cranial radiotherapy for limited-stage small cell lung cancer. Chest. 1995;107(6 Suppl):249S-54S. Notes: NRA. [pmid: 7781402].
Heckmayr M, Gatzemeier U, Hossfeld DK, et al. [Cisplatin-Vepeside versus Endoxan-Vepeside in the treatment of small cell bronchial cancer. A randomized study]. Pneumologie. 1990;44(Suppl 1):256-7. Notes: NRQ. [pmid: 2164193].
Herskovic A, Orton C, Seyedsadr M, et al. Initial experience with a practical hyperfractionated accelerated radiotherapy regimen. Int J Radiat Oncol Biol Phys. 1991;21(5):1275-81. Notes: NSD. [pmid: 1657843].
Herskovic A, Scott C, Demas W, et al. Accelerated hyperfractionation for bronchogenic cancer: Radiation Therapy Oncology Group 9205. Am J Clin Oncol. 2000;23(2):207-12. Notes: NRD. [pmid: 10776986].
Hirsch FR, Osterlind K, Jeppesen N, et al. Superiority of high-dose platinum (cisplatin and carboplatin) compared to carboplatin alone in combination chemotherapy for small-cell lung carcinoma: a prospective randomised trial of 280 consecutive patients. Ann Oncol. 2001;12(5):647-53. Notes: NRQ. [pmid: 11432623].
Hobdy EM, Kraut E, Masters G, et al. A phase II study of topotecan and cyclophosphamide with G-CSF in patients with advanced small cell lung cancer. Cancer Biol Ther. 2004;3(1):89-93. Notes: NRQ, NSP. [pmid: 14726661].
Hollaus PH, Wilfing G, Wurnig PN, et al. Risk factors for the development of postoperative complications after bronchial sleeve resection for malignancy: a univariate and multivariate analysis. Ann Thorac Surg. 2003;75(3):966-72. Notes: NSP. [pmid: 12645725].
Hollen PJ, Gralla RJ, Kris MG, Potanovich LM. Quality of life assessment in individuals with lung cancer: testing the Lung Cancer Symptom Scale (LCSS). Eur J Cancer. 1993;29A(Suppl 1):S51-8. Notes: NRQ. [pmid: 8381294].
Hopwood P, Stephens RJ. Symptoms at presentation for treatment in patients with lung cancer: implications for the evaluation of palliative treatment. The Medical Research Council (MRC) Lung Cancer Working Party. Br J Cancer. 1995;71(3):633-6. Notes: NRQ. [pmid: 7533520].
Hopwood P, Stephens RJ, Machin D. Approaches to the analysis of quality of life data: experiences gained from a medical research council lung cancer working party palliative chemotherapy trial. Qual Life Res. 1994;3(5):339-52. Notes: NRQ. [pmid: 7531054].
Huang Q, Muzitansky A, Mark EJ. Pulmonary neuroendocrine carcinomas: A review of 234 cases and a statistical analysis of 50 cases treated at one institution using asimple clinicopathologic classification. Arch Pathol Lab Med. May. 2002;126(5):545-53. Notes: NRQ NPD. [pmid: 11958659].
Hugli A, Moro D, Mermillod B, et al. Phase II trial of up-front accelerated thoracic radiotherapy combined with chemotherapy and optional up-front prophylactic cranial irradiation in limited small-cell lung cancer. Groupe d'Oncologie Thoracique des Regions Alpines. J Clin Oncol. 2000;18(8):1662-7. Notes: NSD. [pmid: 10764426].
Huisman C, Postmus PE, Giaccone G, et al. Second-line chemotherapy and its evaluation in small cell lung cancer. Cancer Treat Rev. 1999;25(4):199-206. Notes: NRA. [pmid: 10448128].
Huncharek M, McGarry R. A meta-analysis of the timing of chest irradiation in the combined modality treatment of limited-stage small cell lung cancer. Oncologist. 2004;9(6):665-72. Notes: NPD. [pmid: 15561810].
Huttner J, Wiener N, Quadt C, et al. A randomized clinical trial comparing systemic radiotherapy versus chemotherapy versus local radiotherapy in small cell lung cancer. Eur J Cancer Clin Oncol. 1989;25(6):933-7. Notes: NRQ. [pmid: 2546778].
Ichiki M, Gohara R, Rikimaru T, et al. Combination chemotherapy with irinotecan and ifosfamide as second-line treatment of refractory or sensitive relapsed small cell lung cancer: a phase II study. Chemotherapy. 2003;49(4):200-5. Notes: SCS. [pmid: 12886056].
Ichinose Y, Hara N, Ohta M, et al. Comparison between resected and irradiated small cell lung cancer in patients in stages I through IIIa. Ann Thorac Surg. 1992;53(1):95-100. Notes: SCS NSD (retrospective). [pmid: 1309416].
Ihde DC. Small cell lung cancer. State-of-the-art therapy 1994. Chest. 1995;107(6 Suppl):243S-8S. Notes: NRA. [pmid: 7781401].
Iyoda A, Hiroshima K, Baba M, et al. Pulmonary large cell carcinomas with neuroendocrine features are high-grade neuroendocrine tumors. Ann Thorac Surg. Apr. 2002;73(4):1049-54. Notes: NRQ. [pmid: 11996239].
Iyoda A, Hiroshima K, Toyozaki T, et al. Adjuvant chemotherapy for large cell carcinoma with neuroendocrine features. Cancer. Sep 1. 2001;92(5):1108-12. Notes: NRQ. [pmid: 11571722].
Jackson DV Jr. Changing trends in small cell lung cancer. NC Med J. 1986;47(6):297-300. Notes: NRA.
James LE, Gower NH, Rudd RM, et al. A randomised trial of low-dose/high-frequency chemotherapy as palliative treatment of poor-prognosis small-cell lung cancer: a Cancer research Campaign trial. Br J Cancer. 1996;73(12):1563-8. Notes: NRQ. [pmid: 8664131].
Janne PA, Freidlin B, Saxman S, et al. Twenty-five years of clinical research for patients with limited-stage small cell lung carcinoma in North America. Cancer. 2002;95(7):1528-38. Notes: NPD. [pmid: 12237922].
Jassemn J, Karnicka-Mlodkowska H, Drozd-Lula M, et al. [Long-term survival of patients with small cell lung cancer]. Pneumonol Pol. 1989;57(1012):496-503. Notes: NRA. [pmid: 2561613].
Jelinek JS, Redmond J 3rd, Perry JJ, et al. Small cell lung cancer: staging with MR imaging. Radiology. 1990;177(3):837-42. Notes: NRQ. [pmid: 2173844].
Jeremic B, Shibamoto Y, Acimovic L, et al. Carboplatin, etoposide, and accelerated hyperfractionated radiotherapy for elderly patients with limited small cell lung carcinoma: a phase II study. Cancer. 1998;82(5):836-41. Notes: NSD. [pmid: 9486571].
Jett JR, Everson L, Therneau TM, et al. Treatment of limited-stage small-cell lung cancer with cyclophosphamide, doxorubicin, and vincristine with or without etoposide: a randomized trial of the North Central Cancer Treatment Group. J Clin Oncol. 1990;8(1):33-8. Notes: NSD. [pmid: 2153193].
Jett JR, Hatfield AK, Hillman S, et al. Alternating chemotherapy with etoposide plus cisplatin and topotecan plus paclitaxel in patients with untreated, extensive-stage small cell lung carcinoma: a phase II trial of the North Central Cancer Treatment Group. Cancer. 2003;97(10):2498-503. Notes: NRQ. [pmid: 12733149].
Jett JR, Maksymiuk AW, Su JQ, et al. Phase III trial of recombinant interferon gamma in complete responders with small-cell lung cancer. J Clin Oncol. 1994;12(11):2321-6. Notes: NRQ. [pmid: 7964947].
Joel S, O'Byrne K, Penson R, et al. A randomised, concentration-controlled, comparison of standard (5-day) vs. prolonged (15-day) infusions of etoposide phosphate in small-cell lung cancer. Ann Oncol. 1998;9(11):1205-11. Notes: NRQ. [pmid: 9862051].
Johnson BE. Concurrent approaches to combined chemotherapy and chest radiotherapy for the treatment of patients with limited stage small cell lung cancer. Lung Cancer. 1994;10(Suppl 1):S281-7. Notes: NRA NPD. [pmid: 8087521].
Johnson BE. Is more better? Chemotherapy for patients with extensive-stage small-cell lung cancer. J Natl Cancer Inst. Feb 21. 2001;93(4):254-5. Notes: NSP. [pmid: 11181764].
Johnson BE, Becker B, Goff WB 2nd, et al. Neurologic, neuropsychologic, and computed cranial tomography scan abnormalities in 2- to 10-year survivors of small-cell lung cancer. J Clin Oncol. 1985;3(12):1659-67. Notes: FEW. [pmid: 2999346].
Johnson BE, Bridges JD, Sobczeck M, et al. Patients with limited-stage small-cell lung cancer treated with concurrent twice-daily chest radiotherapy and etoposide/cisplatin followed by cyclophosphamide, doxorubicin, and vincristine. J Clin Oncol. 1996;14(3):806-13. Notes: NSD. [pmid: 8622028].
Johnson BE, Fischer T, Fischer B, et al. Phase II study of imatinib in patients with small cell lung cancer. Clin Cancer Res. 2003;9(16 Pt 1):5880-7. Notes: FEW. [pmid: 14676110].
Johnson BE, Glatstein E, Ihde DC. The National Cancer Institute experience with early and late effects of combined modality therapy in small cell lung cancer. Antibiot Chemother. 1988;41:210-2. Notes: NSD. [pmid: 2854442].
Johnson BE, Grayson J, Makuch RW, et al. Ten-year survival of patients with small-cell lung cancer treated with combination chemotherapy with or without irradiation. J Clin Oncol. 1990;8(3):396-401. Notes: NRQ NSD (retrospective). [pmid: 2155310].
Johnson BE, Ihde DC, Bunn PA, et al. Patients with small-cell lung cancer treated with combination chemotherapy with or without irradiation. Data on potential cures chronic toxicities and late relapses after a five- to eleven-year follow-up. Ann Intern Med. 1985;103(3):430-8. Notes: NRQ. [pmid: 2992337].
Johnsonn BE, Kelley MJ. Autocrine growth factors and neuroendocrine markers in the development of small-cell lung cancer. Oncology (Huntingt). 1998;12(1 Suppl 2):11-4. Notes: INV.
Johnson BE, Patronas N, Hayes W, et al. Neurologic, computed cranial tomographic, and magnetic resonance imaging abnormalities in patients with small-cell lung cancer: further follow-up of 6- to 13-year survivors. J Clin Oncol. 1990;8(1):48-56. Notes: NSD. [pmid: 2153196].
Johnson DH, Bass D, Einhorn LH, et al. Combination chemotherapy with or without thoracic radiotherapy in limited-stage small-cell lung cancer: a randomized trial of the Southeastern Cancer Study Group. J Clin Oncol. 1993;11(7):1223-9. Notes: NRQ. [pmid: 8391064].
Johnson DH, Turrisi AT, Chang AY, et al. Alternating chemotherapy and twice-daily thoracic radiotherapy in limited-stage small-cell lung cancer: a pilot study of the Eastern Cooperative Oncology Group. J Clin Oncol. 1993;11(5):879-84. Notes: NSD. [pmid: 8387577].
Johnson E, Lake D, Herndon JE 2nd, Box JW, Lynch TJ, Green MR. Phase II trial of vinorelbine plus doxorubicin in relapsed small-cell lung cancer: CALGB 9332. Am J Clin Oncol. 2004;27(1):19-23. Notes: FEW. [pmid: 14758128].
Johnson JR, Morgan DA, Holland IM. Prophylactic cranial irradiation for small-cell lung cancer: long-term results. Clin Oncol (R Coll Radiol). 1989;1(1):24-7. Notes: NSD. [pmid: 2562085].
Johnson PW, Muers MF, Peake MD, et al. A randomized trial of amifostine as a cytoprotective agent in patients receiving chemotherapy for small cell lung cancer. Br J Cancer. 2001;84(1):19-24. Notes: NRQ. [pmid: 11139307].
Joss RA, Alberto P, Bleher EA, et al. Combined-modality treatment of small-cell lung cancer: randomized comparison of three induction chemotherapies followed by maintenance chemotherapy with or without radiotherapy to the chest. Swiss Group for Clinical Cancer Research (SAKK). Ann Oncol. 1994;5(10):921-8. Notes: NRQ. [pmid: 7696164].
Joss RA, Alberto P, Hurny C, et al. Quality versus quantity of life in the treatment of patients with advanced small-cell lung cancer? A randomized phase III comparison of weekly carboplatin and teniposide versus cisplatin, adriamycin, etoposide alternating with cyclophosphamide, methotrexate, vincristine and lomustine. Swiss Group for Clinical Cancer Research (SAKK). Ann Oncol. 1995;6(1):41-8. Notes: NRQ. [pmid: 7536028].
Joss RA, Bacchi M, Hurny C, et al. Early versus late alternating chemotherapy in small-cell lung cancer. Swiss Group for Clinical Cancer Research (SAKK). Ann Oncol. 1995;6(2):157-66. Notes: NRQ. [pmid: 7786823].
Kaba SE, Kyritsis AP, Hess K, et al. TPDC-FuHu chemotherapy for the treatment of recurrent metastatic brain tumors. J Clin Oncol. 1997;15(3):1063-70. Notes: FEW. [pmid: 9060546].
Kalemkerian GP, Jiroutek M, Ettinger DS, Dorighi JA, Johnson DH, Mabry M. A phase II study of all-trans-retinoic acid plus cisplatin and etoposide in patients with extensive stage small cell lung carcinoma: an Eastern Cooperative Oncology Group Study. Cancer. 1998;83(6):1102-8. Notes: NRQ, NSD. [pmid: 9740074].
Kanard A, Frytak S, Jatoi A. Cognitive dysfunction in patients with small-cell lung cancer: Incidence, causes, and suggestions on management. J Support Oncol. Mar–Apr. 2004;2(2):127-32. discussion 133–5, 138–40. Notes: NRA. [pmid: 15328816].
Karrer K. Surgery in SCLC as first step of multimodality treatment. Anticancer Res. 1994;14(1B):327-31. Notes: NRQ. [pmid: 8166477].
Karrern K, Denck H. Multimodality treatment with surgery in small-cell lung cancer. Int J Clin Pharmacol Res. 1987;7(4):313-28. Notes: NRA. [pmid: 3036724].
Karrer K, Denck H, Drings P, Orel J, Bruno MF. Combination of surgery and chemotherapy for small-cell bronchial carcinoma. Drugs Exp Clin Res. 1986;12(13):191-200. Notes: NRQ. [pmid: 3015543].
Karrer K, Denck H, Karnicka-Mlodkowska H, et al. Surgery for cure followed by combined modality treatment for small cell bronchial carcinoma. ISC Lung Cancer Study Group. Int J Clin Pharmacol Res. 1988;8(6):415-21. Notes: NRQ. [pmid: 2855325].
Karrer K, Denck H, Karnicka-Mlodkowska H, et al. The role of ifosfamide and cyclophosphamide in the multi-modality treatment after surgery for cure for small-cell bronchial carcinomas (SCLC). Med Oncol Tumor Pharmacother. 1989;6(2):143-9. Notes: NRQ. [pmid: 2545979].
Karrer K, Denck H, Karnicka-Mlodkowska H, et al. The importance of surgery as the first step in multimodality treatment of small cell bronchial carcinoma. The ISC Lung Cancer Study Group. Int J Clin Pharmacol Res. 1990;10(5):257-63. Notes: NRQ. [pmid: 1964153].
Karrer K, Shields TW, Denck H, et al. The importance of surgical and multimodality treatment for small cell bronchial carcinoma. J Thorac Cardiovasc Surg. 1989;97(2):168-76. Notes: NRQ. [pmid: 2536867].
Karrer K, Ulsperger E. Surgery for cure followed by chemotherapy in small cell carcinoma of the lung. For the ISC-Lung Cancer Study Group. Acta Oncol. 1995;34(7):899-906. Notes: NRQ. [pmid: 7492378].
Katakami N, Takada M, Negoro S, et al. Dose escalation study of carboplatin with fixed-dose etoposide plus granulocyte-colony stimulating factor in patients with small cell lung carcinoma. A study of the Lung Cancer Study Group of West Japan. Cancer. 1996;77(1):63-70. Notes: NSD, NRQ. [pmid: 8630941].
Kawahara M. [Phase III studies of combined chemotherapy and radiation in locally advanced non-small-cell lung cancer and limited small-cell lung cancer]. Gan To Kagaku Ryoho. 1995;22(3):335-40. Notes: NRA. [pmid: 7880104].
Kelly K, Lovato L, Bunn PA Jr, et al. Cisplatin, etoposide, and paclitaxel with granulocyte colony-stimulating factor in untreated patients with extensive-stage small cell lung cancer: a phase II trial of the Southwest Oncology Group. Clin Cancer Res. 2001;7(8):2325-9. Notes: NRQ. [pmid: 11489808].
Khuri FR, Fossella FV, Lee JS, et al. Phase II trial of recombinant IFN-alpha2a with etoposide/cisplatin induction and interferon/megestrol acetate maintenance in extensive small cell lung cancer. J Interferon Cytokine Res. 1998;18(4):241-5. Notes: NRQ. [pmid: 9568726].
Kies MS, Mira JG, Crowley JJ, et al. Multimodal therapy for limited small-cell lung cancer: a randomized study of induction combination chemotherapy with or without thoracic radiation in complete responders; and with wide-field versus reduced-field radiation in partial responders: a Southwest Oncology Group Study. J Clin Oncol. 1987;5(4):592-600. Notes: NRQ. [pmid: 3031226].
Kirschling RJ, Grill JP, Marks RS, et al. Paclitaxel and G-CSF in previously untreated patients with extensive stage small-cell lung cancer: a phase II study of the North Central Cancer Treatment Group. Am J Clin Oncol. 1999;22(5):517-22. Notes: NRQ. [pmid: 10521070].
Kitase M, Hara M, Katoh K, et al. FDG-PET in patient with clinical T1N0 lung cancer; Determination of nodal status. Jpn J Clin Radiol. 2000;45(1):209-14. Notes: FEW.
Klasa RJ, Murray N, Coldman AJ. Dose-intensity meta-analysis of chemotherapy regimens in small-cell carcinoma of the lung. J Clin Oncol. 1991;9(3):499-508. Notes: NRQ. [pmid: 1847968].
Kobayashi A, Ohno S, Yamasawa H. A clinical assessment of radiation pneumonitis in cases with lung cancer receiving chemoradiotherapy. Jpn J Chest Dis. 2002;61(8):734-42. Notes: NSD, NSP.
Kobayashi K, Hino M, Kurane S, et al. [A comparative randomized phase II study of CDDP, CDDP-carboquone (CQ) and CDDP-etoposide as second-line chemotherapy in small cell lung cancer (SCLC)]. Gan To Kagaku Ryoho. 1989;16(2):207-12. Notes: INV. [pmid: 2537605].
Komaki R, Byhardt RW, Anderson T, et al. What is the lowest effective biologic dose for prophylactic cranial irradiation?. Am J Clin Oncol. 1985;8(6):523-7. Notes: NSD. [pmid: 4083270].
Komaki R, Meyers CA, Shin DM, et al. Evaluation of cognitive function in patients with limited small cell lung cancer prior to and shortly following prophylactic cranial irradiation. Int J Radiat Oncol Biol Phys. 1995;33(1):179-82. Notes: NSD. [pmid: 7642416].
Komaki R, Shin DM, Glisson BS, et al. Interdigitating versus concurrent chemotherapy and radiotherapy for limited small cell lung cancer. Int J Radiat Oncol Biol Phys. 1995;31(4):807-11. Notes: NSD. [pmid: 7860392].
Korn EL, Simon R, Friedman MA, et al. Phase II trials of small-cell lung cancer. J Clin Oncol. 1992;10(8):1369-70. Notes: NPD. [pmid: 1321895].
Kotalik J, Yu E, Markman BR, et al. Practice guideline on prophylactic cranial irradiation in small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2001;50(2):309-16. Notes: NPD. [pmid: 11380216].
Kraft A, Arnold H, Zwingers T, et al. Role of thoracic radiotherapy combined with chemotherapy in limited stage small cell lung cancer (SCLC). A randomized multicenter phase III trial. Onkologie. 1990;13(4):253-8. Notes: NRQ. [pmid: 2172884].
Kris MG. Lung cancer cure, care, and cost: let the data be your guide. J Clin Oncol. 1997;15(9):3027-9. Notes: NPD; but maybe cite in write-up. [pmid: 9294464].
Kristjansen PE. Should current management of small cell lung cancer include prophylactic cranial irradiation?. Lung Cancer. 1994;10(Suppl 1):S319-29. Notes: NPD; but maybe cite in write-up. [pmid: 8087526].
Kristjansen PE, Hansen HH. Prophylactic cranial irradiation in small cell lung cancer--an update. Lung Cancer. 1995;12(Suppl 3):S23-40. Notes: NRA. [pmid: 7551954].
Kristjansen PE, Kristensen CA. The role of prophylactic cranial irradiation in the management of small cell lung cancer. Cancer Treat Rev. 1993;19(1):3-16. Notes: NRA. [pmid: 8381714].
Kristjansen PE, Soelberg Sorensen P, Skov Hansen M, Hansen HH. Prospective evaluation of the effect on initial brain metastases from small cell lung cancer of platinum-etoposide based induction chemotherapy followed by an alternating multidrug regimen. Ann Oncol. 1993;4(7):579-83. Notes: NRQ. [pmid: 8395873].
Krug LM, Miller VA. Introduction: Small cell lung cancer - A frustrating disease. Semin Oncol 2003;30:1–2. Notes: NPD
Kudoh S, Fujiwara Y, Takada Y, et al. Phase II study of irinotecan combined with cisplatin in patients with previously untreated small-cell lung cancer. West Japan Lung Cancer Group. J Clin Oncol. 1998;16(3):1068-74. Notes: NSD. [pmid: 9508192].
Kudoh S, Sawa T, Kurihara N, et al. Phase II study of recombinant human interleukin 3 administration following carboplatin and etoposide chemotherapy in small-cell lung cancer patients. SDZ ILE 964 (IL-3) Study. Cancer Chemother Pharmacol. 1996;38(Suppl):S89-95. Notes: NRQ. [pmid: 8765425].
Kumagai M, Kutsuzawa T, Fuyuno G, Kondo T, Shioya S, Ohta Y. Comparison of carboplatin/etoposide/vincristine with cisplatin/etoposide as combination chemotherapy for small cell lung cancer. Tokai J Exp Clin Med. 1995;20(46):209-14. Notes: NRQ. [pmid: 8956462].
Kwiatkowski DJ, Propert KJ, Carey RW, et al. A phase II trial of cyclophosphamide, etoposide, and cisplatin with combined chest and brain radiotherapy in limited small-cell lung cancer: a Cancer and Leukemia Group B Study. J Clin Oncol. 1987;5(12):1874-9. Notes: NSD. [pmid: 2824709].
Lacroix H, Sculier JP. [Chemotherapy in non-small cell bronchial carcinoma. 12 years' experience in an international cooperative group: EORTC Lung Cancer Working Party]. Bull Cancer. 1990;77(10):997-1005. Notes: NSP NRD (NSCLC). [pmid: 2174277].
Langer CJ. Cognitive dysfunction in small-cell lung cancer: Myth or reality?. J Support Oncol. 2004;2(2):138-40. Notes: NPD.
Lassen U. FDG-PET imaging in small cell lung cancer: any value?. Lung Cancer. 2002;37(1):7. Notes: NPD; exclude, but maybe cite in write-up. [pmid: 12057860].
Lassen U, Kristjansen PE, Osterlind K, et al. Superiority of cisplatin or carboplatin in combination with teniposide and vincristine in the induction chemotherapy of small-cell lung cancer. A randomized trial with 5 years follow up. Ann Oncol. 1996;7(4):365-71. Notes: NRQ. [pmid: 8805928].
Lassen U, Osterlind K, Hansen M, et al. Long-term survival in small-cell lung cancer: posttreatment characteristics in patients surviving 5 to 18+ years--an analysis of 1,714 consecutive patients. J Clin Oncol. 1995;13(5):1215-20. Notes: NRQ. [pmid: 7738624].
Laukkanen E, Klonoff H, Allan B, et al. The role of prophylactic brain irradiation in limited stage small cell lung cancer: clinical, neuropsychologic, and CT sequelae. Int J Radiat Oncol Biol Phys. 1988;14(6):1109-17. Notes: NSD. [pmid: 2838443].
Laurie SA, Logan D, Markman BR, et al. Practice guideline for the role of combination chemotherapy in the initial management of limited-stage small-cell lung cancer. Lung Cancer. 2004;43(2):223-40. Notes: NPD. [pmid: 14739044].
Le Cesne A, Le Chevalier T, Arriagada R. Dealing with initial chemotherapy doses: a new basis for treatment optimisation in limited small-cell lung cancer. Ann Oncol. 1995;6(Suppl 3):S53-6. Notes: NRA. [pmid: 8616117].
Le Chevalier T, Arriagada R. Small cell lung cancer and prophylactic cranial irradiation (PCI): perhaps the question is not who needs PCI but who wants PCI?. Eur J Cancer. 1997;33(11):1717-9. Notes: NPD. [pmid: 9470823].
Le Chevalier T, Arriagada R, Baldeyrou P, et al. [Alternating chemotherapy and radiotherapy in the induction treatment of small cell bronchial carcinoma (forms limited to the thorax)]. Presse Med. 1985;14(21):1181-8. Notes: NRQ. [pmid: 2987902].
Le Chevalier T, Arriagada R, Tubiana M. Combined chemotherapy and radiotherapy in small-cell lung cancer. Cancer Treat Res. 1991;58:139-53. Notes: NRA. [pmid: 1683783].
Le CT, Le CA, Arriagada R. Dealing with initial chemotherapy doses: A new basis for treatment optimization in limited small-cell lung cancer. Bull Cancer 1995 82:24S-8S. Notes: NRA exclude,
Le Pechoux C, Arriagada R. Prophylactic cranial irradiation in small cell lung cancer. Hematol Oncol Clin North Am. 2004;18(2):355-72. Notes: NPD; exclude but cite in write-up. [pmid: 15094176].
Lebeau B. [Global approach to the treatment of small cell bronchial cancers]. Bull Cancer. 1987;74(5):555-8. Notes: NRQ. [pmid: 2825856].
Lebeau B, Chastang C, Brechot JM, et al. Subcutaneous heparin treatment increases survival in small cell lung cancer. “Petites Cellules” Group. Cancer. 1994;74(1):38-45. Notes: NRQ. [pmid: 8004580].
Lebeau B, Chastang C, Schuller MP, et al. [Chemotherapy of small cell bronchial cancers. Prognostic importance of complete response (1,280 patients). Groupe Petites Cellules]. Presse Med. 1995;24(4):217-21. Notes: NRQ. [pmid: 7899367].
Lee JS, Umsawasdi T, Barkley HT Jr, et al. Timing of elective brain irradiation: a critical factor for brain metastasis-free survival in small cell lung cancer. Int J Radiat Oncol Biol Phys. 1987;13(5):697-704. Notes: NSD. [pmid: 3032878].
Lee SH, Ahn YC, Kim HJ, et al. Early concurrent chemoradiotherapy with prolonged oral etoposide and cisplatin for limited-stage small-cell lung cancer. Jpn J Clin Oncol. 2003;33(12):620-5. Notes: NRQ. [pmid: 14769839].
Leon F, Pastorino U. Surgery in small-cell lung carcinoma. Where is the rationale?. Semin Surg Oncol. 2003;21(3):176-81. Notes: NRA. [pmid: 14508850].
Levitan N, Dowlati A, Shina D, et al. Multi-institutional phase I/II trial of paclitaxel, cisplatin, and etoposide with concurrent radiation for limited-stage small-cell lung carcinoma. J Clin Oncol. 2000;18(5):1102-9. Notes: NSD. [pmid: 10694563].
Lewinski T, Zulawski M, Meder J, et al. [Elective (prophylactic) brain irradiation in small cell lung cancer patients treated with chemotherapy combined with surgery]. Nowotwory. 1990;40(4):254-9. Notes: NSD. [pmid: 2177554].
Lexer G, Weitensfelder W, Haiderer O, et al. [Long-term survival following pneumonectomy, chemotherapy and radiotherapy in central small cell bronchial cancer]. Prax Klin Pneumol. Jul. 1988;42(7):588-9. Notes: FEW. [pmid: 2847136].
Liengswangwong V, Bonner JA, Shaw EG, et al. Limited-stage small-cell lung cancer: patterns of intrathoracic recurrence and the implications for thoracic radiotherapy. J Clin Oncol. 1994;12(3):496-502. Notes: SCS NSD (retrospective). [pmid: 8120547].
Liengswangwong V, Bonner JA, Shaw EG, et al. Prophylactic cranial irradiation in limited-stage small cell lung cancer. Cancer. 1995;75(6):1302-9. Notes: NSD. [pmid: 7882280].
Liu X, Li X, Pang Y, et al. The results of treatment in 100 patients with limited-stage small cell lung cancer. Cancer. 1993;71(2):326-31. Notes: NSD. [pmid: 8380751].
Livingston RB. Concurrent is the key: combined modality small-cell lung cancer. J Clin Oncol. 1998;16(4):1631. Notes: NPD; exclude, but maybe cite in write-up. [pmid: 9552077].
Livingston RB, Schulman S, Mira JG, et al. Combined alkylators and multiple-site irradiation for extensive small cell lung cancer: a Southwest Oncology Group Study. Cancer Treat Rep. 1986;70(12):1395-401. Notes: NSD. [pmid: 3024826].
Loehrer PJ Sr. Palliative therapy: extensive small cell lung cancer. Semin Oncol. 1995;22(2 Suppl 3):40-4. Notes: NRA. [pmid: 7537903].
Loehrer PJ Sr, Ansari R, Gonin R, et al. Cisplatin plus etoposide with and without ifosfamide in extensive small-cell lung cancer: a Hoosier Oncology Group study. J Clin Oncol. 1995;13(10):2594-9. Notes: NRQ. [pmid: 7595712].
Lokich JJ. Teniposide (VM-26) as a single drug treatment for patients with extensive small cell lung carcinoma: a Phase II study of the Southwest Oncology Group. Cancer. 1998;82(5):993. Notes: NPD. [pmid: 9486592].
Lorigan P, Lee SM, Betticher D, et al. Chemotherapy with vincristine/ifosfamide/carboplatin/etoposide in small cell lung cancer. Semin Oncol. 1995;22(3 Suppl 7):32-41. Notes: NRA. [pmid: 7610397].
Luce S, Paesmans M, Berghmans T, et al. [Critical review of the randomized trials assessing the role of adjuvant thoracic irradiation and chemotherapy in the treatment of limited-stage small cell lung cancer]. Rev Mal Respir. Oct. 1998;15(5):633-41. Notes: NPD; meta-analysis of TRTX versus no TRTx. [pmid: 9834991].
Macchiarini P, Hardin M, Basolo F, et al. Surgery plus adjuvant chemotherapy for T1-3N0M0 small-cell lung cancer. Rationale for current approach. Am J Clin Oncol. 1991;14(3):218-24. Notes: SCS. [pmid: 1851603].
Mackayn HJ, O'Brien M, Hill S, et al. A phase II study of carboplatin and vinorelbine in patients with poor prognosis small cell lung cancer. Clin Oncol (R Coll Radiol). 2003;15(4):181-5. Notes: NRQ. [pmid: 12846495].
Maddisonn P, Newsom-Davis J, Mills KR, et al. Favourable prognosis in Lambert-Eaton myasthenic syndrome and small-cell lung carcinoma. Lancet. Jan 9. 1999;353(9147):117-8. Notes: NRQ.
Mah K, Keane TJ, Van Dyk, et al. Quantitative effect of combined chemotherapy and fractionated radiotherapy on the incidence of radiation-induced lung damage: a prospective clinical study. Int J Radiat Oncol Biol Phys. 1994;28(3):563-74. Notes: FEW. [pmid: 7509329].
Maksymiuk AW, Jett JR, Earle JD, et al. Sequencing and schedule effects of cisplatin plus etoposide in small-cell lung cancer: results of a North Central Cancer Treatment Group randomized clinical trial. J Clin Oncol. 1994;12(1):70-6. Notes: NRQ. [pmid: 8270988].
Manegold C, Drings P. [Drug therapy in bronchial carcinoma]. Schweiz Med Wochenschr. 1995;125(29):1396-405. Notes: NPD. [pmid: 7545824].
Manzoor A, Kharadi MY, Mushtaq A. Role of prophylactic cranial irradiation in small cell lung cancer. JK Pract. 2002;9(2):96-100. Notes: NRA.
Maranzano E, Crino L, Piro F, et al. Long-term results of induction chemotherapy followed by concurrent chemotherapy and thoracic irradiation in limited small cell lung cancer. Lung Cancer. 2002;37(1):79-85. Notes: NSD. [pmid: 12057871].
Mascaux C, Paesmans M, Berghmans T, et al. A systematic review of the role of etoposide and cisplatin in the chemotherapy of small cell lung cancer with methodology assessment and meta-analysis. Lung Cancer. 2000;30(1):23-36. Notes: NPD; exclude, but maybe cite in write-up. [pmid: 11008007].
Masuda N, Fukuoka M, Furuse K. CODE chemotherapy with or without recombinant human granulocyte colony-stimulating factor in extensive-stage small cell lung cancer. Oncology. 1992;49(Suppl 1):19-24. Notes: NSD. [pmid: 1380148].
Mattson K, Niiranen A, Ruotsalainen T, et al. Interferon maintenance therapy for small cell lung cancer: improvement in long-term survival. J Interferon Cytokine Res. 1997;17(2):103-5. Notes: NRQ. [pmid: 9058316].
Mavroudis D, Papadakis E, Veslemes M, et al. A multicenter randomized clinical trial comparing paclitaxel-cisplatin-etoposide versus cisplatin-etoposide as first-line treatment in patients with small-cell lung cancer. Ann Oncol. 2001;12(4):463-70. Notes: NRQ. [pmid: 11398877].
Mavroudis D, Pavlakou G, Blazoyiannakis G, et al. Sequential administration of cisplatin-etoposide followed by topotecan in patients with extensive stage small cell lung cancer. A multicenter phase II study. Lung Cancer. 2003;39(1):71-6. Notes: NRQ. [pmid: 12499097].
Mavroudis D, Veslemes M, Kouroussis CH, et al. Cisplatin-etoposide alternating with topotecan in patients with extensive stage small cell lung cancer (SCLC). A multicenter phase II study. Lung Cancer. 2002;38(1):59-63. Notes: NRQ. [pmid: 12367794].
McClay EF, Bogart J, Herndon JE, et al. A phase III trial evaluating the combination of cisplatin, etoposide, and radiation therapy with or without tamoxifen in patients with limited-stage small cell lung cancer: Cancer and leukemia group B study (9235). Am J Clin Oncol Cancer Clin Trials. 2005;28(1):81-90. Notes: NRQ.
McCracken JD, Janaki LM, Crowley JJ, et al. Concurrent chemotherapy/radiotherapy for limited small-cell lung carcinoma: a Southwest Oncology Group Study. J Clin Oncol. 1990;8(5):892-8. Notes: NSD. [pmid: 2159055].
Meert AP, Paesmans M, Berghmans T, et al. Prophylactic cranial irradiation in small cell lung cancer: a systematic review of the literature with meta-analysis. BMC Cancer. 2001;1(1):5. Notes: NPD (SR-MA). [pmid: 11432756]. [pmcid: 34096].
Mennecier B, Jacoulet P, Dubiez A, et al. Concurrent cisplatin/etoposide chemotherapy plus twice daily thoracic radiotherapy in limited stage small cell lung cancer: a phase II study. Lung Cancer. 2000;27(3):137-43. Notes: NSD. [pmid: 10699687].
Messori A, Trippoli S, Tendi E. G-CSF for the prophylaxis of neutropenic fever in patients with small cell lung cancer receiving myelosuppressive antineoplastic chemotherapy: meta-analysis and pharmacoeconomic evaluation. J Clin Pharm Ther. 1996;21(2):57-63. Notes: NRQ. [pmid: 8809640].
Meyers CA, Byrne KS, Komaki R. Cognitive deficits in patients with small cell lung cancer before and after chemotherapy. Lung Cancer. 1995;12(3):231-5. Notes: NSD. [pmid: 7655832].
Micke P, Faldum A, Metz T, et al. Staging small cell lung cancer: Veterans Administration Lung Study Group versus International Association for the Study of Lung Cancer--what limits limited disease?. Lung Cancer. 2002;37(3):271-6. Notes: NRQ. [pmid: 12234695].
Miller KL, Marks LB. Long-term changes in pulmonary function tests after definitive irradiation for lung cancer. Int J Radiat Oncol Biol Phys. 2004;58:1008-9. Notes: NPD NSP. [pmid: 14967463].
Mikhina ZP, Bychkov MB, Motorina LI. [The effectiveness of 2 systems of chemoradiation treatment in inoperable small-cell lung cancer]. Vopr Onkol. 1989;35(2):174-80. Notes: NSD. [pmid: 2538962].
Minami H, Saka H, Sakai S, Yamamoton M, Shimokata K. A phase II study of carboplatin and prolonged administration of oral etoposide in patients with small-cell lung cancer. Acta Oncol. 1997;36(7):765-9. Notes: NRQ. [pmid: 9490098].
Mira JG, Chen TT, Livingston RB, Wilson HE. Outcome of prophylactic and therapeutic cranial irradiation in disseminated small cell lung carcinoma: a Southwest Oncology Group Study. Int J Radiat Oncol Biol Phys. 1988;14(5):861-5. Notes: NSD. [pmid: 2834310].
Mitchell EP, Perry MC, Luikart SD, et al. A phase I/II trial of etoposide and cisplatin in extensive small cell lung cancer: a cancer and leukemia group B study. Lung Cancer. 1996;15(2):215-23. Notes: NSD, NRQ. [pmid: 8882988].
Mizutani Y, Nishio M, Myojin M, et al. [Importance of timing for radiation therapy in limited-stage small cell lung cancer]. Nippon Igaku Hoshasen Gakkai Zasshi. 1996;56(11):726-30. Notes: NSD. [pmid: 8914405].
Mok TS, Wong H, Zee B, et al. A Phase I-II study of sequential administration of topotecan and oral etoposide (toposiomerase I and II inhibitors) in the treatment of patients with small cell lung carcinoma. Cancer. 2002;95(7):1511-9. Notes: NRQ, NSD. [pmid: 12237920].
Montazeri A, Gillis CR, McEwen J. Quality of life in patients with lung cancer: a review of literature from 1970 to 1995. Chest. 1998;113(2):467-81. Notes: NPD; exclude, but maybe cite in write-up. [pmid: 9498968].
Moore TD, Korn EL. Phase II trial design considerations for small-cell lung cancer. J Natl Cancer Inst. 1992;84(3):150-4. Notes: NPD. [pmid: 1311772].
Mornex F, Trillet V, Chauvin F, et al. Hyperfractionated radiotherapy alternating with multidrug chemotherapy in the treatment of limited small cell lung cancer (SCLC). Groupe Lyonnais d'Oncologie Thoracique. Int J Radiat Oncol Biol Phys. 1990;19(1):23-30. Notes: NSD. [pmid: 2166018].
Hauber HP, Bohuslavizki KH, Lund CH, et al. Positron emission tomography in the staging of small-cell lung cancer: a preliminary study. Chest. 2001;119(3):950-4. Notes: FEW. [pmid: 11243980].
Havemann K, Wolf M, Drings P, et al. Experience of a German multicenter study group with ifosfamide in small cell lung cancer. Semin Oncol. 1989;16(1 Suppl 3):9-18. Notes: NRQ. [pmid: 2539648].
Hazukan MB, Turrisi AT 3rd. The evolving role of radiation therapy in the treatment of locally advanced lung cancer. Semin Oncol. 1993;20(2):173-84. Notes: NRA. [pmid: 8386856].
Healey EA, Abner A. Thoracic and cranial radiotherapy for limited-stage small cell lung cancer. Chest. 1995;107(6 Suppl):249S-54S. Notes: NRA. [pmid: 7781402].
Heckmayr M, Gatzemeier U, Hossfeld DK, et al. [Cisplatin-Vepeside versus Endoxan-Vepeside in the treatment of small cell bronchial cancer. A randomized study]. Pneumologie. 1990;44(Suppl 1):256-7. Notes: NRQ. [pmid: 2164193].
Herskovic A, Orton C, Seyedsadr M, et al. Initial experience with a practical hyperfractionated accelerated radiotherapy regimen. Int J Radiat Oncol Biol Phys. 1991;21(5):1275-81. Notes: NSD. [pmid: 1657843].
Herskovic A, Scott C, Demas W, et al. Accelerated hyperfractionation for bronchogenic cancer: Radiation Therapy Oncology Group 9205. Am J Clin Oncol. 2000;23(2):207-12. Notes: NRD. [pmid: 10776986].
Hirsch FR, Osterlind K, Jeppesen N, et al. Superiority of high-dose platinum (cisplatin and carboplatin) compared to carboplatin alone in combination chemotherapy for small-cell lung carcinoma: a prospective randomised trial of 280 consecutive patients. Ann Oncol. 2001;12(5):647-53. Notes: NRQ. [pmid: 11432623].
Hobdy EM, Kraut E, Masters G, et al. A phase II study of topotecan and cyclophosphamide with G-CSF in patients with advanced small cell lung cancer. Cancer Biol Ther. 2004;3(1):89-93. Notes: NRQ, NSP. [pmid: 14726661].
Hollaus PH, Wilfing G, Wurnig PN, et al. Risk factors for the development of postoperative complications after bronchial sleeve resection for malignancy: a univariate and multivariate analysis. Ann Thorac Surg. 2003;75(3):966-72. Notes: NSP. [pmid: 12645725].
Hollen PJ, Gralla RJ, Kris MG, Potanovich LM. Quality of life assessment in individuals with lung cancer: testing the Lung Cancer Symptom Scale (LCSS). Eur J Cancer. 1993;29A(Suppl 1):S51-8. Notes: NRQ. [pmid: 8381294].
Hopwood P, Stephens RJ. Symptoms at presentation for treatment in patients with lung cancer: implications for the evaluation of palliative treatment. The Medical Research Council (MRC) Lung Cancer Working Party. Br J Cancer. 1995;71(3):633-6. Notes: NRQ. [pmid: 7533520].
Hopwood P, Stephens RJ, Machin D. Approaches to the analysis of quality of life data: experiences gained from a medical research council lung cancer working party palliative chemotherapy trial. Qual Life Res. 1994;3(5):339-52. Notes: NRQ. [pmid: 7531054].
Huang Q, Muzitansky A, Mark EJ. Pulmonary neuroendocrine carcinomas: A review of 234 cases and a statistical analysis of 50 cases treated at one institution using asimple clinicopathologic classification. Arch Pathol Lab Med. May. 2002;126(5):545-53. Notes: NRQ NPD. [pmid: 11958659].
Hugli A, Moro D, Mermillod B, et al. Phase II trial of up-front accelerated thoracic radiotherapy combined with chemotherapy and optional up-front prophylactic cranial irradiation in limited small-cell lung cancer. Groupe d'Oncologie Thoracique des Regions Alpines. J Clin Oncol. 2000;18(8):1662-7. Notes: NSD. [pmid: 10764426].
Huisman C, Postmus PE, Giaccone G, et al. Second-line chemotherapy and its evaluation in small cell lung cancer. Cancer Treat Rev. 1999;25(4):199-206. Notes: NRA. [pmid: 10448128].
Huncharek M, McGarry R. A meta-analysis of the timing of chest irradiation in the combined modality treatment of limited-stage small cell lung cancer. Oncologist. 2004;9(6):665-72. Notes: NPD. [pmid: 15561810].
Huttner J, Wiener N, Quadt C, et al. A randomized clinical trial comparing systemic radiotherapy versus chemotherapy versus local radiotherapy in small cell lung cancer. Eur J Cancer Clin Oncol. 1989;25(6):933-7. Notes: NRQ. [pmid: 2546778].
Ichiki M, Gohara R, Rikimaru T, et al. Combination chemotherapy with irinotecan and ifosfamide as second-line treatment of refractory or sensitive relapsed small cell lung cancer: a phase II study. Chemotherapy. 2003;49(4):200-5. Notes: SCS. [pmid: 12886056].
Ichinose Y, Hara N, Ohta M, et al. Comparison between resected and irradiated small cell lung cancer in patients in stages I through IIIa. Ann Thorac Surg. 1992;53(1):95-100. Notes: SCS NSD (retrospective). [pmid: 1309416].
Ihde DC. Small cell lung cancer. State-of-the-art therapy 1994. Chest. 1995;107(6 Suppl):243S-8S. Notes: NRA. [pmid: 7781401].
Iyoda A, Hiroshima K, Baba M, et al. Pulmonary large cell carcinomas with neuroendocrine features are high-grade neuroendocrine tumors. Ann Thorac Surg. Apr. 2002;73(4):1049-54. Notes: NRQ. [pmid: 11996239].
Iyoda A, Hiroshima K, Toyozaki T, et al. Adjuvant chemotherapy for large cell carcinoma with neuroendocrine features. Cancer. Sep 1. 2001;92(5):1108-12. Notes: NRQ. [pmid: 11571722].
Jackson DV Jr. Changing trends in small cell lung cancer. NC Med J. 1986;47(6):297-300. Notes: NRA.
James LE, Gower NH, Rudd RM, et al. A randomised trial of low-dose/high-frequency chemotherapy as palliative treatment of poor-prognosis small-cell lung cancer: a Cancer research Campaign trial. Br J Cancer. 1996;73(12):1563-8. Notes: NRQ. [pmid: 8664131].
Janne PA, Freidlin B, Saxman S, et al. Twenty-five years of clinical research for patients with limited-stage small cell lung carcinoma in North America. Cancer. 2002;95(7):1528-38. Notes: NPD. [pmid: 12237922].
Jassemn J, Karnicka-Mlodkowska H, Drozd-Lula M, et al. [Long-term survival of patients with small cell lung cancer]. Pneumonol Pol. 1989;57(1012):496-503. Notes: NRA. [pmid: 2561613].
Jelinek JS, Redmond J 3rd, Perry JJ, et al. Small cell lung cancer: staging with MR imaging. Radiology. 1990;177(3):837-42. Notes: NRQ. [pmid: 2173844].
Jeremic B, Shibamoto Y, Acimovic L, et al. Carboplatin, etoposide, and accelerated hyperfractionated radiotherapy for elderly patients with limited small cell lung carcinoma: a phase II study. Cancer. 1998;82(5):836-41. Notes: NSD. [pmid: 9486571].
Jett JR, Everson L, Therneau TM, et al. Treatment of limited-stage small-cell lung cancer with cyclophosphamide, doxorubicin, and vincristine with or without etoposide: a randomized trial of the North Central Cancer Treatment Group. J Clin Oncol. 1990;8(1):33-8. Notes: NSD. [pmid: 2153193].
Jett JR, Hatfield AK, Hillman S, et al. Alternating chemotherapy with etoposide plus cisplatin and topotecan plus paclitaxel in patients with untreated, extensive-stage small cell lung carcinoma: a phase II trial of the North Central Cancer Treatment Group. Cancer. 2003;97(10):2498-503. Notes: NRQ. [pmid: 12733149].
Jett JR, Maksymiuk AW, Su JQ, et al. Phase III trial of recombinant interferon gamma in complete responders with small-cell lung cancer. J Clin Oncol. 1994;12(11):2321-6. Notes: NRQ. [pmid: 7964947].
Joel S, O'Byrne K, Penson R, et al. A randomised, concentration-controlled, comparison of standard (5-day) vs. prolonged (15-day) infusions of etoposide phosphate in small-cell lung cancer. Ann Oncol. 1998;9(11):1205-11. Notes: NRQ. [pmid: 9862051].
Johnson BE. Concurrent approaches to combined chemotherapy and chest radiotherapy for the treatment of patients with limited stage small cell lung cancer. Lung Cancer. 1994;10(Suppl 1):S281-7. Notes: NRA NPD. [pmid: 8087521].
Johnson BE. Is more better? Chemotherapy for patients with extensive-stage small-cell lung cancer. J Natl Cancer Inst. Feb 21. 2001;93(4):254-5. Notes: NSP. [pmid: 11181764].
Johnson BE, Becker B, Goff WB 2nd, et al. Neurologic, neuropsychologic, and computed cranial tomography scan abnormalities in 2- to 10-year survivors of small-cell lung cancer. J Clin Oncol. 1985;3(12):1659-67. Notes: FEW. [pmid: 2999346].
Johnson BE, Bridges JD, Sobczeck M, et al. Patients with limited-stage small-cell lung cancer treated with concurrent twice-daily chest radiotherapy and etoposide/cisplatin followed by cyclophosphamide, doxorubicin, and vincristine. J Clin Oncol. 1996;14(3):806-13. Notes: NSD. [pmid: 8622028].
Johnson BE, Fischer T, Fischer B, et al. Phase II study of imatinib in patients with small cell lung cancer. Clin Cancer Res. 2003;9(16 Pt 1):5880-7. Notes: FEW. [pmid: 14676110].
Johnson BE, Glatstein E, Ihde DC. The National Cancer Institute experience with early and late effects of combined modality therapy in small cell lung cancer. Antibiot Chemother. 1988;41:210-2. Notes: NSD. [pmid: 2854442].
Johnson BE, Grayson J, Makuch RW, et al. Ten-year survival of patients with small-cell lung cancer treated with combination chemotherapy with or without irradiation. J Clin Oncol. 1990;8(3):396-401. Notes: NRQ NSD (retrospective). [pmid: 2155310].
Johnson BE, Ihde DC, Bunn PA, et al. Patients with small-cell lung cancer treated with combination chemotherapy with or without irradiation. Data on potential cures chronic toxicities and late relapses after a five- to eleven-year follow-up. Ann Intern Med. 1985;103(3):430-8. Notes: NRQ. [pmid: 2992337].
Johnsonn BE, Kelley MJ. Autocrine growth factors and neuroendocrine markers in the development of small-cell lung cancer. Oncology (Huntingt). 1998;12(1 Suppl 2):11-4. Notes: INV.
Johnson BE, Patronas N, Hayes W, et al. Neurologic, computed cranial tomographic, and magnetic resonance imaging abnormalities in patients with small-cell lung cancer: further follow-up of 6- to 13-year survivors. J Clin Oncol. 1990;8(1):48-56. Notes: NSD. [pmid: 2153196].
Johnson DH, Bass D, Einhorn LH, et al. Combination chemotherapy with or without thoracic radiotherapy in limited-stage small-cell lung cancer: a randomized trial of the Southeastern Cancer Study Group. J Clin Oncol. 1993;11(7):1223-9. Notes: NRQ. [pmid: 8391064].
Johnson DH, Turrisi AT, Chang AY, et al. Alternating chemotherapy and twice-daily thoracic radiotherapy in limited-stage small-cell lung cancer: a pilot study of the Eastern Cooperative Oncology Group. J Clin Oncol. 1993;11(5):879-84. Notes: NSD. [pmid: 8387577].
Johnson E, Lake D, Herndon JE 2nd, Box JW, Lynch TJ, Green MR. Phase II trial of vinorelbine plus doxorubicin in relapsed small-cell lung cancer: CALGB 9332. Am J Clin Oncol. 2004;27(1):19-23. Notes: FEW. [pmid: 14758128].
Johnson JR, Morgan DA, Holland IM. Prophylactic cranial irradiation for small-cell lung cancer: long-term results. Clin Oncol (R Coll Radiol). 1989;1(1):24-7. Notes: NSD. [pmid: 2562085].
Johnson PW, Muers MF, Peake MD, et al. A randomized trial of amifostine as a cytoprotective agent in patients receiving chemotherapy for small cell lung cancer. Br J Cancer. 2001;84(1):19-24. Notes: NRQ. [pmid: 11139307].
Joss RA, Alberto P, Bleher EA, et al. Combined-modality treatment of small-cell lung cancer: randomized comparison of three induction chemotherapies followed by maintenance chemotherapy with or without radiotherapy to the chest. Swiss Group for Clinical Cancer Research (SAKK). Ann Oncol. 1994;5(10):921-8. Notes: NRQ. [pmid: 7696164].
Joss RA, Alberto P, Hurny C, et al. Quality versus quantity of life in the treatment of patients with advanced small-cell lung cancer? A randomized phase III comparison of weekly carboplatin and teniposide versus cisplatin, adriamycin, etoposide alternating with cyclophosphamide, methotrexate, vincristine and lomustine. Swiss Group for Clinical Cancer Research (SAKK). Ann Oncol. 1995;6(1):41-8. Notes: NRQ. [pmid: 7536028].
Joss RA, Bacchi M, Hurny C, et al. Early versus late alternating chemotherapy in small-cell lung cancer. Swiss Group for Clinical Cancer Research (SAKK). Ann Oncol. 1995;6(2):157-66. Notes: NRQ. [pmid: 7786823].
Kaba SE, Kyritsis AP, Hess K, et al. TPDC-FuHu chemotherapy for the treatment of recurrent metastatic brain tumors. J Clin Oncol. 1997;15(3):1063-70. Notes: FEW. [pmid: 9060546].
Kalemkerian GP, Jiroutek M, Ettinger DS, Dorighi JA, Johnson DH, Mabry M. A phase II study of all-trans-retinoic acid plus cisplatin and etoposide in patients with extensive stage small cell lung carcinoma: an Eastern Cooperative Oncology Group Study. Cancer. 1998;83(6):1102-8. Notes: NRQ, NSD. [pmid: 9740074].
Kanard A, Frytak S, Jatoi A. Cognitive dysfunction in patients with small-cell lung cancer: Incidence, causes, and suggestions on management. J Support Oncol. Mar-Apr. 2004;2(2):127-32. discussion 133–5, 138–40. Notes: NRA. [pmid: 15328816].
Karrer K. Surgery in SCLC as first step of multimodality treatment. Anticancer Res. 1994;14(1B):327-31. Notes: NRQ. [pmid: 8166477].
Karrern K, Denck H. Multimodality treatment with surgery in small-cell lung cancer. Int J Clin Pharmacol Res. 1987;7(4):313-28. Notes: NRA. [pmid: 3036724].
Karrer K, Denck H, Drings P, Orel J, Bruno MF. Combination of surgery and chemotherapy for small-cell bronchial carcinoma. Drugs Exp Clin Res. 1986;12(13):191-200. Notes: NRQ. [pmid: 3015543].
Karrer K, Denck H, Karnicka-Mlodkowska H, et al. Surgery for cure followed by combined modality treatment for small cell bronchial carcinoma. ISC Lung Cancer Study Group. Int J Clin Pharmacol Res. 1988;8(6):415-21. Notes: NRQ. [pmid: 2855325].
Karrer K, Denck H, Karnicka-Mlodkowska H, et al. The role of ifosfamide and cyclophosphamide in the multi-modality treatment after surgery for cure for small-cell bronchial carcinomas (SCLC). Med Oncol Tumor Pharmacother. 1989;6(2):143-9. Notes: NRQ. [pmid: 2545979].
Karrer K, Denck H, Karnicka-Mlodkowska H, et al. The importance of surgery as the first step in multimodality treatment of small cell bronchial carcinoma. The ISC Lung Cancer Study Group. Int J Clin Pharmacol Res. 1990;10(5):257-63. Notes: NRQ. [pmid: 1964153].
Karrer K, Shields TW, Denck H, et al. The importance of surgical and multimodality treatment for small cell bronchial carcinoma. J Thorac Cardiovasc Surg. 1989;97(2):168-76. Notes: NRQ. [pmid: 2536867].
Karrer K, Ulsperger E. Surgery for cure followed by chemotherapy in small cell carcinoma of the lung. For the ISC-Lung Cancer Study Group. Acta Oncol. 1995;34(7):899-906. Notes: NRQ. [pmid: 7492378].
Katakami N, Takada M, Negoro S, et al. Dose escalation study of carboplatin with fixed-dose etoposide plus granulocyte-colony stimulating factor in patients with small cell lung carcinoma. A study of the Lung Cancer Study Group of West Japan. Cancer. 1996;77(1):63-70. Notes: NSD, NRQ. [pmid: 8630941].
Kawahara M. [Phase III studies of combined chemotherapy and radiation in locally advanced non-small-cell lung cancer and limited small-cell lung cancer]. Gan To Kagaku Ryoho. 1995;22(3):335-40. Notes: NRA. [pmid: 7880104].
Kelly K, Lovato L, Bunn PA Jr, et al. Cisplatin, etoposide, and paclitaxel with granulocyte colony-stimulating factor in untreated patients with extensive-stage small cell lung cancer: a phase II trial of the Southwest Oncology Group. Clin Cancer Res. 2001;7(8):2325-9. Notes: NRQ. [pmid: 11489808].
Khuri FR, Fossella FV, Lee JS, et al. Phase II trial of recombinant IFN-alpha2a with etoposide/cisplatin induction and interferon/megestrol acetate maintenance in extensive small cell lung cancer. J Interferon Cytokine Res. 1998;18(4):241-5. Notes: NRQ. [pmid: 9568726].
Kies MS, Mira JG, Crowley JJ, et al. Multimodal therapy for limited small-cell lung cancer: a randomized study of induction combination chemotherapy with or without thoracic radiation in complete responders; and with wide-field versus reduced-field radiation in partial responders: a Southwest Oncology Group Study. J Clin Oncol. 1987;5(4):592-600. Notes: NRQ. [pmid: 3031226].
Kirschling RJ, Grill JP, Marks RS, et al. Paclitaxel and G-CSF in previously untreated patients with extensive stage small-cell lung cancer: a phase II study of the North Central Cancer Treatment Group. Am J Clin Oncol. 1999;22(5):517-22. Notes: NRQ. [pmid: 10521070].
Kitase M, Hara M, Katoh K, et al. FDG-PET in patient with clinical T1N0 lung cancer; Determination of nodal status. Jpn J Clin Radiol. 2000;45(1):209-14. Notes: FEW.
Klasa RJ, Murray N, Coldman AJ. Dose-intensity meta-analysis of chemotherapy regimens in small-cell carcinoma of the lung. J Clin Oncol. 1991;9(3):499-508. Notes: NRQ. [pmid: 1847968].
Kobayashi A, Ohno S, Yamasawa H. A clinical assessment of radiation pneumonitis in cases with lung cancer receiving chemoradiotherapy. Jpn J Chest Dis. 2002;61(8):734-42. Notes: NSD, NSP.
Kobayashi K, Hino M, Kurane S, et al. [A comparative randomized phase II study of CDDP, CDDP-carboquone (CQ) and CDDP-etoposide as second-line chemotherapy in small cell lung cancer (SCLC)]. Gan To Kagaku Ryoho. 1989;16(2):207-12. Notes: INV. [pmid: 2537605].
Komaki R, Byhardt RW, Anderson T, et al. What is the lowest effective biologic dose for prophylactic cranial irradiation?. Am J Clin Oncol. 1985;8(6):523-7. Notes: NSD. [pmid: 4083270].
Komaki R, Meyers CA, Shin DM, et al. Evaluation of cognitive function in patients with limited small cell lung cancer prior to and shortly following prophylactic cranial irradiation. Int J Radiat Oncol Biol Phys. 1995;33(1):179-82. Notes: NSD. [pmid: 7642416].
Komaki R, Shin DM, Glisson BS, et al. Interdigitating versus concurrent chemotherapy and radiotherapy for limited small cell lung cancer. Int J Radiat Oncol Biol Phys. 1995;31(4):807-11. Notes: NSD. [pmid: 7860392].
Korn EL, Simon R, Friedman MA, et al. Phase II trials of small-cell lung cancer. J Clin Oncol. 1992;10(8):1369-70. Notes: NPD. [pmid: 1321895].
Kotalik J, Yu E, Markman BR, et al. Practice guideline on prophylactic cranial irradiation in small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2001;50(2):309-16. Notes: NPD. [pmid: 11380216].
Kraft A, Arnold H, Zwingers T, et al. Role of thoracic radiotherapy combined with chemotherapy in limited stage small cell lung cancer (SCLC). A randomized multicenter phase III trial. Onkologie. 1990;13(4):253-8. Notes: NRQ. [pmid: 2172884].
Kris MG. Lung cancer cure, care, and cost: let the data be your guide. J Clin Oncol. 1997;15(9):3027-9. Notes: NPD; but maybe cite in write-up. [pmid: 9294464].
Kristjansen PE. Should current management of small cell lung cancer include prophylactic cranial irradiation?. Lung Cancer. 1994;10(Suppl 1):S319-29. Notes: NPD; but maybe cite in write-up. [pmid: 8087526].
Kristjansen PE, Hansen HH. Prophylactic cranial irradiation in small cell lung cancer--an update. Lung Cancer. 1995;12(Suppl 3):S23-40. Notes: NRA. [pmid: 7551954].
Kristjansen PE, Kristensen CA. The role of prophylactic cranial irradiation in the management of small cell lung cancer. Cancer Treat Rev. 1993;19(1):3-16. Notes: NRA. [pmid: 8381714].
Kristjansen PE, Soelberg Sorensen P, Skov Hansen M, Hansen HH. Prospective evaluation of the effect on initial brain metastases from small cell lung cancer of platinum-etoposide based induction chemotherapy followed by an alternating multidrug regimen. Ann Oncol. 1993;4(7):579-83. Notes: NRQ. [pmid: 8395873].
Krug LM, Miller VA. Introduction: Small cell lung cancer - A frustrating disease. Semin Oncol 2003;30:1–2. Notes: NPD
Kudoh S, Fujiwara Y, Takada Y, et al. Phase II study of irinotecan combined with cisplatin in patients with previously untreated small-cell lung cancer. West Japan Lung Cancer Group. J Clin Oncol. 1998;16(3):1068-74. Notes: NSD. [pmid: 9508192].
Kudoh S, Sawa T, Kurihara N, et al. Phase II study of recombinant human interleukin 3 administration following carboplatin and etoposide chemotherapy in small-cell lung cancer patients. SDZ ILE 964 (IL-3) Study. Cancer Chemother Pharmacol. 1996;38(Suppl):S89-95. Notes: NRQ. [pmid: 8765425].
Kumagai M, Kutsuzawa T, Fuyuno G, Kondo T, Shioya S, Ohta Y. Comparison of carboplatin/etoposide/vincristine with cisplatin/etoposide as combination chemotherapy for small cell lung cancer. Tokai J Exp Clin Med. 1995;20(46):209-14. Notes: NRQ. [pmid: 8956462].
Kwiatkowski DJ, Propert KJ, Carey RW, et al. A phase II trial of cyclophosphamide, etoposide, and cisplatin with combined chest and brain radiotherapy in limited small-cell lung cancer: a Cancer and Leukemia Group B Study. J Clin Oncol. 1987;5(12):1874-9. Notes: NSD. [pmid: 2824709].
Lacroix H, Sculier JP. [Chemotherapy in non-small cell bronchial carcinoma. 12 years' experience in an international cooperative group: EORTC Lung Cancer Working Party]. Bull Cancer. 1990;77(10):997-1005. Notes: NSP NRD (NSCLC). [pmid: 2174277].
Langer CJ. Cognitive dysfunction in small-cell lung cancer: Myth or reality?. J Support Oncol. 2004;2(2):138-40. Notes: NPD.
Lassen U. FDG-PET imaging in small cell lung cancer: any value?. Lung Cancer. 2002;37(1):7. Notes: NPD; exclude, but maybe cite in write-up. [pmid: 12057860].
Lassen U, Kristjansen PE, Osterlind K, et al. Superiority of cisplatin or carboplatin in combination with teniposide and vincristine in the induction chemotherapy of small-cell lung cancer. A randomized trial with 5 years follow up. Ann Oncol. 1996;7(4):365-71. Notes: NRQ. [pmid: 8805928].
Lassen U, Osterlind K, Hansen M, et al. Long-term survival in small-cell lung cancer: posttreatment characteristics in patients surviving 5 to 18+ years--an analysis of 1,714 consecutive patients. J Clin Oncol. 1995;13(5):1215-20. Notes: NRQ. [pmid: 7738624].
Laukkanen E, Klonoff H, Allan B, et al. The role of prophylactic brain irradiation in limited stage small cell lung cancer: clinical, neuropsychologic, and CT sequelae. Int J Radiat Oncol Biol Phys. 1988;14(6):1109-17. Notes: NSD. [pmid: 2838443].
Laurie SA, Logan D, Markman BR, et al. Practice guideline for the role of combination chemotherapy in the initial management of limited-stage small-cell lung cancer. Lung Cancer. 2004;43(2):223-40. Notes: NPD. [pmid: 14739044].
Le Cesne A, Le Chevalier T, Arriagada R. Dealing with initial chemotherapy doses: a new basis for treatment optimisation in limited small-cell lung cancer. Ann Oncol. 1995;6(Suppl 3):S53-6. Notes: NRA. [pmid: 8616117].
Le Chevalier T, Arriagada R. Small cell lung cancer and prophylactic cranial irradiation (PCI): perhaps the question is not who needs PCI but who wants PCI?. Eur J Cancer. 1997;33(11):1717-9. Notes: NPD. [pmid: 9470823].
Le Chevalier T, Arriagada R, Baldeyrou P, et al. [Alternating chemotherapy and radiotherapy in the induction treatment of small cell bronchial carcinoma (forms limited to the thorax)]. Presse Med. 1985;14(21):1181-8. Notes: NRQ. [pmid: 2987902].
Le Chevalier T, Arriagada R, Tubiana M. Combined chemotherapy and radiotherapy in small-cell lung cancer. Cancer Treat Res. 1991;58:139-53. Notes: NRA. [pmid: 1683783].
Le CT, Le CA, Arriagada R. Dealing with initial chemotherapy doses: A new basis for treatment optimization in limited small-cell lung cancer. Bull Cancer 1995 82:24S-8S. Notes: NRA exclude,
Le Pechoux C, Arriagada R. Prophylactic cranial irradiation in small cell lung cancer. Hematol Oncol Clin North Am. 2004;18(2):355-72. Notes: NPD; exclude but cite in write-up. [pmid: 15094176].
Lebeau B. [Global approach to the treatment of small cell bronchial cancers]. Bull Cancer. 1987;74(5):555-8. Notes: NRQ. [pmid: 2825856].
Lebeau B, Chastang C, Brechot JM, et al. Subcutaneous heparin treatment increases survival in small cell lung cancer. “Petites Cellules” Group. Cancer. 1994;74(1):38-45. Notes: NRQ. [pmid: 8004580].
Lebeau B, Chastang C, Schuller MP, et al. [Chemotherapy of small cell bronchial cancers. Prognostic importance of complete response (1,280 patients). Groupe Petites Cellules]. Presse Med. 1995;24(4):217-21. Notes: NRQ. [pmid: 7899367].
Lee JS, Umsawasdi T, Barkley HT Jr, et al. Timing of elective brain irradiation: a critical factor for brain metastasis-free survival in small cell lung cancer. Int J Radiat Oncol Biol Phys. 1987;13(5):697-704. Notes: NSD. [pmid: 3032878].
Lee SH, Ahn YC, Kim HJ, et al. Early concurrent chemoradiotherapy with prolonged oral etoposide and cisplatin for limited-stage small-cell lung cancer. Jpn J Clin Oncol. 2003;33(12):620-5. Notes: NRQ. [pmid: 14769839].
Leon F, Pastorino U. Surgery in small-cell lung carcinoma. Where is the rationale?. Semin Surg Oncol. 2003;21(3):176-81. Notes: NRA. [pmid: 14508850].
Levitan N, Dowlati A, Shina D, et al. Multi-institutional phase I/II trial of paclitaxel, cisplatin, and etoposide with concurrent radiation for limited-stage small-cell lung carcinoma. J Clin Oncol. 2000;18(5):1102-9. Notes: NSD. [pmid: 10694563].
Lewinski T, Zulawski M, Meder J, et al. [Elective (prophylactic) brain irradiation in small cell lung cancer patients treated with chemotherapy combined with surgery]. Nowotwory. 1990;40(4):254-9. Notes: NSD. [pmid: 2177554].
Lexer G, Weitensfelder W, Haiderer O, et al. [Long-term survival following pneumonectomy, chemotherapy and radiotherapy in central small cell bronchial cancer]. Prax Klin Pneumol. Jul. 1988;42(7):588-9. Notes: FEW. [pmid: 2847136].
Liengswangwong V, Bonner JA, Shaw EG, et al. Limited-stage small-cell lung cancer: patterns of intrathoracic recurrence and the implications for thoracic radiotherapy. J Clin Oncol. 1994;12(3):496-502. Notes: SCS NSD (retrospective). [pmid: 8120547].
Liengswangwong V, Bonner JA, Shaw EG, et al. Prophylactic cranial irradiation in limited-stage small cell lung cancer. Cancer. 1995;75(6):1302-9. Notes: NSD. [pmid: 7882280].
Liu X, Li X, Pang Y, et al. The results of treatment in 100 patients with limited-stage small cell lung cancer. Cancer. 1993;71(2):326-31. Notes: NSD. [pmid: 8380751].
Livingston RB. Concurrent is the key: combined modality small-cell lung cancer. J Clin Oncol. 1998;16(4):1631. Notes: NPD; exclude, but maybe cite in write-up. [pmid: 9552077].
Livingston RB, Schulman S, Mira JG, et al. Combined alkylators and multiple-site irradiation for extensive small cell lung cancer: a Southwest Oncology Group Study. Cancer Treat Rep. 1986;70(12):1395-401. Notes: NSD. [pmid: 3024826].
Loehrer PJ Sr. Palliative therapy: extensive small cell lung cancer. Semin Oncol. 1995;22(2 Suppl 3):40-4. Notes: NRA. [pmid: 7537903].
Loehrer PJ Sr, Ansari R, Gonin R, et al. Cisplatin plus etoposide with and without ifosfamide in extensive small-cell lung cancer: a Hoosier Oncology Group study. J Clin Oncol. 1995;13(10):2594-9. Notes: NRQ. [pmid: 7595712].
Lokich JJ. Teniposide (VM-26) as a single drug treatment for patients with extensive small cell lung carcinoma: a Phase II study of the Southwest Oncology Group. Cancer. 1998;82(5):993. Notes: NPD. [pmid: 9486592].
Lorigan P, Lee SM, Betticher D, et al. Chemotherapy with vincristine/ifosfamide/carboplatin/etoposide in small cell lung cancer. Semin Oncol. 1995;22(3 Suppl 7):32-41. Notes: NRA. [pmid: 7610397].
Luce S, Paesmans M, Berghmans T, et al. [Critical review of the randomized trials assessing the role of adjuvant thoracic irradiation and chemotherapy in the treatment of limited-stage small cell lung cancer]. Rev Mal Respir. Oct. 1998;15(5):633-41. Notes: NPD; meta-analysis of TRTX versus no TRTx. [pmid: 9834991].
Macchiarini P, Hardin M, Basolo F, et al. Surgery plus adjuvant chemotherapy for T1–-3N0M0 small-cell lung cancer. Rationale for current approach. Am J Clin Oncol. 1991;14(3):218-24. Notes: SCS. [pmid: 1851603].
Mackayn HJ, O'Brien M, Hill S, et al. A phase II study of carboplatin and vinorelbine in patients with poor prognosis small cell lung cancer. Clin Oncol (R Coll Radiol). 2003;15(4):181-5. Notes: NRQ. [pmid: 12846495].
Maddisonn P, Newsom-Davis J, Mills KR, et al. Favourable prognosis in Lambert-Eaton myasthenic syndrome and small-cell lung carcinoma. Lancet. Jan 9. 1999;353(9147):117-8. Notes: NRQ.
Mah K, Keane TJ, Van Dyk, et al. Quantitative effect of combined chemotherapy and fractionated radiotherapy on the incidence of radiation-induced lung damage: a prospective clinical study. Int J Radiat Oncol Biol Phys. 1994;28(3):563-74. Notes: FEW. [pmid: 7509329].
Maksymiuk AW, Jett JR, Earle JD, et al. Sequencing and schedule effects of cisplatin plus etoposide in small-cell lung cancer: results of a North Central Cancer Treatment Group randomized clinical trial. J Clin Oncol. 1994;12(1):70-6. Notes: NRQ. [pmid: 8270988].
Manegold C, Drings P. [Drug therapy in bronchial carcinoma]. Schweiz Med Wochenschr. 1995;125(29):1396-405. Notes: NPD. [pmid: 7545824].
Manzoor A, Kharadi MY, Mushtaq A. Role of prophylactic cranial irradiation in small cell lung cancer. JK Pract. 2002;9(2):96-100. Notes: NRA.
Maranzano E, Crino L, Piro F, et al. Long-term results of induction chemotherapy followed by concurrent chemotherapy and thoracic irradiation in limited small cell lung cancer. Lung Cancer. 2002;37(1):79-85. Notes: NSD. [pmid: 12057871].
Mascaux C, Paesmans M, Berghmans T, et al. A systematic review of the role of etoposide and cisplatin in the chemotherapy of small cell lung cancer with methodology assessment and meta-analysis. Lung Cancer. 2000;30(1):23-36. Notes: NPD; exclude, but maybe cite in write-up. [pmid: 11008007].
Masuda N, Fukuoka M, Furuse K. CODE chemotherapy with or without recombinant human granulocyte colony-stimulating factor in extensive-stage small cell lung cancer. Oncology. 1992;49(Suppl 1):19-24. Notes: NSD. [pmid: 1380148].
Mattson K, Niiranen A, Ruotsalainen T, et al. Interferon maintenance therapy for small cell lung cancer: improvement in long-term survival. J Interferon Cytokine Res. 1997;17(2):103-5. Notes: NRQ. [pmid: 9058316].
Mavroudis D, Papadakis E, Veslemes M, et al. A multicenter randomized clinical trial comparing paclitaxel-cisplatin-etoposide versus cisplatin-etoposide as first-line treatment in patients with small-cell lung cancer. Ann Oncol. 2001;12(4):463-70. Notes: NRQ. [pmid: 11398877].
Mavroudis D, Pavlakou G, Blazoyiannakis G, et al. Sequential administration of cisplatin-etoposide followed by topotecan in patients with extensive stage small cell lung cancer. A multicenter phase II study. Lung Cancer. 2003;39(1):71-6. Notes: NRQ. [pmid: 12499097].
Mavroudis D, Veslemes M, Kouroussis CH, et al. Cisplatin-etoposide alternating with topotecan in patients with extensive stage small cell lung cancer (SCLC). A multicenter phase II study. Lung Cancer. 2002;38(1):59-63. Notes: NRQ. [pmid: 12367794].
McClay EF, Bogart J, Herndon JE, et al. A phase III trial evaluating the combination of cisplatin, etoposide, and radiation therapy with or without tamoxifen in patients with limited-stage small cell lung cancer: Cancer and leukemia group B study (9235). Am J Clin Oncol Cancer Clin Trials. 2005;28(1):81-90. Notes: NRQ.
McCracken JD, Janaki LM, Crowley JJ, et al. Concurrent chemotherapy/radiotherapy for limited small-cell lung carcinoma: a Southwest Oncology Group Study. J Clin Oncol. 1990;8(5):892-8. Notes: NSD. [pmid: 2159055].
Meert AP, Paesmans M, Berghmans T, et al. Prophylactic cranial irradiation in small cell lung cancer: a systematic review of the literature with meta-analysis. BMC Cancer. 2001;1(1):5. Notes: NPD (SR-MA). [pmid: 11432756]. [pmcid: 34096].
Mennecier B, Jacoulet P, Dubiez A, et al. Concurrent cisplatin/etoposide chemotherapy plus twice daily thoracic radiotherapy in limited stage small cell lung cancer: a phase II study. Lung Cancer. 2000;27(3):137-43. Notes: NSD. [pmid: 10699687].
Messori A, Trippoli S, Tendi E. G-CSF for the prophylaxis of neutropenic fever in patients with small cell lung cancer receiving myelosuppressive antineoplastic chemotherapy: meta-analysis and pharmacoeconomic evaluation. J Clin Pharm Ther. 1996;21(2):57-63. Notes: NRQ. [pmid: 8809640].
Meyers CA, Byrne KS, Komaki R. Cognitive deficits in patients with small cell lung cancer before and after chemotherapy. Lung Cancer. 1995;12(3):231-5. Notes: NSD. [pmid: 7655832].
Micke P, Faldum A, Metz T, et al. Staging small cell lung cancer: Veterans Administration Lung Study Group versus International Association for the Study of Lung Cancer--what limits limited disease?. Lung Cancer. 2002;37(3):271-6. Notes: NRQ. [pmid: 12234695].
Miller KL, Marks LB. Long-term changes in pulmonary function tests after definitive irradiation for lung cancer. Int J Radiat Oncol Biol Phys. 2004;58:1008-9. Notes: NPD NSP. [pmid: 14967463].
Mikhina ZP, Bychkov MB, Motorina LI. [The effectiveness of 2 systems of chemoradiation treatment in inoperable small-cell lung cancer]. Vopr Onkol. 1989;35(2):174-80. Notes: NSD. [pmid: 2538962].
Minami H, Saka H, Sakai S, Yamamoton M, Shimokata K. A phase II study of carboplatin and prolonged administration of oral etoposide in patients with small-cell lung cancer. Acta Oncol. 1997;36(7):765-9. Notes: NRQ. [pmid: 9490098].
Mira JG, Chen TT, Livingston RB, Wilson HE. Outcome of prophylactic and therapeutic cranial irradiation in disseminated small cell lung carcinoma: a Southwest Oncology Group Study. Int J Radiat Oncol Biol Phys. 1988;14(5):861-5. Notes: NSD. [pmid: 2834310].
Mitchell EP, Perry MC, Luikart SD, et al. A phase I/II trial of etoposide and cisplatin in extensive small cell lung cancer: a cancer and leukemia group B study. Lung Cancer. 1996;15(2):215-23. Notes: NSD, NRQ. [pmid: 8882988].
Mizutani Y, Nishio M, Myojin M, et al. [Importance of timing for radiation therapy in limited-stage small cell lung cancer]. Nippon Igaku Hoshasen Gakkai Zasshi. 1996;56(11):726-30. Notes: NSD. [pmid: 8914405].
Mok TS, Wong H, Zee B, et al. A Phase I-II study of sequential administration of topotecan and oral etoposide (toposiomerase I and II inhibitors) in the treatment of patients with small cell lung carcinoma. Cancer. 2002;95(7):1511-9. Notes: NRQ, NSD. [pmid: 12237920].
Montazeri A, Gillis CR, McEwen J. Quality of life in patients with lung cancer: a review of literature from 1970 to 1995. Chest. 1998;113(2):467-81. Notes: NPD; exclude, but maybe cite in write-up. [pmid: 9498968].
Moore TD, Korn EL. Phase II trial design considerations for small-cell lung cancer. J Natl Cancer Inst. 1992;84(3):150-4. Notes: NPD. [pmid: 1311772].
Mornex F, Trillet V, Chauvin F, et al. Hyperfractionated radiotherapy alternating with multidrug chemotherapy in the treatment of limited small cell lung cancer (SCLC). Groupe Lyonnais d'Oncologie Thoracique. Int J Radiat Oncol Biol Phys. 1990;19(1):23-30. Notes: NSD. [pmid: 2166018].
Movsas B, Moughan J, Komaki R, et al. Radiotherapy patterns of care study in lung carcinoma. J Clin Oncol. 2003;21(24):4553-9. Notes: NRQ. [pmid: 14597743].
Muller LC, Salzer GM, Huber H, et al. Multimodal therapy of small cell lung cancer in TNM stages I through IIIa. Ann Thorac Surg. 1992;54(3):493-7. Notes: SCS PII. [pmid: 1324655].
Murray N. Timing of thoracic irradiation for limited small-cell lung cancer. J Clin Oncol. 1998;16(4):1633-5. Notes: NPD; exclude, but maybe cite in write-up. [pmid: 9552079].
Murray N, Livingston RB, Shepherd FA, et al. Randomized study of CODE versus alternating CAV/EP for extensive-stage small-cell lung cancer: an Intergroup Study of the National Cancer Institute of Canada Clinical Trials Group and the Southwest Oncology Group. J Clin Oncol. 1999;17(8):2300-8. Notes: NRQ. [pmid: 10561291].
Murray N, Shah A, Osoba D, et al. Intensive weekly chemotherapy for the treatment of extensive-stage small-cell lung cancer. J Clin Oncol. 1991;9(9):1632-8. Notes: NRQ. [pmid: 1651995].
Naka N, Kawahara M, Okishio K, et al. Phase II study of weekly irinotecan and carboplatin for refractory or relapsed small-cell lung cancer. Lung Cancer. 2002;37(3):319-23. Notes: SCS. [pmid: 12234702].
Nakanishi Y, Kawarada Y, Hirose N, et al. Phase II trial of combination chemotherapy with cisplatin, carboplatin and etoposide in stage IIIB and IV small-cell lung cancer. Fukuoka Lung Cancer Study Group. Cancer Chemother Pharmacol. 1998;41(6):453-6. Notes: NRQ. [pmid: 9554588].
Nam YJ, Choi CW, Shin SW, et al. Combination chemotherapy with cyclophosphamide, vincristine, cisplatin and etoposide (COPE) combined with radiotherapy for small cell lung cancer. Korean J Intern Med. 1995;10(1):32-7. Notes: NRQ. [pmid: 7626554].
Naughton MJ, Herndon IJE, Shumaker SA, et al. The health-related quality of life and survival of small-cell lung cancer patients: Results of a companion study to CALGB 9033. Qual Life Res. 2002;11(3):235-48. Notes: NRQ. [pmid: 12074261].
Negoro S, Masuda N, Furuse K, Saijon N, Fukuoka M. Dose-intensive chemotherapy in extensive-stage small-cell lung cancer. Cancer Chemother Pharmacol. 1997;40(Suppl):S70-3. Notes: NRQ. [pmid: 9272138].
Neill HB, Miller AA, Clamon GH, Perry MC, Crawford J, Green MR. A phase II study evaluating the efficacy of carboplatin, etoposide, and paclitaxel with granulocyte colony- stimulating factor in patients with stage IIIB and IV non-small cell lung cancer and extensive small cell lung cancer. Semin Oncol 1997; 24(4 Suppl 12): S12-130-S12-134. Notes: NRQ
Neubauer M, Schwartz J, Caracandas J, et al. Results of a phase II study of weekly paclitaxel plus carboplatin in patients with extensive small-cell lung cancer with Eastern Cooperative Oncology Group Performance Status of 2, or age > or = 70 years. J Clin Oncol. 2004;22(10):1872-7. Notes: NSP NRQ. [pmid: 15143079].
Nichols CR. The role of ifosfamide in germ cell tumors and small cell lung cancer. Semin Oncol. 1995;22(3 Suppl 7):13-7. Notes: NRA. [pmid: 7610394].
Nicolucci A, Grilli R, Alexanian AA, et al. Quality, evolution, and clinical implications of randomized, controlled trials on the treatment of lung cancer. A lost opportunity for meta-analysis. JAMA. 1989;262(15):2101-7. Notes: NRQ, systematic review of quality of RCTs. [pmid: 2677423].
Niiranen A, Holsti P, Salmo M. Treatment of small cell lung cancer. Two-drug versus four-drug chemotherapy and loco-regional irradiation with or without prophylactic cranial irradiation. Acta Oncol. 1989;28(4):501-5. Notes: NRQ. [pmid: 2551355].
Noda K, Nishiwaki Y, Kawahara M, et al. Irinotecan plus cisplatin compared with etoposide plus cisplatin for extensive small-cell lung cancer. N Engl J Med. 2002;346(2):85-91. Notes: NRQ. [pmid: 11784874].
Noel G, Deutch E, Feuvret L, Mazeron JJ. [Prophylactic cranial irradiation is indicated following complete response to induction therapy in small cell lung cancer: results of a multicentre randomized trial.]. Cancer Radiother. 1998;2(3):313-4. Notes: NPD. [pmid: 9749133].
Noell KT, Deland MM, Harwood AR. Re: Prophylactic cranial irradiation for patients with small-cell lung cancer. J Natl Cancer Inst. 1995;87(10):766-7. Notes: NPD. [pmid: 7563157].
Nomori H, Watanabe K, Ohtsuka T, et al. The size of metastatic foci and lymph nodes yielding false-negative and false-positive lymph node staging with positron emission tomography in patients with lung cancer. J Thorac Cardiovasc Surg. 2004;127(4):1087-92. Notes: NSP; exclude. [pmid: 15052206].
Oelmann E, Thomas M, Serve H, et al. Early tandem high-dose ifosfamide, carboplatin, etoposide therapy with stem cell rescue for small-cell lung cancer: brief report on the results of a phase-I/II trial. Oncology. 2002;63(3):248-53. Notes: NRQ, FEW. [pmid: 12381904].
Ohnoshi T, Hiraki S, Fujii M, et al. Mortality and morbidity in two-year disease-free survivors of small cell lung cancer after treatment with combination chemotherapy with or without irradiation. Acta Med Okayama. 1993;47(3):209-14. Notes: SCS. [pmid: 8397470].
Ohnoshi T, Ueoka H, Numata T, et al. [Progress and obstacles in chemotherapy and combined modality treatment of small cell lung cancer]. Nihon Kyobu Shikkan Gakkai Zasshi. 1990;28(2):190-6. Notes: NRQ. [pmid: 2162437].
Okamoto H, Watanabe K, Nishiwaki Y, et al. Phase II study of area under the plasma-concentration-versus-time curve-based carboplatin plus standard-dose intravenous etoposide in elderly patients with small-cell lung cancer. J Clin Oncol. 1999;17(11):3540-5. Notes: NRQ. [pmid: 10550152].
Okawara G, Gagliardi A, Evans WK, et al. The role of thoracic radiotherapy as an adjunct to standard chemotherapy in limited-stage small-cell lung cancer. Curr Oncol. 2000;7(3):162-72. Notes: NPD.
Oldham RK, Greco FH, Einhorn L, et al. Preliminary results of a randomized trial to evaluate the role of radiotherapy in the combined modality therapy of limited stage small cell lung cancer. Proc Am Assoc Cancer Res 1981; 22: C-674 Notes: NRQ, exclude
Oshita F, Kurata T, Kasai T, et al. Prospective evaluation of the feasibility of cisplatin-based chemotherapy for elderly lung cancer patients with normal organ functions. Jpn J Cancer Res. 1995;86(12):1198-202. Notes: NRQ. [pmid: 8636010].
Oshita F, Yamada K, Nomura I, et al. Randomized study of dose or schedule modification of granulocyte colony-stimulating factor in platinum-based chemotherapy for elderly patients with lung cancer. Oncol Rep. 2001;8(4):861-6. Notes: NRQ. [pmid: 11410799].
Osoba D. Intensive chemotherapy for extensive-stage small-cell lung cancer (SCLC). Cancer Invest. 1992;10(2):185-6. Notes: NRQ NPD. [pmid: 1312885].
Osterlindn K, Andersen PK. Prognostic factors in small cell lung cancer: multivariate model based on 778 patients treated with chemotherapy with or without irradiation. Cancer Res. 1986;46(8):4189-94. Notes: NRQ. [pmid: 3015384].
Osterlindn K, Hansen HH. Ways to a better treatment of small cell lung cancer--a commentary. Ann Oncol. 1992;3(1):9-10. Notes: NPD.
Osterlind K, Hansen HH, Dombernowsky P, et al. Determinants of complete remission induction and maintenance in chemotherapy with or without irradiation of small cell lung cancer. Cancer Res. 1987;47(10):2733-6. Notes: NRQ. [pmid: 3032413].
Osterlind K, Hansen HH, Hansen M, et al. Long-term disease-free survival in small-cell carcinoma of the lung: a study of clinical determinants. J Clin Oncol. 1986;4(9):1307-13. Notes: NRQ. [pmid: 3018182].
Paccagnella A, Oniga F, Favaretto A, et al. Elderly patients with small cell lung cancer. Tumori. 2002;88(suppl 1):S145-7. Notes: NPD. [pmid: 11989911].
Pandit N, Gonen M, Krug L, Larson SM. The prognostic value of [18F]FDG-PET imaging in small cell lung cancer. Eur J Nucl Med Mol Imaging. 2003;30(1):78-84. Notes: NSD. [pmid: 12483413].
Payne DG, Murray N, Warde P. [Small cell lung carcinoma: role of thoracic irradiation and its timing in relation to chemotherapy]. Bull Cancer. 1994;81(2):119-28. Notes: NPD. [pmid: 7894117].
Pedersen AG, Kristjansen PE, Hansen HH. Prophylactic cranial irradiation and small cell lung cancer. Cancer Treat Rev. 1988;15(2):85-103. Notes: NRA. [pmid: 2841020].
Peng WX, Sano T, Oyama T, et al. Large cell neuroendocrine carcinoma of the lung: A comparison with large cell carcinoma with neuroendocrine morphology and small cell carcinoma. Lung Cancer. Feb. 2005;47(2):225-33. Notes: NRQ. [pmid: 15639721].
Perez CA, Bauer M, Edelstein S, et al. Impact of tumor control on survival in carcinoma of the lung treated with irradiation. Int J Radiat Oncol Biol Phys. 1986;12(4):539-47. Notes: NRD NSP (NSCLC). [pmid: 3009368].
Perez CA, Pajak TF, Rubin P, et al. Long-term observations of the patterns of failure in patients with unresectable non-oat cell carcinoma of the lung treated with definitive radiotherapy. Report by the Radiation Therapy Oncology Group. Cancer. 1987;59(11):1874-81. Notes: NSP. [pmid: 3032394].
Pignonn JP, Arriagada R. Role of thoracic radiotherapy in limited-stage small-cell lung cancer: quantitative review based on the literature versus meta-analysis based on individual data. J Clin Oncol. 1992;10(11):1819-20. Notes: NPD; but maybe cite in write-up. [pmid: 1328553].
Pignon JP, Arriagada R, Ihde DC, et al. A meta-analysis of thoracic radiotherapy for small-cell lung cancer. N Engl J Med. 1992;327(23):1618-24. Notes: NRQ. [pmid: 1331787].
Pignon JP, Tarayre M, Auquier A, et al. Triangular test and randomized trials: practical problems in a small cell lung cancer trial. Stat Med. 1994;13(1314):1415-21. Notes: NRQ. [pmid: 7973221].
Pirogovn AI, Polotskii BE, Al-Ansari N, et al. [Clinical evaluation of the small-cell and poorly differentiated forms of squamous-cell and glandular lung cancers]. Vopr Onkol. 1989;35(2):154-8. Notes: NRQ. [pmid: 2467441].
Porter D, Boddy A, Thomas H, et al. Etoposide phosphate infusion with therapeutic drug monitoring in combination with carboplatin dosed by area under the curve: a cancer research campaign phase I/II committee study. Semin Oncol. 1996;23(6 Suppl 13):34-44. Notes: NRQ. [pmid: 8996574].
Postmus PE, Kirkpatrick A, Dalesio O, et al. Two carboplatin-containing regimens for small cell lung cancer: preliminary results of a randomized phase II trial. Cancer Treat Rev. 1988;15(Suppl B):41-4. Notes: NRQ. [pmid: 2841023].
Postmus PE, Scagliotti G, Groen HJ, et al. Standard versus alternating non-cross-resistant chemotherapy in extensive small cell lung cancer: an EORTC Phase III trial. Eur J Cancer. 1996;32A(9):1498-503. Notes: NRQ. [pmid: 8911108].
Postmus PE, Smit EF, Berendsen HH, et al. Second-line carboplatin-based chemotherapy for small cell lung cancer: the Groningen experience. Semin Oncol. 1992;19(1 Suppl 2):17-23. Notes: FEWSCS. [pmid: 1329219].
Postmusn PE, Smit EF, Haaxma-Reiche H, et al. Teniposide for brain metastases of small-cell lung cancer: a phase II study. European Organization for Research and Treatment of Cancer Lung Cancer Cooperative Group. J Clin Oncol. 1995;13(3):660-5. Notes: NRQ. [pmid: 7884426].
Pottgen C, Eberhardt W, Stuschke M. Prophylactic cranial irradiation in lung cancer. Curr Treat Options Oncol. 2004;5(1):43-50. Notes: NRA, NPD. [pmid: 14697156].
Prendiville J, Lorigan P, Hicks F, et al. Therapy for small cell lung cancer using carboplatin, ifosfamide, etoposide (without dose reduction), mid-cycle vincristine with thoracic and cranial irradiation. Eur J Cancer. 1994;30A(14):2085-90. Notes: NSD. [pmid: 7857708].
Prior C, Oroszy S, Oberaigner W, et al. Adjunctive interferon-alpha-2c in stage IIIB/IV small-cell lung cancer: a phase III trial. Eur Respir J. 1997;10(2):392-6. Notes: NRQ. [pmid: 9042638].
Proudhom MA, Noel G, Mazeron JJ. [Twice-daily compared with once-daily thoracic radiotherapy in limited small-cell lung cancer treated concurrently with cisplatin and etoposide. Phase III comparison of twice-daily split course irradiation versus once-daily irradiation for patients with limited stage small-cell lung carcinoma]. Cancer Radiother. 2000;4(4):319-20. Notes: NPD. [pmid: 10994398].
Pujol JL, Carestia L, Daures JP. Is there a case for cisplatin in the treatment of small-cell lung cancer? A meta-analysis of randomized trials of a cisplatin-containing regimen versus a regimen without this alkylating agent. Br J Cancer. 2000;83(1):8-15. Notes: NRQ. [pmid: 10883661].
Pujol JL, Daures JP, Riviere A, et al. Etoposide plus cisplatin with or without the combination of 4'-epidoxorubicin plus cyclophosphamide in treatment of extensive small-cell lung cancer: a French Federation of Cancer Institutes multicenter phase III randomized study. J Natl Cancer Inst. 2001;93(4):300-8. Notes: NRQ. [pmid: 11181777].
Pujol JL, Douillard JY, Riviere A, et al. Dose-intensity of a four-drug chemotherapy regimen with or without recombinant human granulocyte-macrophage colony-stimulating factor in extensive-stage small-cell lung cancer: a multicenter randomized phase III study. J Clin Oncol. 1997;15(5):2082-9. Notes: NRQ. [pmid: 9164221].
Puntn CJ, de Jonge MJ, Monfardini S, et al. RFS2000 (9-nitrocamptothecin) in advanced small cell lung cancer, a phase II study of the EORTC New Drug Development Group. Eur J Cancer. 2004;40(9):1332-4. Notes: INV. [pmid: 15177492].
Purohit A, Charloux A, Jung GM, et al. Early alternating chemotherapy and radiotherapy schedule in limited disease stage small cell lung cancer. Eur J Cancer. 1995;31A(9):1434-6. Notes: NSD. [pmid: 7577067].
Quoix E, Breton JL, Daniel C, et al. Etoposide phosphate with carboplatin in the treatment of elderly patients with small-cell lung cancer: a phase II study. Ann Oncol. 2001;12(7):957-62. Notes: NRQ. [pmid: 11521802].
Quoix E, Fraser R, Wolkove N, et al. Small cell lung cancer presenting as a solitary pulmonary nodule. Cancer. 1990;66(3):577-82. Notes: NRQ. [pmid: 2163746].
Raez L, Samuels M, Lilenbaum R. Combined modality therapy for limited-disease Small Cell Lung Cancer. Curr Treat Options Oncol. Jan. 2005;6(1):69-74. Notes: NRA. [pmid: 15610716].
Ramalingam S, Belani CP, Day R, et al. Phase II study of topotecan and paclitaxel for patients with previously untreated extensive stage small-cell lung cancer. Ann Oncol. 2004;15(2):247-51. Notes: NRQ. [pmid: 14760117].
Reck M, Jagos U, Grunwald F, et al. Long-term survival in SCLC after treatment with paclitaxel, carboplatin and etoposide--a phase II study. Lung Cancer. 2003;39(1):63-9. Notes: NRQ. [pmid: 12499096].
Reckn M, von Pawel J, Macha HN, et al. Randomized phase III trial of paclitaxel, etoposide, and carboplatin versus carboplatin, etoposide, and vincristine in patients with small-cell lung cancer. J Natl Cancer Inst. 2003;95(15):1118-27. Notes: NRQ. [pmid: 12902441].
Repetto L, Biganzoli L, Koehne CH, et al. EORTC Cancer in the Elderly Task Force guidelines for the use of colony-stimulating factors in elderly patients with cancer. Eur J Cancer. 2003;39(16):2264-72. Notes: NRQ. [pmid: 14556916].
Reynolds T. Model aims to reduce discrepancy between phase II, phase III trials. J Natl Cancer Inst. 2000;92(19):1554-5, 1556. Notes: NPD. [pmid: 11018083].
Richardson G. Sequential staging systems for small-cell lung cancer. Arch Intern Med. 1994;154(6):699. Notes: NPD. [pmid: 8129504].
Riedeln RF, Crawford J. Small-cell lung cancer: a review of clinical trials. Semin Thorac Cardiovasc Surg. 2003;15(4):448-56. Notes: NRA. [pmid: 14710387].
Ronze S, Noel G, Mazeron JJ. [A randomized clinical trial comparing concurrent and alternating thoracic irradiation for patients with limited small cell lung carcinoma]. Cancer Radiother. 2000;4(4):325-6. Notes: NPD; summary of included trial. [pmid: 10994401].
Rosenstein M, Armstrong J, Kris M, et al. A reappraisal of the role of prophylactic cranial irradiation in limited small cell lung cancer. Int J Radiat Oncol Biol Phys. 1992;24(1):43-8. Notes: SCS, NSD. [pmid: 1324901].
Roszkowski K, Janic G, Jassem J, et al. [Evaluation of the second line of treatment of patients with small cell carcinoma of the lung]. Pneumonol Pol. 1989;57(4):240-8. Notes: FL-PII. [pmid: 2560830].
Rowell NP, Gleeson FV. Steroids, radiotherapy, chemotherapy and stents for superior vena caval obstruction in carcinoma of the bronchus. Cochrane Database Syst Rev 2001;(4): CD001316 Notes: NRQ
Rowland KM Jr, Loprinzi CL, Shaw EG, et al. Randomized double-blind placebo-controlled trial of cisplatin and etoposide plus megestrol acetate/placebo in extensive-stage small-cell lung cancer: a North Central Cancer Treatment Group study. J Clin Oncol. 1996;14(1):135-41. Notes: NRQ. [pmid: 8558188].
Ruffini E, Rena O, Oliaro A, et al. Lung tumors with mixed histologic pattern. Clinico-pathologic characteristics and prognostic significance. Eur J Cardiothorac Surg. Nov. 2002;22(5):701-7. Notes: NSP; but maybe cite in write-up for Q7. [pmid: 12414033].
Ruotsalainen TM, Halme M, Tamminen K, et al. Concomitant chemotherapy and IFN-alpha for small cell lung cancer: a randomized multicenter phase III study. J Interferon Cytokine Res. 1999;19(3):253-9. Notes: NRQ. [pmid: 10213464].
Rushing DA. Phase I/II study of weekly irinotecan and paclitaxel in patients with SCLC. Oncology (Huntingt). 2000;14(7 Suppl 5):63-6. Notes: NSD, FEW. [pmid: 10981293].
Salazar OM. Combined modality treatment of small cell lung cancer. Chest. 1989;96(1 Suppl):74S-8S. Notes: NPD. [pmid: 2544372].
Salzer GM, Muller LC, Huber H. Further evidence of the benefits of surgery in the combined management of small cell lung cancer. Thorac Cardiovasc Surg. 1988;36(3):161. Notes: SCS NSD (retrospective). [pmid: 2850640].
Salzer GM, Prauer H, Muller L, et al. [Long-term results of multimodality therapy of small cell bronchial cancer including surgery]. Langenbecks Arch Chir Suppl Kongressbd 1991;544– 8. Notes: NRQFEW
Samantas E, Kalofonos H, Linardou H, et al. Phase II study of pegylated liposomal doxorubicin: inactive in recurrent small-cell lung cancer. A Hellenic Cooperative Oncology Group Study. Ann Oncol. 2000;11(11):1395-7. Notes: FEW. [pmid: 11142478].
Samantas E, Skarlos DV, Pectasides D, et al. Combination chemotherapy with low doses of weekly Carboplatin and oral Etoposide in poor risk small cell lung cancer. Lung Cancer. 1999;23(2):159-68. Notes: NRQ. [pmid: 10217620].
Sandler AB. Chemotherapy for small cell lung cancer. Semin Oncol. 2003;30(1):9-25. Notes: NRA. [pmid: 12635086].
Santoro A, Parra HS, Bidoli P, et al. A summary of the Milan experience with multimodality therapies in patients with small cell lung cancer: attempts to improve long-term outcome. Semin Oncol. 1995;22(1 Suppl 2):9-14. Notes: SCS. [pmid: 7846540].
Sauer R, Andreas P. [The role of radio-oncology in the treatment of bronchial cancer]. Helv Chir Acta. 1990;56(5):749-62. Notes: NRA. [pmid: 2157688].
Sause WT. What have we accomplished in the management of patients with small cell anaplastic carcinoma of the lung?. Int J Radiat Oncol Biol Phys. 1995;31(4):1019-20. Notes: NPD. [pmid: 7860375].
Sause WT. Combination chemotherapy and radiation therapy in lung cancer. Semin Oncol. 1994;21(3 Suppl 6):72-8. Notes: NRQ. [pmid: 8052877].
Sazon DA, Santiago SM, Soo Hoo, et al. Fluorodeoxyglucose-positron emission tomography in the detection and staging of lung cancer. Am J Respir Crit Care Med. 1996;153(1):417-21. Notes: NSP. [pmid: 8542152].
Schaefer PL, Marks RS, Mahoney MR, et al. Randomized phase II study of daily versus continuous-infusion schedules of topotecan in the treatment of extensive-stage small cell lung cancers. Am J Clin Oncol. 2003;26(3):236-40. Notes: NRQ. [pmid: 12796591].
Schamanek A KK. Importance of surgery in the multimodality treatment for small cell lung cancer (SCLC). adiol Oncol. 1994;28:351-8. Notes: NRQ.
Schedel H, Rohloff R, Huber RM, Duft S, Kantlehner R. [Endoluminal irradiation of tracheobronchial tumors using a high dose rate iridium-192 afterloading device]. Strahlenther Onkol. 1988;164(4):202-7. Notes: NRQ FEW. [pmid: 2834832].
Schiller JH, Adak S, Cella D, et al. Topotecan versus observation after cisplatin plus etoposide in extensive-stage small-cell lung cancer: E7593--a phase III trial of the Eastern Cooperative Oncology Group. J Clin Oncol. 2001;19(8):2114-22. Notes: NRQ. [pmid: 11304763].
Schiller JH, Kim K, Hutson P, et al. Phase II study of topotecan in patients with extensive-stage small-cell carcinoma of the lung: an Eastern Cooperative Oncology Group Trial. J Clin Oncol. 1996;14(8):2345-52. Notes: NRQ, NSD. [pmid: 8708727].
Schirrmeister H, Glatting G, Hetzel J, et al. Prospective evaluation of the clinical value of planar bone scans, SPECT, and (18)F-labeled NaF PET in newly diagnosed lung cancer. J Nucl Med. 2001;42(12):1800-4. Notes: NRQ. [pmid: 11752076].
Schmid RA, Hautmann H, Poellinger B, et al. Staging of recurrent and advanced lung cancer with 18F-FDG PET in a coincidence technique (hybrid PET). Nucl Med Commun. 2003;24(1):37-45. Notes: FEW. [pmid: 12501018].
Schnabel K. [Prophylactic cranial irradiation in small-cell bronchial carcinomas with complete tumor remission]. Strahlenther Onkol. 1995;171(6):363-4. Notes: NPD. [pmid: 7597625].
Schutte J, Niederle N, Alberti W, et al. Sequentially alternating chemotherapy of small-cell lung cancer with etoposide/cisplatinum and adriamycin(4'-epi-adriamycin)/cyclophosphamide/vincristine +/- mediastinalirradiation. rax Klin Pneumol. 1985;39(suppl 1):837-8. Notes: NRQ.
Schutte J, Niederle N, Eberhardt W, et al. [Sequential induction chemotherapy and radiation treatment of inoperable small cell bronchial cancer. Results of a prospective randomized study]. Klin Wochenschr. 1989;67(23):1182-93. Notes: NRA. [pmid: 2558254].
Sculier JP, Feld R, Evans WK, et al. Neurologic disorders in patients with small cell lung cancer. Cancer. 1987;60(9):2275-83. Notes: NRQ. [pmid: 2830955].
Sculier JP, Paesmans M, Bureau G, et al. Randomized trial comparing induction chemotherapy versus induction chemotherapy followed by maintenance chemotherapy in small-cell lung cancer. European Lung Cancer Working Party. J Clin Oncol. 1996;14(8):2337-44. Notes: NRQ. [pmid: 8708726].
Sculier JP, Paesmans M, Lecomte J, et al. A three-arm phase III randomised trial assessing, in patients with extensive-disease small-cell lung cancer, accelerated chemotherapy with support of haematological growth factor or oral antibiotics. Br J Cancer. 2001;85(10):1444-51. Notes: NRQ. [pmid: 11720426].
Sekine I, Nishiwaki Y, Noda K, et al. Randomized phase II study of cisplatin, irinotecan and etoposide combinations administered weekly or every 4 weeks for extensive small-cell lung cancer (JCOG9902-DI). Ann Oncol. 2003;14(5):709-14. Notes: NRQ. [pmid: 12702524].
Serke M, Riedel U, Schonfeld N, et al. [Combined alternating radiochemotherapy in stage III (TNM) (limited disease) small cell bronchial carcinoma: a phase II study with carboplatin/etoposide/vincristine and alternating radiotherapy]. Pneumologie. 1999;53(10):485-92. Notes: NSD. [pmid: 10596551].
Sessa C, Wanders J, Roelvink M, et al. Second-line treatment of small-cell lung cancer with the camptothecin-derivative GI147211: a study of the EORTC Early Clinical Studies Group (ECSG). Ann Oncol. 2000;11(2):207-10. Notes: INV. [pmid: 10761757].
Seydel HG, Creech R, Pagano M, et al. Prophylactic versus no brain irradiation in regional small cell lung carcinoma. Am J Clin Oncol. 1985;8(3):218-23. Notes: NRQ. [pmid: 2996327].
Shah R, Sabanathan S, Richardson J, et al. Results of surgical treatment of stage I and II lung cancer. J Cardiovasc Surg (Torino). 1996;37(2):169-72. Notes: NSD, FEW.
Shaw EG, Frytak S, Eagan RT, et al. Etoposide-cisplatin and thoracic radiation therapy salvage of incomplete responders to a noncisplatin induction regimen for limited and extensive small-cell carcinoma of the lung. Am J Clin Oncol. 1996;19(2):154-8. Notes: SCS. [pmid: 8610640].
Shaw EG, Su JQ, Eagan RT, et al. Prophylactic cranial irradiation in complete responders with small-cell lung cancer: analysis of the Mayo Clinic and North Central Cancer Treatment Group data bases. J Clin Oncol. 1994;12(11):2327-32. Notes: NSD. [pmid: 7964948].
Shepherd FA, Giaccone G, Seymour L, et al. Prospective, randomized, double-blind, placebo-controlled trial of marimastat after response to first-line chemotherapy in patients with small-cell lung cancer: a trial of the National Cancer Institute of Canada-Clinical Trials Group and the European Organization for Research and Treatment of Cancer. J Clin Oncol. 2002;20(22):4434-9. Notes: INV, NRQ. [pmid: 12431965].
Shepherd FA, Ginsberg R, Patterson GA, et al. Is there ever a role for salvage operations in limited small-cell lung cancer. J Thorac Cardiovasc Surg. 1991;101(2):196-200. Notes: SCS. [pmid: 1846927].
Shepherd FA, Ginsberg RJ, Feld R, Evansn WK, Johansen E. Surgical treatment for limited small-cell lung cancer. The University of Toronto Lung Oncology Group experience. J Thorac Cardiovasc Surg. 1991;101(3):385-93. Notes: SCS. [pmid: 1847981].
Simon M, Argiris A, Murren JR. Progress in the therapy of small cell lung cancer. Crit Rev Oncol Hematol. 2004;49(2):119-33. Notes: NRA, NPD. [pmid: 15012973].
Skarlos DV, Dimopoulos AM, Kosmidis P, et al. Docetaxel and gemcitabine combination, as first-line treatment, in patients with extensive disease small-cell lung cancer. A phase II study of the Hellenic Cooperative Oncology Group. Lung Cancer. 2003;41(1):107-11. Notes: NRQ. [pmid: 12826319].
Skarlos DV, Samantas E, Kosmidis P, et al. Randomized comparison of etoposide-cisplatin vs. etoposide-carboplatin and irradiation in small-cell lung cancer. A Hellenic Co-operative Oncology Group study. Ann Oncol. 1994;5(7):601-7. Notes: NRQ. [pmid: 7993835].
Slodkowska J, Radomski P, Remiszewski P, et al. Histologic subtypes of small cell lung carcinoma in postreatment autopsy specimens. Electron J Pathol Histol. 2002;8(1):80-9. Notes: NRQ.
Slotman BJ, Njo KH, de Jonge A, Meyern OW, Karim AB. Consolidative thoracic radiotherapy and prophylactic cranial irradiation in limited disease small cell lung cancer. Lung Cancer. 1993;10(34):199-208. Notes: NSD. [pmid: 8075967].
Smythe WR, Estrera AL, Swisher SG, et al. Surgical resection of non-small cell carcinoma after treatment for small cell carcinoma. Ann Thorac Surg. 2001;71(3):962-6. Notes: NSD. [pmid: 11269481].
Socinski MA, Neubauer MA, Olivares J, et al. Phase II trial of paclitaxel, ifosfamide, and carboplatin in extensive-stage small cell lung cancer. Lung Cancer. 2003;40(1):91-7. Notes: NRQ. [pmid: 12660013].
Sorensen JB. The role of prophylactic brain irradiation in small cell lung cancer treatment. Monaldi Arch Chest Dis. 2003;59(2):128-33. Notes: NRA. [pmid: 14635501].
Soria JC, Johnson BE, Chevalier TL. Imatinib in small cell lung cancer. Lung Cancer. 2003;41(Suppl 1):S49-53. Notes: NRQ. [pmid: 12867062].
Souhami RL. Neuroendocrine phenotype, chemosensitivity and prognosis in adenocarcinoma of the lung. Ann Oncol. 1991;2(5):323-4. Notes: NPD. [pmid: 1659448].
Souhami RL, Spiro SG, Rudd RM, et al. Five-day oral etoposide treatment for advanced small-cell lung cancer: randomized comparison with intravenous chemotherapy. J Natl Cancer Inst. 1997;89(8):577-80. Notes: NRQ. [pmid: 9106647].
Spiron SG, Porter JC. Lung cancer--where are we today? Current advances in staging and nonsurgical treatment. Am J Respir Crit Care Med. 2002;166(9):1166-96. Notes: NRA. [pmid: 12403687].
Spiro SG, Souhami RL, Geddes DM, et al. Duration of chemotherapy in small cell lung cancer: a Cancer Research Campaign trial. Br J Cancer. 1989;59(4):578-83. Notes: NRQ. [pmid: 2540788].
Sportelli G, Loffredo L, Lupi M, et al. A multidisciplinary approach to the treatment of small-cell lung cancer: the role played by surgery. Eur Rev Med Pharmacol Sci. 1999;3(6):261-3. Notes: SCS. [pmid: 11261737].
Steele JP. Gemcitabine/carboplatin versus cisplatin/etoposide for patients with poor-prognosis small cell lung cancer: a phase III randomized trial with quality-of-life evaluation. Semin Oncol. 2001;28(3 Suppl 10):15-8. Notes: NRQ. [pmid: 11510029].
Stephens RJ, Girling DJ, Machin D. Treatment-related deaths in small cell lung cancer trials: can patients at risk be identified? Medical Research Council Lung Cancer Working Party. Lung Cancer. 1994;11(34):259-74. Notes: NRQ. [pmid: 7812703].
Stewardn WP, von Paweln J, Gatzemeier U, et al. Effects of granulocyte-macrophage colony-stimulating factor and dose intensification of V-ICE chemotherapy in small-cell lung cancer: a prospective randomized study of 300 patients. J Clin Oncol. 1998;16(2):642-50. Notes: NRQ. [pmid: 9469353].
Stiess J, Kiricuta IC, Mueller G, Bohndorf W. [Usefulness of prophylactic whole brain irradiation in small-cell bronchial carcinoma]. Strahlenther Onkol. 1995;171(5):284-9. Notes: NSD. [pmid: 7770784].
Stuschke M. [Accelerated hyperfractionated compared with conventional radiotherapy in limited small-cell lung carcinoma, with concurrent chemotherapy]. Strahlenther Onkol. 1999;175(6):296-8. Notes: NPD. [pmid: 10392175].
Sugio K, Ishida T, Kaneko S, et al. Surgically resected lung cancer in young adults. Ann Thorac Surg. 1992;53(1):127-31. Notes: NSP NSD. [pmid: 1309414].
Sugita T, Matsunaga K, Kobayashi H, et al. [Phase II study of a continuous five-day intravenous infusion of cisplatin and etoposide with concurrent chest radiation therapy in limited stage small cell lung cancer]. Gan To Kagaku Ryoho. 1994;21(14):2479-83. Notes: NSD. [pmid: 7944494].
Sundstrom S, Bremnes RM, Kaasa S, et al. Cisplatin and etoposide regimen is superior to cyclophosphamide, epirubicin, and vincristine regimen in small-cell lung cancer: results from a randomized phase III trial with 5 years' follow-up. J Clin Oncol. 2002;20(24):4665-72. Notes: NRQ. [pmid: 12488411].
Szczesny TJ, Szczesna A, Shepherd FA, et al. Surgical treatment of small cell lung cancer. Semin Oncol. 2003;30(1):47-56. Notes: NRA. [pmid: 12635089].
Takigawa N, Fujiwara K, Ueoka H, et al. Fractionated administration of irinotecan and cisplatin for treatment of extensive-disease small-cell lung cancer: a phase II study. Anticancer Res. 2003;23(1B):557-60. Notes: NRQ. [pmid: 12680145].
Tannock IF. Combined modality treatment with radiotherapy and chemotherapy. Radiother Oncol. 1989;16(2):83-101. Notes: NRA. [pmid: 2687956].
Thatcher N, Clark PI, Girling DJ, et al. Comparison of oral etoposide and standard intravenous multidrug chemotherapy for small-cell lung cancer: a stopped multicentre randomised trial. Medical Research Council Lung Cancer Working Party. Lancet. 1996;348(9027):563-6. Notes: NRQ. [pmid: 8774567].
Thatcher N, James RD, Steward WP, et al. Three months' treatment with cyclophosphamide, VP-16-213 followed by methotrexate and thoracic radiotherapy for small cell lung cancer. Cancer. 1985;56(6):1332-6. Notes: NSD. [pmid: 2992736].
Thatcher N, Lorrigan P, Burt P, Stout R. Intensive combined-modality therapy in small cell lung cancer. Semin Oncol. 1994;21(3 Suppl 6):9-22. Notes: NRA. [pmid: 8052879].
The Prophylactic Cranial Irradiation Overview Collaborative Group. Cranial irradiation for preventing brain metastases of small cell lung cancer in patients in complete remission. Cochrane Database Syst Rev 2000; (4):CD002805. Notes: NPD; exclude, but cite and summarize in write-up; systematic review on PCI
Theuer W, Selawry O, Karrer K. The impact of surgery on the multidisciplinary treatment of bronchogenic small cell carcinoma (updated review including ongoing studies). Med Oncol Tumor Pharmacother. 1992;9(3):119-37. Notes: NRQ. [pmid: 1341324].
Thomas CR Jr, Giroux DJ, Janaki LM, et al. Ten-year follow-up of Southwest Oncology Group 8269: a phase II trial of concomitant cisplatin-etoposide and daily thoracic radiotherapy in limited small-cell lung cancer. Lung Cancer. 2001;33(23):213-9. Notes: NRQ. [pmid: 11551416].
Thomas CR Jr, Giroux DJ, Stelzer KJ, et al. Concurrent cisplatin, prolonged oral etoposide, and vincristine plus chest and brain irradiation for limited small cell lung cancer: a phase II study of the Southwest Oncology Group (SWOG-9229). Int J Radiat Oncol Biol Phys. 1998;40(5):1039-47. Notes: NSD. [pmid: 9539558].
Thomas CR Jr, Williams TE, Turrisi AT 3rd. Don't be mis-guided when the data are silent and the editorial misses the mark. J Clin Oncol. 1998;16(4):1631-2. Notes: NPD; exclude, but maybe cite in write-up. [pmid: 9552078].
Thomas JP, Moore T, Kraut EH, et al. A phase II study of CI-980 in previously untreated extensive small cell lung cancer: an Ohio State University phase II research consortium study. Cancer Invest. 2002;20(2):192-8. Notes: NRQ, FEW. [pmid: 11901539].
Thomas P, Castelnau O, Paillotin D, et al. Phase II trial of paclitaxel and carboplatin in metastatic small-cell lung cancer: a Groupe Francais de Pneumo-Cancerologie study. J Clin Oncol. 2001;19(5):1320-5. Notes: NRQ. [pmid: 11230474].
Thomasn P, Rubinstein L. Cancer recurrence after resection: T1 N0 non-small cell lung cancer. Lung Cancer Study Group. Ann Thorac Surg. 1990;49(2):242-6. discussion 246–7. Notes: NSP NRD (NSCLC). [pmid: 2154958].
Tian DL, Liu HX, Zhang L, et al. Surgery for young patients with lung cancer. Lung Cancer. 2003;42(2):215-20. Notes: SCS. [pmid: 14568689].
Tobiasn JS, Spiro SG. Thoracic radiotherapy and chemotherapy for small-cell lung cancer: the discussion continues. J Clin Oncol. 1994;12(3):643-4. Notes: NPD. [pmid: 8120564].
Touranin JM, Jaillon-Abraham C, Coscas Y, et al. Feasibility and preliminary results of intensive chemotherapy and extensive irradiation in selected patients with limited small-cell lung carcinoma--results of three consecutive phase II programs. Acta Oncol. 2000;39(4):501-8. Notes: NSD. [pmid: 11041113].
Trillet-Lenoir V, Mornex F, Chauvin F, et al. Limited disease small cell lung cancer: alternating combination of doxorubicin, etoposide, ifosfamide and hyperfractionated radiotherapy. Final results of a multicentric pilot study for the Groupe Lyonnias d'Oncologie Thoracique (GLOT). Lung Cancer. 1993;10(12):35-45. Notes: NSD. [pmid: 8069602].
Trillet-Lenoir V, Soler P, Arpin D, et al. The limits of chemotherapy dose intensification using granulocyte colony stimulating factor alone in extensive small cell lung cancer. Lung Cancer. 1996;14(23):331-41. Notes: NSD, NRQ. [pmid: 8794414].
Trillet V, Chauvin F, Champel F, et al. [Small cell lung carcinoma. Value of the evaluation of extension for the therapeutic strategy]. Presse Med. 1990;19(14):655-60. Notes: NRQ. [pmid: 2159643].
Tsubota N, Ayabe K, Doi O, et al. Ongoing prospective study of segmentectomy for small lung tumors. Study Group of Extended Segmentectomy for Small Lung Tumor. Ann Thorac Surg. 1998;66(5):1787-90. Notes: NSP. [pmid: 9875790].
Tummarello D, Graziano F, Giordani P, et al. Factors influencing response to second-line treatment with teniposide (VM26) in patients with progressive small cell lung cancer (SCLC). Anticancer Res. 1993;13(4):1055-8. Notes: SCS. [pmid: 8394668].
Tummarello D, Guidi F, Torresi U, et al. Teniposide (VM26) as second-line treatment for small cell lung cancer. Anticancer Res. 1990;10(2A):397-9. Notes: SCS NSD (retrospective). [pmid: 2161198].
Tummarello D, Mari D, Graziano F, et al. A randomized, controlled phase III study of cyclophosphamide, doxorubicin, and vincristine with etoposide (CAV-E) or teniposide (CAV-T), followed by recombinant interferon-alpha maintenance therapy or observation, in small cell lung carcinoma patients with complete responses. Cancer. 1997;80(12):2222-9. Notes: NRQ. [pmid: 9404698].
Turrisi AT. Brain irradiation and systemic chemotherapy for small-cell lung cancer: dangerous liaisons. J Clin Oncol. 1990;8(2):196-9. Notes: NPD. [pmid: 2153762].
Turrisi AT. Considerations on radiotherapy dose intensity for limited small cell lung cancer. Lung Cancer. 1994;10(Suppl 1):S167-73. Notes: NPD NRA. [pmid: 8087507].
Turrisin AT, Sherman CA. The treatment of limited small cell lung cancer: a report of the progress made and future prospects. Eur J Cancer. 2002;38(2):279-91. Notes: NPD, NRA. [pmid: 11803144].
Turrisi AT 3rd. Cisplatin-etoposide based chemoradiation treatment for limited small cell lung cancer: the current situation. Anticancer Res. 1994;14(1B):289-93. Notes: NRA NPD; but maybe cite in write-up. [pmid: 8166469].
Turrisi AT 3rd. Combined platinum etoposide with radiation therapy in limited stage small cell lung cancer: an effective treatment strategy. Lung Cancer. 1995;12(Suppl 3):S41-51. Notes: NRA. [pmid: 7551955].
Turrisi AT 3rd. Innovations in multimodality therapy for lung cancer. Combined modality management of limited small-cell lung cancer. Chest. 1993;103(1 Suppl):56S-9S. Notes: NRA. [pmid: 8380135].
Turrisi AT 3rd. Limited-disease small-cell lung cancer research: sense and nonsense. Int J Radiat Oncol Biol Phys. 2004;59(4):925-7. Notes: NPD; excluded, but cite in write-up. [pmid: 15234025].
Turrisi AT 3rd. Platinum combined with radiation therapy in small cell lung cancer: focusing like a laser beam on crucial issues. Semin Oncol. 1994;21(3 Suppl 6):36-42. Notes: NRA. [pmid: 8052872].
Turrisi AT 3rd, Glover DJ. Thoracic radiotherapy variables: influence on local control in small cell lung cancer limited disease. Int J Radiat Oncol Biol Phys. 1990;19(6):1473-9. Notes: NSD. [pmid: 2175739].
Ueoka H. Prophylactic cranial irradiation is a standard treatment in patients with small-cell lung cancer achieving complete response. Jpn J Lung Cancer. 2002;42(7):805-11. Notes: NRA.
Ueoka H, Kiura K, Tabata M, et al. A randomized trial of hybrid administration of cyclophosphamide, doxorubicin, and vincristine (CAV)/cisplatin and etoposide (PVP) versus sequential administration of CAV-PVP for the treatment of patients with small cell lung carcinoma: results of long term follow-up. Cancer. 1998;83(2):283-90. Notes: NRQ. [pmid: 9669811].
Ulsperger E, Karrer K, Denck H. Multimodality treatment for small cell bronchial carcinoma. Preliminary results of a prospective, multicenter trial. The ISC-Lung Cancer Study Group. Eur J Cardiothorac Surg. 1991;5(6):306-9. discussion 310. Notes: NRQ. [pmid: 1651741].
Urban T, Baleyte T, Chastang CL, et al. Standard combination versus alternating chemotherapy in small cell lung cancer: a randomised clinical trial including 394 patients. ‘Petites Cellules’ Group. Lung Cancer. 1999;25(2):105-13. Notes: NRQ. [pmid: 10470844].
Urban T, Chastang C, Lebas FX, et al. The addition of cisplatin to cyclophosphamide-doxorubicin-etoposide combination chemotherapy in the treatment of patients with small cell lung carcinoma: A randomized study of 457 patients. “Petites Cellules” Group. Cancer. 1999;86(11):2238-45. Notes: NRQ. [pmid: 10590363].
Urtasun RC, Belch A, Bodnar D, et al. Radiation as a non-cross-resistant systemic agent: experience with hemibody and total-body irradiation in patients with small cell lung cancer. Cancer Treat Symp. 1985;2:41-7. Notes: NRA.
van de Poln M, ten Velde GP, Wilmink JT, et al. Efficacy and safety of prophylactic cranial irradiation in patients with small cell lung cancer. J Neurooncol. 1997;35(2):153-60. Notes: NSD. [pmid: 9266453].
van de Velde H, Bosquee L, Weynants P, Canon JL, Rosier JF, Humblet Y. Moderate dose-escalation of combination chemotherapy with concomitant thoracic radiotherapy in limited-disease small-cell lung cancer: prolonged intrathoracic tumor control and high central nervous system relapse rate. Groupe d'Oncologie-Pneumologie Clinique de l'Universite Catholique de Louvain, Brussels and Liege, Belgium. Ann Oncol. 1999;10(9):1051-7. Notes: NSD. [pmid: 10572602].
van der Lindenn YM, van Kempen ML, van der Tweel I, et al. Prophylactic cranial irradiation in limited disease small-cell lung cancer in complete remission: a retrospective analysis. Respir Med. 2001;95(3):235-6. Notes: NSD. [pmid: 11266242].
Van Houtten P, Mornex F. Is concurrent twice-daily thoracic radiotherapy with chemotherapy the reference treatment for small cell lung cancer. Lung Cancer. Mar. 2000;27(3):133-5. Notes: NPD;. [pmid: 10858068].
van Oosterhout AG, Boon PJ, Houx PJ, et al. Follow-up of cognitive functioning in patients with small cell lung cancer. Int J Radiat Oncol Biol Phys. 1995;31(4):911-4. Notes: NSD. [pmid: 7860405].
van Zandwijk N, Groen HJ, Postmus PE, et al. Role of recombinant interferon-gamma maintenance in responding patients with small cell lung cancer. A randomised phase III study of the EORTC Lung Cancer Cooperative Group. Eur J Cancer. 1997;33(11):1759-66. Notes: NRQ. [pmid: 9470829].
Vansteenkiste J, Gatzemeier U, Manegold C, et al. Gemcitabine plus etoposide in chemonaive extensive disease small-cell lung cancer: a multi-centre phase II study. Ann Oncol. 2001;12(6):835-40. Notes: NRQ. [pmid: 11484961].
Vansteenkiste J, Tomita D, Rossi G, et al. Darbepoetin alfa in lung cancer patients on chemotherapy: a retrospective comparison of outcomes in patients with mild versus moderate-to-severe anaemia at baseline. Support Care Cancer. 2004;12(4):253-62. Notes: NRQ. [pmid: 14740283].
Vieitez JM, Valladares M, Gracia M, et al. Phase II study of carboplatin and 1-h intravenous etoposide and paclitaxel in a novel sequence as first-line treatment of patients with small-cell lung cancer. Lung Cancer. 2003;39(1):77-84. Notes: NRQ. [pmid: 12499098].
Vinesn EF, Le Pechoux C, Arriagada R. Prophylactic cranial irradiation in small cell lung cancer. Semin Oncol. 2003;30(1):38-46. Notes: NRA.
Viren M, Liippo K, Ojala A, et al. Carboplatin and etoposide (CarE) combined with radiotherapy and vincristine, doxorubicin and cyclophosphamide (VAC) in limited small cell lung cancer. A phase II study. Acta Oncol. 1992;31(7):761-5. Notes: NSD. [pmid: 1335738].
Vitale V, Scolaro T, Orsatti M. Prophylactic brain irradiation: still an open question (review). Anticancer Res. 1994;14(1B):295-9. Notes: NRA. [pmid: 8166470].
Voinarevich AO. [Metastatic brain lesion in small-cell lung cancer]. Vopr Onkol. 1989;35(2):199-203. Notes: NRA. [pmid: 2538967].
Vokesn EE, Weichselbaum RR. Concomitant chemoradiotherapy: rationale and clinical experience in patients with solid tumors. J Clin Oncol. 1990;8(5):911-34. Notes: NRA. [pmid: 2185342].
von Pawel J, Wilke H, Vallee D, et al. [Phase II study with etoposide/vincristine in small cell bronchial cancer (extensive disease)]. Pneumologie. 1990;44(Suppl 1):582-3. Notes: NRQ. [pmid: 1695002].
Wada H, Tanaka F, Yanagihara K, et al. Time trends and survival after operations for primary lung cancer from 1976 through 1990. J Thorac Cardiovasc Surg. 1996;112(2):349-55. Notes: SCS NSP. [pmid: 8751502].
Waddelln TK, Shepherd FA. Should aggressive surgery ever be part of the management of small cell lung cancer. Thorac Surg Clin. 2004;14(2):271-81. Notes: NPD; review (surgery for very early stage disease); excluded, but cite in write-up. [pmid: 15382303].
Warden P, Payne D. Does thoracic irradiation improve survival and local control in limited-stage small-cell carcinoma of the lung? A meta-analysis. J Clin Oncol. 1992;10(6):890-5. Notes: NRQ; cite in write-up; systematic review and meta-analysis of TRTx versus no TRTx. [pmid: 1316951].
Warren WH, Memoli VA, Jordan AG, et al. Reevaluation of pulmonary neoplasms resected as small cell carcinomas. Significance of distinguishing between well-differentiated and small cell neuroendocrine carcinomas. Cancer. 1990;65(4):1003-10. Notes: NRQ; but maybe cite in write-up. [pmid: 2153433].
Westeel V, Murray N, Gelmon K, et al. New combination of the old drugs for elderly patients with small-cell lung cancer: a phase II study of the PAVE regimen. J Clin Oncol. 1998;16(5):1940-7. Notes: NSD. [pmid: 9586913].
Wetsteinn L, Brenner A. Limited resections for lung cancer. N J Med. 1989;86(3):197-200. Notes: FEW. [pmid: 2539570].
White SC, Lorigan P, Middleton MR, et al. Randomized phase II study of cyclophosphamide, doxorubicin, and vincristine compared with single-agent carboplatin in patients with poor prognosis small cell lung carcinoma. Cancer. 2001;92(3):601-8. Notes: NSP. [pmid: 11505405].
Wiatrn E, Bestry I, Danczak-Ginalskan Z, et al. [The role of radiotherapy in combined treatment of limited small cell lung cancer in relation to results of induction chemotherapy]. Pneumonol Alergol Pol. 1995;63(78):421-6. Notes: NRQ. [pmid: 8520561].
Wick MR, Berg LC, Hertz MI. Large cell carcinoma of the lung with neuroendocrine differentiation. A comparison with large cell “undifferentiated” pulmonary tumors. Am J Clin Pathol. 1992;97(6):796-805. Notes: NRQ; large cell neuroendocrine. [pmid: 1317668].
Williams CJ, McMillan I, Lea R, et al. Surgery after initial chemotherapy for localized small-cell carcinoma of the lung. J Clin Oncol. 1987;5(10):1579-88. Notes: SCS. [pmid: 2821198].
Willkomm P, Bangard M, Guhlke S, et al. Comparison of. Ann Nucl Med. 2002;16(7):503-6. Notes: FEW. [pmid: 12508845].
Wolfn M, Havemann K. Alternating chemotherapy in small cell lung cancer. Onkologie. 1990;13(3):157-64. Notes: NRQ. [pmid: 2168532].
Wolf M, Havemann K, Holle R, Drings P, Hans K, Schroeder M. [Incidence of recurrence and long-term survival in small cell bronchial carcinoma]. Onkologie. 1987;10(6):357-66. Notes: NRQ. [pmid: 2831490].
Woll PJ, Hodgetts J, Lomax L, et al. Can cytotoxic dose-intensity be increased by using granulocyte colony-stimulating factor? A randomized controlled trial of lenograstim in small-cell lung cancer. J Clin Oncol. 1995;13(3):652-9. Notes: NRQ. [pmid: 7533825].
Woo IS, Park YS, Kwon SH, et al. A phase II study of VP-16-fosfamide-cisplatin combination chemotherapy plus early concurrent thoracic irradiation for previously untreated limited small cell lung cancer. Jpn J Clin Oncol. 2000;30(12):542-6. Notes: NSD. [pmid: 11210163].
Wood L, Palmer M, Hewitt J, et al. Results of a phase III, double-blind, placebo-controlled trial of megestrol acetate modulation of P-glycoprotein-mediated drug resistance in the first-line management of small-cell lung carcinoma. Br J Cancer. 1998;77(4):627-31. Notes: NRQ. [pmid: 9484821].
Wu KL, Jiang GL, Qian H, et al. Three-dimensional conformal radiotherapy for locoregionally recurrent lung carcinoma after external beam irradiation: a prospective phase I-II clinical trial. Int J Radiat Oncol Biol Phys. 2003;57(5):1345-50. Notes: FEW. [pmid: 14630272].
Yoshikawa K, Tsubota N, Kodama K, et al. Prospective study of extended segmentectomy for small lung tumors: The final report. Ann Thorac Surg. Apr. 2002;73(4):1055-8. Notes: NSP. [pmid: 11996240].
Zang DY, Lee KH, Lee JS, et al. Phase II trial of a novel platinum analog, SKI 2053R, in patients with previously untreated extensive-stage small-cell lung cancer. Am J Clin Oncol. 1999;22(5):495-8. Notes: NRQ. [pmid: 10521066].
Zarogoulidis K, Ziogas E, Papagiannis A, et al. Interferon alpha-2a and combined chemotherapy as first line treatment in SCLC patients: a randomized trial. Lung Cancer. 1996;15(2):197-205. Notes: NRQ. [pmid: 8882986].
Zatopek NK, Holoye PY, Ellerbroek NA, et al. Resectability of small-cell lung cancer following induction chemotherapy in patients with limited disease (stage II-IIIb). Am J Clin Oncol. 1991;14(5):427-32. Notes: SCS. [pmid: 1659177].
Zhang X. [Surgical treatment for small cell carcinoma of the lung. Report of 102 cases]. Zhonghua Wai Ke Za Zhi 1992; 30(8):492–3, 510. Notes: NRQ NSD
Zvarych IuM, Shevchenko AI. [Intratumoral chemotherapy in the treatment of regional widespread pulmonary cancer]. Klin Khir 2003; (9):32–3. Notes: NRQ