# Appendix C Evidence Tables

Question 1. Alternating, Concurrent and Sequential Radiotherapy

Table 1A Sample Selection

Study | Inclusion | Exclusion | n, Randomized | | | n, Withdrawn | | | n, Evaluated for Primary Outcome
Gregor 1997 | Previously untreated, confirmed SCLC, age < 75, ECOG PS 0–3, limited disease with adequate hematologic and biochemical function | Serious preexisting disease, T1N0M0 disease suitable for resection, bulky mediastinal disease (> 50% of max transverse diameter of thorax on PA X-ray before CTx), pleural effusion obscuring extent of pretreatment disease | Total | Seq | Alt | Total | Seq | Alt | Total | Seq | Alt
EORTC LCCG | | | 349 | 174 | 175 | 14 | 9 | 5 | 335 | 165 | 170
Multiple European institutions, accrual 3/89 through 1/95 | | | | | | (ineligible; 3 incorrect histology, 8 extensive disease, 3 preexisting thrombocytopenia
Lebeau 1999 | Confirmed SCLC; limited stage; no previous RTx, CTx or surgery; ECOG PS 0–3, no history pf previous neoplasm in last 5 yrs | Age > 70; renal, hepatic, respiratory failure, serious cardiac disease | Total | Alt | Conc | Total | Alt | Conc | Total | Alt | Conc
26 French institutions, accrual 5/88 through 5/94 | | | 164 | | | 8 | | | 156 | 74 | 82
| | | | | | (ineligible: 5 extensive disease, 2 NSCLC, 1 inadequate pulmonary function tests)
Takada 2002 | Confirmed SCLS, limited state, measurable/assessable disease, age < 75, ECOG PS ≤ 2, adequate organ function, leukocytes > 4K/mm^3^, hemoglobin > 11 g/dL, platelets > 100K/mm^3^, serum creatinine < 1.5 mg/dL, serum AST/ALT < 2×ULN, serum bilirubin < 2.0 mg/dL, 24 hr creatinine clearance > 60 mL/min/m^2^, arterial oxygen > 70 mmHg. | Malignant pleural effusions or stage I by TNM, symptomatic cardiac disease, history of MI in previous 3 mo | Total | Seq | Conc | Total | Seq | Conc | Total | Seq | Conc
15 Japanese institutions, accrual 5/91 through 1/95 | | | 231 | 117 | 114 | 3 | 3 | 0 | 228 | 114 | 114
| | | | | | (ineligible: 2 extensive disease, 1 malignant lymphoma)
Sun 1995 | Localized disease | Not specified | Total | Seq | Alt | Total | Seq | Conc | Total | Seq | Conc
15 Chinese institutions, accrual 1983 through 1989 | | | | | | | | | 123 | 59 | 64
Work 1997 | confirmed SCLC; age≤70 yr; limited stage (unilateral disease w/wo mediastinal involvement, + ipsilateral supraclavicular nodes, or invasion of trachea or contralateral main bronchus); no prior chemoTx, radioTx; or surgery for 1° tumor; KPS ≥40% | age>70y; extensive stage disease (disease outside one lung, mediastinum and ipselateral supraclav. nodes, or pleural effusion); prior malignancy | Total | L Alt | E Alt | Total | L Alt | E Alt | Total | L Alt | E Alt
Work 1996 | | | 199 | 100 | 99 | 0 | 0 | 0 | 199 | 100 | 99
single-center study
accrual 3/81–9/89
Park 1996 | Diagnosed with limited stage SCLC; age < 80 yrs; ECOG PS ≤ 2; normal liver, hematologic and adrenal function; FEV1 > 1 L; VC > 45% | | Total | Seq | Conc | Total | Seq | Conc | Total | Seq | Conc
Accrual 5/91 – 5/96 | | | 79 | 47 | 32 | | | | 79 | 47 | 32
Korean Center

Table 1B Patient Characteristics

Study | Age | | | | Gender (%) | | | | Race (%) | | | Performance Status | | | Comorbidities or Prognostic Factors
Gregor 1997 | | | [underlined: Seq] | [underlined: Alt] | | | [underlined: Seq] | [underlined: Alt] | | [underlined: Seq] | [underlined: Alt] | [underlined: ECOG] | [underlined: Seq] | [underlined: Alt] | | [underlined: Seq] | [underlined: Alt]
| mn | | | | M | | 67.9 | 65.9 | B | | | 0 | 46.1 | 47.1 | Wt ↓ ≤ 10% | 76.4 | 75.3
| md | | 61 | 61 | F | | 32.1 | 34.1 | W | | | 1 | 47.9 | 44.7 | Wt ↓ ≥ 10% | 9.7 | 11.8
| rng | | 33–75 | 34–74 | | | | | H | | | 2 | 4.2 | 5.9 | NR | 13.9 | 12.9
| sd | | | | | | | | A | | | 3 | 1.8 | 2.4
| | | | | | | | | O
Lebeau 1999 | | | [underlined: Alt] | [underlined: Conc] | | | [underlined: Alt] | [underlined: Conc] | | [underlined: Alt] | [underlined: Conc] | [underlined: ECOG] | [underlined: Alt] | [underlined: Conc] | | [underlined: Alt] | [underlined: Conc]
| mn | | 58 | 57 | M | | 85.1 | 79.3 | B | | | 0 | 50 | 51.2 | Mn vital cap | 86% | 86%
| md | | | | F | | 14.9 | 20.7 | W | | | 1 | 44.6 | 46.3 | Supraclav LN | 12.20% | 8.5%
| rng | | | | | | | | H | | | 2–3 | 4.1 | 2.4
| sd | | | | | | | | A | | | NR | 1.4 | 0
| | | | | | | | | O
Takada 2002 | | | [underlined: Seq] | [underlined: Conc] | | | [underlined: Seq] | [underlined: Conc] | | [underlined: Seq] | [underlined: Conc] | [underlined: ECOG] | [underlined: Seq] | [underlined: Conc] | | [underlined: Seq] | [underlined: Conc]
| mn | | | | M | | 81.6 | 79.8 | B | | | 0 | 28.9 | 21.9 | Wt ↓ < 10% | 89.5 | 91.2
| md | | 64 | 65 | F | | 18.4 | 20.2 | W | | | 1 | 65.8 | 72.8 | Wt ↓ ≥ 10% | 7.0 | 5.3
| rng | | 30–74 | 39–74 | | | | | H | | | 2 | 5.3 | 5.3 | NR | 3.5 | 3.5
| sd | | | | | | | | A | | | | | | Stage II | 8.8 | 6.1
| | | | | | | | | O | | | | | | Stage IIIA | 50.0 | 57.0
| | | | | | | | | | | | | | | Stage IIIB | 41.2 | 36.8
Sun 1995 | | [underlined: All] | [underlined: Seq] | [underlined: Alt] | | [underlined: All] | [underlined: Seq] | [underlined: Alt] | | [underlined: Seq] | [underlined: Alt] | [underlined: ECOG] | [underlined: Seq] | [underlined: Alt] | | [underlined: Seq] | [underlined: Alt]
| mn | | | | M | 72.4 | | | B | | | 0
| md | | | | F | 27.6 | | | W | | | 1
| rng | 29–71 | | | | | | | H | | | 2
| sd | | | | | | | | A | | | 3
| | | | | | | | | O
Work 1997 | | | [underlined: L Alt] | [underlined: E Alt] | | | [underlined: L Alt] | [underlined: E Alt] | | [underlined: L Alt] | [underlined: E Alt] | [underlined: KPS] | [underlined: L Alt] | [underlined: E Alt] | | [underlined: L Alt] | [underlined: E Alt]
Work 1996 | mn | | | | M | | 71 | 55 | B | | | 100 | 10.1 | 13.1
| md | | 59 | 61 | F | | 29 | 45 | W | | | 90-80 | 70.0 | 68.7
| rng | | 36–69 | 36–70 | | | | | H | not reported | | 70-60 | 15.0 | 14.1 | | none reported
| sd | | | | | | | | A | | | 50-40 | 5.0 | 4.0
| | | | | | | | | O
Park 1996 | | | [underlined: Seq] | [underlined: Conc] | | | [underlined: Seq] | [underlined: Conc] | | [underlined: Seq] | [underlined: Conc] | [underlined: ECOG] | [underlined: Seq] | [underlined: Conc] | | [underlined: Seq] | [underlined: Conc]
| | mn | 60.6 | 57.4 | M | | 79.2 | 85.2 | B | | | 0 | 25.0 | 14.8 | Smoking pack-yrs (mn±sd) | 31 | 35
| | md | | | F | | 20.8 | 14.8 | W | | | 1 | 45.8 | 63 | | ±20.6 | ±19.8
| | rng | | | | | | | H | | | 2 | 29.2 | 22.2
| | sd | 8.9 | 8.8 | | | | | A
| | | | | | | | | O

Table 1C Treatments

Study | Chemotherapy regimen, per protocol | | | Control XRT | | Treatment XRT | | PCI
Gregor 1997 | Sequential: | | | Sequential | | Alternating | | Not formal part of treatment, but patients with CR eligible for UKCCCR/ EORTC trial UK02
| [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule]
| cytoxan | 1 g/m^2^ | d 1, wks 1, 4, 7, 10, 13 | 50 Gy | 20 fractions, 1 fraction/d, 5 d/wk, wks 15–18, 1st 15 fractions wider field, last 5 fractions narrower field, > 4 MeV | 50 Gy | 20 fractions, 1 fraction/d, 5 d/wk, wks 7, 11, 15, 19, 1st 15 fractions wider field, last 5 fractions narrower field, > 4 MeV
| doxorubicin | 45 mg/ m^2^ | d 1, wks 1, 4, 7, 10, 13
| etoposide | 100 mg/ m^2^ | d 1, 3, 5, wks 1, 4, 7, 10, 13
| Alternating: same agents, doses, days, wks 1, 5, 9, 13, 17, 19
Lebeau 1999 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Alternating | | Concurrent | | Recommended only if CR induced at dose of 30 Gy in 10 fractions over 16 d using 2 lateral fields
| cytoxan | 1 g/m^2^ | d 1, wks 1, 5, 9, 13, 17, 22 | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule]
| doxorubicin | 45 mg/ m^2^ | d 1, wks 1, 13, 17, 22 | 55 Gy | 1^st^ and 2^nd^ courses: 20 Gy in 8 fractions over 12 d, wks 6–7, 10–11, 3^rd^ course: 15 Gy in 6 fractions over 10 d, wks 14–15, ≥ 8 MeV linac | 50 Gy | 40 Gy 16 fractions over 28 d, then 10 Gy in 4 fractions over 7 d, wks 5–9, ≥ 8 MeV linac
| vindesine | 3 mg/ m^2^ | d 1, wks 5, 9,
| etoposide | 150 mg/ m^2^ | d 1, 2, wks 1, 5, 9, 13, 17, 22
Takada 2002 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Sequential | | Concurrent | | CR or near CR, scar-like shadow on on chest films, no positive cytology and/ or bronchoscopic biopsy, 24 Gy in 16 fractions 2/d, 5/wk
| Sequential | | | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule]
| cisplatin | 80 mg/ m^2^ | d 1, wks 1, 4, 7, 10 | 45 Gy | 30 fractions, 2 fractions/d, 5d/wk, wks 13–15 | 45 Gy | 30 fractions, 2 fractions/d, 5d/wk, wks 1–3
| etoposide | 100 mg/ m^2^ | d 1, 2, 3, wks 1, 4, 7, 10
| Concurrent
| cisplatin | 80 mg/ m^2^ | d 1, wks 1, 5, 9, 13
| etoposide | 100 mg/ m^2^ | d 1, 2, 3, wks 1, 5, 9, 13
Sun 1995 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Sequential | | Alternating | | Not specified
| 1983-1988 | | ea 3 wks, 2–3 cycles | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule]
| cytoxan | 600 mg/m^2^ | d 1, 8 | Local disease | | Local disease
| vincristine | 1 mg/m^2^ | d 1, 8 | 45–60Gy | 6 wks, after 2 cycles of CTx | 45–60Gy | 6 wks, between 2 cylces of CTx
| methotrexate | 20 mg | d 2, 5, 8, 11 | Mediastinum/supraclavicular nodes | | Mediastinum/supraclavicular nodes
| etoposide | 100 mg | d 1–5 | 30–45 Gy | 3–4 wks | 30–45 Gy | 3–4 wks
| 1989 | | ea 2–3 wks, 2–3 cycles
| carboplatin | 300 mg/m^2^ | d 1
| etoposide | 100 mg/ m^2^ | d 1–5
| cytoxan | 600 mg/m^2^ | d 1, 8
| doxorubicin | 40 mg/ m^2^ | d 1,
| cisplatin | 50 mg | d 3–5
Work 1997 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Later Alternating | | Early Alternating | | 33 Gy in 11 fracs, for those in early arm until 10/84; 25 Gy in 11 fracs for all in both arms post 10/84; whole-brain PCI with ^60^Co
Work 1996 | cisplatin | 60 mg/m^2^ | d1; cycles 2, 4, 9 (early) or cycles 1, 2, 8 (late) | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule]
| etoposide | 120 mg/m^2^ | d4, 6, 8; cycles 2, 4, 9 (early) or cycles 1, 2, 8 (late) | 40 Gy n=41; 45 Gy n=59 | wk 18–19 & 23–24 (cycles 7&9); split-course; 1 frac/d, 5 d/wk; 11 frac/course; 20 or 22.5 Gy/course; 8–16 MV photons; chemoTx (dose given between courses; change, 10/84) | 40 Gy n=45; 45 Gy n=54 | wk 1–2 & 6–7 (cycles 1&3); split-course; 1 frac/d, 5 d/ wk; 11 frac/course; 20 or 22.5 Gy/course; 8–16 MV photons; chemoTx given (dose between courses; change, 10/84)
| cytoxan | 1 g/m^2^ | d1; cycles 5–8, 10, 11 (early) or 3–6, 10, 11 (late)
| doxorubicin | 45 mg/m^2^ | d1; same as cytoxan
| vincristine | 1.4 mg/m^2^ | d1; same as cytoxan
Park 1996 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Sequential | | Concurrent | | Only if CR maintained
| cytoxan | 1 g/m^2^ | every 21 d, cycles 1, 3, 5 | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule]
| doxorubicin | 40 mg/m^2^ | every 21 d, cycles 1, 3, 5 | 40–50 Gy | wk 19–24, 1 frac/d, 1.8–2 Gy/frac | 45 Gy | wk 1–3, 2 frac/d, 30 frac 1.5 Gy/frac
| vincristine | 1 mg/m^2^ | every 21 d, cycles 1, 3, 5
| etoposide | 500 ml | every 21 d, cycles 2, 4, 6
| cisplatin | 60 mg/m^2^ | every 21 d, cycles 2, 4, 6
| carboplatin | 324 mg/m^2^ | every 21 d, cycles 2, 4, 6

Table 1D Outcome Assessment

Study | Primary Outcomes | Secondary Outcomes | Response Criteria | Observer | F/U
Gregor 1997 | Overall survival | Time to progression, toxicity, first site of failure | Not specified | Not specified | | [underlined: Total] | [underlined: Seq] | [underlined: Alt]
| | | | | mn
| | | | | md | 43 mo
| | | | | rng
| | | | | sd
Lebeau 1999 | Overall survival | Tumor response, toxicity, toxicity-related mortality | CR= no clinical, radiol, endosc evidence of tumor, ≥1 mo | Not blinded | | [underlined: Total] | [underlined: Alt] | [underlined: Conc]
| | | PR= ↓ by ≥50%, all measureable lesions, ≥1 mo | | mn
| | | SD= ↓ by < 50%, measurable lesions | | md | 66 mo
| | | PD=↑ by >25%, cross sectional area, ≥1 lesion, or any new lesion irrespective of response elsewhere | | rng | ≥ 19 mo or until death
| | | NE= did not receive ≥ 2 courses CTx or refused RTx | | sd
Takada 2002 | Overall survival | Tumor response, progression-free survival, toxicity | WHO criteria | Not specified | | [underlined: Total] | [underlined: Seq] | [underlined: Conc]
| | | | | mn
| | | | | md
| | | | | rng
| | | | | sd
Sun 1995 | Not specified | Not Specified | Not specified | Not specified | | [underlined: Total] | [underlined: Seq] | [underlined: Alt]
| | | | | mn
| | | | | md
| | | | | rng
| | | | | sd
Work 1997 | overall survival | in-field recurrence rate; CNS recurrence rate; response rates; adverse events | WHO criteria | unspecified; blinding not mentioned | | [underlined: Total] | [underlined: L Alt] | [underlined: E Alt]
Work 1996 | no formal power calculation | | | | mn | planned 5 yr post-diagnosis, but actual duration not reported
| | | | | md
| | | | | rng
| | | | | sd
Park 1996 | Not specified | Tumor response, survival, local control, adverse events | CR= no signs of tumor, > 4 wks | Not specified | | [underlined: Total] | [underlined: Seq] | [underlined: Conc]
| | | PR= ↓ by ≥50%, any accountable lesion, no new symptoms, > 4 wks | | mn
| | | SD= ↓ by < 50%, any accountable lesion, > 4 wks | | md
| | | PD= ↑ by >25%, any accountable lesion, > 4 wks | | rng
| | | | | sd

Table 1E Survival Outcomes

Study | Overall Survival | | | | | | | | Progression-Free Survival
Gregor 1997 | | N | Md (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Md (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| Seq | 165 | 15 | 64% | 23% | 15% | ~14% | ~12% | Seq | 165 | 12 | ~50% | ~22% | ~17% | ~15% | ~5%
| Alt | 170 | 14 | 60% | 26% | 12% | ~10% | ~4% | Alt | 170 | 10 | ~43% | ~16% | ~10% | ~8% | ~8%
| (CPHM: RR 0.88, 95% CI 0.68, 1.1, p=0.237; p=0.288, log-rank) | | | | | | | | (Log-rank p=0.07)
Lebeau 1999 | | N | Md (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Md (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| Alt | 74 | 14.0 | 63% | 17% | 11% | 6% | 6% | Alt
| Conc | 82 | 13.5 | 54% | 13% | 6% | 4% | 4% | Conc
| (p=0.15, log-rank, 66 Alt deaths, 77 Conc deaths)
Takada 2002 | | N | Md (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Md (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| Seq | 114 | 19.7 | ~80% | 35.1% | 20.2% | ~20% | 18.3% | Seq | 114 | ~10 | ~38% | ~19% | ~15% | ~14% | ~14%
| Conc | 114 | 27.2 | ~80% | 54.4% | 29.8% | ~25% | 23.7% | Conc | 114 | ~12 | ~50% | ~28% | ~25% | ~20% | ~17%
| (p=0.097 eligible patients, p=0.086 all randomized, log-rank; CPMH: HR 0.70, 95% CI 0.52, 0.94, p=0.02) | | | | | | | | (p=0.084, log-rank))
Sun 1995 | | N | Md (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Md (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| Seq | 59 | | 64.0% | 13.6% | 12.0% | | | Seq
| Alt | 64 | | 62.5% | 28% | 16.0% | | | Alt
Work 1997 | | [underlined: N] | [underlined: Md] (mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr] | PWIFR: | N | [underlined: Md] (mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr]
Work 1996 | L Alt | 100 | 12.0 | ~55% | 18.8% | ~12% | ~12% | 12.0% | L Alt | 100 | ~15 | ~58% | 31.7% | ~27% | ~27% | 27%
| E Alt | 99 | 10.5 | ~43% | 20.2% | ~13% | ~12% | 10.8% | E Alt | 99 | ~9 | ~40% | 27.7% | ~25% | ~23% | 23%
| (p=0.41, not significant)
Park 1996 | | N | Mn (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Md (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| Seq | 47 | 16.0 | 74.4% | 27.7% | 8.8% | 4.4% | 2.2% | Seq
| Conc | 32 | 18.4 | 81.3% | 29.0% | 13.8% | 10.7% | 7.4% | Conc
| (p=0.11)

Table 1F Tumor Response and Quality of Life

Study | Tumor Response | | | | | | | Quality of Life
Gregor 1997 | | N | CR | PR | SD | PD | NE | | | | Seq | Conc | Seq | Conc
| Seq | | | | | | | Scale | Domain | F/U | n | n | mn±sd | mn±sd
| Alt | | | | | | | NOT MEASURED
Lebeau 1999 | | N | CR | PR | SD | PD | NE | | | | Seq | Conc | Seq | Conc
| Alt | 74 | 49% | 46% | | 4% | 1% | Scale | Domain | F/U | n | n | mn±sd | mn±sd
| Conc | 82 | 53% | 37% | | 7% | 3% | NOT MEASURED
| (p=0.26)
Takada 2002 | | N | CR | PR | SD | PD | NE | | | | Seq | Conc | Seq | Conc
| Seq | 114 | 27.2% | 64.9% | 2.6% | 3.5% | 1.8% | Scale | Domain | F/U | n | n | mn±sd | mn±sd
| Conc | 114 | 39.5% | 57.0% | 0.9% | 0.9% | 1.8% | NOT MEASURED
| (CR p=0.07, ORR p=0.25)
Sun 1995 | | N | CR | PR | SD | PD | NE | | | | Seq | Conc | Seq | Conc
| Seq | | | | | | | Scale | Domain | F/U | n | n | mn±sd | mn±sd
| Conc | | | | | | | NOT MEASURED
Work 1997 | | N | CR | PR | SD | PD | NE | Scale | Domain | F/U | Early n | Late n | Early mn+sd | Late mn+sd
Work 1996 | Seq | 100 | 61.2% | 23.5% | 10.2% | 5.1% | | NOT MEASURED
| Conc (NS) | 99 | 59% | 30% | 5% | 6%
Park 1996 | | N | CR | PR | SD | PD | NE | | | | Seq | Conc | Seq | Conc
| Seq | 24 | 13% | 50% | 29% | 4% | 4% | Scale | Domain | F/U | n | n | mn±sd | mn±sd
| Conc | 27 | 30% | 48% | 4% | 11% | 7% | NOT MEASURED
| (response, p=0.13, response duration, mn+sd, Conc 395 d +61.1, Seq 180 d +43.9, p=0.03)

Table 1G Adverse Events

Toxicity Type | Study | Severity or Grade | Group | n | % | Group | n | % | p | Not Reporting
Treatment-related mortality | Lebeau 1999 | Deaths from aplasia | Alt | 74 | 2.7 | Conc | 82 | 3.7 | 0.67 | Gregor 1997; Sun 1995; Work 1997; 1996; Park, 1996
| | Deaths from pulmonary fibrosis | Alt | 74 | 1.4 | Conc | 82 | 7.3 | 0.05
| Takada 2002 | | Seql | 110 | 3.6 | Conc | 112 | 2.7 | 0.72
| Work 1997 | | L Alt | 100 | 0 | E Alt | 99 | 0 | 1
Nausea/Vomiting | Gregor 1997 | Nausea or vomiting, acute (WHO grade) | | | | | | | | Lebeau 1999; Sun 1995; Work 1997; 1996; Park, 1996
| | 0 | Seql | 165 | 25.5 | Alt | 169 | 36.1 | 0.129
| | 1 | | | 21.8 | | | 21.3
| | 2 | | | 37.6 | | | 25.4
| | 3 | | | 13.3 | | | 15.4
| | 4 | | | 0.6 | | | 1.2
| | NR | | | 1.2 | | | 0.6
| Takada 2002 | Nausea or vomiting (WHO grade ≥ 3) | Seql | 110 | 19.1 | Conc | 112 | 10.7 | 0.09
Anorexia | | | | | | | | | | Lebeau 1999; Gregor 1997; Takada 2002; Sun 1995; Work 1997; 1996; Park, 1996
Lethargy | | | | | | | | | | Lebeau 1999; Gregor 1997; Takada 2002; Sun 1995; Work 1997; 1996; Park, 1996
Neurosensory | Work 1997; 1996 | Moderate neurotoxicity (grade ≤ 3) | in 11 (of 199); no difference between groups | | | | | | | Lebeau 1999; Gregor 1997; Takada 2002; Sun 1995; Park, 1996
Hearing loss | | | | | | | | | | Lebeau 1999; Gregor 1997; Takada 2002; Sun 1995; Work 1997; 1996; Park, 1996
Esophagitis | Gregor 1997 | Acute (WHO grade) | | | | | | | | Lebeau 1999; Sun 1995; Work 1997; 1996; Park, 1996
| | 0 | Seql | 165 | 83.0 | Alt | 169 | 75.7 | 0.198
| | 1 | | | 7.9 | | | 11.8
| | 2 | | | 6.1 | | | 9.5
| | 3 | | | 3.0 | | | 3.0
| | Late esophageal stenosis (WHO grade)
| | 0 | Seql | 143 | 82.5 | Alt | 135 | 94.1 | 0.010
| | 1 | | | 11.2 | | | 3.0
| | 2 | | | 2.8 | | | 1.5
| | 3 | | | 2.1 | | | 0.7
| | NR | | | 1.4 | | | 0.7
| Takada 2002 | WHO grade ≥ 3 | Seql | 110 | 3.6 | Conc | 112 | 8.9 | 0.17
Bronchopulmonary | Gregor 1997 | Late Lung fibrosis (RTOG grade) | | | | | | | | Takada 2002; Sun 1995; Work 1997; 1996; Park, 1996
| | 0 | Seql | 143 | 19.6 | Alt | 135 | 11.1 | 0.135
| | 1 | | | 19.6 | | | 20.0
| | 2 | | | 21.7 | | | 27.4
| | 3 | | | 18.2 | | | 14.8
| | 4 | | | 18.9 | | | 24.4
| | NR | | | 2.1 | | | 2.2
| Lebeau 1999 | Pulmonary fibrosis | Alt | 74 | 2.7 | Conc | 82 | 8.5 | 0.17
Pneumonitis | | | | | | | | | | Lebeau 1999; Gregor 1997; Takada 2002; Sun 1995; Work 1997; 1996; Park, 1996
Kidney | Work 1997; 1996 | | quantified by chromium-edathamil clearance; did not differ between groups | | | | | | | Lebeau 1999; Gregor 1997; Takada 2002; Sun 1995
| Park 1996 | ECOG grade 3 | Seql | 24 | 0 | Conc | 27 | 0 | 1.00
| | ECOG grade 4 | | | 0 | | | 0
Anemia | Takada 2002 | WHO grade 3 | Seql | 110 | 41.8 | Conc | 112 | 53.6 | 0.08 | Lebeau 1999; Gregor 1997; Sun 1995; Work 1997; 1996
| Park 1996 | ECOG grade 3 | Seql | 24 | 0 | Conc | 27 | 3.7 | 1.00
| | ECOG grade 4 | | | 0 | | | 0
Thrombocytopenia | Gregor 1997 | Acute (WHO grade) | | | | | | | | Lebeau 1999; Sun 1995;
| | 0 | Seql | 165 | 55.2 | Alt | 169 | 24.9 | <0.001
| | 1 | | | 13.9 | | | 17.2
| | 2 | | | 10.9 | | | 23.1
| | 3 | | | 12.7 | | | 11.8
| | 4 | | | 6.7 | | | 20.7
| | NR | | | 0.6 | | | 2.4
| Takada 2002 | (WHO grade)
| | 3 | Seql | 110 | 12.7 | Conc | 112 | 29.5 | 0.11
| | 4 | | | 13.6 | | | 7.1
| | ≥ 3 | | | 26.4 | | | 36.6
| Work 1997; 1996 | WHO grades 3 & 4 | L Alt | 100 | 13 | E Alt | 99 | 13 | 1.00
| Park 1996 | ECOG grade 3 | Seql | 24 | 0 | Conc | 27 | 0 | 1.00
| | ECOG grade 4 | | | 0 | | | 3.7
Leukopenia or neutropenia | Gregor 1997 | Acute Leukopenia (WHO grade) | | | | | | | | Sun 1995
| | 0 | Seql | 165 | 6.7 | Alt | 169 | 4.1 | <0.001
| | 1 | | | 5.5 | | | 1.2
| | 2 | | | 10.9 | | | 3.6
| | 3 | | | 34.5 | | | 17.8
| | 4 | | | 41.8 | | | 71.6
| | NR | | | 0.6 | | | 1.8
| Lebeau 1999 | Neutropenia (grade 3 or 4) | Alt | 74 | 60.8 | Conc | 82 | 58.5 | 0.87
| Takada 2002 | Leukopenia (WHO grade)
| | 3 | Seql | 110 | 44.5 | Conc | 112 | 50.9 | 0.001
| | 4 | | | 9.1 | | | 37.5
| | 3 or 4 | | | 53.6 | | | 88.4
| Work 1997; 1996 | WHO grades 3 & 4 leukopenia | L Alt | 100 | 39 | E Alt | 99 | 67 | <0.001
| | WHO grade 4 leukopenia | | | 6 | | | 23 | 0.0006
| Park 1996 | Leukopenia ECOG grade 3 | Seql | 24 | 12.5 | Conc | 27 | 40.7 | 0.0176
| | ECOG grade 4 | | | 4.2 | | | 11.1
Infection | Takada 2002 | WHO grade ≥ 3 | Seql | 110 | 0.9 | Conc | 112 | 5.4 | 0.12 | Lebeau 1999; Gregor 1997; Sun 1995
| Work 1997; 1996 | | neutropenic fever in 8 patients; no difference between groups
| Park 1996 | ECOG grade 3 | Seql | 24 | 0 | Conc | 27 | 3.7 | 1.00
| | ECOG grade 4 | | | 0 | | | 0
Other | Takada 2002 | Alopecia (WHO grade ≥ 3) | Seql | 109 | 12.7 | Conc | 109 | 11.6 | 0.99
| Takada 2002 | Fever (WHO grade ≥ 3) | Seql | 110 | 1.8 | Conc | 112 | 1.8 | 0.99
| Takada 2002 | Arrhythmias (WHO grade ≥ 3) | Seql | 110 | 0 | Conc | 112 | 1.8 | 0.50
| Park 1996 | Hepatic ECOG grade 3 | Seql | 24 | 0 | Conc | 27 | 0 | 1.00
| | Hepatic ECOG grade 4 | | 0 | | 0

Table 1H Study Quality Ratings

Study | Initial Assembly of Comparable Groups | Low Loss to Followup, Maintenance of Comparable Groups | Measurements Reliable, Valid, Equal* | Interventions Comparable/ Clearly Defined | Appropriate Analysis of Results | Overall Rating
Gregor 1997 | Yes | Yes | Yes | Yes | Yes | Good
Lebeau 1999 | Yes | Yes | Yes | Yes | Yes | Good
Takada 2002 | Yes | Yes | Yes | Yes | Yes | Good
Sun 1995 | ? | ? | ? | ? | ? | Poor
Work 1997 Work 1996 | Partial (arms balanced but “Randomization... based on a table of random numbers.”) | yes | yes | yes | yes | Fair
Park 1996 | ? | ? | Yes | Yes | ? | Poor

Question 2. Early versus Late Radiotherapy

Table 2A Sample Selection

Study | Inclusion | Exclusion | n, Randomized | | | n, Withdrawn or Excluded | | | n, Evaluated for Primary Outcome
Murray 1993 | confirmed SCLC; limited stage (unilateral disease w/wo vena cava syndrome, mediastinal involvement, or + ipsilateral supraclavicular nodes); no prior chemoTx or radioTx; ECOG PS 0–3; adequate renal, hepatic, hematologic function; vital capacity ≥45%; FEV_1_≥40% | age>80y; extensive stage disease (disease outside one lung, mediastinum and supraclav. nodes, or pleural effusion); tumor size > pre-specified limit of TRTx field size; serious cardiac disease; prior malignancy <5 years ago | Total | Early | Late | Total | Early | Late | Total | Early | Late
Coy 1994 | | | 332 | 168 | 164 | 24 (7%) | 13 | 11 | 308 | 155 | 153
Feld 1988 | | | | | | exclusions:
| | | | | | extensive stage | | 5
22 centers | | | | | | not SCLC | | 10
accrual 1/85 through 12/88 | | | | | | poor lung func | | 3
| | | | | | tumor>RTx field | | 4
| | | | | | non-assessable lesion | | 2
Perry 1987 | confirmed SCLC; limited stage (unilateral disease w/wo vena cava syndrome, mediastinal involvement, or + supraclavic-ular nodes); no prior chemoTx or radioTx; CALGB PS 0–3 | MI within prior 6 mos; extensive stage disease (disease outside one lung, mediastinum and supraclav. nodes, or pleural effusion | Total | Early | Late | Total | Early | Late | Total | Early | Late
Ahles 1994 | | | 426 | | | 27 (6%) | | | 270 | 125 | 145
Perry 1998 | | | 3-arm study; data on regimen III (no TRTx) not abstracted | | | | | | (evaluated for OS; no 1° outcome specified)
22 centers | | | | | | extensive stage | | 7
accrual 1/81 through 6/84 | | | | | | not SCLC | | 5
| | | | | contraindications | | 3
| | | | | | wrong Tx: | | 1
| | | | | | withdrew consent | | 11
Jeremic 1997 | confirmed SCLC; limited stage (unilateral disease w/wo vena cava syndrome, mediastinal involvement, or + ipsilateral supraclavicular nodes); no prior therapy; KPS ≥50%; adequate hematologic, renal, hepatic function | age≥70y; extensive stage disease (disease outside one lung, mediastinum and supraclav. nodes, or pleural effusion); serious cardiac or renal disease; prior malignancy <5 years ago | Total | Early | Late | Total | Early | Late | Total | Early | Late
single center | | | 107 | 54 | 53 | 4 (4%) | 2 | 2 | 103 | 52 | 51
accrual 1/88-12/92; closed early since PI moved | | | | | | exclusions:
| | | | | | extensive stage | | 3
| | | | | | concurrent | | 1
| | | | | | bladder cancer
Qiao 2004 | limited stage SCLC (unilateral disease), previously untreated, could bear comprehensive treatment, KPS >60, age <70, normal liver and kidney function | metastasis beyond homo-lateral hilus, mediastinum, and supraclavicular lymph nodes | Total | Early | Late | Total | Early | Late | Total | Early | Late
single center | | | 90 | 45 | 45 | | | | 90 | 45 | 45
accrual 3/93–1/98
Skarlos 2001 | confirmed SCLC; limited stage (unilateral disease w/wo vena cava syndrome, mediastinal involvement, or + ipsilateral supraclavicular nodes); no prior chemoTx or radioTx; ECOG PS 0–2; adequate renal, hepatic, hematologic function | extensive stage disease (disease outside one lung, mediastinum and ipsilateral supraclav. nodes, or pleural effusion); prior malignancy | Total | Early | Late | Total | Early | Late | Total | Early | Late
Multicenter | | | 86 | | | 5 (6%) | | | 81 | 42 | 39
accrual 12/93 to 11/99 | | | | | | exclusions:
| | | | | | pleural effusion | | 4
| | | | | | adrenal mets | | 1
James 2003 (abstract only) | limited stage disease (definition not reported) | extensive stage disease (definition not reported) | Total | Early | Late | Total | Early | Late | Total | Early | Late
multicenter; accrual 1/1993 through 1/2002 | | | 325 | 159 | 166 | 0 | 0 | 0 | 325 | 159 | 166

Table 2B Patient Characteristics

Study | Age (yr) | | | Gender (%) | | | Race | | | Performance Status (%) | | | Comorbidities or Prognostic Factors (%)
Murray 1993 | | [underlined: Early] | [underlined: Late] | | [underlined: Early] | [underlined: Late] | | [underlined: Early] | [underlined: Late] | [underlined: ECOG] | [underlined: Early] | [underlined: Late] | | [underlined: Early] | [underlined: Late]
Coy 1994 | mn | | | M | 59.4 | 65.4 | B | | | 0 | 21.9 | 22.2 | elevated LDH | 25.1% | 25.5%
Feld 1988 | md | 61.8 y | 61.6 y | F | 40.6 | 34.6 | W | not reported | | 1 | 65.2 | 68 | LDH unknown | 16.2% | 15.7%
| rng | | | | | | H | | | 2 | 12.3 | 9.2 | disease extent:
| sd | | | | | | A | | | 3 | 0.6 | 0.7 | lung only | 38.7% | 39.2%
| | | | | | | O | | | | | | + mediastinum | 53.5% | 56.2%
| | | | | | | | | | | | | + supraclavic-ular nodes | 7.8% | 4.6%
Perry 1987 | | [underlined: Early] | [underlined: Late] | | [underlined: Early] | [underlined: Late] | | [underlined: Early] | [underlined: Late] | [underlined: CALGB] | [underlined: Early] | [underlined: Late] | | [underlined: Early] | [underlined: Late]
Ahles 1994 | <50 | 14% | 12% | M | 62 | 63 | B | | | 0 | 38 | 42 | weight loss >10% at entry
Perry 1998 | 50-9 | 32% | 33% | F | 38 | 37 | W | not reported | | 1 | 48 | 45 | | 14 | 11
| 60-9 | 41% | 43% | | | | H | | | 2 or 3 | 13 | 9
| 70-9 | 13% | 12% | | | | A
| | | | | | | O
Jeremic 1997 | | [underlined: Early] | [underlined: Late] | | [underlined: Early] | [underlined: Late] | | [underlined: Early] | [underlined: Late] | [underlined: KPS] | [underlined: Early] | [underlined: Late] | | [underlined: Early] | [underlined: Late]
| mn | 57 | 57 | M | 59.6 | 60.8 | B | | | 90, 100 | 52 | 47 | weight loss >5% at entry
| md | 59 | 59 | F | 40.4 | 39.2 | W | not reported | | 50–80 | 48 | 53 | | 52 | 53
| rng | 40–67 | 44–66 | | | | H
| sd | | | | | | A
| | | | | | | O
Qiao 2004 | | [underlined: Early] | [underlined: Late] | | [underlined: Early] | [underlined: Late] | | [underlined: Early] | [underlined: Late] | | [underlined: Early] | [underlined: Late] | | [underlined: Early] | [underlined: Late]
| mn | | | M | 75.6 | 66.7 | B | | | KPS ≥70 for all; excluded if KPS ≤60 | | | lung only | 28.9 | 24.4
| md | 57 | 56 | F | 24.4 | 33.3 | W | not reported | | | | | hilum /MS LN | 60 | 60
| rng | 36–68 | 38–69 | | | | H | | | | | | SC LN | 11.1 | 15.6
| sd | | | | | | A
| | | | | | | O
Skarlos 2001 | | [underlined: Early] | [underlined: Late] | | [underlined: Early] | [underlined: Late] | | [underlined: Early] | [underlined: Late] | [underlined: ECOG] | [underlined: Early] | [underlined: Late] | | [underlined: Early] | [underlined: Late]
| mn | | | M | 93 | 90 | B | | | 0 | 26 | 41 | smokers | 100 | 93
| md | 61 | 60 | F | 7 | 10 | W | not reported | | 1 | 50 | 44 | extra-lung disease:
| rng | 40–76 | 37–76 | | | | H | | | 2 | 24 | 15 | mediastinum | 67 | 69
| sd | | | | | | A | | | | | | ips. sup-clav. | 17 | 8
| | | | | | | O | | | | | | weight loss ≥5% in past 6 mos | 21 | 18
James 2003 (abstract only) | | [underlined: Early] | [underlined: Late] | | [underlined: Early] | [underlined: Late] | | [underlined: Early] | [underlined: Late] | [underlined: ECOG] | [underlined: Early] | [underlined: Late] | | [underlined: Early] | [underlined: Late]
| mn | | | M | 60 | 57 | B | | | 0–1 | 91 | 89
| md | 62 | 62 | F | 40 | 43 | W | not reported | | 2–3 | 9 | 11 | | none reported
| rng | 34–74 | 33–74 | | | | H
| sd | | | | | | A
| | | | | | | O

Table 2C Treatments

Study | Chemotherapy regimen, per protocol | | | Early TRTx | | Late TRTx | | PCI
Murray 1993 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule] | 25 Gy in 10 fracs; wks 20 & 21; if no PD post chemoTx and TRTx
Coy 1994 | cytoxan | 1 g/m^2^ | d 1, wk 1, 8, 14 (early) wk 1, 7, 13 (late) | 40 Gy | wks 4–6: 15 fracs, 2.67 Gy each, 1 frac/d, 5 d/wk; ^60^Co or linac photons (4–25 MeV); 1 wk rest post TRTx before chemoTx cycles 3–6 | 40 Gy | wks 16–18: 15 fracs, 2.67 Gy each; 1 frac/d, 5 d/wk; ^60^Co or linac photons (4–25 MeV)
Feld 1988 | doxorubicin | 50 mg/m^2^ | d 1, as for cytoxan
| vincristine | 2 mg | d 1, as for cytoxan
| etoposide | 100 mg/m^2^ | d 1–3 wk 4, 11, 17 (early) wk 4, 10, 16 (late)
| cisplatin | 25 mg/m^2^ | d 1–3, as for etoposide
Perry 1987 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule] | 30 Gy in 10 fractions concurrent with TRTx; all patients
Ahles 1994 | vincristine | 1.4 mg/m^2^ | d1; q21d | 50 Gy | wks 1–5: 40 Gy, then 1 Gy boost; source, # and size of fractions not specified | 50 Gy | wks 10–14: 40 Gy, then 10 Gy boost; source, # and size of fractions not specified
Perry 1998 | cytoxan | 1 g/m^2^ | d1; q21d | | (likely 2 Gy/d, 5 d/wk) | | (likely 2 Gy/d, 5 d/wk)
| etoposide | 80 mg/m^2^ | d1,2,3; q21d (to cycle 7)
| doxorubicin | 50 mg/m^2^ | d1; (replaced etoposide
| (chemoTx for 18 months) | | for odd cycles #7–17, to total dose of 350 mg/m^2^)
Jeremic 1997 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | Schedule | 25 Gy in 10 fracs, wks 16 & 17; given to all with CR or PR
| carboplatin | 30 mg | every RTx day | 54 Gy | wks 1–4; 1.5 Gy fracs 2×/d 4.5–6 hr apart, 5×/wk; 36 fracs on 18 d over 3.6 wk; concurrent chemoTx given during interval between fracs | 54 Gy | wks 6–9; 1.5 Gy fracs 2×/d 4.5–6 hr apart, 5×/wk; 36 fracs on 18 d over 3.6 wk; concurrent chemoTx given during interval between fracs
| etoposide | 30 mg | every RTx day
| cisplatin | 30 mg/m^2^ | d 1–3; wk 6,9,12,15 (early) wk 1,4,11,14 (late)
| etoposide | 120 mg/m^2^ | as for cisplatin
Qiao 2004 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule] | not mentioned
| carboplatin | 100 mg | d 1–5, wks 1,4,7,10,13,16 | 50 or | started in first CTx cycle; given over 6 wks; 2 Gy fracs, 1×/d, 5d/wk, 40 Gy to front and back, 20 Gy from oblique angles/avoiding spinal cord; total 50 Gy if no LN metastasis | 60 Gy | started after 4^th^ CTx cycle same treatement plan radiation areas and dosages as early group
| etoposide | 100 mg | d 1–5, wks 1,4,7,10,13,16 | 60 Gy
Skarlos 2001 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule] | 20 Gy; five daily 4 Gy fracs; only if achieved CR
| carboplatin | AUC of 6 | d1, each of six 21-d | 45 Gy | wks 1–3; 1.5 Gy fracs 2 frac/d, 5 d/wk | 45 Gy | wks 10–12; 1.5 Gy fracs, 2 frac/d, 5 d/wk
| etoposide | 100 mg/m^2^ | d 1–3, each of six 21-d cycles
James 2003 (abstract only) | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule] | 25 Gy in 10 fracs; wks 19 & 20; given to responders w neg, post Tx brain scan
| cytoxan | 1 g/m^2^ | d 1, wks 1, 7, 13 | 40 Gy | wks 4–6: 15 fracs, 2.67 Gy each, 1 frac/d, 5 d/wk; source not specified | 40 Gy | wks 16–18: 15 fracs, 2.67 Gy each; 1 frac/d, 5 d/wk; source not specified
| doxorubicin | 50 mg/m^2^ | d 1, wks 1, 7, 13
| vincristine | 2 mg | d 1, wks 1, 7, 13
| etoposide | 100 mg/m^2^ | ds 1–3, wks 4, 10, 16
| cisplatin | 25 mg/m^2^ | ds 1–3, wks 4, 10, 16

Table 2D Outcome Assessment

Study | Primary Outcomes | Secondary Outcomes | Response Criteria | Observer | F/U
Murray 1993 | overall survival | progression-free survival; response rates; time to local recurrence; time to brain relapse; first relapse pattern (local versus distant versus both); adverse events | CR= no clinical, radiol evidence of tumor, ≥1 mo | unspecified; blinding not mentioned | | [underlined: Total] | [underlined: Early] | [underlined: Late]
Coy 1994 | 80% power to detect increase in 2-year survival from 20% to 35% at 2-sided p<0.05 | | PR= ↓ by ≥50%, all measureable lesions, ≥1 mo | | mn
Feld 1988 | | | SD= ↓ in lesion size by <50% or ↓ by <25%, ≥1 mo | | md | <5 y
| | | PD= ↑ by >25%, cross sectional area, ≥1 lesion, or any new lesion | | rng | 2.7-? y
| | | | | sd
Perry 1987 | not specified; no power calculation | overall, disease-free and failure-free survival; time to failure in chest; response rates; adverse events | CR= no clinical, radiol evidence of tumor, ≥1 mo | unspecified; blinding not mentioned | | [underlined: Total] | [underlined: Early] | [underlined: Late]
Ahles 1994 | | | PR= ↓ by ≥50%, all measureable lesions, ≥1 mo | | | 10 yrs
Perry 1998 | | | SD= ↓ in lesion size by <50% ≥1 mo | | mn
| | | PD= any objective ↑ in lesion size | | md
| | | | | rng
| | | | | sd
Jeremic 1997 | survival at 2 yr planned 80% power to detect 20% Δ in 2 yr survival at p<0.05, assuming 25% baseline survival, but closed early | local recurrence-free and distant mets-free survival; response rates; adverse events | CR= disappearance of all measurable/assessable disease & no new lesions, ≥4 wk | unspecified; blinding not mentioned | | [underlined: Total] | [underlined: Early] | [underlined: Late]
| | | PR= ↓ by ≥50%, Σ_all lesions_ [products of cross-sectional diameters], no new lesions, ≥4 wk | | mn | not reported
| | | SD= ↓ by <50% or ↑ by <25% in above sum | | md
| | | PD= by ↑25% in above sum | | rng
| | | | | sd
Qiao 2004 | not specified; no power calculation | overall survival; response rates at 4 months; adverse events; cause of death | CR= no clinical, radiol evidence of tumor, ≥4 wk | unspecified; blinding not mentioned | | [underlined: Total] | [underlined: Early] | [underlined: Late]
| | | PR= ≥50% ↓, Σ_all lesions_ [products, 2 greatest per-pendicular diams.], no new lesions, ≥4 wk | | | 5 yrs
| | | SD= did not meet criteria for CR, PR or PD | | mn
| | | PD= by ↑25% in above sum, without prior CR, PR or SD (WHO criteria) | | md
| | | | | rng
| | | | | sd
Skarlos 2001 | overall response rate (ORR = CR + PR) | overall survival; time to progression; adverse events | CR= no clinical, radiol evidence of tumor, ≥4 wk | unspecified; blinding not mentioned | | [underlined: Total] | [underlined: Early] | [underlined: Late]
| n=84 had 80% power to detect 25% in ORR at 5% level, if ORR=70% for late TRTx | | PR= ≥50% ↓, Σ_all lesions_ [products, 2 greatest per-pendicular diams.], no new lesions, ≥4 wk | | mn | 35 mos
| | | SD= did not meet criteria for CR, PR or PD | | md
| | | PD= by ↑25% in above sum, without prior CR, PR or SD (WHO criteria) | | rng
| | | | | sd
James 2003 (abstract only) | overall survival | adverse event; overall response rate (CR+PR) | CR= not provided | unspecified; | | [underlined: Total] | [underlined: Early] | [underlined: Late]
| (no power calculation) | | PR= not provided | blinding not mentioned | mn
| | | SD= not provided | | md | not reported
| | | PD= not provided | | rng
| | | | | sd

Table 2E Survival Outcomes

Study | Overall Survival | | | | | | | | Progression-Free Survival (PFS), Time to Failure (TTF), Local Recurrence-Free Survival (LRFS), or Proportion Without In-Field Recurrence (PWIFR)
Murray 1993 | | N | [underlined: Med] (mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr] | PFS: | [underlined: N] | [underlined: Med](mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr]
Coy 1994 | Early | 155 | 21.2 | ~77% | 40% | 29.7% | 23.7% | 20% | Early | 155 | 15.4 | ~64% | ~28% | 26% | ~23% | ~23%
Feld 1988 | Late | 153 | 16.0 | ~63% | 33.7% | 21.5% | 15.1% | 11% | Late | 153 | 11.8 | ~48% | ~24% | 19% | ~17 | ~17%
| (p=0.008, log-rank; 0.005 Wilcoxon) | | | | | | | | (p=0.036, log-rank; 0.014 Wilcoxon)
Perry 1987 | | N | [underlined: Med] (mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr] | TTF: | [underlined: N] | [underlined: Med] (mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr]
Ahles 1994 | Early | 125 | 13.0 | ~53% | ~24% | ~10% | | | Early | 125 | 11.0 | ~48% | 15% | ~9% | ~7% | ~6%
Perry 1998 | Late | 145 | 14.5 | ~62% | ~30% | ~20% | | | Late | 145 | 11.2 | ~52% | 21% | ~14% | ~12% | ~11%
| (p=0.144; not significant) | | | | | | | | (p=0.238; not significant)
Jeremic 1997 | | N | [underlined: Med] (mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr] | LRFS: | [underlined: N] | [underlined: Med] (mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr]
| Early | 52 | 34 | 90% | 71% | 48% | 35% | 30% | Early | 52 | | 94% | 90% | 73% | 63% | 58%
| Late | 51 | 26 | 71% | 53% | 39% | 25% | 15% | Late | 51 | | 74% | 69% | 61% | 46% | 37%
| (p=0.052) | | | | | | | | (p=0.011)
Qiao 2004 | | [underlined: N] | [underlined: Med] (mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr] | | [underlined: N] | [underlined: Med] (mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr]
| Early | 45 | 26 | 78% | | 33% | | 27% | Early
| Late | 45 | 19 | 53% | | 22% | | 16% | Late
| (log-rank, p<0.05)
Skarlos 2001 | | N | [underlined: Med] (mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr] | TTF: | [underlined: N] | [underlined: Med] (mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr]
| Early | 42 | 17.5 | ~65% | 36% | 22% | | | Early | 42 | 9.5 | ~40% | ~25% | ~20%
| Late | 39 | 17 | ~80% | 29% | 13% | | | Late | 39 | 10.5 | ~35% | ~15% | ~15%
| (p=0.65, not significant) | | | | | | | | (p=0.6, not significant)
James 2003 (abstract only) | | [underlined: N] | [underlined: Med] (mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr] | | N | [underlined: Med] (mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr]
| Early | 159 | 13.5 | | | 16% | | | Early
| Late | 166 | 15.1 | | | 20% | | | Late | NOT REPORTED
| (HR = 1.18; 95% CI: 0.93, 1.51; p=0.18)

Table 2F Tumor Response and Quality of Life

Study | Tumor Response | | | | | | | Quality of Life
Murray 1993 | | [underlined: N] | [underlined: CR] | [underlined: PR] | [underlined: SD] | [underlined: PD] | [underlined: NE] | [underlined: Scale] | [underlined: Domain] | [underlined: F/U] | [underlined: Early n] | [underlined: Late n] | [underlined: Early mn+sd] | [underlined: Late mn+sd]
Coy 1994 | Early | 155 | 63.9% | 20.6% | 5.2% | 9.7% | 0.6% | | | NOT MEASURED
Feld 1988 | Late | 153 | 55.6% | 25.5% | 2.0% | 15.0% | 1.9%
| (not significantly different; p= 0.14)
Perry 1987 | | [underlined: N] | [underlined: CR] | [underlined: PR] | [underlined: SD] | [underlined: PD] | [underlined: NE] | [underlined: Scale] | [underlined: Domain] | [underlined: F/U] | [underlined: Early n] | [underlined: Late n] | [underlined: Early mn+sd] | [underlined: Late mn+sd]
Ahles 1994 | Early | 121 | 49% | 30% | 14% | 2% | 4% | Profile of | total score | pre-Tx | 16 | 12 | 20.2±28.5 | 21.7±34.4
Perry 1998 | Late | 141 | 58% | 25% | 9% | 3% | 5% | Mood States | | post RTx | | | 35.3±30.3 | 39.1±33.4
| (not significantly different; p=0.13) | | | | | | | Handicap | total score | pre-Tx | 14 | 10 | 4.5±3.2 | 2.7±2.3
| | | | | | | | Rating Scale | | post RTx | | | 6.6±2.7 | 6.4±2.9
| | | | | | | | Trails B | time to | pre Tx | 17 | 11 | 186±97 | 171±113
| | | | | | | | Test | complete | post RTx | | | 193±97 | 161±91
Jeremic 1997 | wk 15: | [underlined: N] | [underlined: CR] | [underlined: PR] | [underlined: SD] | [underlined: PD] | [underlined: NE] | [underlined: Scale] | [underlined: Domain] | [underlined: F/U] | [underlined: Early n] | [underlined: Late n] | [underlined: Early mn+sd] | [underlined: Late mn+sd]
| Early | 52 | 96% | 2% | | 2%
| Late | 51 | 82% | 2% | | 10% | 6% (dead) | | | NOT MEASURED
| (p=0.023)
Qiao 2004 | | [underlined: N] | [underlined: CR] | [underlined: PR] | [underlined: SD] | [underlined: PD] | [underlined: NE] | [underlined: Scale] | [underlined: Domain] | [underlined: F/U] | [underlined: Early n] | [underlined: Late n] | [underlined: Early mn+sd] | [underlined: Late mn+sd]
| Early | 45 | 67% | 31% | 2%
| Late | 45 | 47% | 44% | 9% | | | | | NOT MEASURED
| (p>0.05)
Skarlos 2001 | | [underlined: N] | [underlined: CR] | [underlined: PR] | [underlined: SD] | [underlined: PD] | [underlined: NE] | [underlined: Scale] | [underlined: Domain] | [underlined: F/U] | [underlined: Early n] | [underlined: Late n] | [underlined: Early mn+sd] | [underlined: Late mn+sd]
| Early | 42 | 40.5% | 35.5% | 14% | 5% | 5%
| Late | 39 | 56.50% | 36.00% | 5% | 2.50% | 0 | | | NOT MEASURED
| (ORR: 76% early, 92.5% late; p=0.07)
James 2003 (abstract only) | | [underlined: N] | [underlined: CR] | [underlined: PR] | [underlined: SD] | [underlined: PD] | [underlined: NE] | [underlined: Scale] | [underlined: Domain] | [underlined: F/U] | [underlined: Early n] | [underlined: Late n] | [underlined: Early mn+sd] | [underlined: Late mn+sd]
| Early | 159 | ORR=79%
| Late | 166 | ORR=78% | | | | | | | NOT MEASURED

ORR = overall response rate (CR + PR)

Table 2G Adverse Events

Toxicity Type | Study | Severity or Grade | Results
Treatment-related mortality | Murray 1993 | | F/U (yr) | Early n | % | Late n | %
| Coy 1994 | not applicable | 2.7–5+ | 155 | 1.3 | 153 | 1.3
| Feld 1988
| Perry 1987 | | F/U (yr) | Early n | % | Late n | %
| Ahles 1994 | not applicable | 1.44 | 125 | 4 | 145 | 1
| Perry 1998
| Jeremic 1997 | not applicable | F/U (yr) | Early n | % | Late n | %
| | | | NOT REPORTED
| Qiao 2004 | not applicable | F/U (yr) | Early n | % | Late n | %
| Skarlos 2001 | | F/U (yr) | Early n | % | Late n | %
| | not applicable | 2.9 (med) | 42 | 0 | 39 | 0
| James 2003 (abstract only) | | F/U (yr) | Early n | % | Late n | %
| | not applicable | | NOT REPORTED
Nausea | Murray 1993 | | F/U (yr) | Early n | % | Late n | %
| Coy 1994
| Feld 1988
| Perry 1987 | | F/U (yr) | Early n | % | Late n | %
| Ahles 1994
| Perry 1998
| Jeremic 1997 | | F/U (yr) | Early n | % | Late n | %
| Qiao 2004 | | F/U (yr) | Early n | % | Late n | %
| Skarlos 2001 | | F/U (yr) | Early n | % | Late n | %
| James 2003 (abstract only) | | F/U (yr) | Early n | % | Late n | %
Vomiting | Murray 1993 | | F/U (yr) | Early n | % | Late n | %
| Coy 1994 | required IV fluids | 2.7–5+ | 155 | 11.6 | 153 | 15.8
| Feld 1988 | | | (p not significant)
| Perry 1987 | | F/U (yr) | Early n | % | Late n | %
| Ahles 1994 | nausea and vomiting, NOS | 1.44 | 122 | 18 | 140 | 10
| Perry 1998
| Jeremic 1997 | acute nausea and vomiting grades 3 & 4 | F/U (yr) | Early n | % | Late n | %
| | | not reported | 52 | 9.6 | 51 | 7.8
| Qiao 2004 | | F/U (yr) | Early n | % | Late n | %
| Skarlos 2001 | grade 3 nausea and vomiting | F/U (yr) | Early n | % | Late n | %
| | | 2.9 (med) | 42 | 2.5 | 39 | 2.5
| James 2003 (abstract only) | nausea and vomiting grades 3 & 4 | F/U (yr) | Early n | % | Late n | %
| | | ??? | 159 | 2 | 166 | 3
Anorexia | Murray 1993 | | F/U (yr) | Early n | % | Late n | %
| Coy 1994
| Feld 1988
| Perry 1987 | | F/U (yr) | Early n | % | Late n | %
| Ahles 1994 | >10% weight loss | 1.44 | ??? | 14 | not reported
| Perry 1998
| Jeremic 1997 | | F/U (yr) | Early n | % | Late n | %
| Qiao 2004 | weight loss (% not specified) | F/U (yr) | Early n | % | Late n | %
| | | ??? | 45 | 20 | 45 | 33.3
| Skarlos 2001 | | F/U (yr) | Early n | % | Late n | %
| James 2003 (abstract only) | | F/U (yr) | Early n | % | Late n | %
Lethargy | Murray 1993 | | F/U (yr) | Early n | % | Late n | %
| Coy 1994
| Feld 1988
| Perry 1987 | | F/U (yr) | Early n | % | Late n | %
| Ahles 1994
| Perry 1998
| Jeremic 1997 | | F/U (yr) | Early n | % | Late n | %
| Qiao 2004 | | F/U (yr) | Early n | % | Late n | %
| Skarlos 2001 | | F/U (yr) | Early n | % | Late n | %
| James 2003(abstract only) | | F/U (yr) | Early n | % | Late n | %
Neurosensory | Murray 1993 | | F/U (yr) | Early n | % | Late n | %
| Coy 1994 | Severe life-threatening lethal | | 155 | 0.6 | 153 | 3.3
| Feld 1988 | | 2.7–5+ | | 0 | | 1.3
| | | | | 0.6 | | 0
| Perry 1987 | “neuromuscular effects” | F/U (yr) | Early n | % | Late n | %
| Ahles 1994 | | 1.44 | 124 | 17 | 144 | 16
| Perry 1998
| Jeremic 1997 | | F/U (yr) | Early n | % | Late n | %
| Qiao 2004 | | F/U (yr) | Early n | % | Late n | %
| Skarlos 2001 | grade 2 & 3 neurotoxicity | F/U (yr) | Early n | % | Late n | %
| | | 2.9 (med) | 42 | 0 | 39 | 0
| James 2003 (abstract only) | | F/U (yr) | Early n | % | Late n | %
Hearing loss | Murray 1993 | | F/U (yr) | Early n | % | Late n | %
| Coy 1994
| Feld 1988
| Perry 1987 | | F/U (yr) | Early n | % | Late n | %
| Ahles 1994
| Perry 1998
| Jeremic 1997 | | F/U (yr) | Early n | % | Late n | %
| Qiao 2004 | | F/U (yr) | Early n | % | Late n | %
| Skarlos 2001 | | F/U (yr) | Early n | % | Late n | %
| James 2003 (abstract only) | | F/U (yr) | Early n | % | Late n | %
Esophagitis | Murray 1993 | | F/U (yr) | Early n | % | Late n | %
| Coy 1994 | fluids only IV fluids | 2.7–5+ | 149 | 11.4 | 133 | 6.8
| Feld 1988 | | | | 3.4 | | 0.8
| Perry 1987 | | F/U (yr) | Early n | % | Late n | %
| Ahles 1994 | not specified | 1.44 | ??? | 10 | ??? | 8
| Perry 1998
| Jeremic 1997 | acute, grades 3 & 4 | F/U (yr) | Early n | % | Late n | %
| | | not reported | 52 | 28.9 | 51 | 25.5
| Qiao 2004 | radio-esophagitis | F/U (yr) | Early n | % | Late n | %
| | | | 45 | 42.2 | 45 | 28.9
| | | (p>0.05)
| Skarlos 2001 | grade 2 | F/U (yr) | Early n | % | Late n | %
| | grade 3 | 2.9 (med) | 42 | 16.5% | 39 | 2.5%
| | | | | 2.5% | | 18%
| | | (p=0.82 for any grade, 0.03 for grade 3)
| James 2003 (abstract only) | grades 3 & 4 | F/U (yr) | Early n | % | Late n | %
| | | ??? | 159 | 7 | 166 | 4
Bronchopulmonary | Murray 1993 | | F/U (yr) | Early n | % | Late n | %
| Coy 1994
| Feld 1988
| Perry 1987 | | F/U (yr) | Early n | % | Late n | %
| Ahles 1994 | not specified | 1.44 | 122 | 9 | 133 | 6
| Perry 1998
| Jeremic 1997 | acute, grades 3 & 4 | F/U (yr) | Early n | % | Late n | %
| | | not reported | 52 | 1.9 | 51 | 0
| Qiao 2004 | | F/U (yr) | Early n | % | Late n | %
| Skarlos 2001 | grade 3 | F/U (yr) | Early n | % | Late n | %
| | | 2.9 (med) | 42 | 5.0% | 39 | 7.5%
| | | p = 0.69
| James 2003 (abstract only) | | F/U (yr) | Early n | % | Late n | %
Pneumonitis | Murray 1993 | | F/U (yr) | Early n | % | Late n | %
| Coy 1994 | any lethal | 2.7–5+ | 149 | 3.2 | 133 | 0.7
| Feld 1988 | | | | 0 | | 0
| Perry 1987 | | F/U (yr) | Early n | % | Late n | %
| Ahles 1994 | not specified | 1.44 | 122 | 9 | 133 | 4.5
| Perry 1998
| Jeremic 1997 | | F/U (yr) | Early n | % | Late n | %
| Qiao 2004 | radio-pneumonia | F/U (yr) | Early n | % | Late n | %
| | | | 45 | 8.9 | 45 | 6.7
| Skarlos 2001 | | F/U (yr) | Early n | % | Late n | %
| James 2003 (abstract only) | | F/U (yr) | Early n | % | Late n | %
Kidney | Murray 1993 | | F/U (yr) | Early n | % | Late n | %
| Coy 1994 | creatinine > 354 μmol/L | 2.7–5+ | 155 | 0 | 153 | 0.7
| Feld 1988 | | (p not significant)
| Perry 1987 | | F/U (yr) | Early n | % | Late n | %
| Ahles 1994
| Perry 1998
| Jeremic 1997 | | F/U (yr) | Early n | % | Late n | %
| Qiao 2004 | | F/U (yr) | Early n | % | Late n | %
| Skarlos 2001 | grade 2 or 3 | F/U (yr) | Early n | % | Late n | %
| | | 2.9 (med) | 42 | 0 | 39 | 0
| James 2003 (abstract only) | | F/U (yr) | Early n | % | Late n | %
Anemia | Murray 1993 | | F/U (yr) | Early n | % | Late n | %
| Coy 1994 | Hb <80 g/L | 2.7–5+ | 155 | 49 | 153 | 36.8
| Feld 1988 | | (p = 0.03)
| Perry 1987 | | F/U (yr) | Early n | % | Late n | %
| Ahles 1994
| Perry 1998
| Jeremic 1997 | acute, grades 3 & 4 | F/U (yr) | Early n | % | Late n | %
| | | not reported | 52 | 13.5 | 51 | 7.8
| Qiao 2004 | | F/U (yr) | Early n | % | Late n | %
| Skarlos 2001 | grades 3 & 4 | F/U (yr) | Early n | % | Late n | %
| | | 2.9 (med) | 42 | 19 | 39 | 12.8
| James 2003 (abstract only) | grades 3 & 4 | F/U (yr) | Early n | % | Late n | %
| | | not reported | 159 | 9 | 166 | 5
Thrombocytopenia | Murray 1993 | | F/U (yr) | Early n | % | Late n | %
| Coy 1994 | <25 × 10^9^/L | 2.7–5+ | 155 | 3.9 | 153 | 2.6
| Feld 1988 | | (p not significant)
| Perry 1987 | <25 × 10^9^/L | F/U (yr) | Early n | % | Late n | %
| Ahles 1994 | | 1.44 | 122 | 1 | 140 | 2
| Perry 1998
| Jeremic 1997 | acute, grades 3 & 4 | F/U (yr) | Early n | % | Late n | %
| | | not reported | 52 | 38.5 | 51 | 21.6
| Qiao 2004 | | F/U (yr) | Early n | % | Late n | %
| Skarlos 2001 | grades 3 & 4 | F/U (yr) | Early n | % | Late n | %
| | | 2.9 (med) | 42 | 21.40% | 39 | 23.1%
| James 2003 (abstract only) | grades 3 & 4 | F/U (yr) | Early n | % | Late n | %
| | | not reported | 159 | 9 | 166 | 9
Leukopenia or neutropenia | Murray 1993 | | F/U (yr) | Early n | % | Late n | %
| Coy 1994 | neutrophils<0.5 × 10^9^/L | 2.7–5+ | 155 | 70.3 | 153 | 61.4
| Feld 1988 | | (p not significant)
| Perry 1987 | | F/U (yr) | Early n | % | Late n | %
| Ahles 1994 | WBC<1 × 10^9^/L | 1.44 | 117 | 35 | 118 | 25
| Perry 1998
| Jeremic 1997 | acute leukopenia, grades 3 & 4 | F/U (yr) | Early n | % | Late n | %
| | | not reported | 52 | 32.7 | 51 | 41.2
| Qiao 2004 | leukocyte decline | F/U (yr) | Early n | % | Late n | %
| | grade 2 | NR | 45 | 6.7 | 45 | 24.4
| | grade 3 | | | 71.1 | | 57.8
| | grade 4 | | | 22.2 | | 17.8
| | | (grade 3 & 4, p<0.05)
| Skarlos 2001 | grades 3 & 4 leukopenia | F/U (yr) | Early n | % | Late n | %
| | | 2.9 (med) | 42 | 35.7 | 39 | 20.5
| James 2003 (abstract only) | grades 3–4 leucopenia | F/U (yr) | Early n | % | Late n | %
| | | not reported | 159 | 74 | 166 | 55
| | | (p=0.006)
Infection | Murray 1993 | | F/U (yr) | Early n | % | Late n | %
| Coy 1994 | neutropenic fever septic shock lethal | | 155 | 4.5 | 153 | 3.3
| Feld 1988 | | 2.7–5+ | | 0.6 | | 0.7
| | | | | 0 | | 1.3
| Perry 1987 | | F/U (yr) | Early n | % | Late n | %
| Ahles 1994 | sepsis fatal sepsis | 1.44 | 125 | 20 | 140 | 15
| Perry 1998 | | | | 3 | | 1
| Jeremeic 1997 | acute grades 3 & 4 | F/U (yr) | Early n | % | Late n | %
| | | not reported | 52 | 13.5 | 51 | 13.7
| Qiao 2004 | | F/U (yr) | Early n | % | Late n | %
| Skarlos 2001 | neutropenic fever | F/U (yr) | Early n | % | Late n | %
| | | 2.9 (med) | 42 | 5 | 39 | 2.5
| James 2003 (abstract only) | | F/U (yr) | Early n | % | Late n | %
Other | Murray 1993 | | F/U (yr) | Early n | % | Late n | %
| Coy 1994 | severe dermatitis blisters | 2.7–5+ | 149 | 2.0 | 133 | 1.5
| Feld 1988 | | | | 4.0 | | 0.7
| Perry 1987 | | F/U (yr) | Early n | % | Late n | %
| Ahles 1994
| Perry 1998
| Jeremic 1997 | | F/U (yr) | Early n | % | Late n | %
| Qiao 2004 | mild digestive tract reaction | F/U (yr) | Early n | % | Late n | %
| | | | 45 | 73.3 | 45 | 55.6
| Skarlos 2001 | | F/U (yr) | Early n | % | Late n | %
| James 2003 (abstract only) | | F/U (yr) | Early n | % | Late n | %

Table 2H Study Quality Ratings

Study | Initial Assembly of Comparable Groups | Low Loss to Followup, Maintenance of Comparable Groups | Measurements Reliable, Valid, Equal* | Interventions Comparable/ Clearly Defined | Appropriate Analysis of Results | Overall Rating
Murray 1993 | Partial (arms balanced but randomization method not described) | yes | yes | yes | yes | fair
Coy 1994 | Partial (arms balanced but randomization method not described) | yes | yes | yes | yes | fair
Feld 1988
Perry 1987 | Partial (arms balanced but randomization method not described) | yes | yes | yes | yes | fair
Ahles 1994
Perry 1998
Jeremic 1997 | Partial (arms balanced but randomization method not described) | yes | yes | yes | yes | fair
Qiao 2004 | Partial (arms balanced but randomization method not described) | yes | yes | yes | yes | fair
Skarlos 2001 | yes | yes | Partial (overall response rate was primary outcome) | yes | yes | fair
James 2003 (abstract only) | Partial (arms balanced but randomization method not described) | Yes | ? | Yes | Yes | not rated since abstract only

* Those who rated response or progression were not described as blinded or masked to patients' allocated treatment in any of these reports.

Question 3. Alternative Fractionation Schemes (once versus twice daily)

Table 3A Sample Selection

Study | Inclusion | Exclusion | n, Randomized | | | n, Withdrawn | | | n, Evaluated for Primary Outcome
Turrisi 1999 | confirmed SCLC confined to one hemithorax, the ipselateral supraclavicular fossa, or both; no previous cancer; adequate organ function (WBC≥4×10^3^/ mm^3^; platelets≥1×10^5^/ mm^3^; serum creatinine<130μmol/L; serum aspartate and alanine aminotransferase levels <2 × upper limit of normal range; serum bilirubin < 8.6 μmol/L; FEV_1_≥ 1.0 L) | bilateral disease, pleural effusion, contralateral hilar or supraclavicular adenopathy; ECOG PS ≥3; symptomatic cardiac disease or MI within past 6 mos; prior chemotherapy or radiotherapy for any malignancy | [underlined: Total] | [underlined: 1 F/d] | [underlined: 2 F/d] | [underlined: Total] | [underlined: 1 F/d] | [underlined: 2 F/d] | [underlined: Total] | [underlined: 1 F/d] | [underlined: 2 F/d]
Yuen 2000 | | | 417 | 206 | 211 | 36 | 21 | 15 | 381 | 185 | 196
multicenter trial ECOG/Intergroup #0096 | | | | | | reasons:
accrual 5/89–7/92 | | | | | | withdrew from Tx | | 7
| | | | | | no preTx tumor size | | 8
| | | | | | extensive disease | | 6
| | | | | | NSCLC | | 6
| | | | | | incomplete staging | | 5
| | | | | | ↑ serum AST | | 1
| | | | | | incorrect Dx | | 1
| | | | | | ECOG PS ≥3 | | 1
Schild 2004 | Confirmed limited disease SCLC, WBC > 3,500/μL, platelets > 100K/ μL, hemoglobin ≥ 9.5 g/dL, serum creatinine ≤ 2 F/dULN, normal total bilirubin, AST/ALT < 3×ULN, FEV-1 > 1 L, ECOG PS ≤ 2, met predefined restaging criteria after 3 cycles prerandomization EP CTx: thoracic disease still within RTx ports, ECOG PS ≤ 2, WBC > 3,500/μL, platelets > 100K/ μL, serum creatinine ≤ 2 F/dULN, FEV-1 > 1 L, other chemistry values < 3xULN, no distant mets other than brain | MI < 3 months, uncontrolled CHF, uncontrolled arrhythmia, more than minimal pleural effusion, recent malignancy, prior therapy for this malignancy, weight loss > 10% < 3 mo, pregnant, lactating | Total | 1 F/d | 2 F/d | Total | 1 F/d | 2 F/d | Total | 1 F/d | 2 F/d
Sloan 2002 | | | 262 | 132 | 130 | 1 | 1 | 0 | 261 | 131 | 130
Bonner 1999 | | | | | | (1 ineligible)
NCCT 89-20-52
Multiple US institutions, accrual 9/90 through 11/96

Table 3B Patient Characteristics

Study | Age (yr) | | | Gender (%) | | | Race (%) | | | Performance Status (%) | | | Comorbidities or Prognostic Factors (%)
Turrisi 1999 | | [underlined: 1F/d] | [underlined: 2F/d] | | [underlined: 1F/d] | [underlined: 2F/d] | | [underlined: 1F/d] | [underlined: 2 F/D] | [underlined: ECOG:] | [underlined: 1F/d] | [underlined: 2F/d] | | [underlined: 1F/d] | [underlined: 2F/d]
Yuen 2000 | mn | | | M | 59 | 58 | B | 7 | 8 | 0 | 43 | 39 | 5–10% ↓ weight | 15% | 13%
| md | 63 | 61 | F | 41 | 42 | W | 90 | 89 | 1 | 51 | 55 | >10% ↓ weight | 5% | 5%
| mg | 34–80 | 30–82 | | | | O | 3 | 3 | 2 | 5 | 5 | ipsilateral lung | 49% | 55%
| sd | | | | | | | | | | | | mediastinum | 59% | 62%
| >65 | 40% | 31% | | | | | | | | | | ips SC nodes | 3% | 5%
| (p=0.07) | | | | | | | | | | | | variant morphol | 2% | 2%
Schild 2004 | | [underlined: 1 F/D] | [underlined: 2 F/D] | | [underlined: 1 F/D] | [underlined: 2 F/D] | | [underlined: 1 F/D] | [underlined: 2 F/D] | [underlined: ECOG] | [underlined: 1 F/D] | [underlined: 2 F/D] | | [underlined: 1 F/D] | [underlined: 2 F/D]
Sloan 2002 | mn | 61.8 | 62.1 | M | 58.0 | 56.9 | B | | | 0–1 | 97.7 | 93.1 | Measurable | 38.9% | 39.2%
Bonner 1999 | md | 63.0 | 62.5 | F | 42.0 | 43.1 | W | | | 2 | 5.3 | 6.9 | Assessable | 61.1% | 60.8%
| mg | 38–81 | 37–79 | | | | H | | | | | | Wt ↓ ≤ 5% | 87.8% | 89.2%
| sd | | | | | | A | | | | | | Wt ↓ 5–10% | 11.5% | 10.0%
| | | | | | | O | | | | | | Wt ↓ > 10% | 0.8% | 0.8%
| | | | | | | | | | | | | CTx, > SD | 93.1% | 94.6%
| | | | | | | | | | | | | CTx, SD | 5.3% | 4.6%
| | | | | | | | | | | | | CTx, LPD | 0.8% | 0.8%
| | | | | | | | | | | | | CTx, BrM | 0.8% | 0.0%

Table 3C Treatments

Study | Chemotherapy regimen, per protocol | | | One Daily Fraction of TRTx | | Two Daily Fractions of TRTx | | PCI
Turrisi 1999 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule] | 25 Gy; 10 × 2.5 Gy fracs, 5 d/wk over 2 wk; for those with CR after 1° therapy
Yuen 2000 | cisplatin | 60 mg/m^2^ | d1, 3-wk cycles × 4 | 45 Gy | 1.8 Gy fracs, 5 d/wk for 5 wk; started in 1^st^ wk of chemoTx; linac photons only | 45 Gy | 1.5 Gy fracs, 2/d; 5 d/wk for 3 wk; started in 1^st^ wk of chemoTx; linac photons only
| etoposide | 120 mg/m^2^ | d1–3, 3-wk cycles × 4
Schild 2004 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule] | 30 Gy; 15 × 2 Gy fracs, 5 d/wk over 3 wk; for those with CR after 1° therapy
Sloan 2002 | Prerandomization
Bonner 1999 | cisplatin | 30 mg/m^2^ | d 1–3, wks 1, 5, 9 | 50.4 Gy | 28 × 1.8 Gy frac, 38 d, 1^st^ 39.6 Gy in AP-PA fields, last 10.8 Gy in oblique fields excluding spine, 4–10 MeV, wks 13–17 | 48 Gy | 32 × 1.5 Gy frac, ≥4 hrs apart; split course, start week 13: 16 fracs over 1.5 wks, 2.5 wk rest, 16 more fracs over 1.5 wks
| etoposide | 130 mg/m^2^ | d 1–3, wks 1, 5, 9 (4-wk cycles)
| Postrandomization
| cisplatin | 30 mg/m^2^ | d 1–3, wks 13, 17, 21
| etoposide | 100 mg/m^2^ | d 1–3, wks 13, 17, 21

Table 3D Outcome Assessment

Study | Primary Outcomes | Secondary Outcomes | Response Criteria | Observer | F/U
Turrisi 1999 | survival at 2 years | median overall survival; time to treatment failure; local failure rates; response rates; adverse events | CR= no clinical evidence of disease | not specified blinding not mentioned | | [underlined: Total] | [underlined: 1 F/d] | [underlined: 2 F/d]
Yuen 2000 | 82% power to detect absolute Δ of 15% (25% 1/d; 40% 2/d) at 0.05 level (2 sided) | | PR= ≥50%↓ in l × w product of any measurable tumor for at least 4 weeks | | mn
| | | SD= not reported | | md | ~8 yr
| | | PD= ≥10%↓ in body weight, (≥25%↑ in diameter of any tumor (≥2 cm diameter, ≥50%↓ in diameter of any tumor <2 cm diameter, or any new tumor | | rng | ~5-? Yr
| | | | | sd
Schild 2004 | Overall survival | Local progression, distant progression, progression-free survival, toxicity | CR= total disappearance of tumor | Not specified | | [underlined: Total] | [underlined: 1 F/d] | [underlined: 2 F/d]
Sloan 2002 | | | PR= ↓ by ≥50% in greatest perpendicular diameters, all measureable lesions, ≥1 mo | | mn
Bonner 1999 | | | SD= ↓ by < 50%, measurable lesions, ↑ by < 25%, no new lesions | | md | 7.4 yrs
| | | PD= ↑ by ≥25%, any 1 lesion, new lesion, ↓ in PS by ≥ 2 levels | | rng | 4.6–11.9 yrs
| | | | | sd

Table 3E Survival Outcomes

Study | Overall Survival (%) | | | | | | | | Progression-Free or Failure-Free Survival (PFS; FFS)
Turrisi 1999 | | [underlined: N] | [underlined: Med] (mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr] | FFS: | [underlined: N] | [underlined: Med] (mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr]
Yuen 2000 | 1 F/d | 206 | 19 | ~75 | 41% | ~32 | ~29 | 16% | 1 F/d | 206 | | | 24%
| 2 F/d | 211 | 23 | ~70 | 47% | ~28 | ~20 | 26% | 2 F/d | 211 | | | 29%
| (log-rank p=0.04; HR 1.2, 95% CI: 1.0, 1.6) | | | | | | | | | | | | (p=0.10)
Schild 2004 | | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
Sloan 2002 | 1 F/d | 131 | 20.6 | ~74% | 44% | ~33% | ~23% | 20.4% | 1 F/d | 131 | ~14 | ~57% | 31.3% | ~25% | ~23% | 19.8%
Bonner 1999 | 2 F/d | 130 | 20.6 | ~74% | 44% | ~31% | ~26% | 22% | 2 F/d | 130 | ~14 | ~58% | 30.8% | ~27% | ~21% | 21%
| (p=0.68, log-rank) | | | | | | | | (p=0.68, log-rank)

Table 3F Tumor Response and Quality of Life

Study | Tumor Response (%) | | | | | | | Quality of Life
Turrisi 1999 | | [underlined: N] | [underlined: CR] | [underlined: PR] | [underlined: SD] | [underlined: PD] | [underlined: NE] | [underlined: Scale] | [underlined: Domain] | [underlined: F/U] | [underlined: 1/d n] | [underlined: 2/d n] | [underlined: 1/d mn+sd] | [underlined: 2/d mn+sd]
Yuen 2000 | 1/d | 185 | 49 | 38 | 4 | 8 | 2 | | | NOT MEASURED
| 2/d | 196 | 56 | 31 | 4 | 6 | 4
| (P=0.23; no significant difference)
Bonner 1999 | | [underlined: N] | [underlined: CR] | [underlined: PR] | [underlined: SD] | [underlined: PD] | [underlined: NE] | [underlined: Scale] | [underlined: Domain] | [underlined: F/U] | [underlined: 1/d n] | [underlined: 2/d n] | [underlined: 1/d mn+sd] | [underlined: 2/d mn+sd]
Sloan 2002 | 1/d | 132 | 55 | | | | | | | NOT MEASURED
Schild 2004 | 2/d | 130 | 69

Table 3G Adverse Events

Toxicity Type | Study | Severity or Grade | Results
Treatment-related mortality | Turrisi 1999 | not applicable | [underlined: F/U (yr)] | [underlined: 1/d n] | [underlined: %] | [underlined: 2/d n] | [underlined: %]
| Yuen 2000 | | med ~8 | 203 | 2 | 206 | 3
| Bonner 1999 | not applicable | [underlined: F/U (yr)] | [underlined: 1/d n] | [underlined: %] | [underlined: 2/d n] | [underlined: %]
| Sloan 2002 | | med 7.4 | 131 | 0 | 130 | 3
| Schild 2004
Nausea | Turrisi 1999 | | [underlined: F/U (yr)] | [underlined: 1/d n] | [underlined: %] | [underlined: 2/d n] | [underlined: %]
| Yuen 2000
| Bonner 1999 | | F/U (yr) | 1 F/d n | % | 2 F/d n | %
| Sloan 2002 | ≥ grade 3 | | 132 | 16.7 | 130 | 16.9
| Schild 2004
Vomiting | Turrisi 1999 | | [underlined: F/U (yr)] | [underlined: 1/d n] | [underlined: %] | [underlined: 2/d n] | [underlined: %]
| Yuen 2000 | grade 3 | med ~8 | 203 | 8 | 206 | 8
| | grade 4 | | | 2 | | 1
| Bonner 1999 | | F/U (yr) | 1 F/d n | % | 2 F/d n | %
| Sloan 2002 | ≥grade 3 | | 132 | 12.1 | 130 | 14.6
| Schild 2004
Anorexia | Turrisi 1999 | grade 3 weight loss | [underlined: F/U (yr)] | [underlined: 1/d n] | [underlined: %] | [underlined: 2/d n] | [underlined: %]
| Yuen 2000 | (grade 4=0, both arms) | med ~8 | 203 | 3 | 206 | 2
| Bonner 1999 | | F/U (yr) | 1 F/d n | % | 2 F/d n | %
| Sloan 2002 | ≥ grade 3 | | 132 | 3.0 | 130 | 2.3
| Schild 2004
Lethargy | Turrisi 1999 | | [underlined: F/U (yr)] | [underlined: 1/d n] | [underlined: %] | [underlined: 2/d n] | [underlined: %]
| Yuen 2000
| Bonner 1999 | | F/U (yr) | 1 F/d n | % | 2 F/d n | %
| Sloan 2002 | ≥ grade 3 | | 132 | 3.0 | 130 | 7.7
| Schild 2004 | | p=0.09
Neurosensory | Turrisi 1999 | | [underlined: F/U (yr)] | [underlined: 1/d n] | [underlined: %] | [underlined: 2/d n] | [underlined: %]
| Yuen 2000
| Bonner 1999 | | F/U (yr) | 1 F/d n | % | 2 F/d n | %
| Sloan 2002 | ≥ grade 3 | | 132 | 7.6 | 130 | 11.5
| Schild 2004
Hearing loss | Turrisi 1999 | | [underlined: F/U (yr)] | [underlined: 1/d n] | [underlined: %] | [underlined: 2/d n] | [underlined: %]
| Yuen 2000
| Bonner 1999 | | F/U (yr) | 1 F/d n | % | 2 F/d n | %
| Sloan 2002 | ≥ grade 3 | | 132 | 1.5 | 130 | 3.8
| Schild 2004
Esophagitis | Turrisi 1999 | | [underlined: F/U (yr)] | [underlined: 1/d n] | [underlined: %] | [underlined: 2/d n] | [underlined: %]
| Yuen 2000 | grade 3 | med ~ 8 | 203 | 11 | 206 | 27
| | grade 4 | | | 5 | | 5
| | | (p<0.001)
| Bonner 1999 | | F/U (yr) | 1 F/d n | % | 2 F/d n | %
| Sloan 2002 | ≥ grade 3 | | 132 | 5.3 | 130 | 12.3
| Schild 2004 | | p=0.05
Bronchopulmonary | Turrisi 1999 | | [underlined: F/U (yr)] | [underlined: 1/d n] | [underlined: %] | [underlined: 2/d n] | [underlined: %]
| Yuen 2000 | grades 3 | med 8 yr | 203 | 3 | 206 | 4
| | grades 4 & 5 | | | 1 | | 2
| Bonner 1999 | | F/U (yr) | 1 F/d n | % | 2 F/d n | %
| Sloan 2002 | ≥ grade 3 | | 132 | 4.5 | 130 | 6.2
| Schild 2004
Pneumonitis | Turrisi 1999 | | [underlined: F/U (yr)] | [underlined: 1/d n] | [underlined: %] | [underlined: 2/d n] | [underlined: %]
| Yuen 2000
| Bonner 1999 | | F/U (yr) | 1 F/d n | % | 2 F/d n | %
| Sloan 2002 | ≥ grade 3 | | 132 | 4.5 | 130 | 6.2
| Schild 2004
Kidney | Turrisi 1999 | | [underlined: F/U (yr)] | [underlined: 1/d n] | [underlined: %] | [underlined: 2/d n] | [underlined: %]
| Yuen 2000
| Bonner 1999 | | [underlined: F/U (yr)] | [underlined: 1/d n] | [underlined: %] | [underlined: 2/d n] | [underlined: %]
| Sloan 2002
| Schild 2004
Anemia | Turrisi 1999 | | [underlined: F/U (yr)] | [underlined: 1/d n] | [underlined: %] | [underlined: 2/d n] | [underlined: %]
| Yuen 2000 | grade 3 | med ~8 | 203 | 23 | 206 | 23
| | grade 4 | | | 3 | | 5
| Bonner 1999 | | [underlined: F/U (yr)] | [underlined: 1/d n] | [underlined: %] | [underlined: 2/d n] | [underlined: %]
| Sloan 2002 | ≥ grade 3 | | 132 | 3.0 | 130 | 2.3
| Schild 2004
Thrombocytopenia | Turrisi 1999 | | [underlined: F/U (yr)] | [underlined: 1/d n] | [underlined: %] | [underlined: 2/d n] | [underlined: %]
| Yuen 2000 | grade 3 | med ~8 | 203 | 16 | 206 | 13
| | grade 4 | | | 8 | | 8
| Bonner 1999 | | F/U (yr) | 1 F/d n | % | 2 F/d n | %
| Sloan 2002 | ≥ grade 3 | | 128 | 60.9 | 127 | 45.7
| Schild 2004 | grade 4 | | | 24.2 | | 20.5
Leukopenia or neutropenia | Turrisi 1999 | | [underlined: F/U (yr)] | [underlined: 1/d n] | [underlined: %] | [underlined: 2/d n] | [underlined: %]
| Yuen 2000 | grade 3 leukopenia | med ~8 | 203 | 41 | 206 | 38
| | grade 4 leukopenia | | | 39 | | 44
| Bonner 1999 | leukopenia | F/U (yr) | 1 F/d n | % | 2 F/d n | %
| Sloan 2002 | ≥ grade 3 | | 128 | 88.3 | 127 | 89.8
| Schild 2004 | grade 4 | | | 37.5 | | 36.2
Hemoglobin | Turrisi 1999 | | [underlined: F/U (yr)] | [underlined: 1/d n] | [underlined: %] | [underlined: 2/d n] | [underlined: %]
| Yuen 2000
| Bonner 1999 | | F/U (yr) | 1 F/d n | % | 2 F/d n | %
| Sloan 2002 | ≥ grade 3 | | 128 | 5.3 | 127 | 3.8
| Schild 2004 | grade 4 | | | 0.0 | | 0.0
Infection | Turrisi 1999 | | [underlined: F/U (yr)] | [underlined: 1/d n] | [underlined: %] | [underlined: 2/d n] | [underlined: %]
| Yuen 2000 | grade 3 | med ~8 | 203 | 6 | 206 | 6
| | grades 4 & 5 | | | 2 | | 3
| Bonner 1999 | | F/U (yr) | 1 F/d n | % | 2 F/d n | %
| Sloan 2002 | ≥ grade 3 | | 132 | 2.3 | 130 | 3.8
| Schild 2004
Other | Turrisi 1999 | | [underlined: F/U (yr)] | [underlined: 1/d n] | [underlined: %] | [underlined: 2/d n] | [underlined: %]
| Yuen 2000 | one or more grade 3, no grade 4 | med ~8 | 203 | 23 | 206 | 25
| | one or more grade 4, no grade 5 | | | 63 | | 62
| | Any hematologic | F/U (yr) | 1 F/d n | % | 2 F/d n | %
| | ≥ grade 3 | | 131 | 90.1 | 130 | 89.2
| | | p=0.82
| | ≥ grade 4 | | | 43.5 | | 42.3
| | | p=0.84
| | Any nonhematologic | F/U (yr) | 1 F/d n | % | 2 F/d n | %
| Bonner 1999 | ≥ grade 3 | | 131 | 38.9 | 130 | 54.6
| Sloan 2002 | | p=0.01
| Schild 2004 | ≥ grade 4 | | | 9.2 | | 13.8
| | | p=0.24
| | grade 5 | | | 0.0 | | 3.1
| | | p=0.04
| | Any toxicity | F/U (yr) | 1 F/d n | % | 2 F/d n | %
| | ≥ grade 3 | | 131 | 91.6 | 130 | 92.3
| | | p=0.83
| | ≥ grade 4 | | | 46.6 | | 46.9
| | | p=0.95
| | grade 5 | | | 0.0 | | 3.1
| | | p=0.04

Question 3. Alternative Fractionation Schemes

Table 3H Study Quality Ratings

Study | Initial Assembly of Comparable Groups | Low Loss to Followup, Maintenance of Comparable Groups | Measurements Reliable, Valid, Equal* | Interventions Comparable/ Clearly Defined | Appropriate Analysis of Results | Overall Rating
Turrisi 1999 | Yes | Yes | Yes | Yes | Yes | Good
Yuen 2000
Bonner 1999 | Yes | Yes | Yes | Yes | Yes | Good
Sloan 2002
Schild 2004

* Those who rated response or progression were not described as blinded or masked to patients' allocated treatment in any of these reports.

Question 4. Chemotherapy with versus without Thoracic Radiation Therapy, Extensive-Stage Disease (ESD)

Table 4A Sample Selection

Study | Inclusion | Exclusion | n, Randomized | | | n, Withdrawn or Excluded | | | n, Evaluated for Primary Outcome
Jeremic 1999 | confirmed SCLC; extensive stage (disease outside one hemithorax, mediastinum and supraclav. nodes; tumor of >size than tolerable RTx field; or w cytology+ pleural effusion); no prior chemoTx or radioTx; KPS ≥70; adequate renal, hepatic, hematologic function; CR outside thorax and CR or PR in thorax after 3 cycles of PE chemoTx | age>70y; limited stage disease (unilateral disease, w/wo mediastinal involvement, + ipsilateral supraclavicular nodes or cytologyneg pleural effusion); recent or concurrent severe uncontrolled cardiovascular or pulmonary disease; CNS mets or substantially impaired mental status; prior cancer except non-melanoma skin | Total | +TRTx | -TRTx | Total | +TRTx | -TRTx | Total | +TRTx | -TRTx
single center: Kragujevac Univ. Hospital, Yugoslavia | | | 109 | 55 | 54 | 0 | 0 | 0 | 109 | 55 | 54
accrual Jan. 1988 through June 1993 | | | unrandomized groups by post-3^rd^ cycle response (thorax/ elsewhere): | | | 0 | | | unrandomized groups by post-3^rd^ cycle response (thorax/ elsewhere):
| | | CR/PR: | 34 | | 0 | | | CR/PR: | 34
| | | PR/PR: | 28 | | 0 | | | PR/PR: | 28
| | | SD or PD: | 35 | | | | | SD or PD: | 35
Nou 1988 | confirmed SCLC; any age, PS, or expected survival; LSD if one hemithorax ± ipselateral supraclavicular nodes; all others, ESD | surgically resected for uncertain tumor type subsequently found to be SCLC; | Total | +TRTx | -TRTx | Total | +TRTx | -TRTx | Total | +TRTx | -TRTx
Univ. Hospital, Uppsala | | | 54 | 28 | 26 | 0 | 0 | 0 | 54 | 28 | 26
accrual 01/80 through 12/83 | | | (also randomized n=56 with LSD)
Lebeau 1993 | confirmed SCLC; any age, gender, performance status, or disease extent; CR after 5 wks ±heparin then 8 cycles of sequential or alternating chemoTx regimens; some outcomes reported separately by treatment arm for ESD | renal failure; previous chemotherapy or radiation therapy; curative thoracic surgery; “patients who could not be followed up closely” | Total | +TRTx | -TRTx | Total | +TRTx | -TRTx | Total | +TRTx | -TRTx
27 centers in France | | | 18 | 10 | 8 | 0 | 0 | 0 | 18 | 10 | 8
accrual 10/85 through 04/88 | | | (also randomized 35 pts w LSD; n=422 for two previous randomizations)
Rosenthal 1991 | confirmed SCLC; evaluable or measurable disease (LSD or ESD); previously untreated; serum creatinine and liver function tests ≤1.5 × ULNR; response (CR or PR) after 3 cycles of chemotherapy | prior chemo- or radiation therapy; cerebral metastasis; advanced age (not defined) and senility; severe co-existent disease (not defined); non-response after 3 cycles of chemotherapy | Total | +TRTx | -TRTx | Total | +TRTx | -TRTx | Total | +TRTx | -TRTx
3 centers in Australia | | | 27 | ? | ? | 0 | ? | ? | 27 | ? | ?
accrual 01/77 through 07/79 | | | treated n=139 (91, LSD; 48, ESD); randomized responders (66, LSD; 27, ESD) to ±TRTx
Brincker 1987 | confirmed SCLC; <70 years of age; WHO PS 0–2; no clinical signs of CNS metastasis; with or without prior thoracotomy or radical resection ESD defined as metastasis to soft tissue, vicera, or bone or malignant pleural effusion | age ≥ 70 years; WHO PS >2; clinical signs of CNS metastasis | Total | +TRTx | -TRTx | Total | +TRTx | -TRTx | Total | +TRTx | -TRTx
Odense Univ. Hospital, Denmark | | | 43 | 25 | 18 | 13 | 9 | 4 | 30 | 16 | 14
accrual 03/81 through 01/84 | | | | | | (patients dead before day 100 not evaluable; didn't receive full RTx therapy)

Table 4B Patient Characteristics

Study | Age (yr) | | | Gender (%) | | | Race | | | Performance Status (%) | | | Comorbidities or Prognostic Factors (%)
Jeremic 1999 | | [underlined: +TRTx] | [underlined: -TRTx] | | [underlined: +TRTx] | [underlined: -TRTx] | | [underlined: +TRTx] | [underlined: -TRTx] | [underlined: KPS] | [underlined: +TRTx] | [underlined: -TRTx] | | [underlined: +TRTx] | [underlined: -TRTx]
| mn | | | M | 60 | 59 | B | | | 100 | 31 | 24 | weight loss | 45.5 | 43.0
| md | 59 | 59 | F | 40 | 41 | W | not reported | | 90 | 36 | 43 | ≥5%
| rng | 38–70 | 39–71 | | [underlined: M] | [underlined: F] | H | | | 80 | 18 | 18 | # metastatic sites:
| sd | | | CR/PR: | 62 | 38 | A | | | 70 | 15 | 15 | 1 | 41.8 | 46.3
| | [underlined: md] | [underlined: rng] | PR/PR: | 61 | 39 | O | | | | [underlined: 70/80] | [underlined: 90/100] | 2 | 49.1 | 42.6
| CR/PR: | 58 | 41–70 | SD or | 60 | 40 | | | | CR/PR | 35 | 65 | ≥3 | 9.1 | 11.1
| PR/PR: | 60 | 44–69 | PD | | | | | | PR/PR | 32 | 68
| SD or PD: | 59 | 41–69 | | | | | | | SD or PD | 31 | 69
Nou 1988 | | [underlined: +TRTx] | [underlined: -TRTx] | | [underlined: +TRTx] | [underlined: -TRTx] | | [underlined: +TRTx] | [underlined: -TRTx] | [underlined: KPS] | [underlined: +TRTx] | [underlined: -TRTx] | | [underlined: +TRTx] | [underlined: -TRTx]
| mn | | | M | 75 | 69 | B | | | med | 60 | 60 | cerebral mets | 7 | 8
| md | 65 | 60 | F | 25 | 31 | W | not reported | | range | 30–90 | 30–90 | 2 metastatic sites | 36 | 38
| rng | 55–78 | 41–81 | | | | H | | | | | | ≥3 metastatic sites | 14 | 15
| sd | | | | | | A
| | | | | | | O
Lebeau 1993 | | [underlined: +TRTx] | [underlined: -TRTx] | | [underlined: +TRTx] | [underlined: -TRTx] | | [underlined: +TRTx] | [underlined: -TRTx] | [underlined: KPS] | [underlined: +TRTx] | [underlined: -TRTx] | | [underlined: +TRTx] | [underlined: -TRTx]
(only reported characteristics of combined LSD & ESD patients) | % | | | M | 96 | 92 | B | | | 90–100 | 63 | 46 | + heparin | 45 | 58
| <50 | 22 | 23 | F | 4 | 8 | W | not reported | | 70–80 | 22 | 50 | - heparin | 30 | 21
| 50–9 | 30 | 38.5 | | | | H | | | 60 | 15 | 4 | not randomized | 25 | 21
| 60–9 | 33 | 23 | | | | A | | | | | | seq. chemoTx | 67 | 69
| 70–81 | 15 | 15.5 | | | | O | | | | | | alt. chemoTx | 33 | 31
Rosenthal 1991 | | [underlined: +TRTx] | [underlined: -TRTx] | | [underlined: +TRTx] | [underlined: -TRTx] | | [underlined: +TRTx] | [underlined: -TRTx] | [underlined: ECOG] | [underlined: +TRTx] | [underlined: -TRTx] | | [underlined: +TRTx] | [underlined: -TRTx]
(only reported characteristics of all enrolled patients, LSD + ESD, w/wo TRTx) | mn | | | M | 76 | | B | | | 0 | 1
| md | 60 | | F | 24 | | W | not reported | | 1 | 88
| rng | 26–77 | | | | | H | | | 2 | 3
| sd | | | | | | A | | | unknown | 8
| | | | | | | O
Brincker 1987 | | [underlined: +TRTx] | [underlined: -TRTx] | | [underlined: +TRTx] | [underlined: -TRTx] | | [underlined: +TRTx] | [underlined: -TRTx] | [underlined: WHO] | [underlined: +TRTx] | [underlined: -TRTx] | | [underlined: +TRTx] | [underlined: -TRTx]
(only reported characteristics of evaluable combined LSD & ESD patients) | mn | | | M | 73 | 73 | B | | | 0 | 34 | 24
| md | 60 | 63 | F | 27 | 27 | W | not reported | | 1 | 51 | 57
| rng | 42–69 | 46–69 | | | | H | | | 2 | 15 | 19
| sd | | | | | | A
| | | | | | | O

Table 4C Treatments

Study | Chemotherapy regimen, per protocol | | | with Thoracic Radiotherapy | | PCI
Jeremic 1999 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule] | 25 Gy whole brain; 10 daily fracs, 2.5 Gy each, 5 days/wk, wks 14 & 15, both arms
| cisplatin | 80 mg/m^2^ | day 1, wks 1, 4, 7, 16 & 19 (+TRTx); also wks 10 & 13, -TRTx and non-randomized CR/PR and PR/PR groups | 54 Gy | 24 fracs, 1.5 Gy ea, twice daily over 2.5 wks, then 12 fracs, 1.5Gy ea, twice daily on 6 days; wks 10–13; 4.5 to 6 hr between fracs; 6–10 MV linac photons | non-randomized CR/PR and PR/PR groups received same PCI regimen, wks 20–21, if distant CR by wk 20
| etoposide | 80 mg/m^2^ | days 1–3, wks 1, 4, 7, 16 & 19 (+TRTx); also wks 10 & 13, -TRTx and non-randomized groups | non-randomized CR/PR and PR/PR groups received same concurrent TRTx and carboplatin/etoposide chemotherapy, wks 16–19
| carboplatin | 50 mg | each day of TRTx, between fracs
| etoposide | 50 mg | each day of TRTX, between fracs
Nou 1988 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] (all cycles, 3 weeks) | [underlined: Dose] | [underlined: Schedule] | none given
| Cytoxan | 250 mg/m^2^ | days 1, 2 and 3, A cycles | 40 Gy | 1 frac/day, 2 Gy each, 5 days/wk, over 4 weeks; beginning after 3 cycles of regimen A; -TRTx arm give 4^th^ cycle of A regimen at same time; then both arms give 4 cycles each, B regimen, then A, then B, then A, then B; 8- or 16 mV linac photons
| vincristine | 2 mg | day 1, A cycles and B cycles
| doxorubicin | 50 mg/m^2^ | day 1, A cycles
| methotrexate | 100 mg/m^2^ | day 1, A and B cycles (leucovorin on day 2)
| lomustine | 40 mg/m^2^ | day 1, every other B cycle
| Cytoxan | 750 mg/m_2_ | day 1, all B cycles
Lebeau 1993 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule] | “...all responder patients in certain centers or by randomization in other centers as part of a separate study.” PCI given to 21 of 27 in +TRTx group and 17 of 26 in no TRTx group, but no information on LSD or ESD subgroups; also no information on PCI dose or schedule
| CCNU | 80 mg | day 1, X8 4-wk cycles (sequential) cycles 1, 3, 5, 7 (alternating) | varied | started 4 wks after final chemotherapy cycle; dosage ranged from 32 Gy in 9 fracs over 11 or 18 days to 65 Gy in 33 fracs over 64 days; mean 46.5 Gy-equivalents (corresponds to 5 fracs/wk, 2 Gy each) per patient; range 41–65 Gy-equivalents; all used megavoltage X-rays, ≥4 MeV
| Cytoxan | 1 gm/m^2^ | day 1, X8 4-wk cycles (sequential) cycles 1, 3, 5, 7 (alternating)
| doxorubicin | 45 mg/m^2^ | day 1, X8 4-wk cycles (sequential) cycles 1, 3, 5, 7 (alternating)
| etoposide | 225 mg/m^2^ | day 1, X8 4-wk cycles (sequential) cycles 2, 4, 6, 8 (alternating)
| cisplatin | 80 mg/m^2^ | day 1 q4 wk, altern. cycles 2, 4, 6, 8
| vindesine | 3 mg/m^2^ | day 1 q4 wk, altern. cycles 2, 4, 6, 8
Rosenthal 1991 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule] | not mentioned
| vincristine | 1 mg/m^2^ | day 1, q3wk, for 10 cycles | 40 Gy | 20 fracs, given between chemotherapy cycles 3 and 4 in +TRTx arm; other details not provided
| Cytoxan | 750 mg/m^2^ | day 1, q3wk, for 10 cycles
| doxorubicin | 50 mg/m^2^ | day 1, q3wk, for 10 cycles
| methotrexate | 12 mg | intrathecal, with each chemo cycle
| or | 1 g/m^2^ | IV, with folinic acid, cycles 1–3 only (initial randomization)
Brincker 1987 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule] | not mentioned
| vincristine | 2 mg | day 1, odd cycles, 4 wk each | 12 Gy | 600 cGy hemi-body irradiation as single fraction, to upper body on day 60 in place of chemoTx cycle 3, and to lower body on day 100 in place of cycle 4; 8 MeV linac photons
| doxorubicin | 50 mg/m^2^ | day 1, odd cycles, 4 wk each | (alternating chemoTx cycles continued to death or progression for up to 18 months in both arms)
| Cytoxan | 600 mg/m^2^ | day 1, odd cycles, 4 wk each
| lomustine | 60 mg/m^2^ | day 1, even cycles, 4 wk each
| methotrexate | 20 mg/m^2^ | days 1&3, even cycles, 4 wk each
| etoposide | 100 mg/m^2^ | days 1–4, even cycles, 4 wk each

Table 4D Outcome Assessment

Study | Primary Outcomes | Secondary Outcomes | Response Criteria | Observer | F/U
Jeremic 1999 | CR rate | overall, local recurrence-free, distant metastasis-free, and relapse-free survival; objective response rates; adverse events | CR= disappearance of all measurable/assessable disease & no new lesions, ≥4 wk | unspecified | | [underlined: Total] | [underlined: +TRTx] | [underlined: -TRTx]
| 80% power to detect ↑ in CR rate from 25% to 50% at 1-sided 0.05 level | | PR= ↓ by ≥50%, Σ_all lesions_ [products of crosssectional diameters], no new lesions, ≥4 wk | (blinding not mentioned) | mn | | not specified
| | | SD= ↓ by <50% or ↑ by <25% in above sum | | md | but >5 years for the few patients still alive at the time of analysis
| | | PD= ↑ by ≥25% in above sum | | rng
| | | | | sd
Nou 1988 | survival duration | response rates and durations; first sites of recurrence or progression; adverse events; autopsy findings | CR= complete disappearance of all recognizable lesions | unspecified | | [underlined: Total] | [underlined: +TRTx] | [underlined: -TRTx]
| | | PR= ↓ by ≥50% in longest X perpendicular diameter, Σ over all measurable lesions | (blinding not mentioned) | mn
| | | anything less than PR defined as “no response” | | md | “minimal observation time of 4 years” for survivors
| | | | | rng
| | | | | sd | (all were LSD patients)
Lebeau 1993 | survival from TRTx randomization (the only outcome reported by treatment arm separately for ESD patients) | time and site of first recurrence; duration of disease-free and treatment-free survival; adverse events | CR= disappearance of all measurable and evaluable lesions | unspecified | | [underlined: Total] | [underlined: +TRTx] | [underlined: -TRTx]
| | | PR= ↓ by ≥50% in longest and perpendicular diameter for all measurable lesions | (blinding not mentioned) | mn
| | | anything less than PR defined as “no response” | | md | “...each patient...for at least 3 years.”
| | | | | rng
| | | | | sd
Rosenthal 1991 | median survival (the only outcome reported by treatment arm separately for ESD patients) | response rates; relapse rates; sites of failure; “non-tumor related” deaths | CR= not provided | unspecified | | [underlined: Total] | [underlined: +TRTx] | [underlined: -TRTx]
| | (all pooled for LSD + ESD patients) | PR= not provided | (blinding not mentioned) | mn
| | | SD= not provided | | md | “ten-year follow-up”
| | | PD= not provided | | rng
| | | | | sd
Brincker 1987 | not specified | response rates; overall survival; time to progression | CR= total disappearance for ≥90 days of all disease manifestations | “all case reviewed independently by two observers” | | [underlined: Total] | [underlined: +TRTx] | [underlined: -TRTx]
| | | PR= ↓ by ≥50% for ≥90 dys in product of longest perpendicular diameters of indicator lesion | (blinding not mentioned) | “Follow-up was complete with only 3 patients still alive at the time of analysis” (16.8, 18.9, and 47.7 months after randomization)
| | | NC= response for <90 days or ↓ by <50%
| | | PD= ≥25% ↑ in size, measured as for PR
| | | (resected patients: CR if no new lesions by day 90)

Table 4E Survival Outcomes

Study | Overall Survival | | | | | | | | Relapse-Free Survival (RFS) or Time to Progression (TTP)
Jeremic 1999 | | [underlined: N] | [underlined: Med] (mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr] | [underlined: RFS] | [underlined: N] | [underlined: Med] (mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr]
| +TRTx | 55 | 17 | 65 | 38 | 22 | 13 | 9.1 | +TRTx | 55 | 13 | 56 | 35 | 20 | 13 | 9.1
| -TRTx | 54 | 11 | 46 | 28 | 13 | 5.6 | 3.7 | -TRTx | 54 | 9 | 41 | 22 | 9.3 | 5.6 | 1.9
| (p=0.041 by log-rank test) | | | | | | | | (p=0.045 by log-rank test)
| unrandomized groups by post-3^rd^ cycle response (thorax/ elsewhere): | | | | | | | | unrandomized groups by post-3^rd^ cycle response (thorax/ elsewhere):
| CR/PR | 34 | 8 | 35 | 8.8 | 2.9 | 0 | 0 | CR/PR | 34 | 6 | 26 | 5.9 | 0 | 0 | 0
| PR/PR | 28 | 6 | 21 | 3.6 | 0 | 0 | 0 | PR/PR | 28 | 5 | 18 | 0 | 0 | 0 | 0
| SD or PD | 35 | 3 | 0 | 0 | 0 | 0 | 0 | SD or PD | 35 | NR | 0 | 0 | 0 | 0 | 0
Nou 1988 | | [underlined: N] | [underlined: Med] (mos) | | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | | [underlined: N] | [underlined: Med] (mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr]
| +TRTx | 28 | 9.2 (range, 3.8–19.3) | | ~32 | 0 | 0 | 0 | +TRTx
| -TRTx | 26 | 7.6 (range, 2.2–22.7) | | ~26 | 0 | 0 | 0 | -TRTx | | not reported for ESD patients
| | | (chi-square 0.045, 0.8<p<0.9, by life-table analysis)
Lebeau 1993 | | [underlined: N] | [underlined: Med] (mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr] | | [underlined: N] | [underlined: Med] (mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr]
| +TRTx | 10 | ~6.3 | ~10 | ~10 | 0 | 0 | 0 | +TRTx
| -TRTx | 8 | ~7.0 | ~25 | ~12 | ~12 | 0 | 0 | -TRTx | | not reported separately for ESD patients
| | | | (p = 0.43 by log-rank test)
Rosenthal 1991 | | [underlined: N] | [underlined: Med] (mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr] | | [underlined: N] | [underlined: Med] (mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr]
| +TRTx | ? | 5 (95% CI: 2–8) | | | | | | +TRTx
| -TRTx | ? | 7 (95% CI: 3–10) | | | | | | -TRTx | | not reported separately for ESD patients
| | | (p=0.796)
Brincker 1987 | | [underlined: N] | [underlined: Med] (mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr] | [underlined: TTP] | [underlined: N] | [underlined: Med] (mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr]
| +TRTx | 16 | 7 | ~25 | 0 | 0 | 0 | 0 | +TRTx | 16 | 7 | ~23 | 0 | 0 | 0 | 0
| -TRTx | 14 | 10 | ~30 | 0 | 0 | 0 | 0 | -TRTx | 14 | 8.5 | ~26 | 0 | 0 | 0 | 0
| | | | (p = 0.44) | | | | | | | | (p = 0.45)

Table 4F Tumor Response and Quality of Life

Study | Tumor Response (%) | | | | | | | Quality of Life
Jeremic 1999 | | [underlined: N] | [underlined: CR] | [underlined: PR] | [underlined: SD] | [underlined: PD] | [underlined: NE] | [underlined: Scale] | [underlined: Domain] | [underlined: F/U] | [underlined: +TRT n] | [underlined: -TRT n] | [underlined: +TRT mn+sd] | [underlined: -TRT mn+sd]
| +TRTx | 55 | 96 | (mean duration: 22 ± 26 mos) | | | | | | NOT MEASURED
| -TRTx | 53 | 66 | (mean duration: 14 ± 16 mos)
| (local CR rates at wk 21, p = 0.00005; duration, p = 0.055)
Nou 1988 | | [underlined: N] | [underlined: CR] | [underlined: med duration] | [underlined: PR] | [underlined: med duration] | [underlined: NR] | [underlined: Scale] | [underlined: Domain] | [underlined: F/U] | [underlined: +TRT n] | [underlined: -TRT n] | [underlined: +TRT mn+sd] | [underlined: -TRT mn+sd]
| +TRTx | 28 | 11 | 12.4 mo | 75 | 1.4 mo | 14 | | | NOT MEASURED
| -TRTx | 26 | 8 | 12.5 mo | 62 | 1.3 mo | 31
Lebeau 1993 | | [underlined: N] | [underlined: CR] | [underlined: PR] | [underlined: SD] | [underlined: PD] | [underlined: NE] | [underlined: Scale] | [underlined: Domain] | [underlined: F/U] | [underlined: +TRT n] | [underlined: -TRT n] | [underlined: +TRT mn+sd] | [underlined: -TRT mn+sd]
| +TRTx | 10 | 100 | (only randomized patients in CR after 8 cycles of chemotherapy) | | | | | | NOT MEASURED
| -TRTx | 8 | 100
Rosenthal 1991 | | [underlined: N] | [underlined: CR] | [underlined: PR] | [underlined: SD] | [underlined: PD] | [underlined: NE] | [underlined: Scale] | [underlined: Domain] | [underlined: F/U] | [underlined: +TRT n] | [underlined: -TRT n] | [underlined: +TRT mn+sd] | [underlined: -TRT mn+sd]
| +TRTx | | | | | | | | | NOT MEASURED
| -TRTx | | not reported separately for ESD patients
Brincker 1987 | | [underlined: N] | [underlined: CR] | [underlined: PR] | [underlined: NC] | [underlined: PD] | [underlined: NE] | [underlined: Scale] | [underlined: Domain] | [underlined: F/U] | [underlined: +TRT n] | [underlined: -TRT n] | [underlined: +TRT mn+sd] | [underlined: -TRT mn+sd]
| +TRTx | 16 | 12 | 44 | 25 | 19 | 0 | | | NOT MEASURED
| -TRTx | 14 | 7 | 50 | 29 | 14 | 0

Table 4G Adverse Events

Toxicity Type | Study | Severity or Grade | Results
Treatment-related mortality | Jeremic 1999 | not applicable | F/U (yr) | +TRTx n | % | -TRTx n | %
| | | | not reported
| Nou 1988 | not applicable | F/U (yr) | +TRTx n | % | -TRTx n | %
| | | all until death | 28 | 4 | 26 | 4
| | | | | (p NS)
| Lebeau 1993 | not applicable | F/U (yr) | +TRTx n | % | -TRTx n | %
| Rosenthal 1991 | not applicable | F/U (yr) | +TRTx n | % | -TRTx n | %
| Brincker 1987 | not applicable | F/U (yr) | +TRTx n | % | -TRTx n | %
Nausea | Jeremic 1999 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Nou 1988 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Lebeau 1993 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Rosenthal 1991 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Brincker 1987 | “no significant differences between the two treatment groups” | F/U (yr) | +TRTx n | % | -TRTx n | %
Vomiting | Jeremic 1999 | acute grades 3/4 nausea and vomiting | F/U (yr) | +TRTx n | % | -TRTx n | %
| | | not reported | 55 | 9 | 54 | 34
| | | | | (p = 0.0038)
| Nou 1988 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Lebeau 1993 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Rosenthal 1991 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Brincker 1987 | | F/U (yr) | +TRTx n | % | -TRTx n | %
Anorexia | Jeremic 1999 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Nou 1988 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Lebeau 1993 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Rosenthal 1991 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Brincker 1987 | | F/U (yr) | +TRTx n | % | -TRTx n | %
Lethargy | Jeremic 1999 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Nou 1988 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Lebeau 1993 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Rosenthal 1991 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Brincker 1987 | | F/U (yr) | +TRTx n | % | -TRTx n | %
Neurosensory | Jeremic 1999 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Nou 1988 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Lebeau 1993 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Rosenthal 1991 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Brincker 1987 | “no significant differences between the two treatment groups” | F/U (yr) | +TRTx n | % | -TRTx n | %
Hearing loss | Jeremic 1999 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Nou 1988 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Lebeau 1993 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Rosenthal 1991 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Brincker 1987 | | F/U (yr) | +TRTx n | % | -TRTx n | %
Esophagitis | Jeremic 1999 | acute grades 3/4 esophageal | F/U (yr) | +TRTx n | % | -TRTx n | %
| | | not reported | 55 | 27 | 54 | 0
| | | | | (p=0.0002)
| Nou 1988 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Lebeau 1993 | 10 cases of dysphagia reported (LSD+ESD patients), but not attributed to esophagitis | F/U (yr) | +TRTx n | % | -TRTx n | %
| Rosenthal 1991 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Brincker 1987 | no significant difference between groups in stomatitis, not attributed to esophagitis | F/U (yr) | +TRTx n | % | -TRTx n | %
Bronchopulmonary | Jeremic 1999 | acute grade 3 (no grade 4, either arm) | F/U (yr) | +TRTx n | % | -TRTx n | %
| | | not reported | 55 | 5 | 54 | 0
| | | | | (p=0.082)
| Nou 1988 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Lebeau 1993 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Rosenthal 1991 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Brincker 1987 | | F/U (yr) | +TRTx n | % | -TRTx n | %
Pneumonitis | Jeremic 1999 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Nou 1988 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Lebeau 1993 | 3 cases radiation pneumonitis reported (one symptomatic), but not separated by SD versus ESD | F/U (yr) | +TRTx n | % | -TRTx n | %
| Rosenthal 1991 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Brincker 1987 | no cases observed | F/U (yr) | +TRTx n | % | -TRTx n | %
Kidney | Jeremic 1999 | acute grades 3 or 4 | F/U (yr) | +TRTx n | % | -TRTx n | %
| | | not reported | 55 | 0 | 54 | 22
| | | | | (p = 0.001)
| Nou 1988 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Lebeau 1993 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Rosenthal 1991 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Brincker 1987 | | F/U (yr) | +TRTx n | % | -TRTx n | %
Anemia | Jeremic 1999 | acute grades 3 or 4 | F/U (yr) | +TRTx n | % | -TRTx n | %
| | | not reported | 55 | 11 | 54 | 20
| | | | | (p = 0.39)
| Nou 1988 | hemoglobin nadir (median, range) | F/U (yr) | [underlined: +TRTx] | [underlined: n] [underlined: med (rng)] | [underlined: -TRTx n] | [underlined: med (rng)]
| | | until death | 28 | 84 g/L | 26 | 84 g/L
| | | | | (62–120) | | (51–117)
| Lebeau 1993 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Rosenthal 1991 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Brincker 1987 | hemoglobin <6 mmol/l | F/U (yr) | +TRTx n | % | -TRTx n | %
| | | until death | 41 | ~50 | 37 | ~27
| | | | (LSD+ESD) | | (LSD+ESD)
Thrombocytopenia | Jeremic 1999 | acute grades 3/4; | F/U (yr) | +TRTx n | % | -TRTx n | %
| | | not reported | 55 | 27 | 54 | 42
| | | | | (p = 0.23)
| Nou 1988 | thrombocyte count nadir (10^9^/L) (median, range) | F/U (yr) | [underlined: +TRTx n] | [underlined: med (rng)] | [underlined: -TRTx n] | [underlined: med (rng)]
| | | until death | 28 | 25 | 26 | 27
| | | | | (<10–140) | | (<10–219)
| Lebeau 1993 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Rosenthal 1991 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Brincker 1987 | platelets <75×10^3^/μl | F/U (yr) | +TRTx n | % | -TRTx n | %
| | | until death | 41 | ~63 | 37 | ~10
| | | | (LSD+ESD) | | (LSD+ESD)
Leukopenia or neutropenia | Jeremic 1999 | acute grade 3/4; leukopenia | F/U (yr) | +TRTx n | % | -TRTx n | %
| | | not reported | 55 | 44 | 54 | 61
| | | | | (p = 0.18)
| Nou 1988 | leukocyte count nadir (10^9^/L) | F/U (yr) | [underlined: +TRTx n] | [underlined: med (rng)] | [underlined: -TRTx n] | [underlined: med (rng)]
| | (median, range) | Until death | 28 | 0.5 | 26 | 0.5
| | | | | (<0.1–2.7) | | (<0.1–3.3)
| Lebeau 1993 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Rosenthal 1991 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Brincker 1987 | leukocytes < 2.5×10^3^/(l | F/U (yr) | +TRTx n | % | -TRTx n | %
| | | Until death | 41 | ~37 | 37 | ~18
| | | | (LSD+ESD) | | (LSD+ESD)
Infection | Jeremic 1999 | acute grades 3–5 | F/U (yr) | +TRTx n | % | -TRTx n | %
| | | not reported | 55 | 23 | 54 | 33
| | | | | (p=0.64)
| Nou 1988 | septicemia number | F/U (yr) | [underlined: +TRTx n] | [underlined: med (rng)] | [underlined: -TRTx n] | [underlined: med (rng)]
| | (median, range) | Until death | 28 | 2 | 26 | 1
| | | | | (0–4) | | (0–4)
| Lebeau 1993 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Rosenthal 1991 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Brincker 1987 | febrile episodes: no significant differences between arms | F/U (yr) | +TRTx n | % | -TRTx n | %
Other | Jeremic 1999 | combined late grades 3/4; toxicities | F/U (yr) | +TRTx n | % | -TRTx n | %
| | | not reported | 55 | 5 | 54 | 0
| | | | | (p = 0.082)
| Nou 1988 | “other serious side effects” | F/U (yr) | +TRTx n | % | -TRTx n | %
| | | until death | 28 | 29 | 26 | 8
| | | | | (p NS)
| Lebeau 1993 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Rosenthal 1991 | | F/U (yr) | +TRTx n | % | -TRTx n | %
| Brincker 1987 | tolerated 75–100% of chemoTx doses in cycles after hemibody radiation completed | F/U (yr) | +TRTx n | % | -TRTx n | %
| | | until prog. or death | 28 | 25 | 32 | 91
| | | | (LSD+ESD) | | (LSD+ESD)

Table 4H Study Quality Ratings

Study | Initial Assembly of Comparable Groups | Low Loss to Followup, Maintenance of Comparable Groups | Measurements Reliable, Valid, Equal* | Interventions Comparable/ Clearly Defined | Appropriate Analysis of Results | Overall Rating
Jeremic 1999 | partial (arms balanced but randomization method not described) | yes | yes | yes | yes | fair
Nou 1988 | partial (arms balanced but randomization method not described) | yes | yes | yes | yes | fair
Lebeau 1993 | partial (arms balanced for LSD+ESD patients, but data unavailable to compare ESD only groups) | yes | yes | partial (varied TRTx regimens; lack of details on PCI regimen and patient selection | partial (only reported overall survival separately for ESD patients) | poor (to address Q4)
Rosenthal 1991 | uncertain (baseline data not reported separately for treatment groups) | uncertain (conflicting information on randomization to ±TRTx) | yes | yes | partial (only reported overall survival separately for ESD patients) | poor (to address Q4)
Brincker 1987 | yes | no (excluded 13/43, died before day 100) | yes | yes | partial (toxicities not reported separately for ESD group) | poor

* Those who rated response or progression were not described as blinded or masked to patients' allocated treatment in any of these reports.

Question 6: Positron Emission Tomography for Staging of Small-Cell Lung Cancer

Table 6A Sample Selection

Study | Design | Inclusion | Exclusion | n, Enrolled | n, Withdrawn or Excluded | n, Evaluated
Blum 2004 | partially prospective, partially retrospective | histologically/cytologically proven SCLC underwent PET imaging at this institution; consecutive patients; newly diagnosed in 15 who also underwent routine initial staging, restaging in 21; in all cases, PET scan based on review of all clinical data and was performed to guide clinical management; clinical information for 19 obtained from prospective PET SCLC database; clinical information for remaining patients was derived retrospectively | | 36 | | 36
Bradley 2004 | prospective | newly diagnosed confirmed limited stage SCLC, completed standard staging procedures, bilateral hilar involvement defined as limited stage, ipsilateral supraclavicular adenopathy eligible | evidence of disease beyond one hemithorax and mediastinum; diabetes-related fasting hyperglycemia | 25 | 1 (refused to undergo PET) | 24
Brink 2004 | prospective | consecutive patients with histologically confirmed SCLC examined with FDG-PET during primary staging | | 120 | 6 (8 sites) (discrepant findings could not be clarified because patients did not attend follow-up) | 114
Kamel 2003 | prospective | consecutive patients with SCLC referred at this institution for whole-body FDG-PET 2/99-1/03; PET and conventional modalities used for initial staging in 24 patients and restaging after therapy in 20 patients (both in 2) | diabetes mellitus | 45 | 3 (incomplete data) | 42
Shen 2002 | retrospective | histologically confirmed SCLC; KPS ≥ 60%; total serum bilirubin ≤ 2.0 mg/dL; serum creatinine ≤ 2.5 mg/dL; fasting blood sugar ≤ 150 mg/dL | prior CTx or RTx | 25 | | 25
Schumacher 2001 | unclear | histologically proven SCLC, primary staging in 24, therapy follow-up in 4, both in 2; therapy was surgery, RTx and CTx (ACO, EPI-CO, VIP-E, VIC-E); all treatment stopped ≥1 mo before PET | | 30 (36 scans, 77 sites) | | 30

Table 6B Patient Characteristics

Study | Age (yr) | | Gender (%) | | Stage | | Race | Performance Status (%) | Comorbidities or Prognostic Factors (%)
| | | | | Limited % | Extensive %
Blum 2004 | med | 64 | M | 66 | 78 | 22 | NR | NR | NR
| | | F | 33
Bradley 2004 | mn | 60 | M | 44 | 87.5 | 12.5 | NR | NR | NR
| rng | 33–90 | F | 56
Brink 2004 | mn | 60.8 | M | 75 | 37 | 63 | NR | NR | NR
| sd | 8.9 | F | 25
Kamel 2003 | mn | 62 | M | 64 | 62.5 | 37.5 | NR | NR | NR
| rng | 45–83 | F | 36
Pandit 2003 | mn | 63.8 | M | 41 | 43 | 57 | NR | NR | NR
| sd | 9.6 | F | 59
Shen 2002 | mn | 56.4 | M | 72 | 40 | 60 | NR | NR | NR
| sd | 7.2 | F | 28
| rng | 45–68
Schumacher 2001 | mn | 57 | M | 77 | 30 | 70 | NR | NR | NR
| sd | 13 | F | 23
| rng | 34–78

Table 6C Test Procedure and Interpretation

Study | PET Procedure | PET Interpretation | Conventional Staging Procedure | Conventonal Staging Interpretation
Blum 2004 | ≥ 4 hr fast; scanner - GE Quest 300-H; images with and without transmission attenuation correction; whole-body scans of neck, thorax, abdomen; images processed using iterative reconstruction of raw and attenuation-corrected data | physician reporting the PET scans had access to the results of the previous imaging and clinical information; PET scans were interpreted qualitatively; sites of increased uptake coded as uninvolved when due to intercurrent pathology or radiation pneumonitis; PET was not reinterpreted based on subsequent clinical course; PET of brain not performed | initial staging - high-quality CT of chest, upper abdomen, brain, usually bone scan; restaging after initial treatment - CT, bone scan, X-ray; technically inadequate outside imaging studies repeated internally | NR
Bradley 2004 | 4-hr fast, blood glucose determination (< 150 mg/dL), patient supine, 10–15 mCi FDG, series of overlapping 2 min transmission and 5 min emission scans at each bed position, 50 min after IV injection, from upper/mid neck to upper thigh, CTI/Siemans ECAT HR+ scanner, emission images reconstructed with ordered-subset estimation-maximization iterative algorithm with segmented attenuation correction, transmission images and non-attenuation-corrected images reconstructed by filtered back projection with a mathematical attenuation correction | FDG-PET images interpreted prospectively by subjective visual assessment (with ROC grading scheme) for presence of abnormal FDG accumulation, 2 experienced nuclear physicians first independently interpreted PET blinded to results of conventional imaging studies, then observers reread PET images in combination with conventional imaging studies, final PET interpretation based on consensus of 2 observers for blinded readings; also performed semiquantitative evaluation of average maximum standardized uptake value for primary tumor and up to 5 mediastinal metastatic disease sites | history, physical exam, chest X-ray, chest CT, upper abdominal CT, bone scan, contrast-enhanced CT/MRI of brain; all conventional staging procedures completed ≤ 4 wk of PET | NR
Brink 2004 | 12 hr fast, IV injection 5 MBq/kg FDG; elevated fasting plasma glucose (> 6.0 mmol/L) normalized with fast-acting insulin; whole-body scan 90 min after injection; scanner -CTI ECAT EXACT 922 tomograph with 16.2 cm field of view; spatial resolution 7.0 mm FWHM; brain scan 60 min after injection; transmission scan for attenuation correction 2m, emission scan 8 min at each bed position; data corrected for dead time, decay, photon attenuation, images reconstructed by iterative algorithm using ordered set expectation-maximisation and segmented attenuation correction. | images viewed on hard copy and computer workstation, read independently by 2 investigators blinded to other data; any hot spots interpreted as either benign or malignant (focal increased tracer uptake exceeding normal regional accumulation and lesion located at typical metastatic site); images then compared, consensus reached by discussion | whole-body PET performed after CT (mean 12 d, range 1–26 d); conventional staging by history, physical exam, bronchoscopy, thoracic/abdominal contrast-enhanced CT, cranial CT/MRI in 91, bone biopsy in 84 (refused in 36) | NR
Kamel 2003 | ≥ 4 hr fast, IV injection of 300–400 MBq FDG, 40–50 rest for organ uptake, , urinary voiding before scan, 2-min transmission scans, static whole-body scan covered patient from pelvic floor to head, 2 scanners (Advance NXi PET scanner, DISCOVERY LS combined PET/CT in-line device); emission scans with 4-min acquisition time at each of 6–7 bed positions; image datasets reconstructed iteratively with segmented attenuation correction in 26 patients; PET/CT device image datasets reconstructed iteratively using CT data for attenuation correction in 16 patients | pre-PET staging and post-PET staging were always performed independently; PET interpreted with all available clinical information, including CT | history, physical exam, blood tests, bronchoscopy, contrast-enhanced CT of chest, upper abdomen, bone scan, CT/MRI of brain in 9 | NR
Shen 2002 | 6 hr fast; fasting sugar levels obtained for all; 10 mCi (370 MBq) FDG IV injection; scan after 40–50 min; scanner - Siemens-CTI EXACT HR+ or GE advance PET system; 7–8 bed positions; transmission 3 min; emission 7 min; whole-body scan | agreement of at least 2 of 3 experienced nuclear medicine specialists blind to clinical stage | within 2 wk of PET: history, physical exam, blood chemistry, chest X-ray ± chest CT/MRI, brain CT/MRI, abdominal CT/MRI ± hepatic US, pelvic CT/MRI, bone scan, bone marrow biopsy | NR
Schumacher 2001 | 12 hr fast; IV injection 5 MBq FDG/kg; scans started after 90 min; scanner - Siemens ECAT EXACT 921/31 tomograph; 31 planes with 10.6 cm field of view; spatial resolution 6.0 mm FWHM; transmission scan 3 min; emission scan 9 min for each of 7–9 bed positions; from subinguingal region to skull base; images produced based on ordered subset expectation maximization iterative reconstruction algorithm including segmented attenuation correction; separate brain scans in 14 | 2 experienced blinded independent investigators; soft tissue/bone lesions defined as focally increased tracer uptake exceeding normal limits of regional FDG uptake in the area, if lesion located in typical metastatic site, or if standardized uptake value > 4; images reviewed on hard copy and computer workstation; if observers disagreed, consensus reached, used for analysis of results | within 2 wk before or after PET: CT/MRI of brain, thorax, abdomen carried out according to standard protocols, thin-section or contrast enhancement used if needed | NR

Table 6D Reference Standard Procedure and Interpretation, Management Decisions

Study | Decision Rules for Receiving Reference Standard | Reference Standard Procedure | Reference Standard Interpretation | Management Decisions
Blum 2004 | NR | NR | in case of discordance, TP defined as 1) site with biopsy+; or 2) site detected only by PET with tumor progression on structural imaging within 6 mo of PET without treatment; TN defined as 1) site with negative adequate biopsy; or 2) equivocal/negative site on conventional assessment with no progression for ≥ 6 mo without treatment | when available, PET data were used to assist in RTx planning (all FDG-avid lesions included in target volume)
Bradley 2004 | protocol-defined approaches for further evaluation or biopsy: PET+ intrapulmonary parenchymal metastases outside RTx portal, do biopsy; thin-cut CT- or US-guided FNA where feasible; liver PET+, do biopsy/FNA cytology; adrenal PET+, do biopsy; bone PET+, evaluate by appropriate imaging studies (X-ray, CT, MRI, repeat bone scan) or biopsy or bone scan/MRI if multiple bone metastases suspected | NR | NR | left to the discretion of the referring physician, but confirmation of potential extensive-stage disease by biopsy was encouraged
Brink 2004 | if discrepancies appeared between conventional staging and PET, selective additional examinations after review by 1–3 physicians; when discordant LN results between staging examinations did not influence disease stage, no validation sought | histology in ~20%; available data; follow-up | committee of physicians (2 clinicians, 2 nuclear specialists) achieved reference standard diagnosis by consensus; when histologic results were unavailable, consensus based on sum of available data, including follow-up, non-validated results excluded from data analysis | NR
Kamel 2003 | when possible, biopsies or other imaging studies were performed to resolve discrepancies between modalities; | NR | NR | it was considered unethical not to use clear but unconfirmed PET findings for further management decisions, especially those with previously unknown extensive-stage disease; an experienced radiation oncologist compared pre-PET and post-PET tumor stages and changes in RTx decisions were determined
Shen 2002 | if final PET interpretation suggested previously unsuspected lesion, physical exam, biopsy, CT and/or additional nuclear imaging performed | final stage was verified by pathologic findings from thoracotomyy/mediastinoscopy. other imaging results, follow-up ≥ 1 yr | NR | NR
Schumacher 2001 | PET findings were compared with the sum of the findings of other staging procedures | if discrepancies between PET and other staging procedures found, selective additional examinations performed or existing images re-evaluated; in some cases, clinical follow-up proved/disproved inconsistent findings; confirmation necessary within 4 wk | NR | NR

Table 6E Diagnostic Accuracy Results

Study | Test | Focus | n | TP | FN | FP | TN | Prev | Sens | Sens 95% CIL | Sens 95% CIU | Spec | Spec 95% CIL | Spec 95% CIU | PPV | NPV | DA
Blum 2004 | PET | any disease | 36 | 36 | 0 | | | | 100% | 90.3% | 100%
Bradley 2004 | PET | any disease | 24 | 24 | 0 | 1 | 0 | | 100% | 85.8% | 100%
Brink 2004 | PET | LNs | 118 | 53 | 0 | 1 | 64 | 44.9% | 100% | 93.3% | 100% | 98.5% | 91.7% | 100% | 98.1% | 100% | 99.2%
| Conv | | 118 | 37 | 16 | 4 | 61 | 44.9% | 69.8% | 55.7% | 81.7% | 93.8% | 85.0% | 98.3% | 90.2% | 79.2% | 83.1%
| PET | dist, non-brain | 70 | 45 | 1 | 2 | 22 | 65.7% | 97.8% | 88.5% | 99.9% | 91.7% | 73.0% | 99.0% | 95.7% | 95.7% | 95.7%
| Conv | | 70 | 38 | 8 | 5 | 19 | 65.7% | 82.6% | 68.6% | 92.2% | 79.2% | 57.8% | 92.9% | 88.4% | 70.4% | 81.4%
| PET | brain | 91 | 6 | 7 | 2 | 76 | 14.3% | 46.2% | 19.2% | 74.9% | 97.4% | 91.0% | 99.7% | 75.0% | 91.6% | 90.1%
| Conv | | 91 | 13 | 0 | 0 | 78 | 14.3% | 100% | 75.3% | 100% | 100% | 95.4% | 100% | 100% | 100% | 100%
Kamel 2003
Shen 2002 | PET | regl mets | 18 | 20 | 0 | 2 | 0 | | 100% | 83.2% | 100%
| | MD/HL LNs | 9 | 9 | 0 | 2 | 0 | | 100% | 66.4% | 100%
| | ips SC LNs | 7 | 7 | 0 | 0 | 0 | | 100% | 59.0% | 100%
| | ips lung | 2 | 2 | 0 | 0 | 0 | | 100% | 15.8% | 100%
| | distant | 24 | 23 | 1 | 1 | 0 | | 95.8% | 78.9% | 100%
| | contr SC LNs | 5 | 5 | 0 | 0 | 0 | | 100% | 47.8% | 100%
| | contr lung | 3 | 3 | 0 | 1 | 0 | | 100% | 29.2% | 100%
| | liver | 3 | 3 | 0 | 0 | 0 | | 100% | 29.2% | 100%
| | bone/marrow | 6 | 6 | 0 | 0 | 0 | | 100% | 54.1% | 100%
| | brain | 2 | 1 | 1 | 0 | 0 | | 50.0% | 1.3% | 99%
| | adrenal | 2 | 2 | 0 | 0 | 0 | | 100% | 15.8% | 100%
| | other extrathorac | 3 | 3 | 0 | 0 | 0 | | 100% | 29.2% | 100%
Schumacher 2001

Table 6F Staging Accuracy Results

Study | Test | Use | Correctly Upstaged | | Incorrectly Upstaged | | Correctly Downstaged | | Incorrectly Downstaged | | Identified Unsuspected Metastases | | | Ruled Out Suspected Metastases | | | Missed Metastases
| | | # | % | # | % | # | % | # | % | Site | # | % | Site | # | % | Site | # | %
Blum 2004 | PET | staging | 3 | 20
Bradley 2004 | PET | staging | 1 | 4.2 | 1 | 4.2 | | | | | lung | 1 | 4.2
| | | | | | | | | | | regl LNs | 6 | 25
Brink 2004 | PET | staging | 10 | 8.3 | | | 3 | 2.5 | | | | | | | | | brain | 1 | 0.8
Kamel 2003 | PET | staging | 3 | 12.5 | 0 | 0 | 1 | 4.2 | 0 | 0 | visceral/soft tissue | 1 | 4.2 | adrenal | 1 | 4.2 | brain | 2 | 8.3
| | restaging | 1 | 5 | 1 | 5 | 2 | 10 | 0 | 0 | lung | 1 | 5 | LN | 2 | 10 | LN | 1 | 5
| | | | | | | | | | | breast/axilla | 1 | 5 | bone | 1 | 5
Shen 2002 | PET | staging | 1 | 4 | 0 | 0 | 1 | 4 | 0 | 0
Schumacher 2001 | PET | staging | 5 | 19.2
| | restaging | 1 | 16.7

Table 6G Patient Management and Other Results

Study | Test | Use | PET Changed Patient Management
| | | # | % | Changes | Other Findings
Blum 2004 | PET | staging | 4 | 26.7 | forgone RTx for ED | in 11 of 14 discordant disease sites (79%) PET was found to be accurate; 9 of 25 follow-up patients achieved PET CR and had 13.7 mo median time to progression, compared with 9.7 mo for non-CR
| | | 1 | 6.7 | ED, received palliative CTx/RTx
| | | 2 | 13.3 | RTx target volume changed
| | restaging | 3 | 12 | PCI omitted
| | | 3 | 12 | PCI selected
| | | 2 | 8 | forgone CTx, observation for NED
Bradley 2004 | PET | Staging | 7 | 29.2 | RTx target volume changed | PET correctly identified tumor in each primary or nodal SCLC mass that was suspected on CT; unblinded PET more accurate than blinded; PET found no brain metastases (all CT/MRI negative); blinded interobserver agreement 83%; unblinded interobserver agreement 96%
Brink 2004 | PET | | 10 | 8.3 | forgone RTx for ED | complete agreement between PET and other staging procedures in 75 patients; differences occurred in 45 patients at 65 sites (PET correct in 47/65, PET incorrect in 10/65, unconfirmed in 8/65); interobserver agreement kappa 0.94
| | | 3 | 2.5 | selected CTx/RTx
| | | 1 | 0.8 | missed brain metastasis, affected treatment
Kamel 2003 | PET | either | 12 | 29 | | incongruence between PET and anatomic imaging in 9 patients, but mismatch did not change final staging decision
| | staging | 9 | 37 | forgone RTx for ED (3)
| | | | | altered radiation field (5)
| | | | | selected surgery (1)
| | restaging | 3 | 15 | CTx reinstituted (1)
| | | | | CTx discontinued (2)
Shen 2002 | | | | | | 41 of 42 (97.6%) metastases were identified by PET; there were 3 PET FPs and 1 FN
Schumacher 2001 | | | | | | PET and other staging tests agreed in 23 of 36 evaluations (6 for LD, 12 for ED, 5 for NED); disagreed in 13 patients (17 sites); 3 PET FPs (1 brain)

Table 6G-1 Study Quality Ratings

Study | Representative sample? | Clear Selection Criteria? | Reference standard correctly classifies target condition? | Period between test, reference standard short enough? | Whole sample or random selection received reference standard?
Blum 2004 | Unclear | Unclear | Unclear | Unclear | Yes
Bradley 2004 | Yes | Yes | Unclear | Unclear | Yes
Brink 2004 | Unclear | Unclear | Unclear | Unclear | Yes
Kamel 2003 | Unclear | Unclear | Unclear | Unclear | Yes
Shen 2002 | Unclear | Unclaar | Unclear | Unclear | Yes
Schumacher 2001 | Unclear | Unclear | Unclear | Unclear | Yes

Table 6G-2 Study Quality Ratings

Study | Patients received reference standard regardless of test results? | Reference standard independent of test? | Test execution sufficiently described? | Reference standard execution sufficiently described?
Blum 2004 | Unclear | Unclear | Yes | No
Bradley 2004 | Unclear | Yes | Yes | No
Brink 2004 | No | Yes | Yes | No
Kamel 2003 | Unclear | Unclear | Yes | No
Shen 2002 | No | Unclear | No | No
Schumacher 2001 | No | Unclear | Yes | No

Table 6G-3 Study Quality Ratings

Study | Test results interpreted blind to reference standard? | Reference standard results interpreted blind to test? | Clinical practice data available for test interpretation? | Uninterpretable/ indeterminate results reported? | Withdrawals explained?
Blum 2004 | Unclear | Unclear | Yes | No | Yes
Bradley 2004 | Unclear | Unclear | Yes/No | No | Yes
Brink 2004 | Yes | Unclear | No | No | Yes
Kamel 2003 | Unclear | Unclear | Yes | No | Yes
Shen 2002 | Unclear | Unclear | No | No | Yes
Schumacher 2001 | Unclear | Unclear | No | Yes | Yes

Question 8. Surgery versus No Surgery for Limited-Stage Disease

Table 8A Sample Selection

Study | Inclusion | Exclusion | n, Randomized | | | n, Withdrawn | | | n, Evaluated for Primary Outcome
Lad et al. 1994 | confirmed diagnosis of pure SCLC histology; limited stage disease (one hemithorax with negative supraclavicular nodes and no pleural effusion); “fit for thoracotomy”; CR or PR after 5 cycles of CAV; resectable disease; normal brain CT scan | “true T1NOM0 small cell lesions: peripheral nodules”; supraclavicular nodal mets.; pleural, pericardial effusion; super. vena cava syndrome; esophageal invasion; <PR after 5 cycles of CAV; unresectable disease; unfit for thoracotomy | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg] | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg] | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg]
multicenter European/American trial (LCSG/ECOG/ EORTC) | | | 146 | 70 | 76 | 0 | 0 | 0 | 146 | 70 | 76
accrual 1983-89 | | | [71 responders refused randomization post CAV]
Liao et al. 1995 | stage II or III lung cancer (40 SCLC and 40 NSCLC, randomized separately, and outcomes reported separately); no other inclusion criteria reported | none reported | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg] | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg] | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg]
one center RCT (Shanghai) | | | 40 | 20 | 20 | 0 | 0 | 0 | 40 | 20 | 20
accrual 1/90-12/91
Badzio et al. 2004; 2005 | [underlined: surgery] if thoracotomy needed to establish diagnosis; stages I-IIIA; included if pre-op data sufficient for clinical staging; | [underlined: surgical patients]: inadequate data for accurate clinical staging; | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg] | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg] | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg]
retrospective “pair-matched case-control” study single institution (Poland) | [underlined: controls]: suitable for surgery (one involved hemithorax, neg. ipsilateral supraclavicular nodes); | [underlined: controls]: pleural effusion; “low performance status”; | | 76 | 176 | | 9 | 109 | 134 | 67 | 67
accrual 1984-96 | | pair matched for: PS, clinical T and N stages, sex | 7 +Surg w inadequate pre-op. data for clinical staging | | | 109 -Surg patients not matched to +Surg | | | (23 in CR)
| | | 2 +Surg not matched to -Surg controls
Shepherd et al. 1989 | confirmed SCLC by histology or cytology; central lesions; surgical candidates (defined as N1 or early N2 disease; or T3 N0) | peripheral nodule; extensive disease; medically unfit for surgery | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg] | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg] | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg]
prospective multicenter study (Toronto); adjuvant surgery post chemo Tx; compared operated with not operated patients | | | 72 | 38 | 34 | 15 | | 15 | 57 | 38 | 19
| | | | | | ineligible for surgery post chemoTx for: poor response, 9 became unfit, 3 died in month1, 2 lost to follow-up, 1 | | | not operated since: randomized to only radiation (diff. protocol) n=10; refused operation, 9
Namikawa et al. 1994 | all non-metastatic SCLC treated over study period | stage IV disease | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg] | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg] | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg]
retrospective analysis of one-center | | | 101 | 58 | 43 | 0 | 0 | 0 | 101 | 58 | 43
(Japan) series; treated 1960-86 | | | resected | 43
| | | explored | 15
Hara et al. 1991a, 1991b; retrospecttive analysis of one-center (Japan) series; 1972-89 | stages I, II or IIIA histologically or cytologically proven localized SCLC; selected for surgery if technically resectable | stage > IIIA; non-resectable for: tumor extension into adjacent structures, medical contra-indications, refusal | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg] | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg] | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg]
| | | 81 | 36 | 45 | 0 | 0 | 0 | 81 | 36 | 45
Friess et al. 1985 | limited disease (1 hemithorax and ipselateral supraclavicular nodes); compared survival of those who underwent surgery before randomization to those not resected | extensive stage disease | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg] | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg] | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg]
retrospective analysis of patients enrolled in SWOG 7628 trial, 1977-9 | | | 262 | 16 | 246 | 1 | 1 | 0 | 261 | 15 | 246
| | | | | | one surgical patient had carcinoid, not SCLC
Osterlind et al. 1985; retrospective analysis of patients from 6 trials at 2 Danish institutions, 3/73-9/81 | histologically confirmed SCLC; no prior therapy but resection; no distant metastasis; operable based on bronchos-copy, mediastinoscopy and lung function tests | no pre-operative diagnosis (i.e., undergoing diagnostic thoracotomy); distant metastasis; mediastinoscopy not done | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg] | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg] | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg]
| | | 79 | 33 | 46 | 0 | 0 | 0 | 79 | 33 | 46
Rostad et al. 2004 | all technically operable (T1 or T2, N0, M0) limited stage (Ia or Ib) SCLC cases in Norway | extensive disease; technically inoperable; medical contra-indication to surgery | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg] | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg] | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg]
retrospective analysis, Cancer Registry of Norway; all cases 1993-9 | | | | 38 | 96 | | 18 | | | 29 | 96
| | | | | | (given adjuv. chemoTx)
George et al. 1986 | limited disease (one hemithorax with or without ipsilateral hilar, supraclavicular or mediastinal lymph node involvement | extensive disease; pleural effusion; inadequate data in chart for staging or evaluation | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg] | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg] | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg]
population-based registry analysis; all SCLC cases in Rochester, NY; 1975-81 | | | 151 | | | 52 (17, improper entry; 3, 2^nd^ malignancy; 13, dead week 1; 1, refused Tx; 12, pathol. unavail.; 4, mixed histol.; 2, NSCLC | | | 101 | 13 | 88
| | | | | | | | | (CTx only 43)
| | | | | | | | | (Rtx only 20)
| | | | | | | | | (CTx+RTx 25)

Table 8B Patient Characteristics

Study | Age (yr) | | | Gender (%) | | | Race (%) | | | Performance Status (%) | | | Comorbidities or Prognostic Factors (%)
Lad et al. 1994 | | [underlined: +Surg] | [underlined: -Surg] | | [underlined: +Surg] | [underlined: -Surg] | | [underlined: +Surg] | [underlined: -Surg] | [underlined: KPS] | [underlined: +Surg] | [underlined: -Surg] | | [underlined: +Surg] | [underlined: -Surg]
multicenter European/American trial (LCSG/ECOG/EORTC) | mn | | | M | 65 | | B | | | >9 | 82 | | ≤10% weight loss | 92
accrual 1983-89 | md | 59 | | F | 35 | | W | 92 | | | ”groups equally balanced” | | >5 cm^2^ resid tumor | 5
| rng | 35–72 | | | “groups evently matched” | | O | “groups evently matched” | | | | | | ”groups equally balanced”
| sd | “groups evently matched”
Liao et al. 1995 | | [underlined: +Surg] | [underlined: -Surg] | | [underlined: +Surg] | [underlined: -Surg] | | [underlined: +Surg] | [underlined: -Surg] | | [underlined: +Surg] | [underlined: -Surg] | | [underlined: +Surg] | [underlined: -Surg]
one center RCT (Shanghai) | mn | 50 | 54.4 | M | 90 | 90 | B | | | | NOT REPORTED | | clinical stage:
accrual 1/90-12/91 | md | | | F | 10 | 10 | W | not reported | | | | | II | 10 | 5
| rng | 33–74 | 31–66 | | | | O | | | | | | III | 90 | 95
| sd
Badzio et al. 2004; 2005 | | [underlined: +Surg] | [underlined: -Surg] | | [underlined: +Surg] | [underlined: -Surg] | | [underlined: +Surg] | [underlined: -Surg] | [underlined: WHO] | [underlined: +Surg] | [underlined: -Surg] | | [underlined: +Surg] | [underlined: -Surg]
retrospective “pair-matched case-control” study | mn | 57 | 54 | M | 85 | 78 | B | | | 0 | 60 | 58 | % T1/T2 | 14/86 | 17/83
| md | | | F | 15 | 22 | W | not reported | | 1 | 36 | 33 | %N0/N1/N2 | 37/33/30 | 38/31/30
| rng | 29–70 | 36–71 | | p=0.27 | | O | | | 2 | 4 | 9 | clinical stage:
| sd | p=0.03 | | | | | | | | | p=0.57 | | % 1/2/3 | 39/32/29 | 37/33/30
| | | | | | | | | | | | | mean tumor size (cm)
| | | | | | | | | | | | | (range) | 26 (1–96) | 21 (1–64)
Shepherd et al. 1989; prospective multi-center study (Toronto); adjuvant surgery post chemo Tx; compared those given vs. not given surgery | | [underlined: +Surg] | [underlined: -Surg] | | [underlined: +Surg] | [underlined: -Surg] | | [underlined: +Surg] | [underlined: -Surg] | | [underlined: +Surg] | [underlined: -Surg] | | [underlined: +Surg] | [underlined: -Surg]
| mn | | | M | 68 | 53 | B | | | | | | (%)
| md | 60 | 59 | F | 32 | 47 | W | not reported | | | NOT REPORTED | | stage I | 29 | 32
| rng | 39–77 | 44–75 | | | | O | | | | | | stage II | 34 | 5
| sd | | | | | | | | | | | | stage III | 37 | 63
Namikawa et al. 1994 | | +Surg | -Surg | | +Surg | -Surg | | +Surg | -Surg | | +Surg | -Surg | | +Surg | -Surg
retrospective analysis of one- center (Japan) series; treated 1960-86 | mn | | | M | | | B | | | | | | mean time from “onset” to initiation of treatment (months):
| md | NOT REPORTED | | F | NOT REPORTED | | W | not reported | | | NOT REPORTED | | resected: | 2.4 | 3.1
| rng | | | “proportion of women higher” in -Surg group | | | O | | | | | | explored: | 2.9
| sd
Hara et al. 1991a, 1991b retrospective analysis of one-center (Japan) series; treated 1972-89 | | [underlined: +Surg] | [underlined: -Surg] | | [underlined: +Surg] | [underlined: -Surg] | | [underlined: +Surg] | [underlined: -Surg] | [underlined: ECOG] | [underlined: +Surg] | [underlined: -Surg] | [underlined: clinical stage] | [underlined: +Surg] | [underlined: -Surg]
| mn | 64 | 63 | M | 83 | 84 | B | | | 0 | 50 | 18 | I | 33 | 4
| md | | | F | 17 | 16 | W | not reported | | 1 | 44 | 78 | II | 31 | 13
| rng | 44–76 | 45–83 | | | | O | | | 2 | 6 | 4 | IIIA | 36 | 82
| sd
Friess et al. 1985; | | [underlined: +Surg] | [underlined: -Surg] | | [underlined: +Surg] | [underlined: -Surg] | | [underlined: +Surg] | [underlined: -Surg] | | [underlined: +Surg] | -[underlined: Surg] | age, sex, and initial PS of surgical subset was “no different” from the nonresected group
retrospective analysis of patients enrolled in SWOG 7628 trial, 1977-9 | mn | | | M | | | B
| md | NOT REPORTED | | F | NOT REPORTED | | W | not reported | | | NOT REPORTED
| rng | | | | | | O
| sd
Osterlind et al. 1985; | | [underlined: +Surg] | [underlined: -Surg] | | [underlined: +Surg] | [underlined: -Surg] | | [underlined: +Surg] | [underlined: -Surg] | AJC^1^ | [underlined: +Surg] | [underlined: -Surg] | | [underlined: +Surg] | [underlined: -Surg]
retrospective analysis of patients from 6 trials at 2 Danish institutions, 3/73-9/81 | mn | 55 | 60 | M | 82 | 72 | B | | | 0–1 | 83 | 91 | symptom duration, months
| md | | | F | 18 | 28 | W | not reported | | 2 | 17 | 6 | (med, rng): | 2 (0–9) | 3 (1–12)
| rng | | | | | | O | | | 3–4 | 0 | 3 | bone marrow or liver
| sd | 8 | 6 | | | | | | | | | | involvement: | 9 | 11
| | | | | | | | | | | | | LDH>ULN^2^: | 50 | 22
| | | | | | | | | | | | | AST>ULN^2^: | 20 | 17
Rostad et al. 2004 | | [underlined: +Surg] | [underlined: -Surg] | | [underlined: +Surg] | [underlined: -Surg] | | [underlined: +Surg] | [underlined: -Surg] | | [underlined: +Surg] | [underlined: -Surg] | | [underlined: +Surg] | [underlined: -Surg]
retrospective analysis, Cancer Registry of Norway; all cases 1993-9 | mn | | | M | | | B
| md | “no age difference” between groups | | F | NOT REPORTED | | W | not reported | | | NOT REPORTED
| rng | | | | | | O
| sd
George et al. 1986; | | [underlined: all 101] | | | [underlined: all 101] | | | [underlined: +Surg] | [underlined: -Surg] | | [underlined: +Surg] | [underlined: -Surg]
population-based registry analysis; all SCLC cases in Rochester, NY; 1975-81 | 31–40 | 2% | | M | 65% | | B
| 41–50 | 12% | | F | 35% | | W | not reported | | | not reported | | 22% enrolled on an ECOG trial protocol
| 51–60 | 29% | | | | | O
| 61–70 | 38%
| 71–80 | 14%
| >80 | 5%

1 American Joint Committee for Cancer Staging, 1979

Table 8C Treatments

Study | Chemotherapy regimen, per protocol | | | Surgical Procedures (+Surgery arm) | TRTx (if included) | | PCI
Lad et al. 1994 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | thoracotomy and attempted resection: 54 complete, 4 partial resections; 12 unresectable (open & close) | [underlined: Dose] | [underlined: Schedule] | 30 Gy in 15 fracs; at same time as TRTx
multicenter European/American trial; accrual 1983-89 | Cytoxan | 1 g/m^2^ | day 1, q3wk, X5 | | 50 Gy | 25 fractions, after surgery for + arm
| doxorubicin | 50 mg/m^2^ | day 1, q3wk, X5
| vincristine | 1.4 mg/m^2^ | day 1, q3wk, X5
Liao et al. 1995 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | procedures not described; surgery done after chemotherapy cycle 2 for most, cycle 3 for a few (#'s not reported); | [underlined: Dose] | [underlined: Schedule]
one center RCT (Shanghai) | ifosfamide | 1.2 g/m^2^ | days 1–5 | up to 4 more chemotherapy cycles post-operatively | TRTx used only in -surg arm, after 1^st^ 2–3 cycles; dose and schedule not reported; up to 4 more chemotherapy cycles post TRTx | | NOT REPORTED
accrual 1/90-12/91 | MESNA | 400 mg | days 1–5
| doxorubicin | 50 mg/m^2^ | day 1
| vincristine | 1 mg/m^2^ | day 1
| (2–3 cycles initially, then surg or RTx, then 4 additional cycles; duration of cycles not reported)
Badzio et al. 2004; 2005 | surgical patients given one of four regimens post-op: CAV, 4–8 cycles; CDE, 4–6 cycles; PE, 4–6 cycles; or MCCC/CAV/VI; | | | pneumonectomy, n=30; lobectomy, n=37 | [underlined: Dose] | [underlined: Schedule] | n=23 from, +surg arm only; doses and schedules not reported
retrospective “pair-matched case-control” study | control patients given CCMV or ACOM | | | | 30, 40 or 50 Gy | n=39 from -surg arm only; in 10, 20 or 25 fractions, respectively
| doses and schedules not reported
Shepherd et al. 1989; prospective multi-center study (Toronto); adjuvant surgery post chemo Tx; compared those given vs. not given surgery | various regimens for variable number of cycles, including: | | | of 38 patients who underwent thoracotomy, 8 required pneumonectomy, 25 had lobectomy, 5 not resected at thoracotomy (4 had unresectable disease; 1 had no identifiable residual tumor to resect); all had radical mediastinal lymph node dissection | post-operative radiotherapy to tumor bed and mediastinum; total dose ranged from 25 Gy in 10 fracs. to 35 Gy in 20 fracs. | | 20 Gy in five fracs, whole brain radioTx
| CAV, 1–6 cycles, n=29 resected, 33 of 34 not resected; | | | no thoracotomy for any -Surg patients | -Surg patients “received the same radiotherapy at completion of chemotherapy”
| CAV+etoposide, 5 cycles, n=1 resected;
| PE, 3–6 cycles, n=2 resected, 1 of 34 not resected
| (chemotherapy regimens reported only for all 34 non-resected patients, eligible or ineligible)
Namikawa et al. 1994 | NOT REPORTED | | | NOT REPORTED | NOT REPORTED | | NOT REPORTED
retrospective single-center (Japan) series; treated 1960-86
Hara et al. 1991a 1991b | various regimens for both [underlined: +surg] and [underlined: -surg] groups; | | | n=19, surgery→ adjuvant chemotherapy | [underlined: Dose] | [underlined: Schedule]
retrospective analysis of one-center (Japan) series; treated 1972-89 | VCMC | 13 | 25 | N=17, neoadj. chemoTx→surgery; | 46 Gy (avg) | 1.4–2.0 Gy daily in 25–36 fractions | NOT REPORTED
| CAV | 3 | 9 | complete pneumonectomy, 4 | 30–70 Gy (range)
| PE | 4 | 3 | lobectomy, 27
| CAV + PMP | 4 | 1 | bilobectomy 5
| CAV + CVMP | 2 | 0 | surgery “complete” 31
| CAV + PE | 8 | 5 | surgery “incomplete” 5
| other | 2 | 2
| (doses and schedules reported but not abstracted)
Friess et al. 1985 | all patients randomized to one of 4 treatment arms that “...included chemotherapy followed by radiation therapy to the primary site and whole brain prophylaxis.” Surgical subset evenly and randomly distributed to 4 treatment arms (5, 3, 3, and 4) | | | 12 lobectomy | 2 courses 30 Gy with 15 Gy optional boost | | NOT REPORTED
retrospective analysis of patients enrolled in SWOG 7628 trial, 1977-9 | | | | 3 pneumonectomy
Osterlind et al. 1985; retrospective analysis of patients from 6 trials; 2 Danish institutions, 3/73-9/81 | various regimens for both [underlined: +surg] and [underlined: -surg] groups; | | | 11 (33%), complete resection | +surg: n=11 (33%) | | + surg: n=4 (12%)
| CCM | 10 | 10 | 13 (39%), partial resection | -surg: n=15 (33%) | | -surg: n=3 (7%)
| CCMV | 19 | 17 | 9 (27%), neither pneumonectomy nor lobectomy (<partial resection) | no details re dose or schedule | | no details re dose, schedule
| CCMV+doxorubicin+ | 4 | 19
| etoposide
| (doses and schedules not reported)
Rostad et al. 2004 | NOT REPORTED (for technically operable but not resected group; “The majority treated with combined chemotherapy or concurrent chemo-radiotherapy” using doxorubicin, cyclophosphamide, vincristine, or cisplatin based regimens) | | | lobectomy: 15 stage Ia, 5 stage Ib | NO DETAILS REPORTED | | NOT SPECIFIED
retrospective analysis, Cancer Registry of Norway; all cases 1993-9 | | | | bilobectomy: 3 stage Ia, 1 stage Ib
| | | | pneumonect.: 3 stage Ia, 4 stage Ib
| | | | minor resect.: 5 stage Ia, 1 stage Ib
| | | | 1 unknown, for stage or surgery
George et al. 1986; population-based registry analysis; all SCLC cases in Rochester, NY; 1975-81 | CTx or CTx+RTx patients given CCM, CMVP, CC, or CAV | | | not specified; of total n=13, 10 given adjuvant chemotherapy and 2 given adjuvant radiation therapy | NO DETAILS REPORTED | | NOT SPECIFIED
| doses and schedules not specified

Table 8D Outcome Assessment

Study | Primary Outcomes | Secondary Outcomes | Response Criteria | | Observer | F/U
Lad 1994 | mortality (90% probability to detect HR = 2 at 2-sided p=0.05, assuming median OS = 30 mos in superior arm) | surgical success rate; sites of treatment failure; survival by TNM stage; | CR= | no evidence of SCLC by pathology | NOT SPECIFIED | | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg]
multicenter European/American trial; accrual 1983-89 | | | PR= | NOT REPORTED | | mn
| | | SD= | | | md | NOT REPORTED
| | | PD= | | | rng
| | | | | | sd
Liao et al. 1995 | overall survival; power analysis not reported | complete responses; rates of local relapse, distant metastasis | CR= | | NOT SPECIFIED | | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg]
one center RCT (Shanghai) | | | PR= | “WHO tumor treatment remission rate standards” (not described or referenced) | | mn
accrual 1/90-12/91 | | | SD= | | | md | NOT REPORTED
| | | PD= | | | rng
| | | | | | sd
Badzio et al. 2004; 2005 | overall survival from time of diagnosis | time to local relapse or progression; | CR=
retrospective “pair-matched case-control” study | | | PR= | NOT REPORTED | NOT SPECIFIED | | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg]
| | | SD= | | | mn
| | | PD= | | | md | 72 mos
| | | | | | rng
| | | | | | sd
Shepherd et al. 1989; prospective multi-center study (Toronto); adjuvant surgery post chemo Tx; compared those given vs. not given surgery | overall survival from start of pre-op chemoTx to date of death or last follow-up | responses to pre-op chemoTx; survival by clinical and patho-logic (-Surg only) stage; sites of relapse | CR= | | | | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg]
| | | PR= | NOT REPORTED | NOT SPECIFIED | mn
| | | SD= | | | md | NOT REPORTED
| | | PD= | | | rng | but “...all patients... followed... for at least 1 year.”
| | | | | | sd
Namikawa et al. 1994 | overall survival | none | CR= | | | | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg]
retrospective analysis of one- center (Japan) series; treated 1960-86 | | | PR= | NOT REPORTED | | mn
| | | SD= | | | md | NOT REPORTED
| | | PD= | | | rng
| | | | | | sd
Hara et al. 1991a | overall survival | response rates (pre-operative chemoTx and -Surg groups); sites of relapse; operative mortality | CR= | no clinical evidence of disease | | | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg]
1991b; retrospective analysis of one-center (Japan) series; treated 1972-89 | | | PR= | >50%↓, sum of shortest+longest dimensions of all measurable lesions for ≥4 wks | NOT SPECIFIED | mn
| | | SD= | no objective progression or regression | | md | NOT REPORTED
| | | PD= | definite progression of disease | | rng
| | | | | | sd
Friess et al. 1985 | overall survival | none | NOT APPLICABLE | | NOT APPLICABLE | | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg]
retrospective analysis of patients enrolled in SWOG 7628 trial, 1977-9 | | | | | | mn
| | | | | | md | NOT REPORTED
| | | | | | rng
| | | | | | sd
Osterlind et al. 1985; retrospective analysis of patients from 6 trials; 2 Danish institutions, 3/73-9/81 | overall survival | disease-free survival; relapse rate | CR= | | | | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg]
| | | PR= | NOT REPORTED | NOT SPECIFIED | mn
| | | SD= | | | md
| | | PD= | | | rng | 3–9+ yr
| | | | | | sd
Rostad et al. 2004 | overall survival | none | CR= | | | | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg]
retrospective analysis, Cancer Registry of Norway; all cases 1993-9 | | | PR= | NOT REPORTED | NOT RELEVANT | mn
| | | SD= | | | md | NOT REPORTED
| | | PD= | | | rng
| | | | | | sd
George et al. 1986; population-based registry analysis; all SCLC cases in Rochester, NY; 1975-81 | overall survival from time of diagnosis | response rates (non-surgical patients) | CR= | | | | [underlined: Total] | [underlined: +Surg] | [underlined: -Surg]
| | | PR= | Used “...standard ECOG criteria determined by the treating physician at the time” | NOT SPECIFIED | mn | 48 mos
| | | SD= | | | md
| | | PD= | | | rng
| | | | | | sd

Table 8E Survival Outcomes

Study | Overall Survival (%) | | | | | | | | Time to Relapse or Progression (TTR/P)
Lad 1994 | | [underlined: N] | [underlined: Med](mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr] | | [underlined: N] | [underlined: Med](mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr]
multicenter European/American trial; accrual 1983-89 | +surg | 70 | 15.4 | ~60 | 20 | ~20 | ~20 | ~20 | +surg
| -surg | 76 | 18.6 | ~65 | 20 | ~20 | ~20 | ~20 | -surg | | | NOT REPORTED
| | | | (log rank p=0.78)
Liao et al. 1995 | | N | [underlined: Med](mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr] | | [underlined: N] | [underlined: Med](mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr]
one center RCT (Shanghai) | +surg | 20 | | 79 | 52 | 24 | | | +surg
accrual 1/90-12/91 | -surg | 20 | | 63 | 18 | 18 | | | -surg | | | NOT REPORTED
| | | | (log rank p=0.12; t-test for OS at 2 yr, p<0.05)
Badzio et al. 2004, 2005; | | [underlined: N] | [underlined: Med](mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr] | | [underlined: N] | [underlined: Med](mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr]
retrospective matched pair case-control | +surg | 67 | 22.3 | 70 | 43 | ~35 | ~30 | 27 | +surg | 67 | 20.9
| -surg | 67 | 11.2 | 45 | 17 | ~12 | ~4 | 4 | -surg | 67 | 7
| in CR | 23 | 22 | | 36 | | | 26 | | | (p < 0.001)
| | | (p < 0.001; HR = 0.42; 95% CI: 0.28, 0.61)
Shepherd et al. 1989; | | [underlined: N] | [underlined: Med](mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr] | | [underlined: N] | [underlined: Med](mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr]
prospective multi-center study (Toronto); adjuvant surgery post chemo Tx; compared those given vs. not given surgery | +surg | 38 | 22.8 | ~63% | ~47% | ~36% | ~36% | 36% | +surg
| -surg | 19 | 11.8 | ~48% | ~10% | ~10% | ~10% | | -surg | | | NOT REPORTED
| | | (p=0.049)
Namikawa et al. 1994 | | [underlined: N] | Mn (mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr] | | [underlined: N] | [underlined: Med](mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr]
retrospective analysis of one- center (Japan) series; treated 1960-86 | +surg | | | | | | | | +surg
| resect. | 43 | 8.1 | | | | | | -surg | | | NOT REPORTED
| eplor. | 15 | 5.1
| -surg | 43 | 5.2 | (statistical test result not stated)
Hara et al. 1991a 1991b | | [underlined: N] | [underlined: Med](mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr] | | [underlined: N] | [underlined: Med](mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr]
retrospective analysis of one-center (Japan) series; treated 1972-89 | +surg | 36 | 33 | | | 56 | | 38 | +surg
| -surg: | | | | | | | | -surg | | | NOT REPORTED
| CR | 19 | 24.5 | | | ~32 | | 21
| PR | 20 | 12.5 | | | | | 0
| SD/PD | 6 | 6.5 | | | | | 0
Friess et al. 1985 | | [underlined: N] | [underlined: Med](mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr] | | [underlined: N] | [underlined: Med](mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr]
retrospective analysis of patients enrolled in SWOG 7628 trial, 1977-9 | +surg | 15 | 25 | | 44 | | | | +surg
| -surg | 246 | 10.5 | | 13.7 | | | | -surg | | | NOT REPORTED
| | | (p=0.0037) | | (p<0.05)
| -surg, selected for “similar initial presentation” as +surg:
| | 33 | 10 | (range, 1–46+; p=0.03)
Osterlind et al. 1985; | +surg | [underlined: N] | [underlined: Med](mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr] | DFS | [underlined: N] | [underlined: Med](mos) | 1.[underlined: 5 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr]
retrospective analysis of patients from 6 trials; 2 Danish institutions, 3/73-9/81 | -surg | 33 | | ~37 | ~16 | ~14 | ~14 | | +surg | 33 | | 15 | 12
| | | | ~50 | ~16 | ~10 | ~8 | | -surg | 46 | | 15 | 13
| (p=0.35 by life table analysis)
Rostad et al. 2004 | | [underlined: N] | [underlined: Med](mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr] | | [underlined: N] | [underlined: Med](mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr]
retrospective analysis, Cancer Registry of Norway; all cases 1993-9 | +surg | 29 | | | | | | 44.9 | +surg
| -surg | 96 | | | | | 95% CI: | 23.9, 65.9 | -surg | | | NOT REPORTED
| | | | | | | | 11.3
| | | | | | | 95% CI: | 4.2, 18.4
George et al. 1986; | | [underlined: N] | [underlined: Med](mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr] | | [underlined: N] | [underlined: Med](mos) | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr] | [underlined: 5 yr]
population-based registry analysis; all SCLC cases in Rochester, NY; 1975-81 | +surg | 13 | 30.8 | ~70 | ~56 | ~46 | ~40 | ~40 | +surg
| -surg | 88 | 12.4 | | | | | | -surg | | | NOT REPORTED
| CTx | 43 | 11.9 | ~43 | ~15 | ~10 | ~4 | 0
| RTX | 20 | 13.4 | ~58 | ~20 | ~20 | ~20 | ~18
| both | 25 | 14.1
| | | | (p=0.009 versus -surg)

Table 8F Tumor Response and Quality of Life

Study | Tumor Response (%) | | | | | | | Quality of Life
Lad 1994 | | [underlined: N] | [underlined: CR] | [underlined: PR] | [underlined: SD] | [underlined: PD] | [underlined: NE] | [underlined: Scale] | [underlined: Domain] | [underlined: F/U] | [underlined: +surg n] | [underlined: -surg n] | [underlined: +surg mn+sd] | [underlined: -surg mn+sd]
multicenter RCT; accrual 1983-89 | +surg | 70 | 19 | | | | | NOT MEASURED
| -surg | 76 | NOT REPORTED
Liao et al. 1995 | | [underlined: N] | [underlined: CR] | [underlined: PR] | [underlined: SD] | [underlined: PD] | [underlined: NE] | [underlined: Scale] | [underlined: Domain] | [underlined: F/U] | [underlined: +surg n] | [underlined: -surg n] | [underlined: +surg mn+sd] | [underlined: -surg mn+sd]
one center RCT (Shanghai) | +surg | 20 | 70 | | | | | NOT MEASURED
1/90-12/91 | -surg | 20 | 80
Badzio et al. 2004, 2005; retrospecttive “matched pair case-control” study | | [underlined: N] | [underlined: CR] | [underlined: PR] | [underlined: SD] | [underlined: PD] | [underlined: NE] | [underlined: Scale] | [underlined: Domain] | [underlined: F/U] | [underlined: +surg n] | [underlined: -surg n] | [underlined: +surg mn+sd] | [underlined: -surg mn+sd]
| +surg | | | | | | | NOT MEASURED
| -surg | | NOT REPORTED
Shepherd et al. 1989; prospective multicenter trial (Toronto); adjuvant surgery post chemoTx; compared those given vs. not given surgery | | [underlined: N] | [underlined: CR] | [underlined: PR] | [underlined: SD] | [underlined: NC/PD] | [underlined: ED*] | [underlined: Scale] | [underlined: Domain] | [underlined: F/U] | [underlined: +surg n] | [underlined: -surg n] | [underlined: +surg mn+sd] | [underlined: -surg mn+sd]
| +surg | 38 | 45 | 50 | — | 5 | 0 | NOT MEASURED
| -surg | 34 | 29 | 32 | — | 32 | 6
| all | 72 | 38 | 42 | — | 18 | 3
| *ED = early death
Namikawa et al. 1994 | | [underlined: N] | [underlined: CR] | [underlined: PR] | [underlined: SD] | [underlined: PD] | [underlined: NE] | [underlined: Scale] | [underlined: Domain] | [underlined: F/U] | [underlined: +surg n] | [underlined: -surg n] | [underlined: +surg mn+sd] | [underlined: -surg mn+sd]
retrospective analysis, one- center (Japan) series; treated 1960-86 | +surg | | | | | | | NOT MEASURED
| -surg | | NOT REPORTED
Hara et al. 1991a 1991b; retrospective analysis of one-center (Japan) series; treated 1972-89 | | [underlined: N] | [underlined: CR] | [underlined: PR] | [underlined: SD] | [underlined: PD] | [underlined: NE] | [underlined: Scale] | [underlined: Domain] | [underlined: F/U] | [underlined: +surg n] | [underlined: -surg n] | [underlined: +surg mn+sd] | [underlined: -surg mn+sd]
| +surg | | NOT APPLICABLE | | | | | NOT MEASURED
| -surg | 45 | 42.5 | 44 | 13.5
Friess et al. 1985; retrospective analysis of patients enrolled in SWOG 7628 trial, 1977-9 | | [underlined: N] | [underlined: CR] | [underlined: PR] | [underlined: SD] | [underlined: PD] | [underlined: NE] | [underlined: Scale] | [underlined: Domain] | [underlined: F/U] | [underlined: +surg n] | [underlined: -surg n] | [underlined: +surg mn+sd] | [underlined: -surg mn+sd]
| +surg | | | | | | | NOT MEASURED
| -surg | | NOT REPORTED
Osterlind et al. 1985; retrospective analysis of patients from 6 trials; 2 Danish institutions, 3/73-9/81 | | [underlined: N] | [underlined: CR] | [underlined: PR] | [underlined: SD] | [underlined: PD] | [underlined: NE] | [underlined: Scale] | [underlined: Domain] | [underlined: F/U] | [underlined: +surg n] | [underlined: -surg n] | [underlined: +surg mn+sd] | [underlined: -surg mn+sd]
| +surg | | | | | | | NOT MEASURED
| -surg | | NOT REPORTED
Rostad et al. 2004 | | [underlined: N] | [underlined: CR] | [underlined: PR] | [underlined: SD] | [underlined: PD] | [underlined: NE] | [underlined: Scale] | [underlined: Domain] | [underlined: F/U] | [underlined: +surg n] | [underlined: -surg n] | [underlined: +surg mn+sd] | [underlined: -surg mn+sd]
retrospective analysis, Cancer Registry of Norway; all cases 1993-9 | +surg | | | | | | | NOT MEASURED
| -surg | | NOT REPORTED
George et al. 1986; population-based registry analysis; all SCLC cases, Rochester, NY; 1975-81 | | [underlined: N] | [underlined: CR] | [underlined: PR] | [underlined: SD/NR] | [underlined: PD] | [underlined: NE] | [underlined: Scale] | [underlined: Domain] | [underlined: F/U] | [underlined: +surg n] | [underlined: -surg n] | [underlined: +surg mn+sd] | [underlined: -surg mn+sd]
| +surg | 13 | 92 | 0 | 0 | 8 | 0 | NOT MEASURED
| -surg | 88 | 32
| CTx | 43 | 12 | 25 | 16 | 47 | 0
| RTx | 20 | 55 | 10 | 15 | 20 | 0
| both | 25 | 48 | 40 | 4 | 8 | 0

Table 8G Adverse Events

Toxicity Type | Study | Severity or Grade | Results
Treatment-related (operative) mortality | Lad et al. 1994 | not applicable | [underlined: F/U (yr)] | [underlined: +surg n] | [underlined: %] | [underlined: -surg n] | [underlined: %]
| | | not reported | 70 | 2.9 | 76 | not reported
| Liao et al. 1994 | not applicable | [underlined: F/U (yr)] | [underlined: +surg n] | [underlined: %] | [underlined: -surg n] | [underlined: %]
| | | not reported | 20 | 0 | 20 | 0
| Badzio et al. 2004, 2005 | not applicable | [underlined: F/U (yr)] | [underlined: +surg n] | [underlined: %] | [underlined: -surg n] | [underlined: %]
| | | NOT REPORTED
| Shepherd et al. 1989 | not applicable | [underlined: F/U (yr)] | [underlined: +surg n] | [underlined: %] | [underlined: -surg n] | [underlined: %]
| | | >1 | 38 | 0 | eligible 19
| | | [2 of 72 (3%) died after 1st course of chemoTx]
| Namikawa et al. 1994 | not applicable | [underlined: F/U (yr)] | [underlined: +surg n] | [underlined: %] | [underlined: -surg n] | [underlined: %]
| | | NOT REPORTED
| Hara et al. 1991a, 1991b | not applicable | [underlined: F/U (yr)] | [underlined: +surg n] | [underlined: %] | [underlined: -surg n] | [underlined: %]
| | | not reported | 36 | 0 | 45 | not reported
| Friess et al. 1985 | not applicable | [underlined: F/U (yr)] | [underlined: +surg n] | [underlined: %] | [underlined: -surg n] | [underlined: %]
| | | NOT REPORTED
| Osterlind et al. 1985 | not applicable | [underlined: F/U (yr)] | [underlined: +surg n] | [underlined: %] | [underlined: -surg n] | [underlined: %]
| | | 3–9+ | NOT REPORTED
| Rostad et al. 2004 | not applicable | [underlined: F/U (yr)] | [underlined: +surg n] | [underlined: %] | [underlined: -surg n] | [underlined: %]
| | | NOT REPORTED
| George et al. 1986 | not applicable | [underlined: F/U (yr)] | [underlined: +surg n] | [underlined: %] | [underlined: -surg n] | [underlined: %]
| | | 3.7 (mn) | 13 | 0 | 88 | 1
| | | | | | (given CTx+RTx)

Shepherd et al. (1989) is the only study that reported postoperative complications other than mortality. Among 38 resected, they observed:

1 severe bronchospasm (2.6%)

1 prolonged atelectasis (2.6%)

1 pulmonary edema (2.6%)

2 transient arrhythmias (5.3%)

1 assisted ventilation for 6 weeks (2.6%)

Table 8H Study Quality Ratings

Study | Initial Assembly of Comparable Groups | Low Loss to Followup, Maintenance of Comparable Groups | Measurements Reliable, Valid, Equal | Interventions Comparable/ Clearly Defined | Appropriate Analysis of Results | Overall Rating
Lad et al. 1994 | uncertain (report states groups “evenly matched” but baseline data pooled across arms) | yes (all randomized patients included in analysis) | yes | yes | uncertain peri-operative mortality only reported adverse event | fair
multicenter RCT European/American
Liao et al. 1995 | uncertain insufficient data on baseline characteristics (no data on performance status) | no | yes | uncertain extent of surgery, TRTx regimen not reported | uncertain operative complications not reported | poor
one center RCT (Shanghai) | | 15–20% per arm lost to follow-up
Badzio et al. 2004 | uncertain not randomized; “pair-matched case-control” study; groups differed significantly in age | yes (all matched pairs followed and analyzed) | yes | uncertain regimens, doses varied and not specified | no no data on adverse events | poor
retrospective “pair-matched case-control” one-center study
Shepherd et al. 1989; | uncertain not randomized; more females, stage III patients in -Surg group; more males, stage II patients in +Surg group | yes all followed and analyzed | yes | uncertain regimens, doses varied and inadequately specified | yes most complete reporting on operative complications | fair
prospective multi-ctr study (Toronto); adjuvant surgery post chemo Tx; compared those given vs. not given surgery
Namikawa et al. 1994 | no not randomized; inadequate data comparing base-line characteristics | yes all followed and analyzed | yes | uncertain regimens, doses varied and not specified | no statistical test results not reported, no data on adverse events | poor
retrospective analysis, one-center series
Hara et al. 1991 | no not randomized; large differences between groups for stage, PS | yes all followed and analyzed | yes | uncertain regimens, doses, varied (although well reported) | yes | poor
retrospective analysis of one-center (Japan) series; treated 1960-86
Friess et al. 1985 | uncertain (report states groups “evenly matched” but baseline data not reported) | yes all followed and analyzed | yes | yes | uncertain surgical group denominator unavailable for mortality | fair
retrospective analysis of patients enrolled in SWOG 7628 trial, 1977-9
Osterlind et al. 1985; | yes while not randomized, groups appear similar | yes all followed and analyzed | yes | partial chemoTx, TRTx and PCI doses and schedules not reported | partial only reported OS and DFS | fair
retrospective analysis of patients from 6 trials; 2 Danish institutions, 3/73-9/81
Rostad et al. 2004 | no not randomized; no data comparing base-line characteristics | yes all in database followed and analyzed | yes | uncertain regimens, doses varied and not specified | no no data on adverse events | poor
population-based registry analysis
George et al. 1986 | no not randomized; no data comparing base-line characteristics | yes all in database followed and analyzed | yes | uncertain regimens, doses varied and not specified | no no data on adverse events | poor
population-based registry analysis

Question 9. Treatment of Recurrent/Progressive Disease

Table 9A Sample Selection, Randomized Trials

Study | Inclusion | Exclusion | n, Randomized | n, Withdrawn or Excluded | n, Evaluated for Primary Outcome
O'Brien 2005 | relapsed SCLC ineligible for further IV CTx; PS 0–2 | | 141 | | 141
Sculier 2002 | Proven SCLC; prior CTx did not include platinum or etoposide; evaluable/ measureable lesion; KPS ≥ 60; adequate hematologic, hepatic, renal function; | Active or non-cured malignancy; age > 75; active infectious disease, psychological disorders, MI < 3 mo, CHF/arrhythmia | 72 | 7 | 65
1/94 - 4/01
European Lung Cancer Working Party
von Pawel 2001 | Limited or extensive SCLC had recurred ≥ 3 mo after CR/PR to 1^st^-line CTx; enrollment stratified by stage, response duration, presence liver metastases; ≥ 2 cm measurable disease; LE ≥ 2 mo; adequate bone marrow, hepatic, renal function; ≥ 4 wks since surgery, 24 hrs since RTx; | Previous/current malignancies; brain metastases allowable if signs/symptoms attributable to them or on corticosteroids; severe or uncontrolled medical problems | 106 | | 106
31 centers in Europe, South Africa and Australia
von Pawel 1999 | Documented progressive, limited or extensive SCLC; PD ≥ 60 d after 1^st^-line CTx; ≥ 1 bidimensionally measurable lesion; ECOG PS 0–2; adequate bone marrow, hepatic, renal function; ≥ 4 wks since surgery, 24 hrs since RTx; | Previous/current malignancies; brain metastases if symptomatic or on corticosteroids; pre-existing cardiac disease (CHF/arrhythmias/MI < 3 mo); CAV contraindicated; exceeded lifetime doses of doxorubicin or epirubicin; prior topotecan; > 1 prior CTx regimen | 211 | | 211
International multicenter trial
Postmus 1993 | Proven SCLC; age ≤ 75; ECOG PS 0–3; adequate hematoogic, hepatic, renal function; documented progression ≤ 3 mo of last CTx; previously treated with combination CTx on EORTC 08862 protocol; | CNS metastases | 68 | | 68
6/86 - 5/90
Multiple European centers
Trillet-Lenoir 1992 | Documented relapsing SCLC to 1^st^-line CTx; adequate hematologic, hepatic function | Age > 65; KPS < 60%; severe renal, cardiac disease | 37 | 5 | 32
8/87 - 4/91
8 centers in France
O'Bryan 1990 | SCLC; failed or relapsed after 1^st^-line CTx; measurable tumor; recovered from prior therapy; KPS 3 or better; LE ≥ 6 wks; good risk = tolerated prior CTx, no prior RTx, age ≤ 65 | Prior treatment with this study's combination of drugs (but use of cisplatin or vincristine allowable); | 103 | | 103
SWOG | | | (+26 nonrandomized patients)
Spiro 1989 | 2-stage randomized trial: stage 1 – 1^st^-line chemotherapy (4 or 8 cycles of CVE), stage 2 – 2^nd^-line chemotherapy/ supportive care; histologically, cytologically proven SCLC; < 75; | Vascular, renal, neurological disease which would preclude chemotherapy | 610 | 440 | 170
02/82 - 09/85
Multiple centers in the United Kingdom
Wolff 1986 | Proven SCLC; prior CTx not including etoposide; recurrent and measurable disease; age ≤ 65; LE > 2 mo; KPS > 60%; normal peripheral blood cell counts; | Evidence of serious organ dysfunction not attributable to tumor | 79 | 2 | 77
US center

Table 9B Patient Characteristics, Randomized Trial

Study | Age (yr) | | | | Gender (%) | | | | Previous Treatment Regimens (%) | | | | Performance Status (%) | | | | Comorbidities or Prognostic Factors (%)
O'Brien 2005 | | [underlined: po T] | [underlined: BSC] | | | [underlined: All] | | | | | | | [underlined: PS] | [underlined: po T] | [underlined: BSC] | | | [underlined: po T] | [underlined: BSC]
| mn | | | | M | 73 | | | | | | | 0/1 | 73 | 67 | | ED | 68 | 61
| md | 60 | 59 | | F | 27 | | | | | | | | | | | med TTP (d) | 84 | 90
| rng
| sd
Sculier 2002 | | [underlined: PE] | [underlined: CbPE] | | | [underlined: PE] | [underlined: CbPE] | | | [underlined: PE] | [underlined: CbPE] | | [underlined: KPS] | [underlined: PE] | [underlined: CbPE] | | | [underlined: PE] | [underlined: CbPE]
| mn | | | | M | 84 | 76 | | EVI | 84 | 79 | | 60–70 | 45 | 32 | | > 5% ↓ wt | 16 | 29
| md | 58 | 59 | | F | 16 | 24 | | VAC, other | 16 | 21 | | 80–100 | 55 | 68 | | OR 1^st^ CTx | 74 | 68
| rng | 41–73 | 39–70 | | | | | | RTx | 6 | 18
| sd | | | | | | | | Surgery | 3 | 0
von Pawel 2001 | | [underlined: po T] | [underlined: iv T] | | | [underlined: po T] | [underlined: iv T] | | | | | | [underlined: PS] | [underlined: po T] | [underlined: iv T] | | | [underlined: po T] | [underlined: iv T]
| mn | 59.9 | 58.2 | | M | 75.0 | 79.6 | | | | | | 0 | 19.2 | 33.3 | | limited | 26.9 | 25.9
| md | | | | F | 25.0 | 20.4 | | | | | | 1 | 65.4 | 38.9 | | extensive | 71.2 | 72.2
| rng | 38–79 | 35–74 | | | | | | | | | | 2 | 15.4 | 27.8 | | liver mets | 30.8 | 31.5
| sd
von Pawel 1999 | | | | | | | | | | [underlined: iv T] | [underlined: CAV] | | [underlined: ECOG] | [underlined: iv T] | [underlined: CAV] | | | [underlined: iv T] | [underlined: CAV]
| | | | | | | | | Platinum | 51.4 | 44.2 | | 0 | 16.8 | 19.2 | | Prior brain RTx | 25.2 | 23.1
| | | | | | | | | CAV | 18.7 | 15.4 | | 1 | 59.8 | 61.5 | | Med TTP-wks | 24.4 | 22.9
| | | | | | | | | PE+CAV | 12.1 | 16.3 | | 2 | 23.4 | 19.2 | | Liver mets | 40.2 | 40.4
| | | | | | | | | RTx | 61.7 | 55.8 | | | | | | Brain mets | 11.2 | 24.0
| | | | | | | | | Immunotherapy | 0.0 | 1.9 | | | | | | Limited | 16.8 | 15.4
| | | | | | | | | Surgery | 14.0 | 27.9 | | | | | | Extensive | 83.2 | 84.6
Postmus 1993 | | [underlined: IMP] | [underlined: VP] | [underlined: CDE] | | [underlined: MP] | [underlined: VP] | [underlined: CDE] | | [underlined: IMP] | [underlined: VP] | [underlined: CDE] | [underlined: ECOG] | [underlined: IMP] | [underlined: VP] | [underlined: CDE] | [underlined: 1^st^-2^nd^-line] | [underlined: IMP] | [underlined: VP] | [underlined: CDE]
| avg | 57 | 58 | 55 | M | 71 | 86 | 88 | 1 1^st^-line cycle | 0 | 9 | 0 | 0 | 24 | 18 | 20 | 0–4 wks | 38 | 64 | 44
| rng | 38- | 39- | 43- | F | 29 | 14 | 12 | 2 cycles | 14 | 32 | 8 | 1 | 43 | 45 | 40 | 5–8 | 29 | 32 | 28
| | 69 | 73 | 67 | | | | | 3 cycles | 10 | 14 | 0 | 2 | 24 | 32 | 20 | 9–13 | 33 | 5 | 28
| sd | | | | | | | | 4 cycles | 5 | 14 | 16 | 3 | 10 | 5 | 20 | [underlined: Stage]
| | | | | | | | | 5 cycles | 71 | 32 | 52 | | | | | Limited | 29 | 45 | 40
| | | | | | | | | > 5 cycles | 0 | 0 | 24 | | | | | Extensive | 71 | 55 | 60
Trillet-Lenoir 1992 | | [underlined: PE1] | [underlined: PE2] | | | [underlined: PE1] | [underlined: PE2] | | | | | | [underlined: KPS] | [underlined: PE1] | [underlined: PE2] | | | [underlined: PE1] | [underlined: PE2]
| mn | 56.73 | 52.47 | | M | 100 | 88 | | | | | | mn | 79.17 | 74.71 | | mn LDH | 431.4 | 565.7
| md | | | | F | 0 | 12 | | | | | | sd | 13.82 | 10.06 | | sd, LDH | 108 | 423.7
| rng | | | | | | | | | | | | | | | | 1^st^-line ORR | 100 | 76
| sd | 8.7 | 5.95
O'Bryan 1990 | | [underlined: BTOC] | [underlined: PE] | | | [underlined: BTOC] | [underlined: PE] | | | [underlined: BTOC] | [underlined: PE] | | [underlined: KPS] | [underlined: BTOC] | [underlined: PE] | | | [underlined: BTOC] | [underlined: PE]
| mn | | | | M | 80 | 64 | | CAV | 49 | 52 | | 0–1 | 53 | 39 | | Limited | 16 | 21
| md | 58 | 61 | | F | 20 | 36 | | Etoposide | 24 | 19 | | 2–3 | 47 | 61 | | Extensive | 84 | 79
| rng | 41–75 | 38–76 | | | | | | Other | 27 | 29 | | | | | | Good risk | 24 | 64
| sd | | | | | | | | | | | | | | | | Poor risk | 76 | 36
Spiro 1989 | | [underlined: MA] | [underlined: PE] | | | [underlined: MA] | [underlined: BSC] | | | [underlined: MA] | [underlined: BSC] | | | [underlined: MA] | [underlined: BSC] | | | [underlined: MA] | [underlined: BSC]
| mn | | | | M
| md | | | | F
| rng
| sd
Wolff 1986 | | [underlined: 100] | [underlined: 200] | [underlined: 300] | | [underlined: 100] | [underlined: 200] | [underlined: 300] | | [underlined: 100] | [underlined: 200] | [underlined: 300] | [underlined: KPS] | [underlined: 100] | [underlined: 200] | [underlined: 300] | [underlined: Site] | [underlined: 100] | [underlined: 200] | [underlined: 300]
| < 50 | 19 | 11 | 15 | M | 58 | 93 | 81 | 1 CTx reg | 88 | 78 | 73 | 60 | 0 | 15 | 0 | Contra lung | 19 | 15 | 4
| 50–60 | 38 | 56 | 46 | F | 42 | 7 | 19 | 2 CTx regs | 12 | 19 | 12 | 70 | 46 | 33 | 46 | Liver | 19 | 26 | 19
| > 60 | 42 | 33 | 31 | | | | | 3 CTx regs | 0 | 4 | 15 | 80 | 27 | 41 | 31 | Brain | 15 | 11 | 19
| | | | | | | | | RTx | 54 | 52 | 73 | 90 | 19 | 7 | 12 | Marrow | 15 | 15 | 12
| | | | | | | | | Surgery | 23 | 22 | 38 | 100 | 8 | 4 | 12 | Bone | 15 | 30 | 23
| | | | | | | | | | | | | | | | | Subcut | 4 | 7 | 4
| | | | | | | | | | | | | | | | | Med LNs | 31 | 22 | 23
| | | | | | | | | | | | | | | | | SC LNs | 27 | 30 | 0

Table 9C Treatments, Randomized Trials

Study | Treatment Regimen | | | | Outcomes | Response Criteria | Observer | Follow-up
O'Brien 2005 | [underlined: Group] | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Overall survival (1°), symptom control, tumor response, adverse events | WHO criteria
| po T | topotecan | 2.3 mg/ m^2^ | d1–5, q 21 d
| BSC | best supportive care
Sculier 2002 | [underlined: Group] | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response (1°), response duration, survival, adverse outcomes | CR= all clinically detectable disease gone, ≥ 4 wks | | mn
| PE | cisplatin | 20 mg/m^2^ | d1–3, q 21 d, ≥ 3 cycles | | PR= ↓ by ≥50%, all measureable lesions, ≥ 4 wks | | md | 46 mo
| | etoposide | 100 mg/m^2^ | d1–3, q 21 d, ≥ 3 cycles | | SD= ↓ in lesion size by <50% or ↑ by <25%, no PD ≥ 3 mo | | rng | 2–90 mo
| CbPE | carboplatin | 200 mg/m^2^ | d1, q 21 d, ≥ 3 cycles | | PD= ↑ by ≥25%, cross sectional area, ≥1 lesion/new lesion | | sd
| | cisplatin | 20 mg/m^2^ | d2–3, q 21 d, ≥ 3 cycles
| | etoposide | 100 mg/m^2^ | d1–3, q 21 d, ≥ 3 cycles
von Pawel 2001 | [underlined: Group] | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response (1°), time to progression, survival, symptoms, adverse events | WHO criteria | Blinded | mn
| po T | topotecan | 2.3 mg/m^2^ | po, d1–5, q 21 d, ≥ 4 cycles | | | | md
| iv T | topotecan | 1.5 mg/m^2^ | iv, d1–5, q 21 d, ≥ 4 cycles | | | | rng
| | | | | | | | sd
Von Pawel 1999 | [underlined: Group] | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response (1°), time to progression, survival, symptoms, adverse events | WHO criteria | Blinded | mn
| iv T | topotecan | 1.5 mg/m^2^ | iv, d1–5, q 21 d, 1–15 cycles | | | | md
| CAV | cytoxan | 1 g/m^2^ | d1, q 21 d, 1–7 cycles | | | | rng
| | doxorubin | 45 mg/m^2^ | d1, q 21 d, 1–7 cycles | | | | sd
| | vincristine | 2 mg | d1, q 21 d, 1–7 cycles
Postmus 1993 | [underlined: Group] | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response (1°), survival, adverse events | WHO criteria | | mn
| IMP | ifosfamide | 5 g/ m^2^ | d1, q 28 d, max 5 cycles | | | | md
| | mesna | 4.35 g/ m^2^ | d1, q 28 d, max 5 cycles | | | | rng
| | carboplatin | 400 mg/ m^2^ | d1, q 28 d, max 5 cycles | | | | sd
| VP | vincristine | 2 mg | d1, 8, q 28 d, max 5 cycles
| | carboplatin | 400 mg/ m^2^ | d1, q 28 d, max 5 cycles
| CDE | cytoxan | 1 g/ m^2^ | d1, q 28 d, max 5 cycles
| | doxorubicin | 45 mg/ m^2^ | d1, q 28 d, max 5 cycles
| | etoposide | 100 mg/ m^2^ | d1, 3, 5, q 28 d, max 5 cycles
| IMP, VP, CDE were 1^st^-line regimens, progression on IMP/VP treated with 2^nd^-line CDE, progression on CDE treated with 2^nd^-line VIMP
Trillet-Lenoir 1992 | [underlined: Group] | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response (1°), survival, adverse events | | | mn
| PE1 | cisplatin | 20 mg/m^2^ | d1–5, q 28 d | | | | md
| | etoposide | 60 mg/m^2^ | d1–5, q 28 d | | | | rng
| PE2 | cisplatin | 40 mg/m^2^ | d1–5, q 28 d | | | | sd
| | etoposide | 100 mg/m^2^ | d1–5, q 28 d
O'Bryan 1990 | [underlined: Group] | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response (1°), survival, adverse events | CR= all clinically detectable disease gone, ≥ 4 wks
| BTOC | vincristine | 2 mg | d1, 21, 42 | | PR= ↓ by ≥50%, all measureable lesions, ≥ 4 wks | | mn
| | thiotepa | 20 mg/m^2^ | d1, 21, 42 | | | | md
| | cytoxan | .375/.5 g/ m^2^ | d1, 21, 42 | | | | rng
| | carmustine | 100 mg/m^2^ | d1, 21, 42 | | | | sd
| PE | cisplatin | 50 mg/m^2^ | d2
| | | 75 mg/m^2^ | d2
| | etoposide | 100 mg/m^2^ | d1, 3, 4
| | | 125 mg/m^2^ | d1, 3, 4
Spiro 1989 | [underlined: Group] | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Survival (1°), progresssion-free survival, tumor ressponse | CR= all clinically detectable disease gone, | | mn
| MA | methotrexate | 50 mg/ m^2^ | q 21 d, ≤ 9 cycles | | PR= ↓ by ≥50%, all measureable lesions, ≥ 3 wks | | md
| | doxorubicin | 50 mg/ m^2^ | q 21 d, ≤ 9 cycles | | SD= ↓ in lesion size by <50% | | rng
| BSC | best supportive care | | | | | | sd
Wolff 1986 | [underlined: Group] | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response (1°), survival, adverse events | SECSG criteria | | mn
| E100 | etoposide | 100 mg/m^2^ | d1–3 | | | | md
| E200 | etoposide | 200 mg/m^2^ | d1–3 | | | | rng
| E300 | etoposide | 300 mg/m^2^ | d1–3 | | | | sd

Table 9D Survival Outcomes

Study | Overall Survival (%) | | | | | | | | Progression-Free Survival (%)
O'Brien 2005 | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| po T | 71 | 26 wks | 49 (6 mo) | | | | | po T | 71 | 84 d
| BSC | 70 | 14 wks | 26 | | | | | BSC | 70 | 90 d
| HR=0.64 (95% CI: 0.45, 0.90, p=0.0104)
Sculier 2002 | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| PE | 31 | 18.9 wks | 18
| CbPE | 34 | 33.0 wks | 19
| Log-rank, p=0.11
von Pawel 2001 | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| po T | 52 | 32.3 wks | ~25 | | | | | po T | 52 | 14.9 wks | ~5
| iv T | 54 | 25.1 wks | ~8 | | | | | iv T | 54 | 13.1 wks
| adjusted RR=0.90 (95% CI 0.55, 1.47, NS) | | | | | | | | adjusted RR=0.98 (95% CI 0.63, 1.54, NS)
von Pawel 1999 | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| iv T | 107 | 25.0 wks | 14.2 | | | | | iv T | 107 | 13.3 wks
| CAV | 104 | 24.7 wks | 14.4 | | | | | CAV | 104 | 12.3 wks
| Log-rank, p=0.772, adjusted RR=1.17 (p=0.322) | | | | | | | | p=0.552
Postmus 1993 | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| VIMP | 43 | 19 wks
| CDE | 25 | 22 wks
Trillet-Lenoir 1992 | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| PE1 | 15 | 13 wks
| PE2 | 17 | 16.5 wks
O'Bryan 1990 | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| BTOC | 45 | 13 wks
| PE | 58 | 16 wks
| (RR 1.3, 95%CI 0.9, 2.0)
| BTOCgood | 11 | 10 wks
| PEgood | 16 | 35 wks
| (RR 3.3, 95%CI 1.2, 9.1)
| BTOCpoor | 34 | 14 wks
| PEpoor | 68 | 12 wks
| (RR1.1, 95%CI 0.7, 1.8)
Spiro 1989 | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| MA
| BSC
Wolff 1986 | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| E100 | 26 | 12.6 wks | ~4
| E200 | 27 | 20.0 wks | ~12
| E300 | 26 | 22.5 wks | ~24
| Log-rank, Gehan-Wilcoxon, p=NS)

Table 9E Tumor Response and Quality of Life, Randomized Trials

Study | Tumor Response (%) | | | | | | | Quality of Life
O'Brien 2005 | | N | CR | PR | SD | PD | NE | | Scale | Domain | | F/U | n | mn±sd
| po T | 71 | 7 | | 44 | | | QoL EQ-5D: significantly faster deterioration in BSC arm
| BSC | 70
Sculier 2002 | | N | CR | PR | SD | PD | NE | | Scale | Domain | | F/U | n | mn±sd
| PE | 31 | 0 | 29
| CbPE | 34 | 9 | 38
| Median response duration: PE 5.2 mo, CbPE 7.8 mo
von Pawel 2001 | | N | CR | PR | SD | PD | NE | | | | po | Topotecan | iv | Topotecan
| po T | 52 | 1.9 | 21.2 | 19.2 | 30.8 | 26.9 | Scale | Domain | F/U | n | % improved | n | % improved
| iv T | 54 | 3.7 | 11.1 | 29.6 | 42.6 | 13.0 | Symptoms | chest pain | post-CTx | 19 | 42.1 | 22 | 31.8
| Difference in ORR = 8.3% (95% CI -6.6%, 23.1%, NS) | | | | | | | | dyspnea | | 29 | 13.8 | 33 | 27.3
| Median response duration: po T 18.1 wks, iv T 13.9 wks | | | | | | | | cough | | 31 | 16.1 | 36 | 22.2
| | | | | | | | | hemoptysis | | 3 | 33.3 | 10 | 40.0
| | | | | | | | | anorexia | | 27 | 18.5 | 29 | 31.0
| | | | | | | | | insomnia | | 25 | 32.0 | 27 | 26.6
| | | | | | | | | hoarseness | | 14 | 35.7 | 24 | 37.5
| | | | | | | | | fatigue | | 33 | 21.2 | 36 | 16.7
| | | | | | | | | impaired ADLs | | 31 | 25.8 | 36 | 22.2
von Pawel 1999 | | N | CR | PR | SD | PD | NE | | | | iv | Topotecan | CAV
| iv T | 107 | 0.0 | 24.3 | 19.6 | 45.8 | 10.3 | Scale | Domain | F/U | n | % improved | n | % improved
| CAV | 104 | 1.0 | 17.3 | 11.5 | 52.9 | 17.3 | Symptoms | chest pain | post-CTx | 44 | 25.0 | 41 | 17.1
| Difference in ORR, p=0.285 | | | | | | | | dyspnea* | | 68 | 27.9 | 61 | 6.6
| Median response duration iv T 14.4, CAV 15.3 (p=0.300) | | | | | | | *p<0.05 | cough | | 69 | 24.6 | 61 | 14.8
| | | | | | | | | hemoptysis | | 15 | 26.7 | 12 | 33.3
| | | | | | | | | anorexia* | | 56 | 32.1 | 57 | 15.8
| | | | | | | | | insomnia | | 57 | 33.3 | 53 | 18.9
| | | | | | | | | hoarseness* | | 40 | 32.5 | 38 | 13.2
| | | | | | | | | fatigue* | | 70 | 22.9 | 65 | 9.2
| | | | | | | | | impaired ADLs* | | 67 | 26.9 | 63 | 11.1
Postmus 1993 | | N | CR | PR | SD | PD | NE | | Scale | Domain | | F/U | n | mn±sd
| VIMP | 25 | 4 | 56 | 8 | 24 | 8
| CDE | 43 | 14 | 37 | 19 | 23 | 7
| Median response duration VIMP 16 wks (4–30), CDE 19 wks (12–34)
Trillet-Lenoir 1992 | | N | CR | PR | SD | PD | NE | | Scale | Domain | | F/U | n | mn±sd
| PE1 | 15 | 6.6 | 20 | 13.3 | 60
| PE2 | 17 | 11.8 | 23.5 | 11.8 | 52.9
O'Bryan 1990 | | N | CR | PR | SD | PD | NE | | Scale | Domain | | F/U | n | mn±sd
| BTOC | 45 | 0 | 13
| PE | 58 | 2 | 10 | (p=0.91)
| BTOCgood | 11 | 27
| PEgood | 16 | 27
| BTOCpoor | 34 | 9
| PEpoor | 68 | 9
Spiro 1989 | | N | CR | PR | SD | PD | NE | | Scale | Domain | | F/U | n | mn±sd
| MA | 170 | 4 | 19 | 45 | 32 | 1
Wolff 1986 | | N | CR | PR | SD | PD | NE | | Scale | Domain | | F/U | n | mn±sd
| E100 | 26 | | 4
| E200 | 27 | | 7
| E300 | 26 | | 4

Table 9F Adverse Events, Randomized Trials

Toxicity Type | Study | Description | Group | n | Gr 3 % | Gr 4 % | p value^1^
Treatment-related mortality | O'Bryan 1990 | Drug-related deaths | BTOC | 45 | 4 | | 0.28
| | | PE | 84 | 1
Alopecia | Sculier 2002 | | PE | 28 | 21 (3/4) | | 0.15
| | | CbPE | 31 | 39
| von Pawel 2001 | | po T | 52 | 1.9 | 0.0 | 0.06
| | | iv T | 54 | 13.0 | 0.0
| von Pawel 1999 | | iv T | 107 | 0.0 (3/4) | | 1.0
| | | CAV | 104 | 0.0
Fatigue | von Pawel 2001 | | po T | 52 | 5.8 | 0.0 | 0.36
| | | iv T | 54 | 1.9 | 0.0
| von Pawel 1999 | | iv T | 107 | 4.7 (3/4) | | 0.28
| | | CAV | 104 | 8.7
Diarrhea | von Pawel 2001 | | po T | 52 | 7.7 | 0.0 | 0.054
| | | iv T | 54 | 0.0 | 0.0
| von Pawel 1999 | | iv T | 107 | 0.9 (3/4) | | 1.0
| | | CAV | 104 | 0.0
Nausea | O'Brien 2005 | | po T | 71 | 1 | | 1.0
| | | BSC | 70 | 0
| von Pawel 1999 | | iv T | 107 | 39.3 (3/4) | | 0.89
| | | CAV | 104 | 40.4
Vomiting | O'Brien 2005 | | po T | 71 | 3 | | 0.50
| | | BSC | 70 | 0
| Sculier 2002 | Nausea/vomiting | PE | 30 | 7 (3/4) | | 0.23
| | | | 32 | 0
| von Pawel 2001 | | po T | 52 | 11.5 | 0.0 | 0.16
| | | iv T | 54 | 3.7 | 0.0
| von Pawel 1999 | | iv T | 107 | 2.9 (3/4) | | 1.0
| | | CAV | 104 | 1.9
| Wolf 1986 | Nausea/vomiting/bloody diarrhea/stomatitis | E100 | 26 | 5 | 0 | 0.44
| | | E200 | 27 | 4 | 0
| | | E300 | 26 | 10 | 0
Anorexia | von Pawel 1999 | | iv T | 107 | 0.9 (3/4) | | 1.0
| | | CAV | 104 | 0.0
Diarrhea | O'Brien 2005 | | po T | 71 | 6 | | 0.12
| | | BSC | 70 | 0
Lethargy | O'Brien 2005 | Fatigue | po T | 71 | 4 | | 1.0
| | | BSC | 70 | 4
Neurosensory | O'Brien 2005 | Pain | po T | 71 | 3 | | 0.44
| | | BSC | 70 | 6
Neuromotor
Hearing loss
Esophagitis
Bronchopulmonary | O'Brien 2005 | Dyspnea | po T | 71 | 3 | | 0.32
| | | BSC | 70 | 9
| von Pawel 2001 | Dyspnea | po T | 52 | 9.6 | 0 | 1.0
| | | iv T | 54 | 9.3 | 0 (5:1.9)
| | Pulmonary embolism | po T | 52 | 1.9 | 0 (5: 3.8) | 0.36
| | | iv T | 54 | 0 | 0 (5: 1.9)
Pneumonitis | von Pawel 2001 | Pneumonia | po T | 52 | 5.8 | 1.9 | 0.054
| | | iv T | 54 | 0.0 | 0.0
Hepatic
Kidney
Hemorrhage
Anemia | O'Brien 2005 | | po T | 71 | 25 (3/4)
| von Pawel 2001 | | po T | 52 | 27.5 | 3.9 | 1.0
| | | iv T | 54 | 26.4 | 3.8
| von Pawel 1999 | | iv T | 104 | 39.4 | 2.9 | 0.001
| | | CAV | 101 | 17.8 | 2.0
Thrombocytopenia | O'Brien 2005 | | po T | 71 | | 7
| Sculier 2002 | | PE | 30 | 17 (3/4) | | 0.07
| | | CbPE | 32 | 38
| von Pawel 2001 | | po T | 52 | 25.5 | 27.5 | 0.85
| | | iv T | 54 | 24.5 | 24.5
| von Pawel 1999 | | iv T | 104 | 28.8 | 28.8 | <0.001
| | | CAV | 101 | 9.9 | 5.0
| Postmus 1993 | | VIMP | 25 | 8 | 45 | <0.001
| | | CDE | 43 | 6 | 3
| Trillet-Lenoir 1992 | | PE1 | 15 | 0 | 7 | 0.041
| | | PE2 | 17 | 18 | 24
| Wolff 1986 | Neutropenia | E100 | 26 | 0 | 15 | <0.001
| | | E200 | 27 | 0 | 13
| | | E300 | 26 | 24 | 33
Leukopenia or neutropenia | O'Brien 2005 | Neutropenia | po T | 71 | | 33
| Sculier 2002 | Leukopenia | PE | 30 | 60 (3/4) | | 0.76
| | | CbPE | 32 | 56
| von Pawel 2001 | Leukopenia | po T | 52 | 27.5 | 17.6 | 0.006
| | | iv T | 54 | 45.3 | 28.3
| | Neutropenia | po T | 52 | 21.6 | 35.3 | <0.001
| | | iv T | 54 | 25.9 | 67.3
Leukopenia or neutropenia | von Pawel 1999 | Leukopenia | iv T | 104 | 54.8 | 31.7 | 0.34
| | | CAV | 101 | 37.6 | 43.6
| | Neutropenia | iv T | 104 | 18.3 | 70.2 | 0.83
| | | CAV | 99 | 15.2 | 71.7
| Postmus 1993 | Leukopenia | VIMP | 25 | 26 | 40 | 1.0
| | | CDE | 43 | 38 | 25
| Trillet-Lenoir 1992 | Leukopenia | PE1 | 15 | 33 | 13 | 0.021
| | | PE2 | 17 | 12 | 76
| Wolff 1986 | | E100 | 26 | 5 | 0 | <0.001
| | | E200 | 27 | 25 | 54
| | | E300 | 26 | 0 | 86
Infection | O'Brien 2005 | Febrile neutropenia | po T | 71 | | 3
| | Neutropenic infections | po T | 71 | | 1
| | Sepsis | po T | 71 | | 4
| Sculier 2002 | | PE | 30 | 3 (3/4) | | 0.96
| | | CbPE | 33 | 3
| von Pawel 2001 | Fever | po T | 52 | 3.8 | 1.9 (5:1.9) | 0.20
| | | iv T | 54 | 1.9 | 0.0
Other

1 Comparison of grade 3 and above versus others Fisher's exact test.

^2^ Comparison of grade 3 and above versus others Fisher's exact test.

Table 9G Study Quality Ratings, Randomized Trials

Study | Initial Assembly of Comparable Groups | Low Loss to Followup, Maintenance of Comparable Groups | Measurements Reliable, Valid, Equal | Interventions Comparable/ Clearly Defined | Appropriate Analysis of Results | Overall Rating
O'Brien 2005 | | | | | | ? Available only in abstract
Sculier 2002 | Partial (arms balanced but randomization method not described) | Yes | Partial (overall response rate was primary outcome) | Yes | Yes | Fair
von Pawel 2001 | Partial (arms balanced but randomization method not described) | Yes | Yes | Yes | Yes | Fair
von Pawel 1999 | Partial (randomization method adequate, but age and gender distributions not specified) | Yes | Yes | Yes | Yes | Fair
Postmus 1993 | Partial (arms balanced but randomization method not described) | Yes | Partial (overall response rate was primary outcome) | Yes | Yes | Fair
Trillet-Lenoir 1992 | Partial (arms balanced but randomization method not described) | Yes | ? | No | Yes | Poor
O'Bryan 1990 | Partial (arms balanced but randomization method not described) | Yes | Partial (overall response rate was primary outcome) | No | Yes | Poor
Spiro 1989 | Partial (arms balanced but randomization method not described) | ? | Yes | Yes | No | Poor
Wolff 1986 | No | Yes | Partial (overall response rate was primary outcome) | No | No | Poor

Table 9H Sample Selection, Phase II Studies

Study | Inclusion | Exclusion | n, Enrolled | n, Withdrawn | n, Evaluated
Ando 2004 | Diagnosis of SCLC; refractory (off CTx < 2 mo, n=16) or relapsed (off CTx > 2 mo, n=9) after initial etoposide regimen; measurable disease; ECOG PS ≥2; adequate bone marrow, hepatic, rental function; age 15–75 | brain metastases; severe medical problems that would interfere with compliance | 25 | | 25
2/98 – 5/01
Multiple centers in Japan
Agelaki 2004 | Confirmed SCLC, refractory or relapsing, bidimensionally measurable disease, limited or extensive and had relapsed after ≥ 1 CTx regimen, WHO PS 0–2, LE ≥ 3 mo, ≥ 4 wks since CTX, RTx to < 25 % of marrow-containing bones ≥ 4 wks after; adequate hematologic, renal, hepatic function; brain metastases allowed if previous RTx with clinical, radiologic improvement; age 18–75 | Infections, malnutrition, concurrent active malignancy | 31 | 5 NE | 26
11/99 – 09/02
Multiple centers in Greece
Goto 2004 | Histologically/cytologically confirmed SCLC; responded to 1^st^-line therapy, relapsed ≥ 8 wks; age ≤ 75; ECOG PS 0–2; measurable disease; adequate hematologic, hepatic, renal function | Massive pleural effusion; prior RTx to area larger than 1/3 bone marrow volume; active infection; contraindications to use or irinotecan | 40 | | 40
10/98–03/01
Multiple centers in Japan
Ardizzoni 2003 | Confirmed SCLC, relapsed, ≥ bidimensionally measurable lesion outside areas of prior RTx, WHO PS 0–2; PD after 1^st^-line CTX (except camptothecin analogues; cisplatin allowable if responsive, CTx ≥ 6 mo before;1^st^-line CTx regimen given twice allowable; all CTx/Rtx stopped ≥ 4wks with recovery from side effects; asymptomatic brain metastases allowable; brain RTx allowable after current treatment; symptomatic brain metastases allowable if prior treatment adequate; adequate hematologic, renal, hepatic function; age 18–75; | Pre-existing uncontrolled cardiac disease; documented MI < 3 mo; ≥ grade 2 sensory/motor neuropathy; active infection; past or current history of neoplasms | 116 | 6 | 110
1/97 – 4/99 | | | | ineligible
Multiple European centers
Hainsworth 2003 | Proven SCLC; PD after 1 CTx regimen; ≤ 2 course prior RTx; < 25% of marrow-bearing bone in RTx fields; brain metastases allowable if minimal neurologic impairment with whole brain RTx; ECOG PS 0–2; adequate hematologic, hepatic, renal function | | 30 | | 30
3/98 – 2/99
6 US centers
Hoang et al. 2003 | Previously treated SCLC patients; sensitive (recurrence > 3 mo after 1^st^-line CTx) or refractory (PD or recurrence ≤ 3 mo); limited or extensive; measurable/evaluable; 1 prior CTx regimen; ECOG PS 0–2; LE ≥ 3 mo; age ≥ 18; adequate hematologic, hepatic, renal function; ≥ 4 wks since CTx/surgery; ≥ 24 hr since RTx; clinically stable brain metastase allowable | | 27 | 3 | 24
4/98 – 10/01
Wiconsin Oncology Group
Masters 2003 | Proven SCLC; sensitive (relapse ≥ 90 d after CTx) or refractory (relapse < 90 d after CTx); limited or extensive; PD after initial CTx; prior RTx allowable, measurable disease outside field or clear PD within field; ECOG PS 0–2; adequate renal, hepatic, bone marrow function | Ongoing toxicity > grade 1; prior gemcitabine treatment | 46 | 4 | 42
12/97 – 9/98 | | | | 2 ineligible,
Multiple US centers | | | | 2 rapid CNS progression
Kosmas 2001 | Confirmed SCLC; relapsed after CbE CTx ± TRTx; not curable by other 2^nd^-line CTx or RTx; WHO PS 0–2; LE ≥ 3 mo; adequate hematopoietic, hepatic, renal function | previous CTx; active CAD; unstable diabetes mellitus; NCI ≥ grade 2 peripheral neuropathy; prior RTx to > 30% of bone marrow | 33 | | 33
Multiple centers in Greece
Kakolyris 2001 | Confirmed SCLC; refractory; had failed 1 prior 1^st^-line CTx; WHO PS 0–2; LE ≥ 3 mo; adequate hematologic, hepatic, renal function; brain metastases allowable if RTx given, lesions stable, clinically improved; Age < 75 | Other medical problems severe enough to affect compliance; ≥ 20% ↓ body weight; active infection; massive liver metastases; second primary tumor | 32 | 3 | 29
11/97 – 8/99 | | | | NE
Multiple centers in Greece
van der Lee 2001 | Proven SCLC; relapsed ≤ 3 mo of last CTx; limited or extensive; prior RTx allowable if not all measurable lesions in field; age ≥ 18; ECOG PS 0–3; adequate hematologic, hepatic, renal function | Uncontrolled infection; prior gemcitabine; symptomatic brain metastases; other malignancy < 3 yr before | 41 | 3 | 38
2/97 – 11/98 | | | | NE
Multiple centers in the Netherlands
Sessa 2000 | Confirmed SCLC; progressive recurrent after 1^st^-line CTx; ≥ 1 bidimensionally measurable lesion; WHO PS 0–2; 1 prior CTx regimen that did not include camptothecin analogues; adequate hematologic, hepatic and renal function | Signs of brain or leptomeningeal disease; history CHF; active heart disease requiring anti-arrhythmics | 67 | 5 | 62
3/95 – 8/97 | | | | NE
16 European centers
Sonpavde 2000 | Recurrent, measurable SCLC; KPS > 50%; adequate hematologic, hepatic, cardiac, renal function; 1 prior combination CTx regimen | | 46 | | 46
8/96 – 1/98
Hoosier Oncology Group
Groen 1999 | Proven SCLC; relapsed < 3 mo after last CTx; age 18–75; ECOG PS 0–3; bidimensionally measurable disease; adequate hematologic, hepatic, renal function; concurrent RTx allowable if not all measurable sites in field | Significant cardiac disease; uncontrolled infection; concurrent CTx | 35 | 1 | 34
2/96 – 9/97 | | | | NE
3 centers in the Netherlands
Ardizzoni 1997 | Confirmed SCLC; PD after 1 1^st^-line CTx that did not include a camptothecin analog; ≥ 1 bidimensionally measurable lesion outside RTx field; age ≤ 75; WHO PS 0–2; LE > 3 mo; ≥ 3 wks since systemic treatment, recovered from side effects; brain mets with neurologic symptoms allowable if controlled by RTx/steroids; adequate hematologic, hepatic, renal function | | 101 | 8 | 93
7/92 – 9/94
22 European centers
Gridelli 1997 | Proven pretreated SCLC; ECOG PS 0–2; age ≤ 75; normal platelet, renal, hepatic function; | Significant heart disease | 30 | | 30
Multiple centers in Italy 8/94–2/96
Einhorn 1995 | Refractory SCLC; no previous ifosfamide | | 46 | 5 | 41
2/90 – 8/93
Hoosier Oncology Group
Faylona 1995 | Previously treated progressive or recurrent SCLC; KPS ≥ 50; adequate bone marrow, renal function; 1 prior CTx regimen | Prior ifosfamide or etoposide; history of CHF; patients who progressed within 4 wks on EP | 46 | 4 | 42
2/90 – 8/93
Hoosier Oncology Group
Sculier 1995 | Proven SCLC; prior non-platinum CTx and failed 1^st^-line; had evaluable/measurable lesion; KPS ≥ 60; age < 75 | Other prior malignancy; active infectious disease, CNS disease, psychiatric disorders, recent MI, ≥ WHO grade II peripheral polyneuropathy; CTx/ RTx < 4 wks before | 41 | | 41
9/91 – 12/93
12 European centers
Smyth 1994 | Verified SCLC; evidence of PD; locally advanced or metastatic extensive disease; ≥ 1 lesion measurable bidimensionally; WHO PS 0–2; age 18–75; adequate hematologic, hepatic, renal function; no more than 1 prior CTx regimen; if prior RTx, assessed site outside field | No more than one prior CTx | 34 | 6 | 28
Multiple European centers
Albain 1993 | Diagnosis of SCLC; measurable or evaluable disease; progressed during initial therapy or relapsed after an interval of response; limited or extensive; ≥ 3 wks since prior CTx; must have failed ≥ 1 CTx regimen; after interim analysis prior CTx limited to regimen with cyclophosphamide or EP; limited stage patients must have failed RTx with measurable/evaluable disease outside field; brain metastases allowable if patients could receive brain RTx; initial SWOG PS 0–4, then limited to 0–2 | | 69 | 2 | 67
SWOG-8605
Multiple US centers
Jassem 1993 | Confirmed SCLC; progressive recurrent not amenable for curative surgery/RTx; response to 1^st^-line CTx; ≥ 3 mo since prior CTx; measurable/evaluable disease outside irradiated area; brain/leptomeningeal disease allowable if controlled by RTx | Previous/current other malignancies; poor medical risks because of non-malignant systemic disease, active uncontrolled infection, peripheral neuropathy | 26 | 1 | 25
6/90 – 5/91
8 European centers
Einhorn 1990 | Consecutive patients diagnosed with SCLC; measurable/evaluable progressive disease; ≥ 1 prior combination CTx regimen; KPS ≥ 50; adequate hematologic, hepatic, renal function; CTx finished ≥ 3 wks | | 26 | | 26
5/88 – 9/88
Hoosier Oncology Group
Graziano 1990 6/83–5/84 Multiple US centers | Documented measurable SCLC, failed to respond to or relapsed after initial response to 1 prior CTx regimen; prior mono etoposide or cisplatin allowable; CALGB PS 0–2; ≥ 4 wks since surgery, RTx, CTx; adequate hematologic, hepatic, renal function | previous/concomitant malignancy; serious medical/ psychiatric illness | 43 | 8 | 35
JCOGLC 1990 | Proven SCLC/NSCLC; nonresected; evaluable/measurable; LE ≥ 3 mo; adequate hematologic, hepatic, renal function; age ≥ 15; > 4 wks since any prior CTx/RTx; 1^st^-line and 2^nd^+-line | | 31 | | 31
1/86 – 1/88
Multiple centers in Japan
Sculier 1990 | Failed (relapse/no response) to a 1^st^-line treatment with etoposide+vindesine±cisplatin; evaluable/measurable disease;KPS ≥ 50; adequate hematologic, hepatic, renal function; ≤ 75 | history of prior malignancy; active infectious disease; recent myocardial infarction; congestive heart failure; cardiac arrhythmia | 49 | 4 | 45
Multiple European centers
Issell 1985 | Refractory SCLC; failure to responde to previous combination CTx with ≥ 3 Rx; measurable disease | Prior etoposide; evidence of liver or renal failure | 116 | 21 | 95
Multiple US centers

Table 9I Patient Characteristics, Phase II Studies

Study | Age | | Gender (%) | | Stage (%) | | Time Since Last CTx (%) | | Initial Reponse (%) | | Previous Treatment Regimens (%) | | | Race (%) | | Performance Status (%) | | | Other Factors (%)
Ando. 2004 | mn | 65.3 | M | 96 | LD | 36 | < 2 mo | 64 | CR | 0 | PE | 16 | | | | [underlined: ECOG] | | | Refractory | 64
| md | | F | 4 | ED | 64 | > 2 mo | 36 | PR | 60 | CbP | 84 | | | | 0–1 | 88 | | Relapsed | 36
| rng | | | | | | | | SD | 32 | TRTx | 20 | | | | 2 | 12
| sd | 9.7 | | | | | | | PD | 8 | Surgery | 4
| | | | | | | | | NE
Agelaki 2004 | mn | | M | 94 | LD | 6 | | | | | #1 CTx | 48 | | | | | | | Refractory | 48
| md | 60 | F | 6 | ED | 94 | | | | | #2 CTx | 39 | | | | | | | Chemosensitive | 52
| rng | 38–78 | | | | | | | | | #3 CTx | 10
| sd | | | | | | | | | | PE | 100
| | | | | | | | | | | Topotecan | 48
| | | | | | | | | | | CVE | 3
| | | | | | | | | | | Docataxel/Gemcitibine | 6
Goto 2004 | mn | | M | 72.5 | LD | 12.5 | | | | | PE | 28 | | | | [underlined: ECOG]
| md | 40 | F | 27.5 | ED | 87.5 | | | | | CbE | 28 | | | | 0 | | 22.5
| rng | 41–74 | | | | | | | | | PE-VAE | 15 | | | | 1 | | 75
| sd | | | | | | | | | | PI | 5 | | | | 2 | | 2.5
| | | | | | | | | | | Other CTx | 10
| | | | | | | | | | | TRTx | 20
Ardizzoni 2003 | Sensitive | | Sensitive | | Sensitive | | Sensitive | | | | | Sen | Ref | | | [underlined: WHO] | Sen | Ref | Sensitive | 62
| md | 60 | M | 79 | LD | 27 | md | 165 d | | | TRTx | 69 | 31 | | | 0 | 18 | 12 | Refractory | 38
| rng | (38–73) | F | 21 | ED | 74 | | | | | med#CTx | 3 | 3 | | | 1 | 71 | 64
| Refractory | | Refractory | | Refractory | | Refractory | | | | Cisplatin | 22 | 5 | | | 2 | 12 | 24
| md | 55 | M | 17 | LD | 33 | md | 30 d | | | Carbopl | 24 | 36
| rng | (35–75) | F | 83 | ED | 67 | | | | | Etopos | 90 | 83
Hainsworth 2003 | mn | | M | 57 | | | | | CR | 23 | Plat/E | 57 | | | | | | | Relapsed | 43
| md | 62 | F | 43 | | | | | PR | 57 | Plat/E/pacl | 40 | | | | | | | Refractory | 57
| rng | 34–78 | | | | | | | SD | 20 | Plat/E/pacl/topotecan | 3
| sd | | | | | | | | PD
| | | | | | | | | NE
Hoang 2003 | mn | | M | 63 | LD | 11 | | | | | CTx | 100 | | | | [underlined: ECOG] | | | Sensitive | 56
| md | 61 | F | 37 | ED | 89 | | | | | RTx | 56 | | | | 0–1 | 93 | | Refractory | 44
| rng | 45–74 | | | | | | | | | | | | | | 2 | 7
| sd
Masters 2003 | mn | 60.6 | M | 59.5 | | | | | CR | 33 | TRTx | 57 | | B | 5 | [underlined: ECOG] | | | Relapsed | 43
| md | 60.1 | F | 40.5 | | | | | PR | 38 | Mono CTx | 7 | | W | 95 | 0 | 24 | | Refractory | 57
| rng | 41–83 | | | | | | | SD | 14 | Comb | 86 | | H | | 1 | 55 | | ≥ 5% ↓ wt | 24
| sd | | | | | | | | PD | 14 | Both | 7 | | A | | 2 | 21
| | | | | | | | | NE | | Surgery | 19 | | O
Kosmas 2001 | mn | 62 | M | 91 | LD | 45 | ≤ 3 mo | 61 | CR | 18 | CTx | 100 | | | | [underlined: WHO] | | | Metastatic sites
| md | | F | 9 | ED | 55 | > 3 mo | 39 | PR | 58 | TRTx | 42 | | | | md | 1 | | LNs | 39
| rng | 55–70 | | | | | | | SD | 12 | | | | | | rng | 0–2 | | Liver | 27
| sd | | | | | | | | PD | 12 | | | | | | | | | Bone | 15
| | | | | | | | | NE | | | | | | | | | | Brain | 18
| | | | | | | | | | | | | | | | | | | Lung nodules | 24
| | | | | | | | | | | | | | | | | | | Adrenals | 27
| | | | | | | | | | | | | | | | | | | Other | 6
Kakolyris 2001 | mn | | M | 84 | LD | 0 | | | | | EP | 84 | | | | [underlined: WHO] | | | Metastatic sites
| md | 60.5 | F | 16 | ED | 100 | | | | | CAB | 16 | | | | 0 | 28 | | 1 metastasis | 28
| rng | 38–77 | | | | | | | | | RTx | 47 | | | | 1 | 63 | | 2 metastases | 50
| sd | | | | | | | | | | Surgery | 6 | | | | 2 | 9 | | 3 metastases | 22
| | | | | | | | | | | | | | | | | | | lung | 91
| | | | | | | | | | | | | | | | | | | liver | 22
| | | | | | | | | | | | | | | | | | | LNs | 75
| | | | | | | | | | | | | | | | | | | Bone | 16
| | | | | | | | | | | | | | | | | | | Adrenal | 13
| | | | | | | | | | | | | | | | | | | CNS | 22
| | | | | | | | | | | | | | | | | | | Skin | 3
van der Lee 2001 | < 60 | 58 | M | 76 | LD | 34 | | | | | #1 CTx | 24
| ≥ 60 | 42 | F | 24 | ED | 66 | | | | | #2 CTx | 47
| | | | | | | | | | | #3 CTx | 29
| | | | | | | | | | | 1^st^ CDE | 89
| | | | | | | | | | | 1^st^ ECE | 3
| | | | | | | | | | | 1^st^ oral E | 8
Sessa 2000 | Sensitive | | Sensitive | | | | Sensitive | | | | CTx + RTx | 44 | | | | [underlined: WHO] | Sen | Ref
| md | 60 | M | 65 | | | md | 7.9 mo | | | | | | | | 0 | 19 | 28
| rng | 39–76 | F | 35 | | | rng | 3.2–19.6 | | | | | | | | 1 | 62 | 55
| Refractory | | Refractory | | | | Refractory | | | | | | | | | 2 | 19 | 17
| md | 61 | M | 69 | | | md | 2.1
| rng | 36–79 | F | 31 | | | rng | 0.2–7.5
Sonpavde 2000 | mn | | M | 54 | LD | 63 | ≤ 3 mo | 30 | CR | 39 | Platinum-E | | | | | [underlined: KPS] | | | Sites
| md | 63 | F | 46 | ED | 37 | > 3 mo | 70 | PR | 46 | [underlined: +] VIP | 100 | | | | med | 80 | | Lung | 91
| rng | 43–77 | | | | | | | SD | 2 | RTx | 59 | | | | rng | 50–90 | | Liver | 43
| sd | | | | | | | | PD | 13 | | | | | | | | | Adrenal | 17
| | | | | | | | | NE | | | | | | | | | | Bone | 13
| | | | | | | | | | | | | | | | | | | Cervical LN | 9
| | | | | | | | | | | | | | | | | | | Brain | 4
Groen 1999 | mn | | M | 69 | LD | 44 | med | 6 wks | CR | 15 | #1 CTx | 53 | | | | [underlined: ECOG]
| md | 59 | F | 31 | ED | 56 | | 0–11 | PR | 65 | #2 CTx | 44 | | | | 0 | 21
| rng | 40–73 | | | | | | | SD | 18 | #3 CTx | 3 | | | | 1 | 56
| sd | | | | | | | | PD | 3 | CTx | 100 | | | | 2 | 18
| | | | | | | | | NE | | RTx | 21 | | | | 3 | 6
| | | | | | | | | | | 1^st^ CDE | 97
Ardizzoni 1997 | mn | | M | 69 | LD | 62 | ≤ 6 mo | 82 | | | ≤ 3 CTx Rx | 58 | | | | [underlined: WHO] | | | Sensitive | 49
| md | 58 | F | 31 | ED | 38 | > 6 mo | 18 | | | > 3 CTx Rx | 42 | | | | 0 | 25 | | Refractory | 51
| rng | | | | | | | | | | RTx | 37 | | | | 1 | 57
| sd | | | | | | | | | | ImmunoTx | 6 | | | | 2 | 18
| | | | | | | | | | | Surgery | 12
Gridelli 1997 | mn | | M | 93 | LD | 10 | | | | | Prior etopos | 73 | | | | [underlined: ECOG] | | | Sensitive | 60
| md | 61 | F | 7 | ED | 90 | | | | | | | | | | 0 | 7 | | Refractory | 40
| rng | 44–74 | | | | | | | | | | | | | | 1 | 47
| sd | | | | | | | | | | | | | | | 2 | 47
Einhorn 1995 | mn | | M | 78 | LD | 22 | < 6 mo | 44 | | | Cisplatin | 85 | | | | [underlined: KKPS]
| md | 61 | F | 22 | ED | 78 | ≥ 6 mo | 56 | | | RTx | 49 | | | | 80–100 | 63
| rng | 45–76 | | | | | | | | | | | | | | 70 | 29
| sd | | | | | | | | | | | | | | | 50–60 | 7
Faylona 1995 | mn | | M | 79 | LD | 21 | < 6 mo | 43 | | | Cisplatin | 86
| md | 60 | F | 22 | ED | 79 | ≥ 6 mo | 57 | | | RTx | 50
| rng | 45–76
| sd
Sculier 1995 | mn | | M | 90 | LD | 25 | | | CR | 3 | IVE | 85 | | | | [underlined: KPS] | | | > 5% ↓ wt | 13
| md | 59 | F | 10 | ED | 75 | | | PR | 78 | IVA | 10 | | | | med | 80
| rng | 40–74 | | | | | | | SD | | EVI | 5 | | | | rng | 60–100
| sd | | | | | | | | PD | 20
| | | | | | | | | NE
Smyth 1994 | mn | | M | 82 | | | | | | CTx | 79 | | | | | [underlined: WHO]
| md | 61 | F | 18 | | | | | | RTx | 24 | | | | | 0 | 24
| rng | 36–72 | | | | | | | | Surgery | 24 | | | | | 1 | 65
| sd | | | | | | | | | | | | | | | 2 | 12
Albain 1993 | mn | | M | 79 | LD | 9 | | | | | 1 CTx reg | 88 | | | | [underlined: SWOG] | | | 1 site | 5
| md | 59 | F | 21 | ED | 91 | | | | | ≥ 2 CTx reg | 12 | | | | 0–1 | 54 | | >1 sites | 95
| rng | 30–76 | | | | | | | | | 2–4 CTx Rx | 46 | | | | 2–4 | 46 | | relapse after response | 27
| sd | | | | | | | | | | > 4 CTX Rx | 54 | | | | | | | PD on treatment | 66
| | | | | | | | | | | RTx | 50
Jassem 1993 | mn | | M | 76 | | | | | CR | 44 | RTx | 60 | | | | [underlined: WHO]
| md | 59 | F | 24 | | | | | PR | 56 | | | | | | med | 1
| rng | 41–73 | | | | | | | SD | | | | | | | rng | 0–2
| sd | | | | | | | | PD
| | | | | | | | | NE
Einhorn 1990 | | | M | 58 | LD | 50 | | | | | EP | 96 | | | | [underlined: KPS]
| | | F | 42 | ED | 50 | | | | | CAV | 54 | | | | med | 70
| | | | | | | | | | | | | | | | rng | 50–100
Graziano 1990 | mn | | M | 66 | | | md | 2 mo | | | md# CTx Rx | 4 | | | | [underlined: CALGB] | | | Time since diagnosis
| md | 60 | F | 34 | | | rng | 1–27 | | | rng | 2–7 | | | | 0 | 11 | | < 1 yr | 71
| rng | 35–69 | | | | | | | | | md# CTx reg | 2 | | | | 1 | 46 | | ≥ 1 yr | 29
| sd | | | | | | | | | | rng | 1–10 | | | | 2 | 40
| | | | | | | | | | | RTX | 74%
JCOGLC 1990
Sculier 1990 | mn | | M | 93 | LD | 33 | | | CR/ | | PEV | 36 | | | | [underlined: KPS]
| md | 59 | F | 7 | ED | 67 | | | PR | 47 | EV | 64 | | | | md | 70
| rng | 36–74 | | | | | | | | | | | | | | rng | 50–90
| sd
Issell 1985 | mn | | M | 74 | LD | 17 | | | | | ADR -CCNU | 61 | | | | [underlined: ECOG] | | | 1^st^ relapse | 80
| md | 60 | F | 26 | ED | 83 | | | | | CCNU -ADR | 21 | | | | 0–1 | 49 | | 2^nd^ relapse | 17
| rng | 27–85 | | | | | | | | | ADR+CCNU | 18 | | | | 2–4 | 51 | | 3^rd^ relapse | 3
| sd

Table 9J Treatments, Phase II Studies

Study | Treatment Regimen | | | Outcomes | Response Criteria | Observer | Follow-up
Ando. 2004 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response, survival, adverse events | WHO criteria
| Irinotecan | 60 mg/m^2^ | d1, 8, 15, q 4 wks, ≥ 2 cycles if no PD
| Cisplatin | 30 mg/m^2^ | d1, 8, 15, q 4 wks, ≥ 2 cycles if no PD
Agelaki 2004 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response, survival, adverse events | WHO criteria
| Gemcitabine | 1g/ m^2^ | d1, 8, q 21 d to progression/max cycles
| Irinotecan | 300 mg/ m^2^ | d8, q 21 d to progression/max cycles
Goto 2004 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response, survival, progression-free survival, adverse events | WHO criteria
| Cisplatin | 25 mg/m^2^ | d1, q 7 d, 9 cycles
| Etoposide | 60 mg/m^2^ | d1–3, q 21 d, 5 cycles
| Irinotecan | 90 mg/m^2^ | d1, q 14 d, 4 cylces
Ardizzoni 2003 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response, adverse events, overall survival, time to progression | WHO criteria
| Topotecan | .75 mg/ m^2^ | d1–5, q 21 d, max 6 cycles
| Cisplatin | 60 mg/m^2^ | d1, q 21 d, max 6 cycles
Hainsworth 2003 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response, response duration, survival, adverse events | CR= all clinically detectable disease gone, ≥ 4 wks
| Vinorelbine | 20 mg/m^2^ | d1, 8, 15, q 28 d, max 6 cycles | | PR= ↓ by ≥50%, all measureable lesions, ≥ 4 wks
| Gemcitabine | 1 g/m^2^ | d1, 8, 15, q 28 d, max 6 cycles | | SD= ↓ in lesion size by <50% ↑ or by <25%, no PD ≥ 3 mo
| | | | | PD= ↑ by ≥25%, cross sectional area, ≥1 lesion, or any new lesion
Hoang 2003 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response, time to progression, survival, adverse events | ECOG criteria
| Gemcitabine | 1.25 g/m^2^ | d1, 8, q 21 d
Masters 2003 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response, duration of remission, survival, adverse events | Standard criteria
| Gemcitabine | 1 g/m^2^ | d1, 8, 15, q 28 d
Kosmas 2001 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response, time to progression, survival, adverse events | CR= no clinical, radiol evidence of tumor, ≥4 wks
| Paclitaxel | 175 mg/m^2^ | d1, planned 6 cycles | | PR= ↓ by ≥50%, all measureable lesions, ≥ 4 wks
| Ifosfamide | 5 g/m^2^ | d1–2, planned 6 cycles | | SD= ↓ in lesion size by <50% or ↑ by ≤25%
| Cisplatin | 100 mg/m^2^ | d1–2, planned 6 cycles | | PD= ↑ by ≥25%, cross sectional area, ≥1 lesion, or any new lesion
Kakolyris 2001 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response, time to progression, survival, adverse events | WHO criteria | | mn
| Paclitaxel | 200 mg/m^2^ | d1, q 4 wks, to 6 cycles | | | | md | 8 mo
| | | or response + 3 cycles | | | | rng | 1–17.5
| Carboplatin | AUC=6 | d2, q 4 wks, to 6 cycles | | | | sd
| | | or response + 3 cycles
van der Lee 2001 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response, survival, adverse events | WHO criteria
| Gemcitabine | 1 g/m^2^ | d1, 8, 15, q 28 d, max 5 Cycles
Sessa 2000 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response, response duration, adverse events | WHO criteria
| GI147211 | 1.2 mg/m^2^ | d1–5, q 21 d, ≥ 2 cycles
| (camptothecin-derivative)
Sonpavde 2000 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response, survival, time to progression, adverse events
| Doxorubicin | 40 mg/m^2^ | q 21 d
| Paclitaxel | 175 mg/m^2^ | q 21 d
Groen 1999 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response, response duration, time to progression, survival, adverse events | CR= complete resolution of all signs of known disease, ≥ 4 wks
| Paclitaxel | 175 mg/m^2^ | q 21 d, max 5 cycles | | PR= ↓ by ≥50%, all measureable lesions, ≥ 4 wks
| Carboplatin | AUC=7 | q 21 d, max 5 cycles | | SD= ↓ in lesion size by <50% or ↑ by <25%
| | | | | PD= ↑ by ≥25%, cross sectional area, ≥1 lesion, or any new lesion
Ardizzoni 1997 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response, time to progression, survival, adverse events
| Topotecan | 1.5 mg/ m^2^ | d1–5, q 21 d, max 6 mo after max response
Gridelli 1997 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response, progression-free survival, survival, adverse events | WHO criteria
| VM-26 | 100 mg/m^2^ | d1–3, q 21 d, max 6 cycles
| Lonidamine | 600 mg | po, d1–5, q 21 d, max 6 Cycles
Einhorn 1995 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response, adverse events
| Ifosfamide | 1.2 g/m^2^ | d1–4, q 28 d, max 4 cycles
| Etoposide | 37.5 mg/m^2^ | d1–4, q 28 d, max 4 cycles
| Cisplatin | 20 mg/m^2^ | d1–4, q 28 d, max 4 cycles
Faylona 1995 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response, progression-free survival, survival, adverse events | CR= all clinically detectable disease gone, ≥ 4 wks
| Ifosfamide | 1.2 g/m^2^ | d1–4, q 28 d, max 4 cycles | | PR= ↓ by ≥50%, all measureable lesions, ≥ 4 wks
| Etoposide | 37.5 mg/m^2^ | po, d1–21/d1–14, q 28 d, max 4 cycles | | SD= ↓ in lesion size by <50% ↑ or by <25%, no PD ≥ 3 mo
| Cisplatin | 20 mg/m^2^ | d1–4, q 28 d, max 4 cycles | | PD= ↑ by ≥25%, cross sectional area, ≥1 lesion, or any new lesion
Sculier 1995 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response, survival, adverse events | CR= all clinically detectable disease gone, ≥ 4 wks
| Carboplatin | 100 mg/m^2^ | d1, q 7 d, max 24 cycles | | PR= ↓ by ≥50%, all measureable lesions, ≥ 4 wks
| Cisplatin | 25 mg/m^2^ | d1, q 7 d, max 24 cycles | | SD= ↓ in lesion size by <50% ↑ or by <25%, no PD ≥ 3 mo
| | | | | PD= ↑ by ≥25%, cross sectional area, ≥1 lesion, or any new lesion
Smyth 1994 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response, respons duration, adverse events | WHO criteria
| Docataxel | 100 mg/m^2^ | d1, q 21 d, max 7 cycles
Albain 1993 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response, survival, adverse events | SWOG criteria
| Cytoxan | 500 mg/ m^2^ | d1, q 21 d, max 4 cycles
| Cytarabine | 250 mg/m^2^ | d1, q 21 d, max 4 cycles
| Vincristine | 2 mg | d14, q 21 d, max 4 cycles
Jassem 1993 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response, adverse events | WHO criteria
| Vinorelbine | 30 mg/m^2^ | d1, q 7 d, max 13 cycles
Einhorn 1990 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response, response duration, survival, adverse events | CR= no clinical, radiol evidence of tumor, ≥1 mo
| Etoposide | 50 mg/m^2^ | po, daily | | PR= ↓ by ≥50%, all measureable lesions, ≥1 mo
| | | | | SD= ↓ in lesion size by <50% or ↑ by <25%
| | | | | PD= ↑ by ≥25%, cross sectional area, ≥1 lesion, or any new lesion
Graziano 1990 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response, survival, adverse events | CR= no clinical, radiol evidence of tumor, ≥ 4 wks
| Etoposide | 80 mg/m^2^ | d1–5, q 21 d, ≥ 2 cycles | | PR= ↓ by ≥50%, all measureable lesions, ≥ 4 wks
| Cisplatin | 20 mg/m^2^ | d1–5, q 21 d, ≥ 2 cycles | | SD= ↓ in lesion size by <50% or ↑ by <25%
| | | | | PD= ↑ by ≥25%, cross sectional area, ≥1 lesion, or any new lesion
JCOGLC 1990 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response | CR= no clinical, radiol evidence of tumor, ≥1 mo
| Carboplatin | 300 mg/m^2^ | d1, q 28 d | | PR= ↓ by ≥50%, all measureable lesions, ≥1 mo
| | | | | SD= ↓ in lesion size by <50% ↑ or ↑ by <25%
| | | | | PD= ↑ by ≥25%, cross sectional area, ≥1 lesion, or any new lesion
Sculier 1990 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response | CR= no clinical, radiol evidence of tumor, ≥ 4 wks
| Cytoxan | 1 g/m^2^ | d1, q 21–28 d, 10 cycles | | PR= ↓ by ≥50%, all measureable lesions, ≥ 4 wks
| Vincristine | 1.4 mg/m^2^ | d1, q 21–28 d, 10 cycles | | SD= ↓ in lesion size by <50% ↑ or ↑ by <25%
| Doxorubicin | 45 mg/m^2^ | d1, q 21–28 d, 10 cycles | | PD= ↑ by ≥25%, cross sectional area, ≥1 lesion, or any new lesion
Issell 1985 | [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | Tumor response, adverse events
| Etoposide | 80 mg/m^2^ | d1–5, q 21–28 d
| | 160 mg/m^2^ | po, d2–5, q 21–28 d (last 16 patients)

Table 9K Survival Outcomes, Phase II Studies

Study | Overall Survival (%) | | | | | | | | Progression-Free Survival (%)
Ando 2004 | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| | 25 | 7.9 mo | 44 | 20
Agelaki 2004 | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| Total | 31 | 6 mo | 17
| Refractory | 15 | 5.37 mo
| Relapsed | 16 | 5.97 mo
Goto 2004 | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| | 40 | 11.8 | 49 | ~15 | ~5 | | | | 40 | 5 | ~10 | ~3
Ardizzoni 2003 | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | TTP | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| Sensitive | 68 | 6.4 mo | 19.7 | | | | | Sensitive | 68 | 4.7 mo
| Refractory | 42 | 6.1 mo | 15.2 | | | | | Refractory | 42 | 3.0 mo
Hainsworth 2003 | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| | 30 | 5 mo | ~15
Hoang 2003 | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| Sensitive | 15 | 8.8 mo | 33.3 | | | | | Sensitive | 15 | 6 mo
| Refractory | 12 | 4.2 | 16.7 | | | | | Refractory | 12 | 5.6
| Total | 27 | 6.4 | 25.4 | | | | | Total | 27 | 6
Masters 2003 | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| Relapsed | 24 | 7.3
| Refractory | 18 | 6.9
| Total | 42 | 7.1 | ~28
Kosmas 2001 | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | TTP | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| | 33 | 28 wks | 12 | | | | | | 33 | 20 wks
Kakolyris 2001 | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | TTP | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| | 32 | 7 mo | 15 | | | | | | 32 | 5.5 mo
van der Lee 2001 | | N | Med | 6 mo | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| | 41 | 17 wks | 30
Sonpavde 2000 | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | TTP | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| | 46 | 25 wks | | | | | | | 46 | 14 wks
Groen 2000 | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | TTP | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| | 34 | 31 wks | 9 | | | | | | 34 | 21 wks
Ardizzoni 1997 | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | TTP | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| Sensitive | 46 | 6.9 mo | ~28 | | | | | Overall | 93 | 2.8 mo
| Refractory | 47 | 4.7 mo | ~9
Gridelli 1997 | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | PFS | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| | 30 | 4 mo | 10% | | | | | | 30 | 2 mo
Einhorn 1995 | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| | 41 | 29 wks
Faylona 1995 | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| | 42 | 29 wks | ~22 | | | | | | 42 | 20 wks | ~5
Sculier 1995 | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| | 40 | 16.6 wks | ~10
Albain 1993 | | N | Med | 6 mo | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| | 67 | 2.5 mo | 16
Einhorn 1990 | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| | 26 | 18 wks
Graziano 1990 | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| | 35 | 6.0 mo | 14
Sculier 1990 | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
Issell 1985 | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| | 95 | 12 wks

Table 9L Tumor Response and Quality of Life, Phase II Studies

Study | Tumor Response (%) | | | | | | | Quality of Life
Ando 2004 | | N | CR | PR | SD | PD | NE | Scale | Domain | F/U | n | mn±sd
| Refractory | 16 | 0 | 81 | 13 | 6
| Relapsed | 9 | 0 | 78 | 22 | 0
| Total | 25 | | 80 | 16 | 4
Agelaki 2004 | | N | CR | PR | SD | PD | NE | Scale | Domain | F/U | n | mn±sd
| Total | 31 | 0 | 10 | 22 | 68
| Refractory | 15 | | 13
| Relapsed | 15 | | 6
Goto 2004 | | N | CR | PR | SD | PD | NE | Scale | Domain | F/U | n | mn±sd
| | 40 | 13 | 65 | 10 | 10 | 3
Ardizzoni 2003 | | N | CR | PR | SD | PD | NE | Scale | Domain | F/U | n | mn±sd
| Sensitive | 68 | 1.5 | 27.9 | 36.8 | 5.9 | 14.7
| Refractory | 42 | 0 | 23.8 | 26.2 | 38.1 | 9.5
Hainsworth 2003 | | N | CR | PR | SD | PD | NE | Scale | Domain | F/U | n | mn±sd
| | 28 | 0 | 10 | 36 | 54
Hoang 2003 | | N | CR | PR | SD | PD | NE | Scale | Domain | F/U | n | mn±sd
| | 27 | 0 | 0 | 11 | 78
Masters 2003 | | N | CR | PR | SD | PD | NE | Scale | Domain | F/U | n | mn±sd
| Relapsed | 24 | 0 | 16.7 | 0 | 75 | 8.3
| Refractory | 18 | 0 | 5.6 | 5.6 | 88.9 | 0
| Total | 42 | 0 | 11.9 | 2.4 | 81 | 4.8
Kosmas 2001 | | N | CR | PR | SD | PD | NE | Scale | Domain | F/U | n | mn±sd
| | 33 | 24.2 | 48.5 | 15 | 12
Kakolyris 2001 | | N | CR | PR | SD | PD | NE | Scale | Domain | F/U | n | mn±sd
| | 32 | 3 | 22 | 22 | 53
| median response duration 3 mo (1–9)
van der Lee 2001 | | N | CR | PR | SD | PD | NE | Scale | Domain | F/U | n | mn±sd
| | 38 | 0 | 13 | 21 | 66
Sessa 2000 | | N | CR | PR | SD | PD | NE | Scale | Domain | F/U | n | mn±sd
| | 66 | 0 | 16.6 | 32
| median response duration 160 d (129–189) PR
| median response duration 146.5 d (77–321) SD
Sonpavde 2000 | | N | CR | PR | SD | PD | NE | Scale | Domain | F/U | n | mn±sd
| | 46 | 7 | 35 | 13
Groen 1999 | | N | CR | PR | SD | PD | NE | Scale | Domain | F/U | n | mn±sd
| | 34 | 6 | 68 | 24 | 3
Ardizzoni 1997 | | N | CR | PR | SD | PD | NE | Scale | Domain | F/U | n | mn±sd
| Sensitive | 46 | 13 | 24 | 31 | 29 | 2
| Refractory | 47 | 2 | 4 | 40 | 43 | 0
| Total | 93 | 8 | 14 | 36 | 36 | 1
| Median response duration 7.6 mo (5.1–12.2)
Gridelli 1997 | | N | CR | PR | SD | PD | NE | Scale | Domain | F/U | n | mn±sd
| | 30 | 3.3 | 10 | 10 | 70
Einhorn 1995 | | N | CR | PR | SD | PD | NE | Scale | Domain | F/U | n | mn±sd
| | 41 | 15 | 39
Faylona 1995 | | N | CR | PR | SD | PD | NE | Scale | Domain | F/U | n | mn±sd
| | 42 | 14 | 40
Sculier 1995 | | N | CR | PR | SD | PD | NE | Scale | Domain | F/U | n | mn±sd
| | 38 | 13 | 21 | 55
Smyth 1994 | | N | CR | PR | SD | PD | NE | Scale | Domain | F/U | n | mn±sd
| | 34 | 0 | 21 | 21 | 35 | 18
| median response duration 4.7 mo (3.5–12.6)
Albain 1993 | | N | CR | PR | SD | PD | NE | Scale | Domain | F/U | n | mn±sd
| | 67 | 0 | 4 | 15
Jassem 1993 | | N | CR | PR | SD | PD | NE | Scale | Domain | F/U | n | mn±sd
| | 25 | 0 | 16 | 28 | 48
Einhorn 1990 | | N | CR | PR | SD | PD | NE | Scale | Domain | F/U | n | mn±sd
| | 26 | 4 | 19 | 23
| median response duration 9 wks (6–20)
Graziano 1990 | | N | CR | PR | SD | PD | NE | Scale | Domain | F/U | n | mn±sd
| | 35 | 3 | 17 | 43 | 17
JCOGLC 1990 | | N | CR | PR | SD | PD | NE | Scale | Domain | F/U | n | mn±sd
| | 31 | 38.7
Sculier 1990 | | N | CR | PR | SD | PD | NE | Scale | Domain | F/U | n | mn±sd
| | 45 | 0 | 13 | 31 | 56
Issell 1985 | | N | CR | PR | SD | PD | NE | Scale | Domain | F/U | n | mn±sd
| | 95 | 1 | 11

Table 9M Adverse Events, Phase II Studies

Toxicity Type | Study | Group/Description | n | Gr 3 % | Gr 4 %
Treatment-related mortality | Agelaki 2004 | | 31 | 0
| Ardizzoni 2003 | Sensitive, early death, toxicity | 68 | 7.4
| | Refractory, early death, toxicity | 42 | 0
| Hainsworth 2003 | | 30 | 0
| Groen 1999 | | 35 | 0
| Gridelli 1997 | | 30 | 0
| Faylona 1995 | | 42 | 14
| Albain 1993 | | 67 | 6
| Sculier 1990 | | 45 | 2
| Issell 1985 | | 95 | 1
Alopecia | Ando 2004 | | 25 | 0
| Goto 2004 | | 40 | 0
| Ardizzoni 2003 | Sensitive | 68 | 19 | 0
| | Refractory | 42 | 10 | 0
| Hainsworth 2003 | | 30 | 0 (3/4)
| Masters, 2003 | | 44 | 0 | 0
| Kosmas 2001 | | 33 | 100 | 0
| Sessa 2000 | | 241 cycles | 0 | 0
| Ardizzoni 1997 | | 403 cycles | 0.7 | 0
| Gridelli 1997 | | 30 | 10 | 0
| Smyth 1994 | | 27 | 0 | 0
| Jassem 1993 | | 25 | 28 | 4
Fatigue | Agelaki 2004 | | 31 | 13
| Hainsworth 2003 | | 30 | 17 (3/4)
| Masters, 2003 | | 44 | 2 | 0
| Kosmas 2001 | | 33 | 0 | 0
| Kakolyris 2001 | | 32 | 19 | 0
| Groen 1999 | | 35 | 0 | 0
| Ardizzoni 1997 | Fatigue/malaise | 403 cycles | 2.7 | 0.7
| Smyth 1994 | Asthenia/malaise/fatigue | 22 | 27 | 5
Diarrhea | Ando 2004 | | 25 | 8 | 0
| Agelaki 2004 | | 31 | 10(3/4)
| Goto 2004 | | 40 | 8
| Ardizzoni 2003 | Sensitive | 68 | 1 | 1
| | Refractory | 42 | 2 | 0
| Kosmas 2001 | | 33 | 0 | 0
| Kakolyris 2001 | | 32 | 0 | 0
| Sonpavde 2000 | | 46 | 2
| Groen 1999 | | 35 | 0 | 3
| Ardizzoni 1997 | | 403 cycles | 0.2 | 0
| Faylona 1995 | | 42 | 2
| Smyth 1994 | | 14 | 7 | 0
Nausea | Ardizzoni 2003 | Sensitive | 68 | 3 | 0
| | Refractory | 42 | 2 | 0
| Masters, 2003 | | 44 | 2 | 0
| van der Lee 2001 | | 38 | 0 | 0
| Sessa 2000 | | 241 cycles | 2.4 | 0.4
| Groen 1999 | | 35 | 0 | 0
| Ardizzoni 1997 | | 403 cycles | 0.7 | 0
| Smyth 1994 | | 16 | 13 | 0
| Jassem 1993 | | 25 | 0 | 0
Vomiting | Ando 2004 | Nausea and vomiting | 25 | 0 | 0
| Goto 2004 | Nausea and vomiting | 40 | 8
| Ardizzoni 2003 | Sensitive | 68 | 0 | 0
| | Refractory | 32 | 10 | 0
| Hainsworth 2003 | Nausea and vomiting | 30 | 3 (3/4)
| Masters, 2003 | | 44 | 0 | 2
| Kosmas 2001 | Nausea and vomiting | 33 | 18 | 0
| Kakolyris 2001 | Nausea and vomiting | 32 | 0 | 0
| Sessa 2000 | | 241 cycles | 1.2 | 0
| Groen 1999 | | 35 | 0 | 0
| Ardizzoni 1997 | | 403 cycles | 0.2 | 0
| Gridelli 1997 | Nausea and vomiting | 30 | 0 | 0
| Faylona 1995 | Nausea and vomiting | 42 | 2
| Sculier 1995 | Nausea and vomiting | 38 | 3 | 3
| Smyth 1994 | | 11 | 0 | 0
| Jassem 1993 | Nausea and vomiting | 25 | 0 | 0
Anorexia | Ardizzoni 2003 | Sensitive | 68 | 4 | 1
| | Refractory | 32 | 2 | 0
| Masters, 2003 | | 44 | 2 | 0
Lethargy | Ardizzoni 2003 | Sensitive | 68 | 15 | 0
| | Refractory | 32 | 7 | 0
Neurosensory | Ardizzoni 2003 | Sensitive | 68 | 1 | 0
| | Refractory | 32 | 0 | 0
| Masters, 2003 | | 44 | 0 | 0
| Kakolyris 2001 | Neurotoxicity | 32 | 0 | 0
| Sonpavde 2000 | Neurotoxicity | 46 | 11
| Groen 1999 | Paresthesia | 35 | 3 | 0
| Faylona 1995 | Neurologic | 42 | 12
| Sculier 1995 | Neurological | 35 | 3 | 0
| Smyth 1994 | | 14 | 7 | 7
| Jassem 1993 | Neurotoxicity | 25 | 4 | 0
Neuromotor | Ardizzoni 2003 | Sensitive | 68 | 1 | 0
| | Refractory | 32 | 0 | 2
| Masters, 2003 | | 44 | 14 | 0
Hearing loss
Esophagitis | Faylona 1995 | | 42 | 2 | 2
Bronchopulmonary | Ando 2004 | | 25 | 0
| Ardizzoni 2003 | Shortness of breath, sensitive | 68 | 10 | 0
| | Refractory | 42 | 7 | 2
| Masters, 2003 | | 44 | 9 | 0
| Kosmas 2001 | | 33 | 0 | 0
| van der Lee 2001 | Dyspnea | 38 | 0 | 0
| Faylona 1995 | | 42 | 2
Pneumonitis | Hoang 2003 | | 27 | | 4 (5)
Hepatic | Ando 2004 | | 25 | 0 | 0
| Goto 2004 | | 40 | 3
| Groen 1999 | AST/ALT elevation | 35 | 0 | 0
| Ardizzoni 1997 | | 403 cycles | 1.0 | 0
| Gridelli 1997 | | 30 | 6.6 | 0
Kidney | Ando 2004 | | 25 | 0 | 0
| Goto 2004 | | 40 | 0
| Kosmas 2001 | | 33 | 0 | 0
| Einhorn 1995 | | 41 | 2 | 2
| Faylona 1995 | | 42 | 2 | 2
| Sculier 1995 | | 35 | 0 | 0
Hemorrhage | Ardizzoni 2003 | Sensitive | 68 | 21 (1–3)
| | Refractory | 42 | 26 (1–3)
| Masters, 2003 | | 44 | 9 | 0
| Sculier 1995 | | 35 | 0 | 0
Anemia | Ando 2004 | | 25 | 4 | 0
| Goto 2004 | | 40 | 45
| Hainsworth 2003 | | 30 | 0 | 6
| Masters, 2003 | | 44 | 5 | 2
| Kosmas 2001 | | 33 | 18 | 0
| Kakolyris 2001 | | 32 | 0 | 3
| van der Lee 2001 | | 38 | 0 | 0
| Sessa 2000 | | 241 cycles | 3 | 0.4
| Groen 1999 | | 132 cycles | 17 | 0
| Ardizzoni 1997 | | 403 cycles | 8.9 | 2.9
| Gridelli 1997 | | 30 | 0 | 0
| Faylona 1995 | | 42 | 29 | 2
| Smyth 1994 | | 22 | 5 | 0
| Jassem 1993 | | 25 | 4 | 0
Thrombocytopenia | Ando 2004 | | 25 | 12 | 0
| Goto 2004 | | 40 | 33
| Hainsworth 2003 | | 30 | 37 | 3
| Hoang 2003 | | 27 | 30 | 0
| Masters, 2003 | | 44 | 18 | 9
| Kosmas 2001 | | 33 | 36 | 9
| Kakolyris 2001 | | 32 | 9 | 0
| van der Lee 2001 | | 38 | 29 | 0
| Sessa 2000 | | 241 cycles | 15 | 7
| Groen 1999 | | 132 cycles | 21 | 10
| Ardizzoni 1997 | | 403 cycles | 17.6 | 11.9
| Gridelli 1997 | | 30 | 0 | 6.6
| Einhorn 1995 | | 41 | | 48
| Faylona 1995 | | 42 | 24 | 48
| Sculier 1995 | | 38 | 31 | 13
| Smyth 1994 | | 5 | 0 | 0
| Jassem 1993 | | 25 | 0 | 0
Leukopenia or neutropenia | Ando 2004 | Neutropenia | 25 | 12 | 12
| Agelaki 2004 | Neutropenia | 31 | 29 (3 or 4)
| | Febrile neutropenia | | 6
| Goto 2004 | Leukopenia | 40 | 55
| | Neutropenia | | 73
| Ardizzoni 2003 | Sensitive, Leukopenia | 68 | 33.8 | 47.1
| | Neutropenia, | | 14.7 | 61.8
| | ≥ 1 episode febrile neutropenia | | 19
| | Refractory, Leukopenia | 42 | 43.9 | 31.7
| | Neutropenia | | 26.8 | 48.8
| | ≥ 1 episode febrile neutropenia | | 15
| Hainsworth 2003 | Leukopenia | 30 | 20 | 6
| | Granulocytopenia | 30 | 33 | 10
| Hoang 2003 | Neutropenia | 27 | 15 | 15
| | Febrile Neutropenia | 27 | 4 | 0
| Masters, 2003 | Leukopenia | 44 | 16 | 2
| | Granulocytopenia | 44 | 20 | 7
| Kosmas 2001 | Leukopenia | 33 | 27 | 46
| | Neutropenia | 33 | 18 | 73
| | Febrile neurtropenia | 33 | 18
| Kakolyris 2001 | Neutropenia | 32 | 22 | 16
| van der Lee 2001 | Leukopenia | 38 | 18 | 0
| Sessa 2000 | Neutropenia | 241 cycles | 16.5 | 9
| Sonpavde 2000 | Granulocytopenia | 46 | 17 | 63
| Groen 1999 | Leukopenia | 132 cycles | 27 | 6
Leukopenia or neutropenia | Ardizzoni 1997 | Leukopenia | 403 cycles | 58.5 | 9.9
| | Neutropenia | | 28.0 | 46.9
| Gridelli 1997 | Leukopenia | 30 | 13.3 | 13.3
| Einhorn 1995 | Granulocytopenia | 41 | | 71
| Faylona 1995 | Granulocytopenia | 42 | 33 | 71
| Sculier 1995 | Leukopenia | 38 | 8 | 5
| Smyth 1994 | Leukopenia | 32 | 41 | 28
| | Neutropenia | 31 | 23 | 71
| Jassem 1993 | Leukopenia | 25 | 28 | 4
| | Neutropenia | 25 | 16 | 16
| Sculier 1990 | Leukopenia | 45 | 27 | 3
Infection | Goto 2004 | | 40 | 3
| Goto 2004 | Fever | 40 | 0
| Masters, 2003 | Fever | 44 | 0 | 0
| van der Lee 2001 | Fever | 38 | 0 | 0
| Sessa 2000 | | 241 cycles | 1.2 | 0.4
| Ardizzoni 1997 | | 403 cycles | 1.0 | 0.5
| Faylona 1995 | | 42 | 29 | 10(5)
| Sculier 1995 | | 35 | 0 | 0
| Smyth 1994 | | 13 | 15 | 15
| Jassem 1993 | | 25 | 0 | 0
Other | Goto 2004 | Hyponatremia | 40 | 5
| Goto 2004 | Mucositis | 40 | 0
| Goto 2004 | Arrhythmia | 40 | 5
| Goto 2004 | Eruption | 40 | 3
| Goto 2004 | Allergy | 40 | 0

## Acronyms/Abbreviations Used in Tables

- | without
# | number
# | number
Δ | change
? | unknown, unclear
+ | with
<p | less than a partial resection
1° | primary
18-FDG | 18-fluorodeoxyglucose
95% CIL | lower limit 95% confidence interval
95% CIU | upper limit 95% confidence interval
A | Asian
A | doxorubicin (Adriamycin®)
abstr | abstract
ACCP | American College of Chest Physicians
AHRQ | Agency for Healthcare Research and Quality
ALT | alanine transaminase
Alt | alternating
AP | anterioposterior
ASCO | American Society of Clinical Oncology
AST | aspartate transaminases
ASTRO | American Society for Therapeutic Radiology and Oncology
B | bilobectomy
B | Black
BSC | best supportive care
c | complete
C | cyclophosphamide
CALGB | Cancer and Leukemia Group B
Cb | carboplatin
CCNU | lomustine
CD | cyclophosphamide- and/or doxorubicin-based chemotherapy
chemoTx | chemotherapy
CI | confidence interval
CNS | central nervous system
Conc | concurrent
cont'd | continued
contr | contralateral
Conv | conventional
CPHM | Cox proportional hazard model
CR | complete response
CT | computed tomography
Ctrl | control
CTx | chemotherapy
d | day
DA | diagnostic accuracy
dist | distant
Dx | diagnosis
E Alt | early alternating
E | etoposide
E | etoposide
ea | each
ECOG | Eastern Cooperative Oncology Group
endosc | endoscopic
EORTC LCCG | European Organization for the Research and Treatment of Cancer Lung Cancer Cooperative Group
EPC | Evidence-based Practice Center
EQ-5D | EuroQOL 5-dimension health-related quality of life instrument
ES | extensive stage
ESD | extensive-stage disease
F | female
F | fractions
F/d | fractions per day
F/U | follow-up
FDA | Food and Drug Administration
FE | fixed effects
FEV1 | forced expiratory volume in 1 second
FN | false negative
FNA | fine-needle aspiration
FP | false positive
Frac(s) | fraction(s)
FWHM | full width, half maximum
GQ | good quality
Gy | Gray
H | Hispanic
HL | hilar
HR | hazard ratio
hr | hour
Hyper | hyperfractionated
ips | ipsilateral
IV | intravenous
K-M | Kaplan-Meier
KPS | Karnofsky Performance Status
L Alt | late alternating
L | lobectomy
L | lomustine
L95 | upper limit 95% confidence interval
LCSG | Lung Cancer Study Group
LDH | lactic dehydrogenase
LINAC | linear accelerator
LN | lymph node
LRFS | local recurrence-free survival
LRFS | local recurrence-free survival
LS | limited stage
LSD | limited-stage disease
M | male
M | methotrexate
MBq | megabecquerel
mCi | milliCurie
md | median
MD | mediastinal
mets | metastases
MeV | megaelectron volt
mg | milligram
M-H | Mantel-Haenszel
MI | myocardial infarction
mn | mean
mo(s). | month(s)
MR | meta regression
MRI | magnetic resonance imaging
MS | mediastinal
N | no
n | number
N | pooled number
NCI | National Cancer Institute
NE | not evaluable
NED | no evidence of disease
neg | negative
NNEC | non-neuroendocrine carcinoma
NNT | number needed to treat
nonrandom. | nonrandomized
NOS | not otherwise specified
NR | not reported
NS | nonsignificant
NSCLC | non-small-cell lung cancer
O | other
OR | odds ratio
ORR | overall response rate
OS | overall survival
P | cisplatin
p | partial
P | pneumonectomy
PA | posterioanterior
PCI | prophylactic cranial radiation
PD | progressive disease
PE | platinum/etoposide chemotherapy
PET | positron emission tomography
PFS | progression-free survival
PI | primary investigator
po | oral
P-OR | Peto odds ratio
pos | positive
PR | partial response
PS | performance status
Pt | platinum
pub | publication
PWIFR | percent/proportion with in-field recurrence
Q | heterogeneity statistic
QoL | quality of life
QUADAS | Quality Assessment of Diagnostic Accuracy Studies
R/I | ruled in
R/O | ruled out
radiol | radiologic
RadioTx | radiotherapy
RCT | randomized, controlled trial
RD | risk difference
RE | random effects
reg | regimen
regl | regional
retrospect | retrospective
RFS | recurrence-free survival
rng | range
RNS | radionuclide scan
ROC | receiver operating characteristic
RR | relative risk
RR | risk ratio
SC | supraclavicular
SC/LC | small-cell/large-cell subtype
SCLC | small cell lung cancer
SD | stable disease
SE | standard error
Sens | sensitivity
Seq | sequential
Spec | specificity
STARD | Standards for Reporting of Diagnostic Accuracy
sup-clav | supraclavicular
supraclav | supraclavicular
surg | surgery
SWOG | Southwest Oncology Group
T | thoracotomy only (open and close)
TN | true negative
TNM | Tumor, Node, Metastasis (staging system)
TP | true positive
TRTx | thoracic radiotherapy
TTF | time to failure
Tx | treatment; therapy
U.S. | United States
U95 | upper limit 95% confidence interval
ULN | upper limit of normal
US | ultrasound
V | vincristine
VC | vital capacity
Ve | vindesine
W | White
WBC | white blood cell
WHO | World Health Organization
wk(s) | week(s)
Wt | weight
XRT | radiotherapy
Y | yes
yr | year

## Abbreviations of Combination Chemotherapy Regimens

ACO | doxorubicin, cyclophosphamide, and vincristine
ACOM | doxorubicin, lomustine, methotrexate, vincristine
BTOC | vincristine, thiotepa, cyclophosphamide, carmustine
CAE | cyclophosphamide, doxorubicin, etoposide
CAV | cyclophosphamide, doxorubicin, vincristine
CbE | carboplatin, etoposide
CbPE | carboplatin, cisplatin, etoposide
CC | cyclophosphamide, lomustine
CCM | cyclophosphamide, lomustine, methotrexate
CCMV | cyclophosphamide, lomustine, methotrexate, vincristine
CDE | cyclophosphamide, doxorubicin, etoposide
CE-CAP | cyclophosphamide, doxorubicin, cisplatin
COME | cyclophosphamide, vincristine, methotrexate, etoposide
COMF | cyclophosphamide, vincristine, methotrexate, fluorouracil
CVMP | cyclophosphamide, vincristine, methotrexate, cisplatin
EP | etoposide, platinum compound
iv T | intravenous topotecan
LCAE | lomustine, cyclophosphamide, doxorubicin, etoposide
M-CAV | methotrexate, cyclophosphamide, doxorubicin, vincristine
MCCC/VI | methotrexate, cyclophosphamide, lomustine, ifosfamide, etoposide
PE | cisplatin, etoposide
PEVe | platinum, epirubicin, etoposide
PMP | cisplatin, methotrexate, procarbazine
po T | oral topotecan
VCMV | vincristine, cyclophosphamide, mitomycin, chromomycin
VIC-E/VICE | vincristine, ifosfamide, carboplatin, etoposide
VIMP | vincristine, ifosfamide, mesna, carboplatin
VIP-E | etoposide, ifosfamide, cisplatin, and epirubicin

## References Cited in Appendix Tables

Ahles TA, Silberfarb PM, Rundle AC, et al. Quality of life in patients with limited small-cell carcinoma of the lung receiving chemotherapy with or without radiation therapy, for cancer and leukemia group B. Psychother Psychosom. 1994;62(34):193-9. [pmid: 7846263].
Albain KS, Crowley JJ, Hutchins L, et al. Predictors of survival following relapse or progression of small cell lung cancer. Southwest Oncology Group Study 8605 report and analysis of recurrent disease data base. Cancer. 1993;72(4):1184-91. [pmid: 8393365].
Ando M, Kobayashi K, Yoshimura A, et al. Weekly administration of irinotecan (CPT-11) plus cisplatin for refractory or relapsed small cell lung cancer. Lung Cancer. 2004;44(1):121-7. [pmid: 15013590].
Ardizzoni A, Hansen H, Dombernowsky P, et al. Topotecan, a new active drug in the second-line treatment of small-cell lung cancer: a phase II study in patients with refractory and sensitive disease. The European Organization for Research and Treatment of Cancer Early Clinical Studies Group and New Drug Development Office, and the Lung Cancer Cooperative Group. J Clin Oncol. 1997;15(5):2090-6. [pmid: 9164222].
Ardizzoni A, Manegold C, Debruyne C, et al. European organization for research and treatment of cancer (EORTC) 08957 phase II study of topotecan in combination with cisplatin as second-line treatment of refractory and sensitive small cell lung cancer. Clin Cancer Res. 2003;9(1):143-50. [pmid: 12538462].
Badzio A, Jassem J, Kurowski K, et al. The impact of primary pulmonary resection on local control and survival in limited disease (LD) small cell lung cancer (SCLC) patients (pts): a retrospective comparative study. Lung Cancer. 2005;49(suppl2):S316. Abstract P-750.
Badzio A, Kurowski K, Karnicka-Mlodkowska H, et al. A retrospective comparative study of surgery followed by chemotherapy vs. non-surgical management in limited-disease small cell lung cancer. Eur J Cardiothorac Surg. 2004;26(1):183-8. [pmid: 15200999].
Blum R, MacManus MP, Rischin D, et al. Impact of positron emission tomography on the management of patients with small-cell lung cancer: preliminary experience. Am J Clin Oncol. 2004;27(2):164-71. [pmid: 15057156].
Bonner JA, Sloan JA, Shanahan TG, et al. Phase III comparison of twice-daily split-course irradiation versus once-daily irradiation for patients with limited stage small-cell lung carcinoma. J Clin Oncol. 1999;17(9):2681-91. [pmid: 10561342].
Bradley JD, Dehdashti F, Mintun MA, et al. Positron emission tomography in limited-stage small-cell lung cancer: a prospective study. J Clin Oncol. 2004;22(16):3248-54. [pmid: 15310768].
Brincker H, Hindberg J, Hansen PV. Cyclic alternating polychemotherapy with or without upper and lower half-body irradiation in small cell anaplastic lung cancer. A randomized study. Eur J Cancer Clin Oncol. 1987;23(2):205-11. [pmid: 2832178].
Brink I, Schumacher T, Mix M, et al. Impact of (18F)FDG-PET on the primary staging of small-cell lung cancer. Eur J Nucl Med Mol Imaging. 2004;31(12):1614-20. [pmid: 15258700].
Coy P, Hodson DI, Murray N, et al. Patterns of failure following loco-regional radiotherapy in the treatment of limited stage small cell lung cancer. Int J Radiat Oncol Biol Phys. 1994;28(2):355-62. [pmid: 8276650].
Einhorn LH, Loehrer PJ. Hoosier Oncology Group studies in extensive and recurrent small cell lung cancer. Semin Oncol. 1995;22(1 Suppl 2):28-31. [pmid: 7846539].
Einhorn LH, Pennington K, McClean J. Phase II trial of daily oral VP-16 in refractory small cell lung cancer: a Hoosier Oncology Group study. Semin Oncol. 1990;17(1 Suppl 2):32-5. [pmid: 2154857].
Faylona EA, Loehrer PJ, Ansari R, Sandler AB, Gonin R, Einhorn LH. Phase II study of daily oral etoposide plus ifosfamide plus cisplatin for previously treated recurrent small-cell lung cancer: a Hoosier Oncology Group Trial. J Clin Oncol. 1995;13(5):1209-14. [pmid: 7738623].
Feld R, Payne D, Hodson I, et al. Complications of treatment of small cell carcinoma of the lung. Experience from a recent Canadian trial. Antibiot Chemother. 1988;41:204-9. [pmid: 2854441].
Friess GG, McCracken JD, Troxell ML, Pazdur R, Coltman CA Jr, Eyre HJ. Effect of initial resection of small-cell carcinoma of the lung: a review of Southwest Oncology Group Study 7628. J Clin Oncol. 1985;3(7):964-8. [pmid: 2991477].
George TK, Fitzgerald D, Brown BS, et al. Long-term survival in limited-stage small cell lung carcinoma. Experience in Rochester, New York from 1975 to 1981. Cancer. 1986;58(6):1193-8. [pmid: 3017533].
Graziano SL, Lee K, Propert KJ, et al. Phase II trial of etoposide and cisplatin for refractory small cell lung cancer: a Cancer and Leukemia Group B Study. Med Pediatr Oncol. 1990;18(1):22-6. [pmid: 2152956].
Gregor A, Drings P, Burghouts J, et al. Randomized trial of alternating versus sequential radiotherapy/chemotherapy in limited-disease patients with small-cell lung cancer: a European Organization for Research and Treatment of Cancer Lung Cancer Cooperative Group Study. J Clin Oncol. 1997a;15(8):2840-9. [pmid: 9256127].
Gridelli C, De Marinis F, Rossi A, et al. A phase II study of VM-26 plus lonidamine in pretreated small cell lung cancer. Anticancer Res. 1997;17(2B):1277-9. [pmid: 9137485].
Groen HJ, Fokkema E, Biesma B, et al. Paclitaxel and carboplatin in the treatment of small-cell lung cancer patients resistant to cyclophosphamide, doxorubicin, and etoposide: a non-cross-resistant schedule. J Clin Oncol. 1999;17(3):927-32. [pmid: 10071286].
Hainsworth JD, Burris HA 3rd, Erland JB, et al. Combination chemotherapy with gemcitabine and vinorelbine in the treatment of patients with relapsed or refractory small cell lung cancer: a phase II trial of the Minnie Pearl Cancer Research Network. Cancer Invest. 2003;21(2):193-9. [pmid: 12743984].
Hara N, Ichinose Y, Kuda T, et al. Long-term survivors in resected and nonresected small cell lung cancer. Oncology. 1991;48(6):441-7. [pmid: 1660999].
Hara N, Ohta M, Ichinose Y, et al. Influence of surgical resection before and after chemotherapy on survival in small cell lung cancer. J Surg Oncol. 1991;47(1):53-61. [pmid: 1850811].
Hoang T, Kim K, Jaslowski A, et al. Phase II study of second-line gemcitabine in sensitive or refractory small cell lung cancer. Lung Cancer. 2003;42(1):97-102. [pmid: 14512193].
Issell BF, Einhorn LH, Comis RL, et al. Multicenter Phase II trial of etoposide in refractory small cell lung cancer. Cancer Treat Rep. 1985;69(1):127-8. [pmid: 2981617].
James LE, Spiro S, O'Donnell KM, et al. A randomised study of timing of thoracic irradiation in small cell lung cancer (SCLC) - study 8. Lung Cancer. 2003;41(Suppl 2):S23. Abstract.
Japan Cooperative Oncology Group on Lung Cancer. Phase II study of carboplatin in patients with nonresected lung cancer. Cancer Chemother Pharmacol. 1990;26(2):101-4. [pmid: 2161295].
Jassem J, Karnicka-Mlodkowska H, van Pottelsberghe C, et al. Phase II study of vinorelbine (Navelbine) in previously treated small cell lung cancer patients. EORTC Lung Cancer Cooperative Group. Eur J Cancer. 1993;29A(12):1720-2. [pmid: 8398301].
Jeremic B, Shibamoto Y, Acimovic L, et al. Initial versus delayed accelerated hyperfractionated radiation therapy and concurrent chemotherapy in limited small-cell lung cancer: a randomized study. J Clin Oncol. 1997;15(3):893-900. [pmid: 9060525].
Jeremic B, Shibamoto Y, Nikolic N, et al. Role of radiation therapy in the combined-modality treatment of patients with extensive disease small-cell lung cancer: A randomized study. J Clin Oncol. 1999;17(7):2092-9. [pmid: 10561263].
Kakolyris S, Mavroudis D, Tsavaris N, et al. Paclitaxel in combination with carboplatin as salvage treatment in refractory small-cell lung cancer (SCLC): a multicenter phase II study. Ann Oncol. 2001;12(2):193-7. [pmid: 11300323].
Kamel EM, Zwahlen D, Wyss MT, et al. Whole-body (18)F-FDG PET improves the management of patients with small cell lung cancer. J Nucl Med. 2003;44(12):1911-7. [pmid: 14660716].
Kosmas C, Tsavaris NB, Malamos NA, et al. Phase II study of paclitaxel, ifosfamide, and cisplatin as second-line treatment in relapsed small-cell lung cancer. J Clin Oncol. 2001;19(1):119-26. [pmid: 11134204].
Lad T, Piantadosi S, Thomas P, et al. A prospective randomized trial to determine the benefit of surgical resection of residual disease following response of small cell lung cancer to combination chemotherapy. Chest. 1994;106(6 Suppl):320S-3S. [pmid: 7988254].
Lebeau B, Chastang C, Brechot JM, et al. A randomized trial of delayed thoracic radiotherapy in complete responder patients with small-cell lung cancer. Petites Cellules Group. Chest. 1993;104(3):726-33. [pmid: 8396000].
Lebeau B, Urban T, Brechot JM, et al. A randomized clinical trial comparing concurrent and alternating thoracic irradiation for patients with limited small cell lung carcinoma. “Petites Cellules” Group. Cancer. 1999;86(8):1480-7. [pmid: 10526276].
Liao M, Zhao J, Zhou Y. [Multimodality therapy of late stage lung cancer]. Zhonghua Zhong Liu Za Zhi. 1995;17(5):384-6. [pmid: 8697983].
Masters GA, Declerck L, Blanke C, et al. Phase II trial of gemcitabine in refractory or relapsed small-cell lung cancer: Eastern Cooperative Oncology Group Trial 1597. J Clin Oncol. 2003;21(8):1550-5. [pmid: 12697880].
Murray N, Coy P, Pater JL, et al. Importance of timing for thoracic irradiation in the combined modality treatment of limited-stage small-cell lung cancer. The National Cancer Institute of Canada Clinical Trials Group. J Clin Oncol. 1993;11(2):336-44. [pmid: 8381164].
Namikawa S, Den T, Kimura M, et al. The role of surgical resection and the effects of neo-adjuvant therapy in the management of small cell lung cancer. Surg Today. 1994;24(4):342-6. [pmid: 8038511].
Nou E, Brodin O, Bergh J. A randomized study of radiation treatment in small cell bronchial carcinoma treated with two types of four-drug chemotherapy regimens. Cancer. 1988;62(6):1079-90. [pmid: 2457422].
O'Brien M, Ciuleanu T, Tsekov H, et al. Survival benefit of oral topotecan plus supportive care versus supportive care alone in relapsed, resistant SCLC. Lung Cancer. 2005;49(suppl2):S54. Abstract O-157.
O'Bryan RM, Crowley JJ, Kim PN, et al. Comparison of etoposide and cisplatin with bis-chloro-ethylnitrosourea, thiotepa, vincristine, and cyclophosphamide for salvage treatment in small cell lung cancer. A Southwest Oncology Group Study. Cancer. 1990;65(4):856-60. [pmid: 2153435].
Osterlind K, Hansen M, Hansen HH, et al. Treatment policy of surgery in small cell carcinoma of the lung: retrospective analysis of a series of 874 consecutive patients. Thorax. 1985;40(4):272-7. [pmid: 2992111]. [pmcid: 460045].
Park SK, Kim GH, Jeong SS, et al. The effects according to the timing of thoracic radiotherapy in limited stage small cell lung cancer. Tuberc Respir Dis. 1996;43:903-15.
Perry MC, Eaton WL, Propert KJ, et al. Chemotherapy with or without radiation therapy in limited small-cell carcinoma of the lung. N Engl J Med. 1987;316(15):912-8. [pmid: 3029592].
Perry MC, Herndon JE 3rd, Eaton WL, et al. Thoracic radiation therapy added to chemotherapy for small-cell lung cancer: an update of Cancer and Leukemia Group B Study 8083. J Clin Oncol. 1998;16(7):2466-7. [pmid: 9667265].
Postmus PE, Smit EF, Kirkpatrick A, et al. Testing the possible non-cross resistance of two equipotent combination chemotherapy regimens against small-cell lung cancer: a phase II study of the EORTC Lung Cancer Cooperative Group. Eur J Cancer. 1993;29A(2):204-7. [pmid: 8380697].
Qiao TK, Zhou DA, Xin L, et al. [Concurrent radiotherapy combined with carboplatin and etoposide in limited stage small cell lung cancer]. Zhonghua Jie He He Hu Xi Za Zhi. 2004;27(4):237-9. [pmid: 15144613].
Rosenthal MA, Tattersall MHN, Fox RM, et al. Adjuvant thoracic radiotherapy in small cell lung cancer: Ten-year follow-up of a randomized study. Lung Cancer. 1991;7(4):235-41.
Rostad H, Naalsund A, Jacobsen R, et al. Small cell lung cancer in Norway: should more patients have been offered surgical therapy?. Eur J Cardiothorac Surg. Oct. 2004;26(4):782-6. [pmid: 15450573].
Schild SE, Bonner JA, Shanahan TG, et al. Long-term results of a phase III trial comparing once-daily radiotherapy with twice-daily radiotherapy in limited-stage small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2004;59(4):943-51. [pmid: 15234027].
Schumacher T, Brink I, Mix M, et al. FDG-PET imaging for the staging and follow-up of small cell lung cancer. Eur J Nucl Med. 2001;28(4):483-8. [pmid: 11357499].
Sculier JP, Lafitte JJ, Lecomte J, et al. A phase II randomised trial comparing the cisplatin-etoposide combination chemotherapy with or without carboplatin as second-line therapy for small-cell lung cancer. Ann Oncol. 2002;13(9):1454-9. [pmid: 12196372].
Sculier JP, Thiriaux J, Bureau G, et al. A phase II study testing weekly platinum derivative combination chemotherapy as second-line treatment in patients with advanced small cell lung cancer. Int J Oncol. 1995;6(2):425-9. [pmid: 21556555].
Sessa C, Wanders J, Roelvink M, et al. Second-line treatment of small-cell lung cancer with the camptothecin-derivative GI147211: a study of the EORTC Early Clinical Studies Group (ECSG). Ann Oncol. 2000;11(2):207-10. [pmid: 10761757].
Shen YY, Shiau YC, Wang JJ, et al. Whole-body 18F-2-deoxyglucose positron emission tomography in primary staging small cell lung cancer. Anticancer Res. 2002;22(2B):1257-64. [pmid: 12168935].
Shepherd FA, Ginsberg RJ, Patterson GA, Evans WK, Feld R. A prospective study of adjuvant surgical resection after chemotherapy for limited small cell lung cancer. A University of Toronto Lung Oncology Group study. J Thorac Cardiovasc Surg. 1989;97(2):177-86. [pmid: 2536868].
Skarlos DV, Samantas E, Briassoulis E, et al. Randomized comparison of early versus late hyperfractionated thoracic irradiation concurrently with chemotherapy in limited disease small-cell lung cancer: a randomized phase II study of the Hellenic Cooperative Oncology Group (HeCOG). Ann Oncol. 2001;12(9):1231-8. [pmid: 11697833].
Sloan JA, Bonner JA, Hillman SL, et al. A quality-adjusted reanalysis of a Phase III trial comparing once-daily thoracic radiation vs. twice-daily thoracic radiation in patients with limited-stage small-cell lung cancer(1). Int J Radiat Oncol Biol Phys. 2002;52(2):371-81. [pmid: 11872282].
Smyth JF, Smith IE, Sessa C, et al. Activity of docetaxel (Taxotere) in small cell lung cancer. The Early Clinical Trials Group of the EORTC. Eur J Cancer. 1994;30A(8):1058-60. [pmid: 7654428].
Sonpavde G, Ansari R, Walker P, et al. Phase II study of doxorubicin and paclitaxel as second-line chemotherapy of small-cell lung cancer: a Hoosier Oncology Group Trial. Am J Clin Oncol. 2000;23(1):68-70. [pmid: 10683082].
Spiro SG, Souhami RL, Geddes DM, et al. Duration of chemotherapy in small cell lung cancer: a Cancer Research Campaign trial. Br J Cancer. Apr. 1989;59(4):578-83. [pmid: 2540788].
Sun Y, Zhang XR, Yin WB, et al. Prospective multimodality treatment of SCLC—experience during the past 18 years. Gan To Kagaku Ryoho. 1995;22(Suppl 3):222-5. [pmid: 7661586].
Takada M, Fukuoka M, Kawahara M, et al. Phase III study of concurrent versus sequential thoracic radiotherapy in combination with cisplatin and etoposide for limited-stage small-cell lung cancer: results of the Japan Clinical Oncology Group Study 9104. J Clin Oncol. 2002;20(14):3054-60. [pmid: 12118018].
Trillet-Lenoir V, Lasset C, Arpin D, et al. [Comparison of 2 cisplatin and etoposide dosages in relapsing small cell lung cancer]. Bull Cancer. 1992;79(12):1173-81. [pmid: 1339011].
Turrisi AT 3rd, Kim K, Blum R, et al. Twice-daily compared with once-daily thoracic radiotherapy in limited small-cell lung cancer treated concurrently with cisplatin and etoposide. N Engl J Med. 1999;340(4):265-71. [pmid: 9920950].
van der Lee I, Smit EF, van Putten JW, et al. Single-agent gemcitabine in patients with resistant small-cell lung cancer. Ann Oncol. 2001;12(4):557-61. [pmid: 11398892].
von Pawel J, Gatzemeier U, Pujol JL, et al. Phase ii comparator study of oral versus intravenous topotecan in patients with chemosensitive small-cell lung cancer. J Clin Oncol. 2001;19(6):1743-9. [pmid: 11251005].
von Pawel J, Schiller JH, Shephered FA, et al. Topotecan versus cyclophosphamide, doxorubicin, and vincristine for the treatment of recurrent small-cell lung cancer. J Clin Oncol. 1999;17(2):658-67. [pmid: 10080612].
Wolff SN, Birch R, Sarma P, et al. Randomized dose-response evaluation of etoposide in small cell carcinoma of the lung: a Southeastern Cancer Study Group Trial. Cancer Treat Rep. 1986;70(5):583-7. [pmid: 3011257].
Work E, Bentzen SM, Nielsen OS, et al. Prophylactic cranial irradiation in limited stage small cell lung cancer: survival benefit in patients with favourable characteristics. Eur J Cancer. 1996;32A(5):772-8. [pmid: 9081352].
Work E, Nielsen OS, Bentzen SM, et al. Randomized study of initial versus late chest irradiation combined with chemotherapy in limited-stage small-cell lung cancer. Aarhus Lung Cancer Group. J Clin Oncol. 1997;15(9):3030-7. [pmid: 9294465].
Yuen AR, Zou G, Turrisi AT, et al. Similar outcome of elderly patients in intergroup trial 0096: Cisplatin, etoposide, and thoracic radiotherapy administered once or twice daily in limited stage small cell lung carcinoma. Cancer. 2000;89(9):1953-60. [pmid: 11064352].