# Appendix B. Sample Data Abstraction Forms

Question #

Table A Sample Selection

Study | Inclusion | Exclusion | n, Randomized | | | n, Withdrawn | | | n, Evaluated for Primary Outcome
| | | Total | Grp1 | Grp2 | Total | Grp1 | Grp2 | Total | Grp1 | Grp2
| | | Total | Grp1 | Grp2 | Total | Grp1 | Grp2 | Total | Grp1 | Grp2
| | | Total | Grp1 | Grp2 | Total | Grp1 | Grp2 | Total | Grp1 | Grp2
| | | Total | Grp1 | Grp2 | Total | Grp1 | Grp2 | Total | Grp1 | Grp2
| | | Total | Grp1 | Grp2 | Total | Grp1 | Grp2 | Total | Grp1 | Grp2
| | | Total | Grp1 | Grp2 | Total | Grp1 | Grp2 | Total | Grp1 | Grp2

Question #

Table B Patient Characteristics

Study | Age | | | Gender (%) | | | Race (%) | | | Performance | | | Comorbidities or Prognostic Factors
| | [underlined: Grp1] | [underlined: Grp2] | | [underlined: Grp1] | [underlined: Grp2] | | [underlined: Grp1] | [underlined: Grp2] | [underlined: ECOG] | [underlined: Grp1] | [underlined: Grp2] | | [underlined: Grp1] | [underlined: Grp2]
| | | | | | | | | | 0
| mn | | | M | | | B | | | 1
| md | | | F | | | W | | | 2
| rng | | | | | | H | | | 3
| sd | | | | | | A
| | | | | | | O
| | [underlined: Grp1] | [underlined: Grp2] | | [underlined: Grp1] | [underlined: Grp2] | | [underlined: Grp1] | [underlined: Grp2] | [underlined: ECOG] | [underlined: Grp1] | [underlined: Grp2] | | [underlined: Grp1] | [underlined: Grp2]
| | | | | | | | | | 0
| mn | | | M | | | B | | | 1
| md | | | F | | | W | | | 2
| rng | | | | | | H | | | 3
| sd | | | | | | A
| | | | | | | O
| | [underlined: Grp1] | [underlined: Grp2] | | [underlined: Grp1] | [underlined: Grp2] | | [underlined: Grp1] | [underlined: Grp2] | [underlined: ECOG] | [underlined: Grp1] | [underlined: Grp2] | | [underlined: Grp1] | [underlined: Grp2]
| | | | | | | | | | 0
| mn | | | M | | | B | | | 1
| md | | | F | | | W | | | 2
| rng | | | | | | H | | | 3
| sd | | | | | | A
| | | | | | | O
| | [underlined: Grp1] | [underlined: Grp2] | | [underlined: Grp1] | [underlined: Grp2] | | [underlined: Grp1] | [underlined: Grp2] | [underlined: ECOG] | [underlined: Grp1] | [underlined: Grp2] | | [underlined: Grp1] | [underlined: Grp2]
| | | | | | | | | | 0
| mn | | | M | | | B | | | 1
| md | | | F | | | W | | | 2
| rng | | | | | | H | | | 3
| sd | | | | | | A
| | | | | | | O

Question #

Table C Treatments

Study | Chemotherapy regimen, per protocol | | | Group 1 XRT | | Group 2 XRT | | PCI
| [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule]
| [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule]
| [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule]
| [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule]
| [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule]
| [underlined: Agent] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule] | [underlined: Dose] | [underlined: Schedule]

Question #

Table D Outcome Assessment

Study | Primary Outcomes | Secondary Outcomes | Response Criteria | Observer | F/U
| | | | | | [underlined: Total] | [underlined: Grp1] | [underlined: Grp2]
| | | | | mn
| | | | | md
| | | | | rng
| | | | | sd
| | | | | | Total | Grp1 | Grp2
| | | | | mn
| | | | | md
| | | | | rng
| | | | | sd
| | | | | | Total | Grp1 | Grp2
| | | | | mn
| | | | | md
| | | | | rng
| | | | | sd
| | | | | | Total | Grp1 | Grp2
| | | | | mn
| | | | | md
| | | | | rng
| | | | | sd
| | | | | | Total | Grp1 | Grp2
| | | | | mn
| | | | | md
| | | | | rng
| | | | | sd
| | | | | | Total | Grp1 | Grp2
| | | | | mn
| | | | | md
| | | | | rng
| | | | | sd

Question #

Table E Survival Outcomes

Study | Overall Survival | | | | | | | | Progression-Free Survival
| | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| Grp1 | | | | | | | | Grp1
| Grp2 | | | | | | | | Grp2
| Statistical Test Results | | | | | | | | Statistical Test Results
| | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| Grp1 | | | | | | | | Grp1
| Grp2 | | | | | | | | Grp2
| Statistical Test Results | | | | | | | | Statistical Test Results
| | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| Grp1 | | | | | | | | Grp1
| Grp2 | | | | | | | | Grp2
| Statistical Test Results | | | | | | | | Statistical Test Results
| | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| Grp1 | | | | | | | | Grp1
| Grp2 | | | | | | | | Grp2
| Statistical Test Results | | | | | | | | Statistical Test Results
| | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| Grp1 | | | | | | | | Grp1
| Grp2 | | | | | | | | Grp2
| Statistical Test Results | | | | | | | | Statistical Test Results
| | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr
| Grp1 | | | | | | | | Grp1
| Grp2 | | | | | | | | Grp2
| Statistical Test Results | | | | | | | | Statistical Test Results

Question #

Table F Tumor Response and Quality of Life

Study | Tumor Response | | | | | | | Quality of Life
| | N | CR | PR | SD | PD | NE | | | | Grp1 | Grp2 | Grp1 | Grp2
| | | | | | | | Scale | Domain | F/U | n | n | mn+sd | mn+sd
| Grp1
| Grp2
| Statistical Test Results
| | N | CR | PR | SD | PD | NE | | | | Grp1 | Grp2 | Grp1 | Grp2
| | | | | | | | Scale | Domain | F/U | n | n | mn+sd | mn+sd
| Grp1
| Grp2
| Statistical Test Results
| | N | CR | PR | SD | PD | NE | | | | Grp1 | Grp2 | Grp1 | Grp2
| | | | | | | | Scale | Domain | F/U | n | n | mn+sd | mn+sd
| Grp1
| Grp2
| Statistical Test Results
| | N | CR | PR | SD | PD | NE | | | | Grp1 | Grp2 | Grp1 | Grp2
| | | | | | | | Scale | Domain | F/U | n | n | mn+sd | mn+sd
| Grp1
| Grp2
| Statistical Test Results
| | N | CR | PR | SD | PD | NE | | | | Grp1 | Grp2 | Grp1 | Grp2
| | | | | | | | Scale | Domain | F/U | n | n | mn+sd | mn+sd
| Grp1
| Grp2
| Statistical Test Results
| | N | CR | PR | SD | PD | NE | | | | Grp1 | Grp2 | Grp1 | Grp2
| | | | | | | | Scale | Domain | F/U | n | n | mn+sd | mn+sd
| Grp1
| Grp2
| Statistical Test Results

Question #

Table G Adverse Events

Toxicity Type | Study | Severity or Grade | Results
Treatment-related mortality | | | F/U (yr) | Grp1 n | % | Grp2 n | % | p
Nausea | | | F/U (yr) | Grp1 n | % | Grp2 n | % | p
Vomiting | | | F/U (yr) | Grp1 n | % | Grp2 n | % | p
Anorexia | | | F/U (yr) | Grp1 n | % | Grp2 n | % | p
Lethargy | | | F/U (yr) | Grp1 n | % | Grp2 n | % | p
Neurosensory | | | F/U (yr) | Grp1 n | % | Grp2 n | % | p
Hearing loss | | | F/U (yr) | Grp1 n | % | Grp2 n | % | p
Esophagitis | | | F/U (yr) | Grp1 n | % | Grp2 n | % | p
Bronchopulmonary | | | F/U (yr) | Grp1 n | % | Grp2 n | % | p
Pneumonitis | | | F/U (yr) | Grp1 n | % | Grp2 n | % | p
Kidney | | | F/U (yr) | Grp1 n | % | Grp2 n | % | p
Anemia | | | F/U (yr) | Grp1 n | % | Grp2 n | % | p
Thrombocytopenia | | | F/U (yr) | Grp1 n | % | Grp2 n | % | p
Leukopenia or neutropenia | | | F/U (yr) | Grp1 n | % | Grp2 n | % | p
Infection | | | F/U (yr) | Grp1 n | % | Grp2 n | % | p
Other | | | F/U (yr) | Grp1 n | % | Grp2 n | % | p

Question #

Table H Study Quality Ratings

Study | Initial Assembly of Comparable Groups | Low Loss to Followup, Maintenance of Comparable Groups | Measurements Reliable, Valid, Equal* | Interventions Comparable/ Clearly Defined | Appropriate Analysis of Results | Overall Rating

Question 6: Positron Emission Tomography for Staging of Small-Cell Lung Cancer

Table 6A Sample Selection

Study | Design | Inclusion | Exclusion | n, Enrolled | n, Withdrawn or Excluded | n, Evaluated

Question 6: Positron Emission Tomography for Staging of Small-Cell Lung Cancer

Table 6B Patient Characteristics

Study | Age (yr) | Gender (%) | Stage | | Race | Performance Status (%) | Comorbidities or Prognostic Factors (%)
| | | Limited % | Extensive %
| med | M
| | F
| med | M
| | F
| med | M
| | F
| med | M
| | F
| med | M
| | F
| med | M
| | F

Question 6: Positron Emission Tomography for Staging of Small-Cell Lung Cancer

Table 6C Test Procedure and Interpretation

Study | PET Procedure | PET Interpretation | Conventional Staging Procedure | Conventonal Staging Interpretation

Question 6: Positron Emission Tomography for Staging of Small-Cell Lung Cancer

Table 6D Reference Standard Procedure and Interpretation, Management Decisions

Study | Decision Rules for Receiving Reference Standard | Reference Standard Procedure | Reference Standard Interpretation | Management Decisions

Question 6: Positron Emission Tomography for Staging of Small-Cell Lung Cancer

Table 6E Diagnostic Accuracy Results

Study | Test | Focus | n | TP | FN | FP | TN | Prev | Sens | Sens 95% CIL | Sens 95% CIU | Spec | Sens 95% CIL | Sens 95% CIU | PPV | NPV | DA

Question 6: Positron Emission Tomography for Staging of Small-Cell Lung Cancer

Table 6F Staging Accuracy Results

| | | Correctly Upstaged | | Incorrectly Upstaged | | Correctly Downstaged | | Incorrectly Downstaged | | Identified Unsuspected Metastases | | | Ruled Out Suspected Metastases | | | Missed Metastases
Study | Test | Use | # | % | # | % | # | % | # | % | Site | # | % | Site | # | % | Site | # | %

Question 6: Positron Emission Tomography for Staging of Small-Cell Lung Cancer

Table 6G Patient Management and Other Results

| | | PET Changed | | | Patient Management
Study | Test | Use | # | % | Changes | Other Findings

Question 6: Positron Emission Tomography for Staging of Small-Cell Lung Cancer

Table 4G Study Quality Ratings

Study | Representative sample? | Clear Selection Criteria? | Reference standard correctly classifies target condition? | Period between test, reference standard short enough? | Whole sample or random selection received reference standard?

Study | Patients received reference standard regardless of test results? | Reference standard independent of test? | Test execution sufficiently described? | Reference standard execution sufficiently described?

Study | Test results interpreted blind to reference standard? | Reference standard results interpreted blind to test? | Clinical practice data available for test interpretation? | Uninterpretable/ indeterminate results reported? | Withdrawals explained?