# Appendix A. Exact Search Strings

MEDLINE search (performed through 12/21/04)

EMBASE search (performed through 03/04/05)

Cochrane Controlled Clinical Trials Register (performed through 03/11/05)

Database Search Strategies: Key Questions 1–5, 7–9

- (lung neoplasms [mh] AND (“small cell” [tw] OR “small-cell” [tw])) OR
- carcinoma, small cell [mh] OR
- ((“small cell” [tw] OR “small-cell” [tw]) AND (lung [tw] OR pulmonary [tw] OR bronchial [tw] OR bronchogenic [tw]))

Results of this search will be limited to citations also identified by the Cochrane Handbook search strategy for controlled trials (Alderson et al. 2004):

- randomized controlled trial [pt] OR
- controlled clinical trial [pt] OR
- randomized controlled trials [mh] OR
- random allocation [mh] OR
- double-blind method [mh] OR
- single-blind method [mh] OR
- clinical trial [pt] OR
- clinical trials [mh] OR
- “clinical trial” [tw] OR
- ((singl* [tw] OR doubl* [tw] OR trebl* [tw] OR tripl* [tw]) AND (mask* [tw] OR blind* [tw])) OR
- placebos [mh] OR
- placebo* [tw] OR
- random* [tw] OR
- research design [mh:noexp] OR
- comparative study [mh] OR
- evaluation studies [mh] OR
- follow-up studies [mh] OR
- prospective studies [mh] OR
- control* [tw] OR
- prospectiv* [tw] OR
- volunteer* [tw])

For Key Question 6 (PET Imaging), the following search terms were used:

(carcinoma, small cell [mh] OR ((“small cell” [tw] OR “small-cell” [tw]) AND (lung [tw] OR pulmonary [tw] OR bronchial [tw] OR bronchogenic [tw]))) AND (positron* [tw] OR pet [tw] OR “PET-CT” OR “PET/CT” OR FDG*)