# Appendixes

Appendix A. Exact Search Strings

Appendix B. Sample Data Abstraction Forms

Appendix C Evidence Tables

Appendix D. Listing of Excluded Studies

Appendix E.Technical Expert Panel (TEP) and Reviewers