# Glossary

## Statistical/Methodological Terms Defined

ANOVA. Analysis of Variance. A test of the statistical significance of the differences among the mean scores of two or more groups on one or more variables

Backward selection logistic regression. See stepwise regression (variables are removed one at a time)

Chi-square χ ^ 2 ^ test. Any statistical hypothesis test in which the test statistic has a chi-square distribution if the null hypothesis is true. For example, it is used to compute the probability that there is no significant difference between the expected frequency of an occurrence with the observed frequency of that occurrence.

Cochranes's Q test. A test for statistical heterogeneity between studies, calculated as the sum of the squared differences between each study's effect estimate and the overall effect estimate, weighted for the information provided by the study. Under the null hypothesis, it follows a chi-squared distribution with degrees of freedom equal to the total number of studies less one

Correlation Coefficient. The correlation coefficient measures the strength of a linear relationship between two variables. Commonly designated as r, its values range from -1 to +1, indicating a strong negative relationship to a strong positive relationship with 0 (zero) as neutral

Cox Regression Model. A regression technique that allows adjustment for known differences in baseline characteristics between experimental and control groups as applied to survival data

Diagnostic Odds Ratio. This is a useful measure when combining studies in a systematic review. The DOR describes the odds of positive test results in participants with disease compared with the odds of positive test results in those without disease. A single diagnostic odds ratio corresponds to a set of sensitivities and specificities depicted by a receiver operating characteristic curve

Fisher's exact test. A test which can be used to determine if there are nonrandom associations between two [underlined: categorical variables]. It is an alternative to the Chi-square test. The test is based on exact probabilities from a specific distribution. The Chi-square test relies on a large sample approximation. Therefore, Fisher's test may be used in situations where a large sample approximation is inappropriate

Forest Plots. A graphical display tool that presents individual studies (black squares) with confidence interval lines through them, stacked upon each other, and summarized in a pooled effect estimate (black diamond)

Forward logistic regression. See stepwise regression. (variables are added one at a time)

Hazard Ratio. The weighted relative risk over the entire period of the study

Kaplan Meier Survival Analysis. Often shown as a curve that starts at 100% of the study population and shows the percentage of the population still surviving (or free of disease or some other outcome) at successive times for as long as information is available. Synonymous with Survival Curve

Kruskal Wallis. This is a non-parametric test for assessing differences between the medians of two or more samples to determine if the samples have come from different populations. It is useful for situations where the ANOVA normality assumptions may not apply.

Likelihood ratio. This statistic incorporates both the sensitivity and specificity of the test and provides a direct estimate of how much a test result will change the odds of having a disease. The likelihood ratio for a positive result (LR+) tells you how much the odds of the disease increase when a test is positive. The likelihood ratio for a negative result (LR-) tells you how much the odds of the disease decrease when a test is negative

Logistic regression. A term used for a regression analysis in which the dependent or target variable is dichotomous.

Multiple linear mixed effects. These fit linear relationships between dependent and independent variables using mixed-effects models. Mixed effects models provide a powerful and flexible tool for the analysis of balanced and unbalanced grouped data in the presence of fixed and random effects.

Multiple linear regression. This aim of this analysis is to find a linear relationship between one dependent variable, and multiple independent variables

Multiple logistic regression. An extension of logistic regression to accommodate a dependent variable with more than 2 levels or categories (i.e. polytomous or multinomial variable)

Negative predictive value. The probability that the patient will not have the disease when restricted to all patients who test negative

Odds Ratio. This term differs from risk in that it involves two probabilities instead of just one and these are expressed in terms of a ratio. Specifically, odds are the ratio of the probability of an event occurring to the probability of the event not occurring

Pearson product-moment correlation coefficient. It is one example of a correlation coefficient. It is a measure of the linear association between two variables that have been measured on interval or ratio scales. It is calculated by dividing the covariance of the two variables by the product of their standard deviations

Positive Predictive Value. The probability that the patient has the disease when restricted to those patients who test positive

Relative Risk. A measure of the number of outcome events in the treatment group vs. the number in the control group. An RR = 1 indicates that the outcome rate is the same in both groups, i.e. the treatment group is no better or worse than the control group. An RR < 1 indicates that the event rate is less in the treatment group and an RR > 1 indicates that the event rate is more in the treatment group. The further that the RR is from 1, the greater the difference in event rates between the treatment and control

ROC. Receiver Operating Characteristic Curves. Used as a measure to assess the accuracy of diagnostic tests. They display the relationship between sensitivity (true positive rate) and 1-specificity (false positive rate) across all possible threshold values that define the positivity of a disease or condition. Summary measures i.e., the area under the curve (AUC) can explain the capacity of a test to discriminate a diseased from a non-diseased subject. An ROC curve for a perfect test has an area under the curve = 1.0 while a test that performs no better than by chance has an area under the curve of only 0.5

Sensitivity. The probability that the test is positive when given to a group of patients with the disease. A large sensitivity means that a negative test can rule out the disease

Simple (univariate) linear regression. This analysis aims to find a linear relationship between a response variable and a possible predictor variable by the method of least squares (the most common method of defining a straight line through a set of points on a scatterplot)

Simultaneous logistic regression. See multiple logistic regression.

Spearman's rank correlation coefficient. The nonparametric equivalent to the standard correlation coefficient (an expression of the relationship between two variables with one another)

Specificity. The probability that the test will be negative among patients who do not have the disease. A large specificity means that a positive test can rule in the disease

Standard Error (SE). The standard deviation of an estimate of a population parameter (thus, the standard error of the mean is the standard deviation of the estimate of the population mean value)

Stepwise Regression. Related to multiple regression analysis, but differs in that variables are entered into or removed from computational analysis one at a time to determine how much is “gained” or “lost” by each variable

Wilcoxon Mann-Whitney Test. This test does not require the assumption that the differences between the two samples are [underlined: normally distributed]. It is one of the most powerful of the non-parametric tests for comparing two populations. The t-test for independent samples (between groups), would be the comparable parametric test