# List of Acronyms/Abbreviations

ACC | American College of Cardiology
ACE | Angiotensin Coverting Enzyme
ACID | Automatic Implantable Cardiac Defibrillator
ACS | Acute Coronary Syndrome
AF | Atrial Fibrillation
AHA | American Heart Association
AHRQ | Agency for Healthcare Research Quality
AMED | Allied and Complementary Medicine
ANP | A-Type Natriuretic Peptide
AR | Aortic Regurgitation
AS | Aortic Stenosis
AUC | Area Under the (plasma time) Curve
BMI | Body Mass Index
BNP | B-Type Natriuretic Peptide
CAD | Coronary Artery Disease
CAGB | Coronary Artery Bypass Graft
CHF | Congestive Heart Failure
CCS | Canadian Cardiovascular Society
cGMP | Cyclic guanosine mononucleotide phosphate
CI | Confidence Interval
CPE | Cardiogenic pulmonary edema
CRP | C-reactive protein
CRT | Cardiac Resynchronization Therapy
CT | Computerized Tomography
CVD | Cardiovascular Disease
DOR | Diagnostic Odds Ratio
E/A | Early to late(atrial) echocardiographic phases of ventricular filling
ECG | Electrocardiogram
ECP | Enhanced Counterpulsation
ED | Emergency Department
EF | Ejection Fraction
ELISA | Enzyme Linked ImmunoSorbent Assay
FDA | Food and Drug Administration
FN | False Negative
FPR | False-Positive Rates
HbA1c | Hemoglobin A1c
HF | Heart Failure
HR | Hazard Ratio
IABP | Intra-Aortic Balloon Pump
IHD | Idiopathic Heart Disease
JVP | Jugular Venous Pressure
LAD | Left Anterior Descending
LR | Likelihood Ratio
LR- | Negative Likelihood Ratio
LR+ | Positive Likelihood Ratio
LV | Left Ventricular
LVD | Left Ventricular Dysfunction
LVEDD | Left Ventricular End Diastolic Diameter
LVEF | Left Ventricular Ejection Fraction
LVESD | Left Ventricular End Systolic Dimension
LVSD | Left Ventricular Systolic Dysfunction
MIBG | ^123^I-metaiodobenzylguanidine
MI | Myocardial Infarction
MRI | Magnetic Resonance Imaging
MRNA | Myocardial Radionuclide Angiogram
MS | Mitral Stenosis
NHANES | National Health and Nutrition Examination Survey
NPV | Negative Predictive Value
NSTEMI | Non ST-Elevation Myocardial Infarction
NT-proBNP | N-Terminal proBNP
NYHA | New York Heart Association
PCI | Percutaneous Coronary Interventions
PTCA | Percutaneous Transluminal Coronary Angioplasty
PCWP | Pulmocapillary wedge pressure
QoL | Quality of Life
QUADS | Quality Assessment of Diagnostic Accuracy Studies
RCT | Randomized Controlled Trial
RNA | Radionuclide Angiogram
ROC | Receiver Operator Characteristic
RR | Relative Risk
SROC | Summary Receiver Operator Characteristic
SRS | Systematic Review Software
STEMI | ST-Elevation Myocardial Infarction
TEP | Technical Expert Panel
TIA | Transient ischemic attack
TN | True Negative
TOO | Task Order Officer
TP | True Positive
TPR | True-Positive Rates
UKNPS | United Kingdom Natriuretic Peptide Study
VAD | Ventricular Assist Device