# References

1 Silver MA, Maisel A, Yancy CW, et al. BNP Consensus Panel 2004: A clinical approach for the diagnostic, prognostic, screening, treatment monitoring, and therapeutic roles of natriuretic peptides in cardiovascular diseases. [Review] [153 refs]. Congest Heart Fail. Sep. 2004;10(5 Suppl 3):1-30.
2 Rademaker MT, Richards AM. Cardiac natriuretic peptides for cardiac health. [Review] [105 refs]. Clin Sci (Colch ). Jan. 2005;108(1):23-36. [pmid: 15476436].
3 Grabowski M, Filipiak KJ, Karpinski G, et al. Serum B-type natriuretic peptide levels on admission predict not only short-term death but also angiographic success of procedure in patients with acute ST-elevation myocardial infarction treated with primary angioplasty. Am Heart J. Oct. 2004;148(4):655-62. [pmid: 15459597].
4 Olsen MH, Wachtell K, Tuxen C, et al. N-terminal pro-brain natriuretic peptide predicts cardiovascular events in patients with hypertension and left ventricular hypertrophy: a LIFE study. J Hypertens. Aug. 2004;22(8):1597-604. [pmid: 15257184].
5 Redfield MM, Rodeheffer RJ, Jacobsen SJ, et al. Plasma brain natriuretic peptide to detect preclinical ventricular systolic or diastolic dysfunction: a community-based study. Circulation. Jun 29. 2004;109(25):3176-81. [pmid: 15184280].
6 Weber M, Arnold R, Rau M, et al. Relation of N-terminal pro-B-type natriuretic peptide to severity of valvular aortic stenosis. Am J Cardiol. Sep 15. 2004;94(6):740-5. [pmid: 15374777].
7 Lainchbury JG, Campbell E, Frampton CM, et al. Brain natriuretic peptide and n-terminal brain natriuretic peptide in the diagnosis of heart failure in patients with acute shortness of breath. J Am Coll Cardiol. Aug 20. 2003;42(4):728-35. [pmid: 12932611].
8 James SK, Lindahl B, Siegbahn A, et al. N-terminal pro-brain natriuretic peptide and other risk markers for the separate prediction of mortality and subsequent myocardial infarction in patients with unstable coronary artery disease: a Global Utilization of Strategies To Open occluded arteries (GUSTO)-IV substudy. Circulation. Jul 22. 2003;108(3):275-81. [pmid: 12847065].
9 Ueda R, Yokouchi M, Suzuki T, et al. Prognostic value of high plasma brain natriuretic peptide concentrations in very elderly persons. Am J Med. Mar. 2003;114(4):266-70. [pmid: 12681452].
10 Suzuki M, Hamada M, Yamamoto K, et al. Brain natriuretic peptide as a risk marker for incident hypertensive cardiovascular events. Hypertens Res. Sep. 2002;25(5):669-76. [pmid: 12452317].
11 Bettencourt P, Ferreira A, Dias P, et al. Evaluation of brain natriuretic peptide in the diagnosis of heart failure. Cardiology. 2000;93(12):19-25. [pmid: 10894902].
12 Tsutamoto T, Wada A, Maeda K, et al. Attenuation of compensation of endogenous cardiac natriuretic peptide system in chronic heart failure: prognostic role of plasma brain natriuretic peptide concentration in patients with chronic symptomatic left ventricular dysfunction. Circulation. Jul 15. 1997;96(2):509-16. [pmid: 9244219].
13 Omland T, Aakvaag A, Bonarjee VV, et al. Plasma brain natriuretic peptide as an indicator of left ventricular systolic function and long-term survival after acute myocardial infarction. Comparison with plasma atrial natriuretic peptide and N-terminal proatrial natriuretic peptide. Circulation. Jun 1. 1996;93(11):1963-9. [pmid: 8640969].
14 Lindahl B, Lindback J, Jernberg T, et al. Serial analyses of N-terminal pro-B-type natriuretic peptide in patients with non-ST-segment elevation acute coronary syndromes A Fragmin and fast Revascularisation during InStability in coronary artery disease (FRISC)-II substudy. J Am Coll Cardiol. Feb 15. 2005;45(4):533-41. [pmid: 15708700].
15 Tarnow L, Hildebrandt P, Hansen BV, et al. Plasma N-terminal pro-brain natriuretic peptide as an independent predictor of mortality in diabetic nephropathy. Diabetologia. Jan. 2005;48(1):149-55. [pmid: 15616804].
16 Bayes-Genis A, Santalo-Bel M, Zapico-Muniz E, et al. N-terminal probrain natriuretic peptide (NT-proBNP) in the emergency diagnosis and in-hospital monitoring of patients with dyspnoea and ventricular dysfunction. Eur J Heart Fail. Mar 15. 2004;6(3):301-8. [pmid: 14987580].
17 Logeart D, Saudubray C, Beyne P, et al. Comparative value of Doppler echocardiography and B-type natriuretic peptide assay in the etiologic diagnosis of acute dyspnea. J Am Coll Cardiol. Nov 20. 2002;40(10):1794-800. [pmid: 12446063].
18 Maisel AS, Krishnaswamy P, Nowak RM, et al. Rapid measurement of B-type natriuretic peptide in the emergency diagnosis of heart failure.summary for patients in J Fam Pract. 2002 Oct;51(10):816; PMID: 12401145]. N Engl J Med. Jul 18. 2002;347(3):161-7. [pmid: 12124404].
19 Dokainish H, Pillai M, Murphy SA, et al. Prognostic implications of elevated troponin in patients with suspected acute coronary syndrome but no critical epicardial coronary disease: a TACTICS-TIMI-18 substudy. J Am Coll Cardiol. Jan 4. 2005;45(1):19-24. [pmid: 15629367].
20 Jarai R, Iordanova N, Jarai R, et al. Risk assessment in patients with unstable angina/non-ST-elevation myocardial infarction and normal N-terminal pro-brain natriuretic peptide levels by N-terminal pro-atrial natriuretic peptide. Eur Heart J. Feb. 2005;26(3):250-6. [pmid: 15618049].
21 Bazzino O, Fuselli JJ, Botto F, et al. Relative value of N-terminal probrain natriuretic peptide, TIMI risk score, ACC/AHA prognostic classification and other risk markers in patients with non-ST-elevation acute coronary syndromes. Eur Heart J. May. 2004;25(10):859-66. [pmid: 15140534].
22 Jernberg T, Lindahl B, Siegbahn A, et al. N-terminal pro-brain natriuretic peptide in relation to inflammation, myocardial necrosis, and the effect of an invasive strategy in unstable coronary artery disease. J Am Coll Cardiol. Dec 3. 2003;42(11):1909-16. [pmid: 14662251].
23 Ishii J, Cui W, Kitagawa F, et al. Prognostic value of combination of cardiac troponin T and B-type natriuretic peptide after initiation of treatment in patients with chronic heart failure. Clin Chem. Dec. 2003;49(12):2020-6. [pmid: 14633873].
24 Jernberg T, Stridsberg M, Venge P, et al. N-terminal pro brain natriuretic peptide on admission for early risk stratification of patients with chest pain and no ST-segment elevation. J Am Coll Cardiol. Aug 7. 2002;40(3):437-45. [pmid: 12142108].
25 Bertinchant JP, Combes N, Polge A, et al. Prognostic value of cardiac troponin T in patients with both acute and chronic stable congestive heart failure: comparison with atrial natriuretic peptide, brain natriuretic peptide and plasma norepinephrine. Clin Chim Acta. Feb. 2005;352(12):143-53. [pmid: 15653109].
26 Taniguchi R, Sato Y, Yamada T, et al. Combined measurements of cardiac troponin T and N-terminal pro-brain natriuretic peptide in patients with heart failure. Circ J. Dec. 2004;68(12):1160-4. [pmid: 15564700].
27 Mega JL, Morrow DA, de Lemos JA, et al. B-type natriuretic peptide at presentation and prognosis in patients with ST-segment elevation myocardial infarction: an ENTIRE-TIMI-23 substudy. J Am Coll Cardiol. Jul 21. 2004;44(2):335-9. [pmid: 15261928].
28 Morrow DA, de Lemos JA, Sabatine MS, et al. Evaluation of B-type natriuretic peptide for risk assessment in unstable angina/non-ST-elevation myocardial infarction: B-type natriuretic peptide and prognosis in TACTICS-TIMI 18.[erratum appears in J Am Coll Cardiol. 2003 May 21;41(10):1852]. J Am Coll Cardiol. Apr 16. 2003;41(8):1264-72. [pmid: 12706919].
29 Panteghini M, Cuccia C, Bonetti G, et al. Rapid determination of brain natriuretic peptide in patients with acute myocardial infarction. Clin Chem Lab Med. Feb. 2003;41(2):164-8. [pmid: 12667002].
30 Kyuma M, Nakata T, Hashimoto A, et al. Incremental prognostic implications of brain natriuretic peptide, cardiac sympathetic nerve innervation, and noncardiac disorders in patients with heart failure. J Nucl Med. Feb. 2004;45(2):155-63. [pmid: 14960630].
31 Kawai K, Hata K, Takaoka H, et al. Plasma brain natriuretic peptide as a novel therapeutic indicator in idiopathic dilated cardiomyopathy during beta-blocker therapy: a potential of hormone-guided treatment. Am Heart J. Jun. 2001;141(6):925-32. [pmid: 11376305].
32 Akioka K, Takeuchi K, Yanagi S, et al. Prognostic value of Doppler transmittal flow patterns and cardiac natriuretic peptides in patients with chronic congestive heart failure admitted for episodes of acute decompensation. Heart Vessels. 2000;15(2):53-60. [pmid: 11199504].
33 Bettencourt P, Ferreira A, Pardal-Oliveira N, et al. Clinical significance of brain natriuretic peptide in patients with postmyocardial infarction. Clin Cardiol. Dec. 2000;23(12):921-7. [pmid: 11129679].
34 Bettencourt P, Ferreira A, Sousa T, et al. Brain natriuretic peptide as a marker of cardiac involvement in hypertension. Int J Cardiol. May 15. 1999;69(2):169-77. [pmid: 10549840].
35 Hartmann F, Packer M, Coats AJ, et al. NT-proBNP in severe chronic heart failure: rationale, design and preliminary results of the COPERNICUS NT-proBNP substudy. Eur J Heart Fail. Mar 15. 2004;6(3):343-50. [pmid: 14987586].
36 Bettencourt P, Frioes F, Azevedo A, et al. Prognostic information provided by serial measurements of brain natriuretic peptide in heart failure. Int J Cardiol. Jan. 2004;93(1):45-8. [pmid: 14729434].
37 Shiga T, Hosaka F, Wakaumi M, et al. Amiodarone decreases plasma brain natriuretic peptide level in patients with heart failure and ventricular tachyarrhythmia. Cardiovasc Drugs Ther. Jul. 2003;17(4):325-33. [pmid: 14618094].
38 Fung JW, Yu CM, Yip G, et al. Effect of beta blockade (carvedilol or metoprolol) on activation of the renin-angiotensin-aldosterone system and natriuretic peptides in chronic heart failure. Am J Cardiol. Aug 15. 2003;92(4):406-10. [pmid: 12914870].
39 Latini R, Masson S, Anand I, et al. Effects of valsartan on circulating brain natriuretic peptide and norepinephrine in symptomatic chronic heart failure: the Valsartan Heart Failure Trial (Val-HeFT). Circulation. Nov 5. 2002;106(19):2454-8. [pmid: 12417542].
40 Yoshimura M, Mizuno Y, Nakayama M, et al. B-type natriuretic peptide as a marker of the effects of enalapril in patients with heart failure. Am J Med. Jun 15. 2002;112(9):716-20. [pmid: 12079712].
41 Stanek B, Frey B, Hulsmann M, et al. Prognostic evaluation of neurohumoral plasma levels before and during beta-blocker therapy in advanced left ventricular dysfunction. J Am Coll Cardiol. Aug. 2001;38(2):436-42. [pmid: 11499735].
42 Brunner-La Rocca HP, Weilenmann D, Kiowski W, et al. Within-patient comparison of effects of different dosages of enalapril on functional capacity and neurohormone levels in patients with chronic heart failure. Am Heart J. Oct. 1999;138(4 Pt 1):654-62. [pmid: 10502210].
43 Baruch L, Glazer RD, Aknay N, et al. Morbidity, mortality, physiologic and functional parameters in elderly and non-elderly patients in the Valsartan Heart Failure Trial (Val-HeFT). Am Heart J. Dec. 2004;148(6):951-7. [pmid: 15632877].
44 Yoshizawa A, Yoshikawa T, Nakamura I, et al. Brain natriuretic peptide response is heterogeneous during beta-blocker therapy for congestive heart failure. J Card Fail. Aug. 2004;10(4):310-5. [pmid: 15309697].
45 Krum H, Carson P, Farsang C, et al. Effect of valsartan added to background ACE inhibitor therapy in patients with heart failure: Results from Val-HeFT. Eur J Heart Fail. 2004;6(7):937-45. [pmid: 15556056].
46 Maggioni AP, Anand I, Gottlieb SO, et al. Effects of valsartan on morbidity and mortality in patients with heart failure not receiving angiotensin-converting enzyme inhibitors. J Am Coll Cardiol. 2002;40(8):1414-21. [pmid: 12392830].
47 Sliwa K, Norton GR, Kone N, et al. Impact of initiating carvedilol before angiotensin-converting enzyme inhibitor therapy on cardiac function in newly diagnosed heart failure. J Am Coll Cardiol. 2004;44(9):1825-30. [pmid: 15519014].
48 Barcarse E, Kazanegra R, Chen A, et al. Combination of B-type natriuretic peptide levels and non-invasive hemodynamic parameters in diagnosing congestive heart failure in the emergency department. Congest Heart Fail. Jul. 2004;10(4):171-6. [pmid: 15314474].
49 Maisel AS, Clopton P, Krishnaswamy P, et al. Impact of age, race, and sex on the ability of B-type natriuretic peptide to aid in the emergency diagnosis of heart failure: results from the Breathing Not Properly (BNP) multinational study. Am Heart J. Jun. 2004;147(6):1078-84. [pmid: 15199359].
50 Knudsen CW, Riis JS, Finsen AV, et al. Diagnostic value of a rapid test for B-type natriuretic peptide in patients presenting with acute dyspnoe: effect of age and gender. Eur J Heart Fail. Jan. 2004;6(1):55-62. [pmid: 15012919].
51 Knudsen CW, Omland T, Clopton P, et al. Diagnostic value of B-Type natriuretic peptide and chest radiographic findings in patients with acute dyspnea. Am J Med. Mar 15. 2004;116(6):363-8. [pmid: 15006584].
52 Villacorta H, Duarte A, Duarte NM, et al. The role of B-type natriuretic peptide in the diagnosis of congestive heart failure in patients presenting to an emergency department with dyspnea. Arq Bras Cardiol. 2002;79(6):569-72. [pmid: 12532240].
53 Jose JV, Gupta SN, Selvakumar D. Utility of N-terminal pro-brain natriuretic peptide for the diagnosis of heart failure. Indian Heart J. Jan. 2003;55(1):35-9. [pmid: 12760585].
54 McCullough PA, Nowak RM, McCord J, et al. B-type natriuretic peptide and clinical judgment in emergency diagnosis of heart failure: analysis from Breathing Not Properly (BNP) Multinational Study. Circulation. Jul 23. 2002;106(4):416-22. [pmid: 12135939].
55 Morrison LK, Harrison A, Krishnaswamy P, et al. Utility of a rapid B-natriuretic peptide assay in differentiating congestive heart failure from lung disease in patients presenting with dyspnea. J Am Coll Cardiol. Jan 16. 2002;39(2):202-9. [pmid: 11788208].
56 Dao Q, Krishnaswamy P, Kazanegra R, et al. Utility of B-type natriuretic peptide in the diagnosis of congestive heart failure in an urgent-care setting. J Am Coll Cardiol. Feb. 2001;37(2):379-85. [pmid: 11216950].
57 Ray P, Arthaud M, Lefort Y, et al. Usefulness of B-type natriuretic peptide in elderly patients with acute dyspnea. Intensive Care Med. Dec. 2004;30(12):2230-6. [pmid: 15502931].
58 Seino Y, Ogawa A, Yamashita T, et al. Application of NT-proBNP and BNP measurements in cardiac care: a more discerning marker for the detection and evaluation of heart failure. Eur J Heart Fail. Mar 15. 2004;6(3):295-300. [pmid: 14987579].
59 Lee SC, Stevens TL, Sandberg SM, et al. The potential of brain natriuretic peptide as a biomarker for New York Heart Association class during the outpatient treatment of heart failure. J Card Fail. Jun. 2002;8(3):149-54. [pmid: 12140807].
60 Hammerer-Lercher A, Neubauer E, Muller S, et al. Head-to-head comparison of N-terminal pro-brain natriuretic peptide, brain natriuretic peptide and N-terminal pro-atrial natriuretic peptide in diagnosing left ventricular dysfunction. Clin Chim Acta. Aug 20. 2001;310(2):193-7. [pmid: 11498085].
61 Maeda K, Tsutamoto T, Wada A, et al. Plasma brain natriuretic peptide as a biochemical marker of high left ventricular end-diastolic pressure in patients with symptomatic left ventricular dysfunction. Am Heart J. May. 1998;135(5 Pt 1):825-32. [pmid: 9588412].
62 Yamada Y, Goto J, Yokota M, et al. Brain natriuretic peptide is a sensitive indicator of impaired left-ventricular function in elderly patients with cardiovascular disease. Cardiology. Sep. 1997;88(5):401-7. [pmid: 9286500].
63 Hobbs FD, Davis RC, Roalfe AK, et al. Reliability of N-terminal proBNP assay in diagnosis of left ventricular systolic dysfunction within representative and high risk populations. Heart. Aug. 2004;90(8):866-70. [pmid: 15253955]. [pmcid: 1768355].
64 Wright SP, Doughty RN, Pearl A, et al. Plasma amino-terminal pro-brain natriuretic peptide and accuracy of heart-failure diagnosis in primary care: a randomized, controlled trial. J Am Coll Cardiol. Nov. 2003;42(10):1793-800. [pmid: 14642690].
65 Nielsen LS, Svanegaard J, Klitgaard NA, et al. N-terminal pro-brain natriuretic peptide for discriminating between cardiac and non-cardiac dyspnoea. Eur J Heart Fail. Jan. 2004;6(1):63-70. [pmid: 15012920].
66 Landray MJ, Lehman R, Arnold I. Measuring brain natriuretic peptide in suspected left ventricular systolic dysfunction in general practice: cross-sectional study. BMJ. Apr 8. 2000;320(7240):985-6. [pmid: 10753153]. [pmcid: 27340].
67 Alehagen U, Eriksson H, Nylander E, et al. Heart failure in the elderly: Characteristics of a Swedish primary health care population. Heartdrug. 2002;2(5):211-20.
68 Gustafsson F, Badskjaer J, Hansen FS, et al. Value of N-terminal proBNP in the diagnosis of left ventricular systolic dysfunction in primary care patients referred for echocardiography. Heartdrug. 2003;3(3):141-6.
69 Bhalla MA, Chiang A, Epshteyn VA, et al. Prognostic role of B-type natriuretic peptide levels in patients with type 2 diabetes mellitus. J Am Coll Cardiol. Sep 1. 2004;44(5):1047-52. [pmid: 15337217].
70 Gaede P, Hildebrandt P, Hess G, et al. Plasma N-terminal pro-brain natriuretic peptide as a major risk marker for cardiovascular disease in patients with type 2 diabetes and microalbuminuria. Diabetologia. 2005;48(1):156-63. [pmid: 15619076].
71 Kellett J. Prediction of in-hospital mortality by brain natriuretic peptide levels and other independent variables in acutely ill patients with suspected heart disease. Can J Cardiol. May 15. 2004;20(7):686-90. [pmid: 15197420].
72 Nagao K, Hayashi N, Kanmatsuse K, et al. B-type natriuretic peptide as a marker of resuscitation in patients with cardiac arrest outside the hospital. Circ J. May. 2004;68(5):477-82. [pmid: 15118292].
73 Wendelboe Nielsen O, Kirk V, Bay M, et al. Value of N-terminal pro brain natriuretic peptide in the elderly: data from the prospective Copenhagen Hospital Heart Failure study (CHHF). Eur J Heart Fail. Mar 15. 2004;6(3):275-9. [pmid: 14987576].
74 Wang TJ, Larson MG, Levy D, et al. Plasma natriuretic peptide levels and the risk of cardiovascular events and death. N Engl J Med. Feb 12. 2004;350(7):655-63. [pmid: 14960742].
75 de Winter RJ, Stroobants A, Koch KT, et al. Plasma N-terminal pro-B-type natriuretic peptide for prediction of death or nonfatal myocardial infarction following percutaneous coronary intervention. Am J Cardiol. Dec 15. 2004;94(12):1481-5. [pmid: 15589000].
76 Galvani M, Ottani F, Oltrona L, et al. N-terminal pro-brain natriuretic peptide on admission has prognostic value across the whole spectrum of acute coronary syndromes. Circulation. Jul 13. 2004;110(2):128-34. [pmid: 15197143].
77 Jiang CY, Li N, Wang JA. Use of B-type natriuretic peptide in evaluation of early percutaneous coronary intervention in patients with acute coronary syndrome. Chin Med J. Aug. 2004;117(8):1130-4. [pmid: 15361283].
78 Wylie JV, Murphy SA, Morrow DA, et al. Validated risk score predicts the development of congestive heart failure after presentation with unstable angina or non-ST-elevation myocardial infarction: results from OPUS-TIMI 16 and TACTICS-TIMI 18. Am Heart J. Jul. 2004;148(1):173-80. [pmid: 15215808].
79 Takase H, Toriyama T, Sugiura T, et al. Brain natriuretic peptide in the prediction of recurrence of angina pectoris. Eur J Clin Invest. Feb. 2004;34(2):79-84. [pmid: 14764069].
80 Richards AM, Nicholls MG, Espiner EA, et al. B-type natriuretic peptides and ejection fraction for prognosis after myocardial infarction. Circulation. Jun 10. 2003;107(22):2786-92. [pmid: 12771003].
81 Palmer BR, Pilbrow AP, Yandle TG, et al. Angiotensin-converting enzyme gene polymorphism interacts with left ventricular ejection fraction and brain natriuretic peptide levels to predict mortality after myocardial infarction. J Am Coll Cardiol. Mar 5. 2003;41(5):729-36. [pmid: 12628714].
82 Omland T, Persson A, Ng L, et al. N-terminal pro-B-type natriuretic peptide and long-term mortality in acute coronary syndromes. Circulation. Dec 3. 2002;106(23):2913-8. [pmid: 12460871].
83 Sabatine MS, Morrow DA, de Lemos JA, et al. Multimarker approach to risk stratification in non-ST elevation acute coronary syndromes: simultaneous assessment of troponin I, C-reactive protein, and B-type natriuretic peptide. Circulation. Apr 16. 2002;105(15):1760-3. [pmid: 11956114].
84 Richards AM, Nicholls MG, Yandle TG, et al. Plasma N-terminal pro-brain natriuretic peptide and adrenomedullin: new neurohormonal predictors of left ventricular function and prognosis after myocardial infarction. Circulation. May. 1998;97(19):1921-9. [pmid: 9609085].
85 Schnabel R, Rupprecht HJ, Lackner KJ, et al. Analysis of N-terminal-pro-brain natriuretic peptide and C-reactive protein for risk stratification in stable and unstable coronary artery disease: results from the AtheroGene study. Eur Heart J. Feb. 2005;26(3):241-9. [pmid: 15618051].
86 Heeschen C, Hamm CW, Mitrovic V, et al. N-terminal pro-B-type natriuretic peptide levels for dynamic risk stratification of patients with acute coronary syndromes. Circulation. Nov 16. 2004;110(20):3206-12. [pmid: 15533869].
87 Latini R, Maggioni AP, Peri G, et al. Prognostic significance of the long pentraxin PTX3 in acute myocardial infarction. Circulation. Oct. 2004;110(16):2349-54. [pmid: 15477419].
88 Suzuki S, Yoshimura M, Nakayama M, et al. Plasma level of B-type natriuretic peptide as a prognostic marker after acute myocardial infarction: a long-term follow-up analysis. Circulation. Sep 14. 2004;110(11):1387-91. [pmid: 15353502].
89 Richards AM, Nicholls MG, Troughton RW, et al. Antecedent hypertension and heart failure after myocardial infarction. J Am Coll Cardiol. 2002;39(7):1182-8. [pmid: 11923044].
90 Shimpo M, Morrow DA, Weinberg EO, et al. Serum Levels of the Interleukin-1 Receptor Family Member ST2 Predict Mortality and Clinical Outcome in Acute Myocardial Infarction. Circulation. 2004;109(18):2186-90. [pmid: 15117853].
91 Hutfless R, Kazanegra R, Madani M, et al. Utility of B-type natriuretic peptide in predicting postoperative complications and outcomes in patients undergoing heart surgery. J Am Coll Cardiol. May. 2004;43(10):1873-9. [pmid: 15145114].
92 Kerbaul F, Collart F, Giorgi R, et al. Increased plasma levels of pro-brain natriuretic peptide in patients with cardiovascular complications following off-pump coronary artery surgery. Intensive Care Med. Sep. 2004;30(9):1799-806. [pmid: 15138672].
93 Song MH, Kobayashi Y, Michi H. Clinical implication of atrial and brain natriuretic Peptide in coronary artery bypass grafting. Asian Cardiovasc Thorac Ann. Mar. 2004;12(1):41-6. [pmid: 14977741].
94 Watanabe M, Egi K, Hasegawa S, et al. Significance of serum atrial and brain natriuretic peptide release after coronary artery bypass grafting. SURG. 2003;33(9):671-3.
95 Sadanandan S, Cannon CP, Chekuri K, et al. Association of elevated B-type natriuretic peptide levels with angiographic findings among patients with unstable angina and non-ST-segment elevation myocardial infarction. J Am Coll Cardiol. Aug 4. 2004;44(3):564-8. [pmid: 15358021].
96 Wiviott SD, Cannon CP, Morrow DA, et al. Differential expression of cardiac biomarkers by gender in patients with unstable angina/non-ST-elevation myocardial infarction: a TACTICS-TIMI 18 (Treat Angina with Aggrastat and determine Cost of Therapy with an Invasive or Conservative Strategy-Thrombolysis In Myocardial Infarction 18) substudy. Circulation. Feb 10. 2004;109(5):580-6. [pmid: 14769678].
97 James S. Coagulation, inflammation and myocardial dysfunction in unstable coronary artery disease and the influence of glycoprotein IIb/IIIa inhibition and low molecular weight heparin. Ups J Med Sci. 2004;109(2):71-122. [pmid: 15259448].
98 Ueland T, Jemtland R, Godang K, et al. Prognostic value of osteoprotegerin in heart failure after acute myocardial infarction. J Am Coll Cardiol. 2004;44(10):1970-6. [pmid: 15542278].
99 Julier K, Da Silva R, Garcia C, et al. Preconditioning by sevoflurane decreases biochemical markers for myocardial and renal dysfunction in coronary artery bypass graft surgery: A double-blinded, placebo-controlled, multicenter study. Anesthesiology. 2003;98(6):1315-27. [pmid: 12766638].
100 Zeller M, Cottin Y, Laurent Y, et al. N-terminal pro-brain natriuretic peptide levels in patients with non-ST-elevation myocardial infarction. Cardiology. 2004;102(1):37-40. [pmid: 14988617].
101 de Groote P, Dagorn J, Soudan B, et al. B-type natriuretic peptide and peak exercise oxygen consumption provide independent information for risk stratification in patients with stable congestive heart failure.[see comment]. J Am Coll Cardiol. May 5. 2004;43(9):1584-9. [pmid: 15120815].
102 Maisel A, Hollander JE, Guss D, et al. Primary results of the Rapid Emergency Department Heart Failure Outpatient Trial (REDHOT). A multicenter study of B-type natriuretic peptide levels, emergency department decision making, and outcomes in patients presenting with shortness of breath. J Am Coll Cardiol. Sep 15. 2004;44(6):1328-33. [pmid: 15364340].
103 Gwechenberger M, Hulsmann M, Berger R, et al. Interleukin-6 and B-type natriuretic peptide are independent predictors for worsening of heart failure in patients with progressive congestive heart failure. J Heart Lung Transplant. Jul. 2004;23(7):839-44. [pmid: 15261178].
104 van der MP, Voors AA, Lipsic E, et al. Prognostic value of plasma erythropoietin on mortality in patients with chronic heart failure. J Am Coll Cardiol. Jul 7. 2004;44(1):63-7. [pmid: 15234408].
105 Sakatani T, Hadase M, Kawasaki T, et al. Usefulness of the percentage of plasma lymphocytes as a prognostic marker in patients with congestive heart failure. Jpn Heart J. Mar. 2004;45(2):275-84. [pmid: 15090704].
106 Latini R, Masson S, Anand I, et al. The comparative prognostic value of plasma neurohormones at baseline in patients with heart failure enrolled in Val-HeFT. Eur Heart J. Feb. 2004;25(4):292-9. [pmid: 14984917].
107 Logeart D, Thabut G, Jourdain P, et al. Predischarge B-type natriuretic peptide assay for identifying patients at high risk of re-admission after decompensated heart failure. J Am Coll Cardiol. Feb 18. 2004;43(4):635-41. [pmid: 14975475].
108 Horwich TB, Patel J, MacLellan WR, et al. Cardiac troponin I is associated with impaired hemodynamics, progressive left ventricular dysfunction, and increased mortality rates in advanced heart failure. Circulation. Aug. 2003;108(7):833-8. [pmid: 12912820].
109 Vrtovec B, Delgado R, Zewail A, et al. Prolonged QTc interval and high B-type natriuretic peptide levels together predict mortality in patients with advanced heart failure. Circulation. Apr 8. 2003;107(13):1764-9. [pmid: 12665499].
110 Anand IS, Fisher LD, Chiang YT, et al. Changes in brain natriuretic peptide and norepinephrine over time and mortality and morbidity in the Valsartan Heart Failure Trial (Val-HeFT). Circulation. Mar 11. 2003;107(9):1278-83. [pmid: 12628948].
111 Bettencourt P, Ferreira S, Azevedo A, et al. Preliminary data on the potential usefulness of B-type natriuretic peptide levels in predicting outcome after hospital discharge in patients with heart failure. Am J Med. Aug 15. 2002;113(3):215-9. [pmid: 12208380].
112 Hulsmann M, Berger R, Sturm B, et al. Prediction of outcome by neurohumoral activation, the six-minute walk test and the Minnesota Living with Heart Failure Questionnaire in an outpatient cohort with congestive heart failure. Eur Heart J. Jun. 2002;23(11):886-91. [pmid: 12042010].
113 Tsutsui T, Tsutamoto T, Wada A, et al. Plasma oxidized low-density lipoprotein as a prognostic predictor in patients with chronic congestive heart failure. J Am Coll Cardiol. Mar 20. 2002;39(6):957-62. [pmid: 11897436].
114 Harrison A, Morrison LK, Krishnaswamy P, et al. B-type natriuretic peptide predicts future cardiac events in patients presenting to the emergency department with dyspnea. Ann Emerg Med. Feb. 2002;39(2):131-8. [pmid: 11823766].
115 Dias P, Rodrigues RA, Queiros MC, et al. Prognosis in patients with heart failure and preserved left ventricular systolic function. Rev Port Cardiol. Dec. 2001;20(12):1223-32. [pmid: 11865682].
116 Koglin J, Pehlivanli S, Schwaiblmair M, et al. Role of brain natriuretic peptide in risk stratification of patients with congestive heart failure. J Am Coll Cardiol. Dec. 2001;38(7):1934-41. [pmid: 11738297].
117 Imamura Y, Fukuyama T, Mochizuki T, et al. Prognostic value of iodine-123-metaiodobenzylguanidine imaging and cardiac natriuretic peptide levels in patients with left ventricular dysfunction resulting from cardiomyopathy. Jpn Circ J. Mar. 2001;65(3):155-60. [pmid: 11266187].
118 Tamura K, Takahashi N, Nakatani Y, et al. Prognostic impact of plasma brain natriuretic peptide for cardiac events in elderly patients with congestive heart failure. Gerontology. Jan. 2001;47(1):46-51. [pmid: 11244291].
119 Cheng V, Kazanagra R, Garcia A, et al. A rapid bedside test for B-type peptide predicts treatment outcomes in patients admitted for decompensated heart failure: a pilot study. J Am Coll Cardiol. Feb. 2001;37(2):386-91. [pmid: 11216951].
120 Maeda K, Tsutamoto T, Wada A, et al. High levels of plasma brain natriuretic peptide and interleukin-6 after optimized treatment for heart failure are independent risk factors for morbidity and mortality in patients with congestive heart failure. J Am Coll Cardiol. Nov 1. 2000;36(5):1587-93. [pmid: 11079662].
121 Tsutamoto T, Wada A, Maeda K, et al. Plasma brain natriuretic peptide level as a biochemical marker of morbidity and mortality in patients with asymptomatic or minimally symptomatic left ventricular dysfunction. Comparison with plasma angiotensin II and endothelin-1. Eur Heart J. Dec. 1999;20(24):1799-807. [pmid: 10581138].
122 Wallen T, Landahl S, Hedner T, et al. Brain natriuretic peptide predicts mortality in the elderly. Heart. Mar. 1997;77(3):264-7. [pmid: 9093047]. [pmcid: 484695].
123 Watanabe J, Shiba N, Shinozaki T, et al. Prognostic value of plasma brain natriuretic peptide combined with left ventricular dimensions in predicting sudden death of patients with chronic heart failure. J Card Fail. Feb. 2005;11(1):50-5. [pmid: 15704064].
124 Hamada Y, Tanaka N, Murata K, et al. Significance of predischarge BNP on one-year outcome in decompensated heart failure-comparative study with echo-Doppler indexes. J Card Fail. Feb. 2005;11(1):43-9. [pmid: 15704063].
125 Berger R, Huelsmann M, Strecker K, et al. Neurohormonal risk stratification for sudden death and death owing to progressive heart failure in chronic heart failure. Eur J Clin Invest. Jan. 2005;35(1):24-31. [pmid: 15638816].
126 Van Beneden R, Gurne O, Selvais PL, et al. Superiority of big endothelin-1 and endothelin-1 over natriuretic peptides in predicting survival in severe congestive heart failure: a 7-year follow-up study. J Card Fail. Dec. 2004;10(6):490-5. [pmid: 15599839].
127 Alehagen U, Dahlstrom U, Lindahl TL. Elevated D-dimer level is an independent risk factor for cardiovascular death in out-patients with symptoms compatible with heart failure. Thromb Haemost. Dec. 2004;92(6):1250-8. [pmid: 15583730].
128 Berger R, Strecker K, Huelsmann M, et al. Prognostic power of neurohumoral parameters in chronic heart failure depends on clinical stage and observation period. J Heart Lung Transplant. Sep. 2003;22(9):1037-45. [pmid: 12957614].
129 Ishii J, Nomura M, Nakamura Y, et al. Risk stratification using a combination of cardiac troponin T and brain natriuretic peptide in patients hospitalized for worsening chronic heart failure. Am J Cardiol. Mar 15. 2002;89(6):691-5. [pmid: 11897211].
130 Bettencourt P, Ferreira A, Dias P, et al. Predictors of prognosis in patients with stable mild to moderate heart failure. J Card Fail. Dec. 2000;6(4):306-13. [pmid: 11145755].
131 Rossig L, Fichtlscherer S, Heeschen C, et al. The pro-apoptotic serum activity is an independent mortality predictor of patients with heart failure. Eur Heart J. Sep. 2004;25(18):1620-5. [pmid: 15351161].
132 Rothenburger M, Wichter T, Schmid C, et al. Aminoterminal pro type B natriuretic peptide as a predictive and prognostic marker in patients with chronic heart failure. J Heart Lung Transplant. Oct. 2004;23(10):1189-97. [pmid: 15477114].
133 Kirk V, Bay M, Parner J, et al. N-terminal proBNP and mortality in hospitalised patients with heart failure and preserved vs. reduced systolic function: data from the prospective Copenhagen Hospital Heart Failure Study (CHHF). Eur J Heart Fail. Mar 15. 2004;6(3):335-41. [pmid: 14987585].
134 Gardner RS, Ozalp F, Murday AJ, et al. N-terminal pro-brain natriuretic peptide. A new gold standard in predicting mortality in patients with advanced heart failure. Eur Heart J. Oct. 2003;24(19):1735-43. [pmid: 14522568].
135 O'Brien RJ, Squire IB, Demme B, et al. Pre-discharge, but not admission, levels of NT-proBNP predict adverse prognosis following acute LVF. Eur J Heart Fail. Aug. 2003;5(4):499-506. [pmid: 12921811].
136 Fisher C, Berry C, Blue L, et al. N-terminal pro B type natriuretic peptide, but not the new putative cardiac hormone relaxin, predicts prognosis in patients with chronic heart failure. Heart. Aug. 2003;89(8):879-81. [pmid: 12860863]. [pmcid: 1767758].
137 Zugck C, Haunstetter A, Kruger C, et al. Impact of beta-blocker treatment on the prognostic value of currently used risk predictors in congestive heart failure. J Am Coll Cardiol. May 15. 2002;39(10):1615-22. [pmid: 12020488].
138 Richards AM, Doughty R, Nicholls MG, et al. Plasma N-terminal pro-brain natriuretic peptide and adrenomedullin: prognostic utility and prediction of benefit from carvedilol in chronic ischemic left ventricular dysfunction. Australia-New Zealand Heart Failure Group. J Am Coll Cardiol. Jun 1. 2001;37(7):1781-7. [pmid: 11401111].
139 Bettencourt P, Azevedo A, Pimenta J, et al. N-terminal-pro-brain natriuretic peptide predicts outcome after hospital discharge in heart failure patients. Circulation. Oct 12. 2004;110(15):2168-74. [pmid: 15451800].
140 Hartmann F, Packer M, Coats AJ, et al. Prognostic impact of plasma N-terminal pro-brain natriuretic peptide in severe chronic congestive heart failure: a substudy of the Carvedilol Prospective Randomized Cumulative Survival (COPERNICUS) trial. Circulation. Sep 28. 2004;110(13):1780-6. [pmid: 15381643].
141 Hedberg P, Lonnberg I, Jonason T, et al. Electrocardiogram and B-type natriuretic peptide as screening tools for left ventricular systolic dysfunction in a population-based sample of 75-year-old men and women. Am Heart J. Sep. 2004;148(3):524-9. [pmid: 15389243].
142 Atisha D, Bhalla MA, Morrison LK, et al. A prospective study in search of an optimal B-natriuretic peptide level to screen patients for cardiac dysfunction. Am Heart J. Sep. 2004;148(3):518-23. [pmid: 15389242].
143 Bibbins-Domingo K, Ansari M, Schiller NB, et al. Is B-type natriuretic peptide a useful screening test for systolic or diastolic dysfunction in patients with coronary disease? Data from the Heart and Soul Study. Am J Med. Apr 15. 2004;116(8):509-16. [pmid: 15063811].
144 Vasan RS, Benjamin EJ, Larson MG, et al. Plasma natriuretic peptides for community screening for left ventricular hypertrophy and systolic dysfunction: the Framingham heart study. JAMA. Sep 11. 2002;288(10):1252-9. [pmid: 12215132].
145 Groenning BA, Raymond I, Hildebrandt PR, et al. Diagnostic and prognostic evaluation of left ventricular systolic heart failure by plasma N-terminal pro-brain natriuretic peptide concentrations in a large sample of the general population. Heart. Mar. 2004;90(3):297-303. [pmid: 14966052]. [pmcid: 1768111].
146 Konishi H, Nishio S, Tsutamoto T, et al. Serum carvedilol concentration and its relation to change in plasma brain natriuretic peptide level in the treatment of heart failure: a preliminary study. Int J Clin Pharmacol Ther. Dec. 2003;41(12):578-86. [pmid: 14692707].
147 Troughton RW, Frampton CM, Yandle TG, et al. Plasma amino-terminal B-type natriuretic peptide measured by Elecsys 2010 assay in a trial of hormone-guided treatment for heart failure. Clin Chem. Jul. 2003;49(7):1212-5. [pmid: 12816929].
148 Troughton RW, Frampton CM, Yandle TG, et al. Treatment of heart failure guided by plasma aminoterminal brain natriuretic peptide (N-BNP) concentrations. Lancet. Apr 1. 2000;355(9210):1126-30. [pmid: 10791374].
149 Murdoch DR, McDonagh TA, Byrne J, et al. Titration of vasodilator therapy in chronic heart failure according to plasma brain natriuretic peptide concentration: randomized comparison of the hemodynamic and neuroendocrine effects of tailored versus empirical therapy. Am Heart J. Dec. 1999;138(6 Pt 1):1126-32. [pmid: 10577444].
150 Thompson LO, Skrabal CA, Loebe M, et al. Plasma neurohormone levels correlate with left ventricular functional and morphological improvement in LVAD patients. J Surg Res. Jan. 2005;123(1):25-32. [pmid: 15652947].
151 Clerico A, Emdin M. Diagnostic accuracy and prognostic relevance of the measurement of cardiac natriuretic peptides: a review. [Review] [151 refs]. Clin Chem. Jan. 2004;50(1):33-50. [pmid: 14633912].
152 Holmes SJ, Espiner EA, Richards AM, et al. Renal, endocrine, and hemodynamic effects of human brain natriuretic peptide in normal man. J Clin Endocrinol Metab. Jan. 1993;76(1):91-6. [pmid: 8380606].
153 Mair J, Friedl W, Thomas S, et al. Natriuretic peptides in assessment of left-ventricular dysfunction. [Review] [21 refs]. Scand J Clin Lab Invest Suppl. 1999;230:132-42. [pmid: 10389212].
154 Hall C. Essential biochemistry and physiology of (NT-pro)BNP. [Review] [25 refs]. Eur J Heart Fail. Mar 15. 2004;6(3):257-60. [pmid: 14987573].
155 McGrath MF, de Bold ML, de Bold AJ. The endocrine function of the heart. [Review] [118 refs]. Trends in Endocrinology & Metabolism. 2005;16(10):469-77. Dec. [pmid: 16269246].
156 Hunt SA, Abraham WT, Chin MH, et al. ACC/AHA 2005 guideline update for the diagnosis and management of chronic heart failure in the adult: A report of the American College of Cardiology/American Heart Association Task Force on practice guidelines (writing committee to update the 2001 guidelines for the evaluation and management of heart failure). J Am Coll Cardiol. 2005;46(6):e1-e82. [pmid: 16168273].
157 Mair J, Friedl W, Thomas S, et al. Natriuretic peptides in assessment of left-ventricular dysfunction. [Review] [21 refs]. Scandinavian Journal of Clinical and Laboratory Investigation Supplement. 1999;230:132-42. [pmid: 10389212].
158 Liu P, Arnold JM, Belenkie I, et al. The 2002/3 Canadian Cardiovascular Society consensus guideline update for the diagnosis and management of heart failure. Can J Cardiol. 2003;19(4):347-56. [pmid: 12704478].
159 Remme WJ, Swedberg K. European Society of Cardiology. Comprehensive guidelines for the diagnosis and treatment of chronic heart failure. Task force for the diagnosis and treatment of chronic heart failure of the European Society of Cardiology. Eur J Heart Fail. 2002;4(1):11-22. [pmid: 11812661].
160 Ho KK, Pinsky JL, Kannel WB, et al. The epidemiology of heart failure: the Framingham Study. J Am Coll Cardiol 1993;22(4:Suppl:A):Suppl-13A
161 McKelvie R. Heart failure.[update in Clin Evid. 2002 Dec;(8):60–81; PMID: 12603873]. [Review][59 refs]. Clinical Evidence (7):57–78, 2002 Jun;
162 McKie PM, Burnett JC Jr. B-type natriuretic peptide as a biomarker beyond heart failure: speculations and opportunities. [Review] [67 refs]. Mayo Clinic Proceedings. 2005;80(8):1029-36. Aug. [pmid: 16092582].
163 Doust JA, Pietrzak E, Dobson A, et al. How well does B-type natriuretic peptide predict death and cardiac events in patients with heart failure: systematic review. [Review] [9 refs]. BMJ. Mar. 2005;330(7492):625. [pmid: 15774989]. [pmcid: 554905].
164 Mueller T, Gegenhuber A, Poelz W, et al. Comparison of the Biomedica NT-proBNP enzyme immunoassay and the Roche NT-proBNP chemiluminescence immunoassay: implications for the prediction of symptomatic and asymptomatic structural heart disease. Clin Chem. Jun. 2003;49(6 Pt 1):976-9. [pmid: 12766002].
165 Whiting P, Rutjes A, Reitsma J, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Medical Research Methodology. 2003;3(1):25. [pmid: 14606960]. [pmcid: 305345].
166 Whiting P, Rutjes AW, Dinnes J, et al. A systematic review finds that diagnostic reviews fail to incorporate quality despite available tools. [Review] [116 refs]. J Clin Epidemiol. Jan. 2005;58(1):1-12. [pmid: 15649665].
167 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. Feb. 1996;17(1):1-12. [pmid: 8721797].
168 Altman DG, Altman DG. Systematic reviews of evaluations of prognostic variables. BMJ. Jul 28. 2001;323(7306):224-8. [pmid: 11473921]. [pmcid: 1120839].
169 Patrick Bossuyt, Les Irwig Paul Glasziou. Diagnostic Test Appraisal Form. Screening and Test Evaluation Program (STEP). Internet. http://www.health.usyd.edu.au/step/about/appraisal.htm
170 Deeks JJ, Deeks JJ. Systematic reviews in health care: Systematic reviews of evaluations of diagnostic and screening tests.. [Review] [24 refs]. BMJ. Jul 21. 2001;323(7305):157-62. [pmid: 11463691].
171 Littenberg B, Moses LE, Littenberg B, et al. Estimating diagnostic accuracy from multiple conflicting reports: a new meta-analytic method. Med Decis Making. Oct. 1993;13(4):313-21. [pmid: 8246704].
172 Nakayama T, Soma M, Mizutani Y, et al. A novel missense mutation of exon 3 in the type A human natriuretic peptide receptor gene: possible association with essential hypertension. Hypertens Res. May. 2002;25(3):395-401. [pmid: 12135318].
173 Doust JA, Glasziou PP, Pietrzak E, et al. A systematic review of the diagnostic accuracy of natriuretic peptides for heart failure. [Review] [41 refs]. Arch Intern Med. Oct 11. 2004;164(18):1978-84. [pmid: 15477431].
174 Cardarelli R, Lumicao TG Jr. B-type natriuretic peptide: a review of its diagnostic, prognostic, and therapeutic monitoring value in heart failure for primary care physicians. [Review] [21 refs]. J Am Board Fam Pract. Jul. 2003;16(4):327-33. [pmid: 12949034].
175 van der Sloot JA. New developments in the management of heart failure: a review of the literature in 2002. [Review] [7 refs]. Neth J Med. May. 2003;61(5 Suppl):19-27. [pmid: 12918546].
176 Jortani SA, Prabhu SD, Valdes R Jr.,, et al. Strategies for developing biomarkers of heart failure. [Review] [120 refs]. Clin Chem. 2004;50(2):265-78. [pmid: 14656906].
177 Khunti K, Squire I, Abrams KR, et al. Accuracy of a 12-lead electrocardiogram in screening patients with suspected heart failure for open access echocardiography: a systematic review and meta-analysis. [Review] [36 refs]. Eur J Heart Fail. Aug. 2004;6(5):571-6. [pmid: 15352303].
178 Thomas MD, Fox KF, Coats AJ, et al. The epidemiological enigma of heart failure with preserved systolic function. [Review] [109 refs]. Eur J Heart Fail. Mar 1. 2004;6(2):125-36. [pmid: 14984719].
179 McGowan JH, Cleland JG. Reliability of reporting left ventricular systolic function by echocardiography: a systematic review of 3 methods. [Review] [82 refs]. Am Heart J. Sep. 2003;146(3):388-97. [pmid: 12947354].
180 Ahmed A. American College of Cardiology/American Heart Association Chronic Heart Failure Evaluation and Management guidelines: relevance to the geriatric practice. J Am Geriatr Soc. Jan. 2003;51(1):123-6. [pmid: 12534856].
181 Khunti K, Baker R, Grimshaw G. Diagnosis of patients with chronic heart failure in primary care: usefulness of history, examination, and investigations. [Review] [75 refs]. Br J Gen Pract. Jan. 2000;50(450):50-4. [pmid: 10695070]. [pmcid: 1313613].
182 Wang CS, FitzGerald JM, Schulzer M, et al. Does this dyspneic patient in the emergency department have congestive heart failure?. [Review] [70 refs]. JAMA. Oct. 2005;294(15):1944-56. [pmid: 16234501].
183 Craig J et al. The use of B-type natriuretic peptides (BNP and NT-proBNP) investigation of patients with suspected heart failure. report 2005 http://www.nhshealthquality.org/nhsqis/files/bnp_final_report.pdf. 2005.
184 Doust JA, Saunders S, Pirozzo S et al. The diagnosis and recognition of congestive cardiac failure. The Centre for Evidence Based Practice at the Universtiy of Queensland; 2002.
185 Fischer JE, Bachmann LM, Jaeschke R. A readers' guide to the interpretation of diagnostic test properties: clinical example of sepsis. [Review] [23 refs]. Intensive Care Medicine. 2003;29(7):1043-51. Jul. [pmid: 12734652].
186 Missouris CG, Varma C, Ward D, et al. Cardiac peptides and plasma renin activity in acute dilated cardiomyopathy. Eur J Heart Fail. Jan. 2001;3(1):109-11. [pmid: 11163744].
187 Inoue M, Kanda T, Arai M, et al. Impaired expression of brain natriuretic peptide gene in diabetic rats with myocardial infarction. Exp Clin Endocrinol Diabetes. 1998;106(6):484-8. [pmid: 10079029].
188 Yoshinari K, Yaoita H, Maehara K, et al. Different therapeutic responses to treadmill exercise of heart failure due to ischemia and infarction in rats. Cardiovasc Res. Feb 1. 2005;65(2):457-68. [pmid: 15639485].
189 Mueller C. Rapid measurement of B-type natriuretic peptides reduced time to discharge and treatment costs in patients with acute dyspnea. ACP J Club. Jan. 2005;142(1):A14-A15. [pmid: 15656555].
190 Mantone J. The need for speed. Rapid blood tests have quickened the diagnostic process, and even faster products are on the way. Mod Healthc. Aug 9. 2004;34(32):30-1. [pmid: 15352767].
191 Clerico A, Emdin M. Endocrine paradox in heart failure: resistance to biological effects of cardiac natriuretic hormones. Clin Chem. Dec. 2004;50(12):2465-7. [pmid: 15563503].
192 Scharhag J, Urhausen A, Herrmann M, et al. No difference in N-terminal pro-brain natriuretic peptide (NT-proBNP) concentrations between endurance athletes with athlete's heart and healthy untrained controls. Heart. Sep. 2004;90(9):1055-6. [pmid: 15310701]. [pmcid: 1768458].
193 Publication Committee for the VMAC Investigators (Vasodilatation in the Management of Acute CHF). Intravenous nesiritide vs nitroglycerin for treatment of decompensated congestive heart failure: a randomized controlled trial.[erratum appears in JAMA 2002 Aug 7;288(5):577]. JAMA 2002 Mar 27;287(12):1531–40.
194 Iqbal R, Rizvi SA, Akbay C, et al. Chiral separations in microemulsion electrokinetic chromatography. Use of micelle polymers and microemulsion polymers. J Chromatogr 2004 Jul 23;A.. 1043(2):291–302.
195 Nagai T, Imamura M, Inukai T, et al. Brain natriuretic polypeptide in type 2 NIDDM patients with albuminuria. J. 2001;32(34):169-80.
196 Puddy VF, Amirmansour C, Williams AF, et al. Plasma brain natriuretic peptide as a predictor of haemodynamically significant patent ductus arteriosus in preterm infants. Clin Sci (Colch ). Jul. 2002;103(1):75-7. [pmid: 12095406].
197 Richards M. Outpatient management of heart failure. [Review] [44 refs]. Heart Fail Rev. Oct. 2003;8(4):345-8. [pmid: 14574055].
198 Apple FS, Panteghini M, Ravkilde J, et al. Quality specifications for B-type natriuretic peptide assays. Clinical Chemistry. 2005;51(3):486-93. Mar. [pmid: 15738513].
199 Bibbins-Domingo K, Ansari M, Schiller NB, et al. B-type natriuretic peptide and ischemia in patients with stable coronary disease: data from the Heart and Soul study. Circulation. Dec 16. 2003;108(24):2987-92. [pmid: 14662720].
200 Cowie MR, Struthers AD, Wood DA, et al. Value of natriuretic peptides in assessment of patients with possible new heart failure in primary care. Lancet. Nov 8. 1997;350(9088):1349-53. [pmid: 9365448].
201 Morgan S, Smith H, Simpson I, et al. Prevalence and clinical characteristics of left ventricular dysfunction among elderly patients in general practice setting: cross sectional survey. BMJ. Feb 6. 1999;318(7180):368-72. [pmid: 9933201]. [pmcid: 27725].
202 McDonagh TA, Morrison CE, Lawrence A, et al. Symptomatic and asymptomatic left-ventricular systolic dysfunction in an urban population. Lancet. Sep 20. 1997;350(9081):829-33. [pmid: 9310600].
203 Mosterd A, Hoes AW, de Bruyne MC, et al. Prevalence of heart failure and left ventricular dysfunction in the general population; The Rotterdam Study. Eur Heart J. Mar. 1999;20(6):447-55. [pmid: 10213348].
204 Raymond I, Groenning BA, Hildebrandt PR, et al. The influence of age, sex and other variables on the plasma level of N-terminal pro brain natriuretic peptide in a large sample of the general population. Heart. Jul. 2003;89(7):745-51. [pmid: 12807847]. [pmcid: 1767734].
205 Januzzi JL, van Kimmenade R, Lainchbury J, Bayes-Genis A, Ordonez-Llanos J, Santalo-Bel M, Pinto YM, and Richards M. NT-proBNP testing for diagnosis and short-term prognosis in acute destabilized heart failure: an international pooled analysis of 1256 patients The International Collaborative of NT-proBNP Study. Eur Heart J. 2005; 2005 Nov 17; [Epub ahead of print]
206 Zaphiriou A, Robb S, Murray-Thomas T, et al. The diagnostic accuracy of plasma BNP and NTproBNP in patients referred from primary care with suspected heart failure: results of the UK natriuretic peptide study. European Journal of Heart Failure. 2005;7(4):537-41. Jun. [pmid: 15921792].
207 Davenport C, Cheng EYL, Kwok YTT, et al. Assessing the diagnostic test accuracy of natriuretic peptides and ECG in the diagnosis of left ventricular systolic dysfunction: A systematic review and meta-analysis. Br J Gen Pract. 2006;56(522):48-56. [pmid: 16438815]. [pmcid: 1821403].
208 Shimizu Y, Uematsu M, Nagaya N, et al. Myocardial velocity gradient reflects the severity of myocardial damage regardless of the presence or absence of mitral regurgitation. J Am Soc Echocardiogr. Mar. 2003;16(3):246-53. [pmid: 12618733].
209 Gheorghiade M, Zannad F, Sopko G, et al. Acute heart failure syndromes: current state and framework for future research. Circulation. 2005;112(25):3958-68. Dec 20. [pmid: 16365214].
210 Cowie MR, Jourdain P, Maisel A, et al. Clinical applications of B-type natriuretic peptide (BNP) testing. [Review] [68 refs]. Eur Heart J. Oct. 2003;24(19):1710-8. [pmid: 14522565].
211 Jourdain P, Funck F, Gueffet P, et al. Benefit of BNP plasma levels for optimizing therapy: the Systolic Heart Failure Treatment Supported by BNP Multicenter Randomised Trial (STARS-BNP). J Am Coll Cardiol. 2005;45(Supp A):1001-151.
212 Bruins S, Fokkema MR, Romer JW, et al. High intraindividual variation of B-type natriuretic peptide (BNP) and amino-terminal proBNP in patients with stable chronic heart failure. Clin Chem. Nov. 2004;50(11):2052-8. [pmid: 15345664].
213 Wu AH, Smith A, Wieczorek S, et al. Biological variation for N-terminal pro- and B-type natriuretic peptides and implications for therapeutic monitoring of patients with congestive heart failure. Am J Cardiol. Sep 1. 2003;92(5):628-31. [pmid: 12943894].
214 Melzi dG, Tagnochetti T, Nauti A, et al. Biological variation of N-terminal pro-brain natriuretic peptide in healthy individuals. Clin Chem. 2003;49(9):1554-5. [pmid: 12928248].
215 Jones GRD B L S H-G. Clin Biochem Rev, editor. 70. 2002; 40th Annual Scientific Conference of the AACB, Adelaide: Clin Biochem Rev; 2002.
216 Pagani F, Stefini F, Panteghini M. Biological variation in serum concentrations of N-terminal pro-brain natriuretic peptide (NT-proBNP). [Abstract]. Clin Chem. 2003;49(Suppl 6):A34.
217 Fraser GC. Biological variation: from principles to practice. Washington: AACC press; 2001.
218 Hammerer-Lercher A, Ludwig W, Falkensammer G, et al. Natriuretic peptides as markers of mild forms of left ventricular dysfunction: effects of assays on diagnostic performance of markers. Clin Chem. Jul. 2004;50(7):1174-83. [pmid: 15142976].
219 Fischer Y, Filzmaier K, Stiegler H, et al. Evaluation of a new, rapid bedside test for quantitative determination of B-type natriuretic peptide. Clin Chem. Mar. 2001;47(3):591-4. [pmid: 11238315].
220 Rawlins ML, Owen WE, Roberts WL. Performance characteristics of four automated natriuretic peptide assays. American Journal of Clinical Pathology. 2005;123(3):439-45. Mar. [pmid: 15716241].
221 Nielsen OW, Kirk V, Bay M, et al. Value of N-terminal pro brain natriuretic peptide in the elderly: Data from the prospective Copenhagen Hospital Heart Failure study (CHHF). Eur J Heart Fail. 2004;6(3):275-9. [pmid: 14987576].