# Executive Summary

B-type natriuretic peptide (BNP) and N-terminal proBNP (NT-proBNP) are promising markers for heart failure diagnosis, prognosis, and treatment. ^1,^ ^2^ This systematic review addresses these four main questions:

1 What are the determinants of both BNP and NT-proBNP measurement?
2 With respect to the diagnosis of heart failure:
  a What are the clinical performance characteristics of both BNP and NT-proBNP measurement in patients with symptoms suggestive of heart failure (HF) or with known HF
    i presenting to the emergency department (ED)
    ii in a specialized clinic or outpatient setting
    iii presenting to a primary care setting
    iv presenting in long term care setting
    v all settings combined
  b Does measurement of BNP or NT-proBNP add independent diagnostic information to the traditional diagnostic measures of HF in patients with symptoms suggestive of HF?
3 Do BNP or NT-proBNP levels predict cardiac events in populations:
  a Specific populations
    i at risk for coronary artery disease (CAD)
    ii with diagnosed CAD
    iii with diagnosed HF
  b What are the screening characteristics of BNP or NT-proBNP in general asymptomatic populations?
4 Can BNP or NT-proBNP measurement be used to monitor response to therapy?

## Methods

Two search strategies were undertaken, one for the main report and a smaller review of reviews for Question 2b. MEDLINE®, EMBASE, CINAHL, Cochrane Central and AMED (Allied and Complementary Medicine) were searched from 1989 to February 2005. Hand searching was not undertaken. For Question 2b, which compared other diagnostic tests relative to BNP and NT-proBNP, a review of reviews was undertaken in MEDLINE® and EMBASE only, from January 2000 to September 2005.

Only English language studies and those that measured BNP in blood by methods predominately available for use in clinical laboratories were eligible. There were no restrictions on study design. Outcomes for prognosis were restricted to mortality and other cardiac events.

Standard systematic review methodology was employed for the screening of studies to meet eligibility criteria and included two reviewers. Further specific criteria were developed for each research question. Both qualitative and quantitative (meta-analysis) summary of the results were undertaken.

## Results and Discussion

The search yielded 4338 citations, from which 1733 proceeded to full text screening. After the final eligibility screening, data were abstracted from a total of 144 studies.

### What Are the Determinants of Both BNP and NT-proBNP?

A total of 72 studies showed a relationship between B-type natriuretic peptides and a determinant. These determinants have the potential to affect accurate diagnosis, prognosis and the ability to monitor treatment effectively.

For demographic determinants, age was the most frequently reported determinant and in 13 of 15 studies was positively correlated with both BNP and NT-proBNP. ^3–^ ^15^ Few functional measures were evaluated. Of these weight, ^8^ but not BMI, ^9,^ ^10^ showed a negative relationship with B-type natriuretic peptides and these two studies had no, ^9^ or very few, ^10^ patients who were obese.

In general, evidence available on 21 cardiac diseases was associated with an increase in the B-type natriuretic peptides. However, there were differences among diseases within the broad category of cardiac ischemia. The evidence available on 11 non-cardiac diseases and B-type natriuretic peptide levels was mixed; the non-cardiac causes of dyspnea, ^16–^ ^18^ diabetic nephropathy, ^15^ and stroke ^8^ were all associated with higher levels of B-type natriuretic peptides. There were 29 biochemical and hematological markers where an association with the B-type natriuretic peptides was made. Markers of myocardial damage, including Tn-I, ^3,^ ^19,^ ^20^ Tn-T, ^8,^ ^14,^ ^16,^ ^21–^ ^26^ myoglobin, ^21^ and CK-MB, ^21,^ ^27–^ ^29^ were mostly positively associated with B-type natriuretic peptide levels. There were 23 measures from 14 studies reported for heart function. ^4,^ ^8–^ ^12,^ ^14,^ ^15,^ ^29–^ ^34^ Most of the hemodynamic, electrocardiographic and echocardiographic measures were compared to BNP and a few were compared to NT-proBNP. Both positive and negative associations were found. There were 14 studies, including nine different drug treatments, with data on the effect of drug therapy. ^31,^ ^35–^ ^47^ All showed a decrease in, or no effect on, B-type natriuretic peptide levels.

### What Are the Clinical Performance Characteristics of Both BNP and NT-proBNP Measurement in Patients with Symptoms Suggestive of HF or with Known HF?

There were a total of 27 studies eligible for evaluation of the clinical performance of BNP and NT-proBNP and not all of these reported performance characteristics or were suitable for meta-analysis. We meta-analyzed studies within specific settings and also across all study settings where sufficient data were available to calculate sensitivity, specificity, positive likelihood ratio (LR+) and negative likelihood ratio (LR-), diagnostic odds ratio (DOR) and summary ROC curves. Since there is no guideline for meta-analyzing studies that present results with single and multiple cut points the lowest cut point was chosen in studies with multiple cut points to maximize sensitivity. Summary estimates for studies within setting and across all settings were calculated.

Presenting to emergency department. Fourteen articles ^7,^ ^16–^ ^18,^ ^48–^ ^57^ were selected for data abstraction. The 12 studies evaluating BNP utilized several cut point values ranging from 50 to 400 pg/mL and reported sensitivities from 60 to 100 percent, specificities from 27 to 99 percent, and areas under the curve (AUC) of 0.67 to 0.99. In addition, the LR+ ranged from 0.69 to 70 and the LR- from 0 to 0.44. DOR values ranged from 13 to 1635 and based on the meta-analysis of eight studies the summary estimate was 81 (95 percent CI: 29 to 219).

The three studies evaluating NT-proBNP utilized values ranging from 254 to 4567 pg/mL and reported sensitivities from 74 to 98 percent, specificities from 47 to 93 percent, and AUC values of 0.89 to 0.96. The LR+ ranged from 1.85 to 13.43 and the LR- from 0.03 to 0.29. DOR values ranged from 17 to 291 with a summary estimate of 60 (95 percent CI: 9 to 407).

Most studies of the studies scored high on the Quality Assessment of Diagnostic Accuracy Studies (QUADAS) items indicating lack of bias.

Specialized clinic or outpatient setting. There were a total of six studies eligible for review in specialized clinics, ^11,^ ^58–^ ^62^ though diagnostic performance data could be abstracted in only three. All studies evaluated BNP except two ^58,^ ^60^ which compared both BNP and NT-proBNP. These two studies evaluated BNP using the same method, had similar cut points (135 and 142 pg/mL) and gave similar sensitivities (72 and 73 percent), specificities (73 and 77 percent), AUC (0.79 and 0.83), LR+ (2.7 and 3.17) and LR- (0.38 and 0.35), respectively.

Although different methods and cut points were used for NT-proBNP measurement, the diagnostic performance data were similar to each other and to the BNP data. The cut points were 695 and 4127 pg/mL, with corresponding sensitivities of 85 and 70 percent, specificities of 73 and 77 percent, AUC of 0.82 and 0.79, LR+ of 3.19 and 2.59 and LR- of 0.2 and 0.41.

Methodological quality was high on the QUADAS for these studies.

Primary care setting. There were a total of seven papers ^34,^ ^63–^ ^68^ from this setting and data could be abstracted from only five. Two studies evaluated BNP with cut points ranging from 10 to 115 pg/mL and reported sensitivities from 66 to 92 percent, specificities from 18 to 88 percent, AUC from 0.70 to 0.88, LR+ from 1.12 to 5.7, and LR- from 0 to 0.27. Meta-analysis gave a summary DOR of 2 (95 percent CI: 1 to 6).

The three studies evaluating NT-proBNP with cut points from 67 to 338 pg/mL and reported sensitivities from 67 to 100 percent, specificities from 18 to 84 percent, AUC from 0.70 to 0.93, LR+ from 1.22 to 5.7, and LR- from 0 to 0.27. Meta-analysis gave a summary DOR 17 (95 percent CI: 9 to 32).

These studies generally rated well on the QUADAS.

Long term care setting. There were no studies with patients with symptoms suggestive of HF or with known HF presenting in long term care settings.

All settings. From the all settings combined, 15 studies had sufficient data for meta-analysis. The cut points across all settings ranged from 10 to 200 pg/mL (mean = 95 pg/mL) for BNP and 125 to 1691 pg/mL (mean = 642 pg/mL) for NT-proBNP. Sensitivities for BNP and NT-proBNP ranged from 50 to 99 percent and 83 to 99 percent, respectively. Specificities for BNP and NT-proBNP ranged from 19 to 97 percent and 46 to 89 percent, respectively.

We observed significant heterogeneity when the data were meta-analyzed and the sources were subsequently explored. The Moses-Littenberg regression model was not significant indicating that cut point was not a factor in explaining heterogeneity. The meta-analysis indicated the diagnostic parameters remain similar even when results from all settings are combined. The summary estimate of sensitivity was high for both BNP (94 percent; 95 percent CI: 32 to 97) and NT-proBNP (92 percent; 95 percent CI: 87 to 97), whereas the summary estimate for specificity was low for BNP (66 percent; 95 percent CI: 52 to 79) and NT-proBNP (65 percent; 95 percent CI: 51 to 78). The LR- summary estimates for BNP (0.10; 95 percent CI: 0.05 to 0.22) and NT-proBNP (0.14; 95 percent CI: 0.09 to 0.23) were much better than the summary estimates for LR+ for both BNP (2.92; 95 percent CI: 2.09 to 4.09) and NT-proBNP (2.67; 95 percent CI: 1.98 to 3.59).

The summary ROC curves for BNP and NT-proBNP both tended to curve strongly towards the upper left hand corner, signifying high accuracy. Furthermore, the AUC values were 0.86 for both BNP and NT-proBNP, suggesting that regardless of the clinical setting, the cut point chosen, or the test used, measurement of B-type natriuretic peptides is useful in the diagnosis of HF.

Further analysis of heterogeneity was possible to do in six studies from the ED setting that measured BNP by one method with a cut point of 100 (± 5) pg/mL. Even with this uniformity, specificity remained wide (28 to 94 percent). Given that the inclusion and exclusion criteria were not the same in these studies, and are themselves possible determinants of BNP, this heterogeneity is not unexpected.

Overall, there is not clear evidence to suggest the superiority of either BNP or NT-proBNP when all settings are considered.

### Does Measurement of BNP or NT-proBNP Add Independent Diagnostic Information to the Traditional Diagnostic Measures of HF in Patients with Suggestive HF?

We first examined the subset of primary papers from Question 2a that performed multivariate logistic regression analysis to determine whether or not BNP or NT-proBNP measurement provided independent information in the diagnosis of HF. Odds ratios for the B-type natriuretic peptides ranged from 9 to 220 and were generally as high as or higher than, other diagnostic variables. This suggests that measurement of the B-type natriuretic peptide does provide information independent from the traditional diagnostic measures.

Secondly, we examined existing systematic reviews of the diagnosis of HF. These reviews considered many diagnostic tests for HF, both alone and in combination. The DOR ranged from 11 to 569 for BNP and 15 to 230 for NT-proBNP.

These data suggest measurement of the BNP or NT-proBNP are as good as, or better than traditional diagnostic measures for ruling out HF.

### Do BNP or NT-proBNP Levels Predict Cardiac Events in Populations at Risk of CAD, with Diagnosed CAD and HF?

There were 108 studies eligible for evaluating the ability of BNP or NT-proBNP levels to predict cardiac events. Both B-type natriuretic peptides were found to be independent predictors of mortality and other cardiac composite endpoints in patients, but few evaluated NT-proBNP and even fewer evaluated both. Thus there is limited evidence to suggest that either of these B-type natriuretic peptides is a better prognostic marker of mortality or cardiac events than the other.

At risk of CAD. The prognostic value of BNP or NT-proBNP for mortality and cardiac events was examined in 12 studies ^4,^ ^9,^ ^9,^ ^10,^ ^15,^ ^24,^ ^69–^ ^74^ of individuals with risk factors for CAD. These studies differed in terms of the age and gender of their participants, methods of diagnosing risk factors for CAD, lengths of follow up, and outcomes. Multiple regression analyses consistently showed that the level of BNP or NT-proBNP was positively associated (adjusted measures of risk 1.10 to 5.40) with the outcome.

With diagnosed CAD. The 38 studies ^3,^ ^8,^ ^13,^ ^14,^ ^19–^ ^22,^ ^27–^ ^29,^ ^33,^ ^75–^ ^100^ evaluating CAD patients varied with respect to the age and gender of participants, sample size, length of follow up, and outcomes. However, consistent positive associations were found between the level of BNP or NT-proBNP and the outcome of interest. For BNP the range of risk estimate is 2.00 to 3.00 and for NT-proBNP it is 1.50 to 3.00. For both these B-type natriuretic peptides, the small number of studies prevents any differential prediction in persons with or without prior cardiac related surgery.

With diagnosed HF. There were 58 studies eligible for evaluating BNP or NT-proBNP levels in predicting cardiac events in HF patients. The majority of the 38 studies ^12,^ ^23,^ ^25,^ ^30,^ ^32,^ ^36,^ ^41,^ ^48,^ ^101–^ ^130^ found baseline BNP levels to be independent predictors of mortality across various cut points and six studies evaluated both BNP and NT-proBNP tests. The adjusted hazard ratio (HR) showed a 2.5 to a 7.2 fold increase relative to those subjects with lower levels of BNP. Baseline BNP values were independent predictors of composite outcomes with HR estimates from 1.7 to 3.2. Studies comparing baseline and predischarge BNP levels suggest differences in the prediction of mortality. More research is required to establish the relative contribution of these two measurements of BNP. Primarily single studies evaluated the combined use of baseline BNP levels with other markers of cardiac dysfunction (e.g., troponin I and T, or percent VO2 max) as predictors of mortality and composite outcomes. Although the findings may suggest that the combined markers increase the ability to predict future outcomes, more research is needed to establish their relative benefit.

The majority of the 18 NT-proBNP studies ^26,^ ^35,^ ^41,^ ^103,^ ^112,^ ^125,^ ^126,^ ^128,^ ^131–^ ^140^ found this marker to be a significant independent predictor of death or composite endpoints at various cut points. The adjusted risk estimates varied from 2.17 to 9.35 for mortality outcomes, and 2.11 to 5.96 for cardiac composite outcomes.

### What Are the Screening Performance Characteristics of the BNP or NT-proBNP in General Asymptomatic Populations?

A screening test was defined as being used to detect preclinical cardiac dysfunction, systolic or diastolic, in the general population. There were eight studies ^5,^ ^74,^ ^122,^ ^141–^ ^145^ in populations without established or overt disease; two studies had no sensitivity or specificity data. ^74,^ ^122^ BNP generally shows poor screening test characteristics for both the detection of moderate to severe LVSD and of diastolic dysfunction. It is even less accurate for the detection of milder degrees of systolic dysfunction. There was a single NT-proBNP study ^145^ and it showed the screening highest for those with LVEF > 40, and over 70 years of age.

### Can BNP or NT-proBNP Measurement Be Used To Monitor Response to Therapy?

There were 18 studies meeting the eligibility criteria. ^31,^ ^37–^ ^47,^ ^110,^ ^146–^ ^150^ The studies included chronic HF patients with at least three B-type natriuretic peptide measurements over time. Only half these studies reported the change in BNP or NT-proBNP and related the change to other outcomes including cardiac function, exercise capacity, symptoms or clinical events.

A number of these studies demonstrated a relationship between the change in BNP or NT-proBNP and either mortality, morbidity or other clinical parameters. Although promising, the findings have not been uniform and the majority of studies were of poor methodological quality; overall this suggests limited evidence that BNP or NT-proBNP may be useful to monitor therapy in HF patients.

## Conclusions

### Determinants

Numerous factors have been found to be associated with the levels of B-type natriuretic peptides. However, the value of these associations for clinical use is not clear and future research should explore these associations, particularly as a function of HF severity.

### Diagnostic Properties for HF

In all settings (ED, specialized clinics, and primary care) both BNP and NT-proBNP have high sensitivity and lower specificity. This would suggest that these measurements could serve as a test for ruling out cardiac dysfunction. Measurement of B-type natriuretic peptide levels adds independent information relative to traditional diagnostic measures for this condition. Large multicentre trials (especially in ED with complex clinical patients) that allow for multivariate analyses to evaluate variables that contribute to low specificity should be undertaken in the future.

### Prognosis

BNP and NT-proBNP have been shown to be independent predictors of mortality and other cardiac composite endpoints for populations with risk of CAD, diagnosed CAD, and diagnosed HF. There were few studies which evaluated B-type natriuretic peptides in populations without known heart failure. All but a single study suggest these are not sufficiently accurate to be an effective screening test for unrecognized left ventricular dysfunction. Future research should explore the relative merits of B-type natriuretic peptides compared to and combined with other markers of cardiac dysfunction to predict future outcomes.

### Monitoring Treatment

There is insufficient evidence to demonstrate that BNP and NT-proBNP levels show change in response to therapies to manage stable chronic HF patient. Future research could include large randomized trials to show whether therapy guided by changes in B-type natriuretic peptides affect outcome.