# Acknowledgments

We are grateful to members of the technical expert panel who were instrumental in developing the questions and defining the scope of this review: Dr. Robert Christenson, Dr. John G. Cleland, Ms. Carla Herrerias, Dr. Allan Jaffe, Dr. Ijaz Khan, Dr. Theresa McDonagh, Dr. Thomas Moyer, Dr. Mark Richards, Dr. Scott Silvers, Dr. Vincenza Snow.

Our thanks go to Dr. Stephen D. Walter for his statistical consultation as well as to Dr. George Heckman for his thoughtful input. We would like to thank the following people who helped with the data abstraction for this review: Richard Cleve, Paul Malinowski, Curtis Oleschuk, Rosemary Milcz, Christine Mance, Carolyn Archer, Keith Kim, Chi Okonkwo, Dawn Kingston, and Marcia James.

Our editorial staff, Roxanne Cheeseman and Maureen Rice, have provided invaluable input into this document.