# Discussion

Question 1: What Are the Determinants of Both BNP and NT-proBNP?

Factors associated with changes in B-type natriuretic levels were extracted from all studies used to answer Questions 2, 3 and 4 of this review. The identification of determinants is important, as they are potential confounders to accurate diagnosis of heart failure (HF), prediction of cardiac events, and the ability to monitor therapy in patients with HF. The identification of determinants is also useful for the purpose of defining reference intervals and for interpreting unanticipated, patient specific, BNP or NT-proBNP values. Furthermore, they can be used to gain an increased understanding of the physiology and pathophysiology of BNP and NT-proBNP as well as to identify aspects which have been well investigated and to identify gaps where further research is needed. It is also important, for effective design and interpretation of future research, to know what the determinants for BNP and NT-proBNP are.

The determinants found in this systematic review were clinical or biological parameters such as age, gender, diseases, and treatments. There were no data available on factors that affect the analytical test method for BNP or NT-proBNP. Much of this data is not published in journals, but is instead largely in the grey literature, most commonly in the literature supplied by the diagnostic company when applying for FDA approval to market their test method. One recent review, however, does present an overview of analytical determinants. ^198^

The impact of age and gender on B-type natriuretic peptide levels has been reported extensively in the literature and this systematic review has clearly shown that increasing age is positively associated with increased B-type natriuretic peptide levels. In the populations evaluated in this systematic review, the female gender did not consistently show higher levels of B-type natriuretic peptides compared to the male gender. In healthy populations B-type natriuretic concentrations are significantly higher in females compared to males, but it appears that these differences are attenuated with disease processes, at least in the studies included for this systematic review.

The relationships of the B-type natriuretic peptides with various diseases and measures are listed in Table 3. For the most part, all cardiac diseases showed an increase in B-type natriuretic peptides. Stable angina and ischemic heart disease showed a positive effect only when other cardiovascular risk factors were also present. Furthermore, B-type natriuretic peptides were positively associated with many biochemical markers of inflammation such as C-reactive protein (CRP), interleukin-6, ST2 soluble receptor and osteoprotegerin, supporting their role as potential risk markers for cardiovascular disease (CVD). The most frequently reported non-cardiac determinants were non-cardiac dyspnea, hypertension and diabetes. The B-type natriuretic peptides were elevated in both non-cardiac dyspnea and hypertension. For diabetes, three of four studies reported no association. However, other diabetes related determinants including creatinine levels, decrease in glomerular filtration rate, and nephropathy, were positively associated with B-type natriuretic peptides. From this it is rational to extrapolate that B-type natriuretic peptides could be a marker of diabetes complications.

There were few studies ^5,^ ^8–^ ^10,^ ^14,^ ^34,^ ^199^ in this systematic review that looked at the independent association of B-type natriuretic peptide with any determinant using multivariate models. Of these studies, only two included HF severity using left ventricular ejection fraction (LVEF) as a continuous variable in the model. ^5,^ ^11^ There were three determinants (age, gender and creatinine level) which appeared more than twice among the studies that performed multivariate analysis. All studies included age as a variable and all except one study found age to be independently associated with B-type natriuretic peptides. The reason this one study ^34^ did not find this association is probably due to its very small sample size (n = 36). There was also no association with creatinine levels seen in this study. However, the level of creatinine was positively and independently associated with BNP ^9^ and NT-proBNP ^8^ in two other studies. Female gender was associated with increased BNP ^5^ and NT-proBNP ^8,^ ^14^ in three studies, and no increase in one study that contained a high proportion of females (79 percent). ^9^

Even though determinants, such as age, gender and creatinine levels, may be found to be independently associated with B-type natriuretic peptide levels, it is not clear how clinically important it would be to adjust for them. The identification of determinants found in this systematic review does not imply either their causal association with, or their importance in regards to, altered BNP or NT-proBNP concentration. Rather, they offer a basis towards a better understanding of variance in BNP and NT-proBNP levels.

These determinants reflect what is reported in studies central to our clinical research questions but may have different effects in other studies. The magnitude or consistency of the determinant's association with the B-type natriuretic peptides will dictate how it is used. In addition, their use may vary depending on the situation in which they are used, from epidemiological studies and large clinical cohorts to specific clinical settings and individual patient care. Consideration of these variables is made in the context of the individual's disease state and treatment. A statistically significant effect may not translate to a clinically significant effect. Also, the populations where an effect has been shown may range from a small homogenous population to a large heterogeneous population and that effect may not be applicable to an individual. Specifically, in relation to this systematic review, these determinants may be used to explain variation among studies.

Question 2a: What Are the Clinical Performance Characteristics of Both BNP and NT-proBNP Measurement in Patients with Symptoms Suggestive of HF or with Known HF in the Four Clinical Settings of Emergency Department, Specialized Clinic or Outpatient, Primary Care, and Long Term Care?

One objective of this systematic review was to focus on studies that enrolled patients with clinical symptoms of HF as the presenting complaint regardless of comorbidity in order to generate a clinically applicable summary with maximum generalizability. With the exception of HF referred to specialized clinics, this review excluded all studies in which a diagnosis of any disease or medical condition (e.g., heart transplant) was an inclusion criterion for enrolment. To this end, and compared to previous systematic reviews, we screened a greater number of primary studies and evaluated the diagnostic performance of BNP and NT-proBNP as a function of clinical setting.

The diagnosis of HF is challenging. It is typically based on the clinical history, physical examination, electrocardiogram (ECG), chest x-ray, and assessment of left ventricular function. ^54^ Diagnosis by consensus decisions of cardiologists based on interpretation of these clinical data will reveal that many patients with symptoms of HF do not have the disease. ^200^ This can be explained in part by the fact that some of these patients may have comorbidities that could account for their symptoms. ^173^ Conversely, not all patients with left ventricular dysfunction (LVD) have symptomatic HF. ^201–^ ^203^ The concern is that cardiac function can be interpreted as normal in the presence of a normal systolic function if an assessment of diastolic function is not also included. Diagnostic imaging methods best suited for evaluation of diastolic function (doppler echocardiography, M-mode echocardiography, multiple gated acquisition scan, cardiac catheterization) were not used in the majority of studies evaluated in this review. Diagnostic tests other than those specified above were used as reference standards and this is problematic. Therefore, the misinterpretation of normal systolic function as indicating the absence of HF could result in misclassification by the reference test. Given that the levels of B-type natriuretic peptide markers are reported to rise in the presence of myocardial wall stress resulting from systolic and/or diastolic dysfunction, this misclassification can result in a false negative interpretation of the corresponding B-type natriuretic peptide measurement.

The high pooled diagnostic odds ratios (DORs) and high sensitivities reported in this review indicate that these B-type natriuretic peptide markers have diagnostic value. However, there is no consensus on the optimum cut point for clinical application. Doust et al. ^173^ found, as we did in this review, that there is variation in the estimates of diagnostic accuracy between studies, and that this does not seem to be accounted for by differences in the clinical setting or the type of test used. This is explained, in part, by misclassification bias, which can underestimate the diagnostic accuracy of the B-type natriuretic peptides and subsequently yield a falsely elevated cut point.

Raymond et al. ^204^ also reported problems in determining a cut point for the diagnosis of HF. They concluded that in the determination and application of a cut point, an adjustment should be made at least for the independent effects of age and gender. Hence, the changes in BNP and NT-proBNP are not specific to HF; a conclusion that has also been supported by the results of Question 1 in this review. This means that elevated peptide markers do not confirm HF as a cause of the patient's symptoms. These markers, however, do appear to be sensitive to HF.

In summary, patients who present with symptoms of HF who are found to have a normal BNP or NT-proBNP are highly unlikely to have HF as a cause of their symptoms. These patients require further investigation of their condition to determine the reason for increased B-type natriuretic peptide levels.

Question 2ai: Emergency Department

With regards to emergency department (ED) settings, the findings are consistent with suggesting that BNP and NT-proBNP tests may be useful in ruling out cardiac dysfunction. In general, all studies enrolled patients with shortness of breath, which is typical of ED settings. Although, a variety of different cut points were evaluated, in all studies the sensitivity was reported as greater than 90 percent, however specificity varied widely from 27 to 91 percent. A similar pattern of high sensitivity and widely ranging specificity was observed for NT-proBNP. Although a cut point cannot unequivocally rule in HF, according to Doust, ^173^ BNP values less than 51.75 pg/ can be used to exclude the disease in patients in whom it is suspected. This is lower than most of the cut points reported in this systematic review. There have been fewer studies evaluating the diagnostic performance of NT-proBNP than BNP. Januzzi et al. ^205^ report an age-independent cut point of NT-proBNP to rule out acute HF of 300 pg/mL (95 percent CI: 241 to 369) demonstrating a sensitivity of 99 percent, specificity of 60 percent, and a negative predictive value of 98 percent. However, their pooled analysis was not based on a systematic review, but rather on three selected clinical trials without any specific a priori inclusion criteria. Our review revealed that a study by Jose employing a cut point of 200 pg/mL had the highest sensitivity (97.2 percent) and DOR (291). ^53^

In the studies reviewed, there was minimal insight into the diagnostic utility of B-type natriuretic peptides in complex cases where there is uncertainty in diagnosis. It is these cases that present a greater diagnostic challenge where it would be particularly valuable to have a test that could increase the certainty for HF. Based on the findings of our systematic review, the most likely use of B-type natriuretic peptides in the ED setting would be to identify which patients require further investigation to determine the cause of their symptoms. Patients with normal peptide levels will most likely have a condition other than HF as a cause of their symptoms, while those with elevated levels will likely need confirmatory testing for the disease. ^173^ One study ^17^ considered cases with inconclusive BNP values (80 to 300 pg/mL) and found BNP to be a poor predictor of the final diagnosis using multivariate regression analysis (OR 1.85, 95 percent CI: 0.4 to 7.8, p = 0.4). Overall, the quality of the studies in the ED setting was high. Except for the problem with misclassification bias, the literature was very consistent and the external validity was good. Future research should ideally include multicentre studies enrolling patients with symptoms of HF and employing definitive diagnostic imaging as the objective determinant of the presence or absence of the disease. Given large enough study populations, subgroup analyses will identify confounding variables and their impact on B-type natriuretic peptide levels.

Question 2aii: Specialized Clinic or Outpatient Setting

With regards to specialized clinics and outpatient settings, BNP and NT-proBNP levels correlate with cardiac function as well as symptoms. However, there are some important limitations to all of these studies. They have generally had relatively small sample sizes and have exclusively been single centre studies. The wide range of cut points for both BNP and NT-proBNP was also apparent in this setting as it was in other settings. It should be recognized that a rather select group of patients has been evaluated in these studies. These are patients referred for symptoms suggestive of HF or are patients with stable chronic HF. As sensitivity, specificity and the AUC for the ROC curves are dependent on the patient population studied, it is difficult to generalize these results to the broader population and to those within specialized clinics. A single study ^60^ that compared BNP with NT-proBNP in stable HF patients found no difference in the performance characteristics of these two markers.

Based on the limited number of studies in clinical or outpatient settings, the B-type natriuretic peptides are not useful to rule in HF. The low specificity of the test precludes it from being used in this way. In some situations within specialized clinics the high sensitivity of these peptides may be useful in ruling out HF as a cause of the symptoms. In both cases, however, supplementary investigations may be required to guide clinical management of the patient. Measurement of the natriuretic peptides does not reduce the need for these additional investigations. Overall, these studies had high internal validity as they scored well on the QUADAS items. The results of these studies are very encouraging, but further studies are required to better define the role of BNP and NT-proBNP in diagnosing HF in a specialized clinic or outpatient setting.

Question 2aiii: Primary Care

With regards to the primary care setting, the findings of this review do not differ from those in the ED and clinic settings. One of the dilemmas facing physicians is how to appropriately manage patients who present with suspected HF. BNP and NT-proBNP tests are less expensive and are probably easier to obtain in primary care situations than echocardiography and thus offer the possibility of use as a first line diagnostic test. Echocardiography will be needed in the confirmation of the diagnosis and for staging and prognosis. BNP or NT-proBNP measurement might aid the physician in distinguishing between those patients who can be safely discharged and those who should be sent to specialist clinics or physicians for further work up and confirmation.

Of the few studies included in the meta-analysis, only one study ^63^ stood out as being different from the others. In this study, a random sampling of patients over 45 years old was selected (using computerized practice registers) from 16 random primary care practices in England. The sample was stratified by age and socioeconomic status. Four cohorts were identified: general population, patients labelled as having HF (may not be confirmed), patients prescribed diuretics, and those at high risk for HF (history of previous myocardial infarction (MI), angina, hypertension, or diabetes). The high-risk cohort group from this study was compared to the other cohorts which were selected based on a family practitioner's suspicion that the patient may have HF. The data from the high risk cohort shows a lower prevalence of HF and poorer diagnostic performance of the B-type natriuretic peptides (Figures 3, 4). Furthermore, the large difference in the DOR between BNP and NT-proBNP measurements in this study suggests either the cut point(s) chosen were not comparable or that the NT-proBNP test has a higher diagnostic accuracy.

Table 24 presents the results of a hypothetical analysis designed to answer who can be safely discharged and who should be referred on. Following the example set in the paper by Redfield et al., ^5^ we calculated the following: (1) the portion of the population that would test positive if BNP or NT-proBNP were used as a first line diagnostic test, (2) the portion of those positive tests that would subsequently be confirmed as negative, (3) the portion that would test negative and not be further followed, and (4) the portion of subjects with a positive outcome that would be missed.

Table 24 Hypothetical analysis using BNP and NT-proBNP as first line tests and demonstrating the potential for reduction in subsequent requirement for further confirmatory testing for HF*

Report | Population | Prevalence | Index test^⁁^ | % of population with positive test | % of positive tests subsequently confirmed negative | % of population with negative test | % of population with outcome missed (negative screening test, but positive outcome)
Hobbs ^63^ 2004 | primary care general population | 1.6 | BNP(1) | 13 | 90 | 87 | 20
| primary care Clinical Dx of HF | 20.3 | | 53 | 72 | 74 | 28
| primary care, on diuretics | 33.3 | | 39 | 82 | 61 | 14
| primary care, high risk HF | 7.5 | | 34 | 89 | 66 | 50
Redfield ^5^ 2004 | ≥ 45 yrs, random sample of pop'n | 1.9 | BNP(2) | 24 | 96 | 76 | 10
Groenning ^145^ 2004 | primary care recruit from GP, 50 –90 y, exclude nursing homes | 5.6 | NT-proBNP(7) | 35 | 87 | 65 | 7.8
Gustafsson ^68^ 2003 | primary care with dyspnea referred for echo | 8.9 | NT proBNP(9) | 63 | 78 | 37 | 3
Hobbs ^63^ 2004 | primary care general population | 1.6 | NT-proBNP(9) | 28 | 95 | 72 | 20
| primary care Clinincal Dx of HF | 20.3 | | 85 | 76 | 15 | 0
| primary care, on diuretics | 33.3 | | 62 | 88.8 | 38 | 14
| primary care, high risk HF | 7.5 | | 57 | 86 | 43 | 0
Wright ^64^ 2003 | > 40 y, Present to GP with dyspnea/edema | 25 | NT-proBNP(6) | 47 | 28 | 53 | 17

Abbreviations: Dx=diagnosis, GP=general practitioner, HF=heart failure, y=years.

5 Based on Redfield et al.).

⁁ Number in bracket refers to row number in Table 1 or Table 2 describing method used to measure B-type natriuretic peptide.

Two studies using BNP, ^5,^ ^66^ three using NT-proBNP, ^64,^ ^68,^ ^145^ and one using both, ^63^ could be analyzed in this way (Table 24). Using this two-step approach would mean that 13 to 63 percent of the population would be referred for an ECG. In all cases (except one, ^64^ which used a high NT-proBNP cut point of 245 pg/mL), 60 to 90 percent of these positive tests would be subsequently confirmed negative by echocardiography. Ten to 40 percent of those with a positive B-type natriuretic peptide test result would be confirmed positive by echocardiography. The portion of the general primary care population with a false negative result that would be missed using this approach is less than 4 percent. Negative likelihood ratios (LR-) (Table 6) ranged from 0 (highly useful) to 0.27 (marginally useful). These two pieces of information suggest that B-type natriuretic peptides measurement is useful for ruling out HF. Because of the poor specificity of the test, a positive result does not necessarily rule in HF.

One randomized controlled trial (RCT) ^64^ examined the effect of NT-proBNP measurement on the diagnosis of HF in a primary care situation. Patients in the study group had their NT-proBNP results sent to their general practitioner along with an interpretive comment, whereas those in the control group had their NT-proBNP results withheld. The ability of physicians to accurately diagnose HF was compared between the two groups. The diagnostic accuracy was significantly increased when the NT-proBNP was available to the physician, with the greatest improvement being in the ability to rule out HF. They conclude that NT-proBNP measurement adds value over and above the current diagnostic strategies available to primary care physicians.

One paper, ^206^ published after the close of the literature search for this systematic review, describes the results of a multicentre trial to assess the diagnostic accuracy of BNP, NT-proBNP and ECG in 306 primary care patients referred for investigation of suspected HF. They report a high sensitivity for NT-proBNP (0.98 at 125 pg/mL) and a somewhat lower sensitivity for BNP (0.87 at 65 pg/mL). Negative likelihood ratios were 0.05 and 0.23 respectively. These authors' conclusions are similar to those in our systematic review, which is that B-type natriuretic peptides are useful to rule out HF as a cause of the symptoms, but not useful as a rule in tool. In primary care situations, B-type natriuretic peptide measurements may aid in the diagnosis of HF. Results below the diagnostic cut point can reliably rule out the diagnosis. Results above the cut point identify patients who require additional investigations to determine the cause of their symptoms.

Question 2aiv: Long Term Care Settings

This review did not find any relevant papers to address this question. Patients in long term care settings are likely to be older and have more comorbidities than the general population. This places them at higher risk for the development of HF. This is an area that requires further investigation to assess the utility of BNP or NT-proBNP as a diagnostic marker of HF.

Question 2a: All Settings Combined

The diagnostic ability of BNP and NT-proBNP was examined by setting in Question 2ai through 2aiii. Further investigations were performed to assess the diagnostic performance of BNP or NT-proBNP, irrespective of the clinical setting.

In each of the clinical settings, measurement of the B-type natriuretic peptides was shown to be of value in the diagnosis of HF. Patients who are found to have a BNP or NT-proBNP below the diagnostic cut point are unlikely to have HF as a cause of their symptoms.

In the ED setting there were enough papers to justify combining them to determine pooled estimates of the diagnostic characteristics. This was not the case for either the specialized clinic or primary care settings and therefore we combined all studies together. Since there is no guideline for pooling studies that present results with single and multiple cut points the choice was made to select the lowest one in studies with multiple cut points. Thelowestcut point corresponds to the highest sensitivity and is therefore the best test characteristic to rule out HF. We also examined the special case of BNP using the cut point of 100 (±5) pg/mL. This was the single most common cut point amongst the studies in this review. It is also the cut point suggested by manufacturers of the common commercial assays.

The meta-analysis indicated the diagnostic parameters remain similar even when results from all settings are combined. The pooled sensitivity was high (94 percent for BNP and 92 percent for NT-proBNP) and the pooled specificity was low (66 percent for BNP and 65 percent for NT-proBNP). In the absence of clearly demonstrated superiority of either BNP or NT-proBNP, the choice of analyte will likely depend on factors such as local expertise and availability of analytical instruments.

The largest difference among studies in all settings was seen with specificity. There are number of factors that could explain the heterogeneity including test type (BNP or NT-proBNP), test method, setting, study population, study design, study sample size, and reference test (from LVEF measurement alone to clinical classification with all available patients results). Multivariate analysis did not show a difference with respect to study design, sample size or reference test. There were too few studies in the subgroups of test type or test method to perform a sub-group analysis.

The determinants for BNP and NT-proBNP were not often considered in the diagnostic papers. The effect of determinants such as age, obesity, other diseases (e.g., hypertension, diabetes, renal failure) or drugs (e.g., beta blockers, diuretics, angiotensin converting enzyme (ACE) inhibitor) on B-type natriuretic levels is important to consider and is the only reason we could find that could explain the wide variation in specificity among the studies.

Further analyses to examine the issue of heterogeneity was possible using six studies that used the BNP Biosite test with a cut point of 100 pg/mL (±5 pg/mL). The average study sample size was 472 (range 163 to 1586). Five of the six studies were cross-sectional in design and one was a diagnostic study design. All studies used a clinical diagnosis of HF for the reference test. However, even with this high level of homogeneity among the studies there was still a wide range in specificities (28 to 94 percent) (Figure 5). The sensitivities were much higher and tighter ranging from 90 to 97 percent. The only explanation to account for these diagnostic parameters appears to lie in the heterogeneity of the study populations.

The average age range was 63 to 80 years and the percentage of males ranged from 49 to 94 percent. All six studies included patients with dyspnea, two studies had no exclusion criteria, ^7,^ ^57^ and the other four had various exclusion criteria. Three studies ^18,^ ^55,^ ^56^ excluded patients with cardiac tamponade, MI and trauma. Additional exclusion criteria for these studies were renal failure, ^18^ unstable angina, ^18,^ ^55^ and acute coronary syndrome (ACS). ^56^ The sixth study ^17^ excluded patients with acute MI, trauma, recent surgery and treatments started 2 hours before arrival to the ED (mechanical ventilation, diuretics, nitrates, or inotropic agents). Since many of these included and excluded parameters are factors that affect the BNP concentration, it is not surprising that there is a wide variation in the specificity of the test.

The specificity of the BNP is higher (76, 86 and 94 percent) ^18,^ ^55,^ ^56^ in those studies that excluded patients that were very likely to have elevated BNP levels compared to those that did not (28, 51 and 59 percent). ^7,^ ^17,^ ^57^ The false positive (FP) rate in the three studies with the highest specificity ranged from 3.6 to 12.7 percent compared to a much higher FP rate (20.2 to 32.2 percent) in the three studies with the lowest specificity. If further exclusion criteria are employed in studies assessing HF in the ED such as chronic obstructive pulmonary disease (COPD) there could be a further reduction in the FP rate.

The number of misclassified patients who would be ruled out with a B-type natriuretic peptide test but who would actually have HF is low. The overall mean false negative (FN) rate for ED studies including BNP and NT-proBNP tests was 1.9 percent (range = 0.7 to 4.6 percent, n = 11) using a variety of cut points (10 to 200 pg/mL for BNP and 125 to 1691 pg/mL for NT-proBNP). The FN rate is similar even if limited to studies using the Triage BNP method using 100 (± 5) pg/mL as the cut point (mean = 2.9 percent, range = 1.0 to 4.6 percent, n = 6). Based on this data, the FN rate would only be expected to go lower if the patient selection was more specific.

Question 2b: Does Measurement of BNP or NT-proBNP add Independent Diagnostic Information to the Traditional Diagnostic Measures of HF in Patients with Suggestive HF?

We examined the subset of primary papers that performed multivariate logistic regression analysis to determine whether or not BNP or NT-proBNP measurement provided independent information in the diagnosis of HF. Odds ratios for the B-type natriuretic peptides ranged from 9 to 220 and were usually as high as, or higher than, other diagnostic variables. The conclusion from this analysis is that measurement of the B-type natriuretic peptides does indeed provide information independent from the traditional diagnostic measures.

Secondly, we examined existing systematic reviews of the diagnosis of HF. These reviews considered many diagnostic tests for HF, both alone and in combination. The DORs, actual and estimated, ranged from 10 to 569 for BNP and 14 to 230 for NT-proBNP.

These two lines of evidence both point to the conclusion that the measurement of the B-type natriuretic peptides is as good as, or better than, the traditional diagnostic measures for ruling out cardiac dysfunction. For these purposes, BNP and NT-proBNP appear to be of equivalent value. The information provided by the BNP or NT-proBNP tests is independent of that provided by the other measures.

A recent systematic review compared the ECG to BNP and found no difference in diagnostic accuracy for LVSD. ^207^ The echocardiogram is a better diagnostic test for HF; however, there were no systematic reviews identified which either evaluated the echocardiogram for HF or that compared BNP to the echocardiogram. If there is difficulty obtaining an echocardiogram or, if reducing costs is an issue, the B-type natriuretic test is a sensitive test to rule out HF. The caveat is that there will be FP cases that will need further workup.

Question 3a: Do BNP or NT-proBNP Levels Predict Cardiac Events in Populations at Risk of CAD, with Diagnosed CAD and HF?

Across the three different cardiac groups evaluated for Question 3a, both BNP and NT-proBNP have predictive value with respect to the outcomes of mortality or composite cardiac endpoints. The discussion is summarized according to each of these cardiac groups. In general, there were fewer studies evaluating NT-proBNP than BNP and even less comparing both these.

Question 3ai: At Risk of CAD

There were 12 studies that examined whether BNP or NT-proBNP had prognostic value for mortality or the occurrence of cardiac events in persons with risk factors for coronary artery disease (CAD). The 12 studies differed from one another in terms of the age and gender of the participants, the methods of diagnosing risk factors for CAD, the length of follow up, and the outcomes.

Despite these differences, the results of the multiple regression analyses consistently showed that the level of BNP or NT-proBNP was positively associated with the outcome, which was usually mortality. The adjusted measures of association in cases where BNP or NT-proBNP was treated as categorical were in the relatively tight range of 1.10 to 5.40. Although point estimates of the measures of association appeared to be larger for NT-proBNP than for BNP, the heterogeneity of the studies allowed for only tenuous comparisons between the two forms of peptide. There was no firm evidence to suggest that NT-proBNP was a better prognostic marker of mortality or cardiac events than BNP. Due to study heterogeneity, a meta-analysis was not conducted to summarize the data.

In conclusion, the overall consistency of the studies' results suggests that BNP and NT-proBNP do have prognostic value for persons who present with risk factors for CAD. This agrees with the conclusion of Doust et al. ^163^ Future research should compare the relative merits of BNP and NT-proBNP, as well as focus on how this prognostic information can be applied for patient care.

Question 3aii: With Diagnosed CAD

Overall, the 38 studies evaluating CAD patients varied from one another with respect to the age and gender of participants, sample size, length of follow up, and outcomes. Despite the heterogeneity, consistent positive associations were found between the level of BNP or NT-proBNP and the outcome of interest (mortality or otherwise). This suggests that BNP and NT-proBNP do have some predictive value with respect to these outcomes. However, given the diversity of the studies — a fact that precluded the use of a meta-analysis to summarize the data and the potential for selection or information bias, a single, global predictive effect for either peptide cannot be estimated from the available data.

If BNP and NT-proBNP are taken separately, then the approximate general effects appear to be in the range of an odds or hazard ratio of 2.00 to 3.00 for BNP and 1.50 to 3.00 for NT-proBNP (excluding studies with extreme results ^3,^ ^79,^ ^84^ ). However, in the case of both peptides, the small number of studies does not allow for a determination of whether outcomes are predicted differently in persons with or without prior cardiac related surgery. Nor can a judgment be made about whether one of the peptides is a better predictor of mortality or non-fatal outcomes. In fact, there is no evidence at this time to suggest that BNP or NT-proBNP are different from one another in predicting outcomes such as mortality or re-infarction in persons with CAD.

Question 3aiii: With Diagnosed HF

The majority of the 38 studies evaluated in this review found baseline BNP levels to be an independent predictor of mortality outcomes across various cut points. When calculated, the adjusted HR varied from a 2.5 to a 7.2 fold increase relative to those subjects with lower BNP levels. Similarly, baseline BNP values were independent predictors of composite outcomes with HR estimates varing from 1.7 to 3.2. Some studies compared baseline and predischarge BNP levels and the findings would suggest differences in the ability to predict subsequent mortality; more research is required to establish the relative contribution between these two measurements of BNP. Several studies evaluated the combined use of baseline BNP levels with other markers of cardiac dysfunction (e.g., troponin I and T, percent VO2 max, or EF) as predictors of mortality and composite outcomes. The studies evaluating these markers were primarily single studies. Although the findings may suggest that the combined markers increase the ability to predict future outcomes, more research is needed to establish the relative benefit of these combined parameters. Similar to BNP levels, the majority of the 18 studies showed that NT-proBNP was a significant independent predictor of death or composite endpoints. The estimates of adjusted risk estimates varied from 2.17 to 9.35 for mortality outcomes, and 2.11 to 5.96 for cardiac composite outcomes. Similar to BNP, NT-proBNP was shown to be a significant predictor of outcomes at various cut points. Overall, the quality of studies was limited suggesting the potential for selection and particularly, misclassification bias in the majority of studies.

There was some interest in evaluating the evidence with respect to potential differences in the predictive ability of BNP and NT-proBNP for future cardiac events in HF patients. These two B-type natriuretic peptides are different molecules with different half-lives and blood concentrations and so there are some plausible physiological reasons to consider potential differences in performance as a clinical test. As such, there is currently some controversy about whether poor kidney function is a confounder for the interpretation of NT-proBNP levels. In addition, since the concentration of NT-proBNP is higher than BNP it has the potential to have greater (or finer) sensitivity. With respect to prognosis, few studies overall evaluated NT-proBNP and even fewer evaluated both types within the same study (n = 6). Within these six studies at least one of these B-type natriuretic peptides was a significant predictor of the outcome. Only two studies found both BNP and NT-proBNP to be independent predictors of mortality and the ability to predict varied with the year of follow up and the timing of the measurement. In general, the sample sizes within these studies were small and this may have been a factor in the multivariate analyses. No clear pattern emerges to suggest superiority of one type of B-type natriuretic peptide relative to the other in these head to head studies. Further research aimed at exploring potential differences in the prognostic abilities of these tests is required.

## Methodological Caveats with Interpretation of BNP and NT-proBNP as Predictors of Future Cardiac Events

Much of the variation in the strength of BNP and NT-proBNP as a predictor of mortality and composite endpoints can be attributed to several key factors including: (1) differing HF populations with respect to severity, (2) the study settings, (3) differing BNP cut points, and (4) differing parameters included in multivariate regression models. Many studies had small sample sizes and the outcomes were relatively rare in some severity groups; small sample sizes reduce the validity of undertaking multivariate analyses. There were also a number of important potential confounders identified in Question 1 of this review that was not controlled for in many studies. In particular, most studies did not control for treatment interventions as a confounder. For example, ACE inhibitors, which are commonly used in the management of HF patients, are suspected to affect HF prognosis. The mechanism of influence of some of these commonly used drugs on B-type natriuretic peptide levels is poorly understood in the literature. In general, the types of drug therapies and their doses were not controlled for or well described in many studies. Similarly, the majority of studies employed prospective cohort research designs and as such subjects were not randomized; this decreases confidence that differences between groups within these studies did not exist with respect to treatment interventions. Moreover, standard treatment varied between studies, which may serve as an important source of heterogeneity. Although drugs are an important intervention within this population, other treatments had the potential to influence prognosis estimates. For example, several studies performed catheterization procedures after admission and evaluation of B-type natriuretic peptide levels and as such, the estimates of prognosis would be influenced by these if not controlled for in the analysis. Thus, future research should attempt to control for and evaluate the influence of various treatments for HF on B-type natriuretic peptide levels.

Other diseases that HF subjects had were also not consistently controlled for in many studies. An overriding aim of most studies was to determine the independent contribution of B-type natriuretic peptide levels relative to other hemodynamic markers. Diseases such as diabetes or renal dysfunction, which affect both the B-type natriuretic peptide levels and prognosis estimates, were not always included in regression models.

Many studies did not specify the time the B-type natriuretic peptide measurements were taken, although the majority did so at some point in the admission process. Whether sampling of B-type natriuretic peptide levels occurred before or after acute interventions (in emergency for example) was not always specified. For baseline measures of B-type natriuretic peptide, it is not known if time dependent changes in B-type natriuretic peptide levels can improve or worsen prognosis estimates. In the case of longer-term studies, B-type natriuretic peptide levels may change due to worsening HF and influence the strength of the prediction estimate. The ValHeft studies ^106,^ ^208^ would suggest that the changes in BNP levels are related to prognosis as well. Whether baseline measures are sufficient in longer-term studies may be a concern for future research in this area. Conversely, it may be difficult to determine the best timing or interval for BNP measurement during the clinical course of HF. Consensus on best timing is required, particularly for those that maintain that serial measurements improve the ability of BNP or NT-proBNP to serve as a predictor of outcomes. ^36^

Diagnosis of HF is another important source of heterogeneity within the studies evaluated in this systematic review. Specifically, classification of HF severity (disconnect between clinical presentation and hemodynamic function of the heart) is problematic; in part this is due to the differing classification systems and reference tests used to establish diagnosis. Accepted classification systems currently used to assist in determining the severity and functional status of patients serve to broadly classify HF groups and are limited in their precision. Alternative classifications have been recently proposed ^209^ for acute HF syndrome, dividing patients into three clinical groups: worsening chronic HF associated with reduced or preserved LVEF, (70 percent of all admissions); de novo HF, (25 percent of all admissions); and advanced HF (i.e., refractory to HF) with severe LV systolic dysfunction, associated with a continually worsening low output state (5 percent of admissions). These authors acknowledge that it may be difficult to classify patients at time of hospital presentation, but may be more useful in classifying patients in hospital or post discharge. Similar to problems with admission for HF, variations in discharge criteria for HF patients following an acute episode ^107^ are also an important source of heterogeneity for the prognosis estimates. Thus, not only is the diagnosis of HF potentially inconsistent and inaccurate, but also, the clinical impressions of “sufficient circulatory stabilization” may be inconsistent between studies in addition to being inaccurate. ^107^ Greater uniformity in criteria for discharge would also assist in understanding the role of BNP levels in predicting future outcomes.

Variation between studies in the types of HF patients or HF subgroups that were excluded was also evident and a rationale was frequently not provided. This variation in exclusion criteria may have had the potential to influence prognosis. For example, one study ^124^ excluded patients with a degree of mitral regurgitation, as this might influence a hemodynamic parameter (transmitral flow). The aim of that study was to evaluate how well transmitral flow as well as BNP levels predicted mortality; this exclusion likely influenced prognosis and limited comparison of results with other studies. Differentiation between subgroups of HF patients (for example those with and without preserved systolic function) were not always evaluated within studies; demonstrating that there were no differences between subgroups rather than assuming this would have been preferred. The problem in defining some subgroups is further compounded by the lack of consensus on features to classify patients (for example, the exact percent EF to classify those with or without preserved left ventricular systolic function is not currently established).

Unbiased verification of the outcomes was limited in the studies in this review, as most assessors were not blinded. Some studies did attempt to have adjudicators of outcome that were external to those managing the patients (who were blind to BNP or NT-proBNP levels). However, there are some additional challenges in determining some of the outcomes, such as sudden death or sudden cardiac events and whether these are “witnessed” or not; consensus on what constitutes sudden is not yet established. For subjects who were admitted to acute care hospitals some medications would be stopped, new ones introduced, and doses of existing maintenance drugs altered as a strategy to manage the acute episode. It has been suggested that often patients with the worse conditions receive less therapy because they can tolerate only lower doses (for example ACE inhibitor). ^112^ Thus, hospitalized patients, particularly those with increasing severity of HF, may have worse outcomes because of the use or contraindications of medications (beta blockers versus ACE inhibitor for example) rather than their BNP levels.

Study setting was also another important source of heterogeneity amongst studies influencing the magnitude of predictive estimates of risk. Most patients were either recruited at admission to acute care hospital, to ED or outpatient clinics. Those admitted to acute care centers were typically in a decompensated state and required rapid and intense interventions to stabilize conditions. For those enrolled in studies from outpatient and emergency settings, subjects that were subsequently hospitalized (versus those that were not) were not always stratified in the analyses; as such differential bias was a concern. It was not always clear if those studies that admitted patients with high acuity also had increased severity of HF relative to those patients that were not hospitalized or were recruited in outpatient settings or ED. Disentangling the relationships between study setting, patient acuity (decompensated versus stable), and severity of HF should be an important consideration in future research evaluating prognosis. Exploration of these factors will account for the heterogeneity of the estimated risk levels and the varying thresholds that were observed in this systematic review.

Many studies in this systematic review were aimed at establishing the relative strength and independent contribution of BNP or NT-proBNP levels in predicting the outcomes of interest. Moreover, the literature reflected interest in establishing the relative merit of B-type natriuretic peptides in combination with other parameters such as troponin T and I, percent VO2max, percent lymphocytes and in particular hemodynamic factors. Since HF is complex and HF mortality is not only caused by mechanical dysfunction of the heart but also by arrhythmic disturbances, ^116^ it is likely that consideration of a wide variety of factors (rather than a single hemodynamic parameter) may improve their diagnostic and prognostic ability.

Question 3b: What Are the Screening Performance Characteristics of BNP or NT-proBNP in General Asymptomatic Populations?

In general, a test is considered important to utilize as a screening tool if the burden of suffering is high, the test itself is accurate and if early detection of the disease with the test is an effective intervention such that mortality/morbidity is reduced for those that were screened.

In the studies that used BNP as the index test, adequate screening characteristics were not observed, and this is true even for the detection of moderate to severe LVSD. It is even less accurate for detection of milder degrees of systolic dysfunction, which is more common in the general population. BNP is also quite poor for the detection of diastolic dysfunction. One requirement for screening is that there is evidence that early detection and intervention reduces morbidity and mortality. This evidence cannot be provided for BNP since it fails to detect those with milder degrees of systolic dysfunction who are known to be at increased risk. A single study using NT-proBNP as the index test with Danish patients recruited from general practices showed some promise for select subgroups of patients. There is also a need for more screening studies using NT-proBNP before any conclusions can be reached.

Question 4: Can BNP or NT-proBNP Measurement Be Used To Monitor Response to Therapy?

The findings from these studies suggest that BNP or NT-proBNP may be useful to monitor therapy in HF patients. A number of these studies demonstrated a relationship between the change in BNP or NT-proBNP and either mortality, morbidity or other clinical parameters such as left ventricular function. However, the findings have not been uniform as some of the studies do not show a relationship and therefore would not support the suggestion that BNP or NT-proBNP could be used to monitor a response to treatment. There are a number of limitations to the studies undertaken to date. Aside from one large study of over 4000 patients that was part of a clinical trial, the studies have been small with patient enrolment in most cases being less than 100 individuals. In some cases the studies have been single blinded and some were retrospective observational studies. Only two of the studies have altered therapies in response to the change in BNP or NT-proBNP and then assessed the outcome in a group treated by natriuretic peptides guided therapy compared to usual clinical management. For many of the studies patients were not being treated with beta blocker therapy, and the effect of this form of therapy on BNP or NT-proBNP concentrations has been observed to be variable. Thus the results from these studies should be considered as pilot data, they provide the rational for larger studies of hormone-guided treatment including the use of beta blocker therapy. These larger studies would more reliably answer the question of whether BNP or NT-proBNP measurement can be used to monitor a response to therapy for HF patients. Four large studies are ongoing and include the United Kingdom Natriuretic Peptide Study (UKNPS), BNP-Assisted Treatment To Lessen Serial Cardiovascular Readmissions and Death (BATTLE-SCARRED), Rapid Assessment of Bedside BNP in Treatment of Heart Failure (RABBIT) and Suivi du Traitement dans l-innsuffisAnce caRdiaque Systolique (STARS) or treatment monitoring of systolic cardiac insufficiency. ^210^ The STARS trial in an abstract has reported preliminary findings on 220 patients showing HF events (death or hospitalizations) were reduced and delayed in the BNP guided therapy group compared to the clinically guided therapy group (p = 0.001, median follow up time was 15 months). ^211^

Monitoring therapy with BNP or NT-proBNP requires serial measurements. Therefore knowledge of their biological variation is needed to know when a change in concentration signals a change in the pathophysiological process of the disease. Several studies have looked at the within day, day to day and week to week variation of these peptides in healthy individuals and patients with stable chronic HF. ^212–^ ^216^ The biological variation for individuals (CV_I_) was found to increase with time between measurements for both BNP and NT-proBNP. The within-day day variation was 8.4 percent and 8.6 percent, the day-to-day was 25 percent and 20 percent and the week-to-week variation was 44 percent and 35 percent, for BNP and NT-proBNP, respectively. ^212^ There is also a slight increase in BNP and NT-proBNP from morning to early afternoon (approximately, 10 percent and 20 percent, respectively). ^212^

Other studies looked at only week to week variation but found similar results for healthy individuals and patients with stable chronic HF. ^213,^ ^215,^ ^216^ There was also no difference between assay methods (BNP methods included Abbott, Bayer and Biosite while only the Roche method was used for NT-proBNP). Ultimately, the parameter that is used to monitor serial measurements is the reference change value (RCV) and includes both the analytical variation (CV_A_) and individual variation (CV_I_). At a 95 percent CI the formula is: RCV = 1.96 x 2^1/2^ (CV_A_ ^2^ + CV_I_ ^2^)^1/2^. ^217^ The RCV values calculated for these studies ^212,^ ^213,^ ^215,^ ^216^ showed that the RCV for BNP was slightly higher than for NT-proBNP (about 120 percent and 100 percent, respectively), but very similar among methods and between healthy and stable HF patients. These large RCV's indicate that a substantial change (about double or half) in serial measurements is required to indicate a significant change in concentration.

There is therefore a need to know if there are relevant and easily modifiable determinants that can be reduced such that the CV_I_, since this is by far the largest component to the RCV (CV_A_'s are less than 25 percent of CV_I_'s). Standardized protocols (e.g., time of day, exercise, fluid intake) or taking replicate samples may help to reduce the RCV. Interestingly, the Melzi d'Eril study ^214^ found a much lower CV_I_ using the NT-proBNP method (9.1 percent). Although data analysis in this study was done using log-transformed data this would not account for the value being almost 75 percent lower. Although collection time could be a factor (since there is some diurnal variation), the collection times varied among studies. This observation merits further investigation since a lower CV_I_ would make monitoring of B-type natriuretic peptides more feasible. Since BNP is a hormone that is highly responsive to hemodynamic change this likely explains why biological variation is high.

The reduction in B-type natriuretic peptide concentration is variable among treated HF patients and rarely does it fall back into the normal reference range. Most treatment studies in this review reported decreases of about 40 percent and none exceeded 80 percent for any medication or B-type natriuretic peptide. Considering the large CV_I_ for both BNP (44 percent) and NT-proBNP (35 percent) this poses a major limitation for their use in monitoring therapy. However, there is good evidence, as described in Question 3 of this review that the risk of adverse events increases with higher concentrations of B-type natriuretic peptides. In view of this, and the association of decreasing B-type natriuretic peptide concentration with drug therapy, B-type natriuretic peptides show promise for use in optimizing therapy in a more objective way then querying symptoms. An analogy of B-type natriuretic peptide measurement in HF may be that of HbA1c in diabetes. The goal of therapy would be to stabilize the B-type natriuretic peptide levels and readjust therapy when significant changes occur. The results of the larger trials will provide more information on how the B-type natriuretic peptides can be used and possible target levels.

## Limitations to this Systematic Review

The studies selected for this systematic review are English-language only. The budget and timelines available were a limiting factor to obtaining, translating, and abstracting non-English trials. In addition, we did not undertake to collect additional unpublished studies or to provide results/data that were not presented in the published articles. Although contact with the original authors of the studies (to supplement the missing information from the included publications) could have compensated for many of the reporting challenges we encountered, this strategy was not feasible given the timeline of this systematic review. Our experience at the McMaster University Evidence-based Practice Center suggests that the majority of authors do not respond in a timely fashion, if at all. Additionally, efforts were not made to contact industry for unpublished studies. Not contacting authors of eligible studies for additional data and not attempting to locate unpublished studies (either by other authors/ experts or by industry) may introduce publication bias in this systematic review.

Another possible limitation to this systematic review was the restriction of the BNP and NT-proBNP methods to a subset; our rationale was to reduce heterogeneity amongst studies to assay. Also, we wished to maximize external validity of the findings of this study by selecting predominately assays that are widely available for use in clinical laboratories. Lastly, we limited the collection of determinants to only studies included for research Questions 2, 3, and 4 due to issues of feasibility and relevance.

### Comparison of Test Methods

Although this systematic review did not address the question of method differences it is important to note that differences do exist even among the methods selected for this review. All BNP methods included for this systematic review can be traced back to the original BNP method produced by Shionogi & Company in 1993. However, they vary in assay design and type of antibody (recognition to different epitopes) which results in quantitative measurement differences both systematically and randomly. Similarly, differences among the NT-proBNP methods include antibodies recognizing different epitopes and assay design. A systematic difference refers to a consistent difference between methods, independent of test sample or concentration, which can be applied without condition. However, there are also random differences between methods that cannot be clearly described and can vary with test sample and concentration. As a consequence these differences demonstrate a lack of standardization among B-type natriuretic peptide methods.

For example, the Triage BNP assay when compared to the Shionoria assay gives consistently higher values and the magnitude of difference increases with both concentration and severity of HF. ^218,^ ^219^ One study found that at 100 pg/mL using the Triage system, there was a bias of -26 pg/mL, -10 pg/mL and +7 pg/mL compared to the ADVIA Centaur and Access, and AxSYM assays, respectively. ^220^

Comparisons among NT-proBNP methods show considerably higher values for the Roche Diagnostics method versus the Biomedica method. ^164,^ ^218^ In a healthy population the difference is about 20 fold but decreases with severity of HF. ^164^ Similarly, the Christchurch method also produces lower values compared to the Roche Diagnostics method but not of the same magnitude (about 20 percent lower). ^147^ The bias between the early generation of the Roche assay (manual) and the present assay (Elecsys) is 2.7 fold. ^221^

A review of the issues that need to be addressed regarding standardization have been presented in the publication “Quality specifications for B-type natriuretic peptide assays”. ^198^ Consideration of these quality specifications and action to fulfill them will improve the comparability between assay methods. This will result in reduced heterogeneity among clinical studies especially with respect to cut point.

## Conclusions

The volume of literature that has been published on B-type natriuretic peptides in such a short period of time exceeds that of any other biomarker. The rate of publication is unprecedented and as such many publications did not fall within the timeline established for this systematic review. However, the number of studies included in this review exceeds those in other reviews published on B-type natriuretic peptides as well as including a wider range of questions and interpretations.

In this systematic review we were cognizant that the setting, test type, and method were important considerations when evaluating the applicability of B-type natriuretic peptides. Therefore, this review, in contrast to the few that have been published so far, established these criteria at the outset and groups studies accordingly.

### Determinants

Numerous determinants have been found to be associated with the B-type natriuretic peptides. However, the value of these associations for clinical use is not clear.

Future recommendations

- Further studies are required to assess the independent association of B-type natriuretic peptides with determinants, particularly as a function of HF severity.
- There is a need to design clinical studies to assess the magnitude of the effect determinants have on the diagnostic, prognostic and monitoring treatment roles of the B-type natriuretic peptides.

### Diagnostic Properties for HF

In all settings (ED, clinics, and primary care) both BNP and NT-proBNP have high sensitivity and lower specificity, suggesting these measurements could play a role in ruling out cardiac dysfunction. In addition, the measurement of B-type natriuretic peptide levels adds independent information to traditional diagnostic measures for ruling out cardiac dysfunction.

Future recommendations

- Future research is required to explore the variation in optimum cut points for clinical applications. In particular, the potential influence of clinical determinants and population subgroups should be evaluated with respect to these optimum cut points for ruling out the presence of disease.
- The reporting of diagnostic metrics requires standardization to enable consistent comparisons. Ideally, all studies could report diagnostic characteristics based on a common sensitivity, specificity, likelihood value or cut point.
- Further studies are needed to evaluate the diagnostic value of B-type natriuretic peptides in diastolic HF.
- Large multicentre studies with sufficient sample size are needed to allow for adequate multivariate analysis to understand the variables that account for low specificity.
- Further studies evaluating NT-proBNP in all settings are needed to more clearly establish its role for diagnosis.
- There is a need to evaluate the B-type natriuretic peptides in long term care settings as this has been identified as a significant gap in the literature.
- Future research should increase the number of studies evaluating both NT-proBNP and BNP within the same study to compare their relative merits.
- Further studies are needed that are designed to compare B-type natriuretic peptides with other diagnostic tests, particularly echocardiography.
- Future studies should address the subset of patients who present to the ED with complex clinical pictures or atypical clinical findings.

### Prognosis

BNP and NT-proBNP are consistent independent predictors of mortality and other cardiac composite endpoints for populations with risk of CAD, diagnosed CAD, and diagnosed HF.

There is insufficient evidence to make any conclusion as to the value of B-type natriuretic peptides for screening for HF.

Future recommendations

- Future research should compare the relative merits of BNP and NT-proBNP, as well as focus on whether there are differences in prognostic value for persons with HF.
- Conduct studies in acutely ill HF patients and compare predictive abilities of B-natriuretic type peptides at baseline relative to predischarge levels.
- Compare the relative merits of BNP and NT-proBNP, as well as focus on whether there are differences in prognostic value for persons with and without prior cardiac surgery in populations who are at risk for CAD or who have CAD.
- Future research should explore the relative merits of B-type natriuretic peptides compared to and combined with other markers of cardiac dysfunction to predict future outcomes.
- Large multicentre studies with sufficient sample size are needed to allow for adequate multivariate analysis and adjustment of determinants.
- As more studies become available that can be grouped together, meta-analysis of these would be useful to provide information on the overall predictive effect of B-type natriuretic peptides for cardiac events.

### Monitoring Treatment

There is insufficient evidence to demonstrate that BNP or NT-proBNP levels show change in response to therapies to manage stable chronic HF patients.

Future recommendations

- There is a need for large randomized trials to show whether therapy guided by increases and decreases in B-type natriuretic peptides affect outcome.
- Studies should be conducted to assess optimal timing for B-type natriuretic peptide testing for serial monitoring in stable chronic HF patients.
- Further research is needed to investigate if there are determinants of the biological variation that can be controlled for.