# Appendix E: Technical Expert Panel

Robert Christenson, PhD, DABCC, FACB

Professor

Director of Rapid Response Laboratories

University of Maryland School of Medicine

John G. Cleland, MD

Academic Department of Cardiology

Castle Hill Hospital

Carla Herrerias, BS, MPH

Clinical Research Analyst

American College of Chest Physicians

Allan Jaffe, MD

Cardiovascular Diseases

Mayo Medical School/Clinic

Ijaz Khan,

Associate Professor of Medicine

University of Maryland School of Medicine

Theresa McDonagh

Honorary Clinical Senior Lecturer

Royal Brompton Hospital

Thomas Moyer

Mayo Clinic

Rochester, Minnesota

Mark Richards

Professor

Christchurch School of Medicine and Health Sciences

Scott Silvers, MD

Assistant Professor of Medicine

Mayo Clinic

Vincenza Snow

American College of Physicians

## Peer Reviewers

Fred Apple, PhD, University of Minnesota School of Medicine, Minneapolis, MN, USA

Brad Brimhall, MD, MPH, University of Colorado Hospital, Denver, CO, USA

Robert Christenson, PhD, DABCC, FACB, University of Maryland School of Medicine, Baltimore, MD, USA

John G. Cleland MD, Castle Hill Hospital, Kingston upon Hull, UK

Jenny Doust, BMBS, FRACGP, University of Queensland, Herston, Queensland, Australia

Carla Herrerias, BS, MPH, American College of Chest Physicians, Northbrook, IL, USA

Ijaz Khan, MD, University of Maryland School of Medicine, Baltimore, MD, USA

Stephen C. Mockrin, Ph.D., National Institutes of Health, Bethesda, MD, USA

Amir Qaseem, MD, PhD, MHA, American College of Physicians, Philadelphia, PA, USA

Scott Silvers, MD, Mayo Clinic, Jacksonville, FL, USA

Wilson Tang, MD, FACC, Cleveland Clinic Foundation, Cleveland OH, USA

David Atkins, MD, MPH, Agency for Healthcare Research and Quality, Rockville, MD, USA,

### Structured format for collecting referee comments

We are pleased that you have agreed to review this interim report and thank you in advance for your time. We greatly value your feedback and have provided a series of questions to collect your comments. We have structured these queries into two parts: the first asks for your global impressions of the report and the second part concerns specific components of the systematic review. Lastly, we provide a section for you to write any additional comments that we did not directly probe.

Please note that we are constrained to the format and style of the report as prescribed by AHRQ publication guidelines. However, within this framework, we also ask that you comment on the style and format of the report for purposes of disseminating these findings.

Please complete this form providing as much information as possible including any references or website links. Thank you again for reviewing this report.

### Part I - General comments for the AHRQ report

1 Is the Abstract clear and does it provide the pertinent findings?
2 Would you like to see the Executive Summary highlighting different information? Is there information that is excessive or lacking?
3 Is the information in the introduction (Chapter 1) sufficient background to prepare the reader for grasping the complexities of the topic and research questions being undertaken in the systematic review?
4 Does the analytic framework convey the essence of how the report was conceptualized?
5 Were the selection criteria appropriate and clearly presented? Do you have any concerns about them and how they may have affected the relevance of the report?
6 Was there conceptual clarity and methodological rigor? (clarity of assumptions and results, treatment of literature, logical reasoning)
7 Do you have any general concerns about the applicability of this report?
8 What are the strengths of this report or those components you valued most?

### Part II - Question specific section comments for the AHRQ report

Study Identification

- Is there a thorough search for relevant data using appropriate resources?
- Are there unbiased explicit searching strategies that are appropriately matched to the question?

Study Selection

- Are appropriate inclusion and exclusion criteria used to select articles?
- Are selection criteria applied in a manner that limits bias?
- Are efforts made to identified unpublished data, if this is appropriate?
- Are major changes in selection criteria avoided during the review process?
- Are reasons for excluding studies from the report stated?

Appraisal of Studies

- Is the validity of individual studies addressed in a reliable manner?
- Are important parameters (e.g., setting, study population, study design) that could affect study results systematically addressed?

Data Collection

- Is there a minimal amount of missing information regarding outcomes and other variables considered key to interpretation of results?
- Are efforts made to reduce bias in the data collection process?

Data Synthesis

- Are important parameters, such as study designs, considered in the synthesis?
- Are reasonable decisions made concerning whether and how to combine the data?
- Are results sensitive to changes in the way the analysis was done?
- Is precision of results reported?

Discussion

- Are limitations and inconsistencies of studies stated?
- Are limitations of the review process stated?
- Are review finding integrated within the context of relevant indirect evidence?
- Are implications for research discussed
- Are implications for practice discussed?

Conclusions

- Are conclusions supported by the data reviewed?
- Are plausible competing explanations of observed effects addressed?
- Is evidence appropriately interpreted as inconclusive (no evidence of effect) or as showing a particular strategy did not work (evidence of no effect)?
- Are important considerations for decision makers identified, including values and contextual factors that might influence decisions?
- Is a summary of pertinent findings provided?

Future Recommendations

- Are the future directions described relevant?

Open Comments

- Are there any other comments or suggestions you would like to make ?

This is the end

Thank you for your expertise in reviewing this report for us.