# Appendix D: Excluded Studies

Abdulla H H.M. The natriuretic peptides: universal volume controllers. Medical Hypotheses. 2001;56(4):451-453. Excluded because not a report of a primary study. [pmid: 11339846].
Abe S, Okura Y, Hoyano M, Kazama R, Watanabe S, Ozawa T, et al. Plasma concentrations of cytokines and neurohumoral factors in a case of fulminant myocarditis successfully treated with intravenous immunoglobulin and percutaneous cardiopulmonary support. Circulation Journal. 2004;68(12):1223-1226. Excluded because this is a case report or series with 10 subjects. [pmid: 15564712].
Abraham WT. Physiology and therapeutic implications of natriuretic peptides in heart failure. Heart Failure. 1996;12(2):55-72. Excluded because not a report of a primary study.
Abraham WT. Natriuretic peptides in heart failure. Prevention & Management of Congestive Heart Failure. 1998;4(2):23-33. Excluded because not a report of a primary study.
Abraham W, Lowes B, Ferguson D, Odom J, Kim J, Robertson A, et al. Systemic hemodynamic, neurohormonal, and renal effects of a steady-state infusion of human brain natriuretic peptide in patients with hemodynamically decompensated heart failure. Journal of Cardiac Failure. 1998;4(1):37-44. Excluded because adult blood not measured. [pmid: 9573502].
Adams KF Jr. Are angiotensin-converting enzyme inhibitors and beta-blockers making an impact on the epidemiology of heart failure?. Current Cardiology Reports. 2004;6(3):162-168. Excluded because not a report of a primary study. [pmid: 15075049].
Adams J. Markers to define ischemia: Are they ready for prime time use in patients with acute coronary syndromes?. Current Cardiology Reports. 2004;6(4):253-258. Excluded because not a report of a primary study. [pmid: 15182599].
Afzal A, Brawner C, Keteyian SJ. Exercise training in heart failure. Progress in Cardiovascular Diseases. 1998;41(3):175-190. Excluded because not a report of a primary study. [pmid: 9872605].
Aggarwal A D.M. Neurohormonal assessment of cardiac function. Coronary Artery Disease. 2002;13(8):415-419. Excluded because not a report of a primary study. [pmid: 12544715].
Aghababian R G.C. Acutely decompensated heart failure: Opportunities to improve care outcomes in the emergency department. Reviews in Cardiovascular Medicine. 2002;3(SUPPL. 4):S1-S2. Excluded because not a report of a primary study. [pmid: 12508806].
Akaji K, Tatsumi T, Yoshida M, Kimura T, Fujiwara Y, and Kiso Y. Synthesis of cystine-peptide by a new disulphide bond-forming reaction using the silyl chloride-sulphoxide system. Journal of the Chemical Society - Series Chemical Communications 1991;(pp 167–168):167–168. Excluded because adult blood not measured
Akaji K, Tatsumi T, Yoshida M, Kimura T, Fujiwara Y, Kiso Y. Disulfide bond formation using the silyl chloride-sulfoxide system for the synthesis of a cystine peptide. Journal of the American Chemical Society. 1992;114(11):4137-4143. Excluded because adult blood not measured.
Akama H B.P. The kidney in heart failure: Vasodilator-natriuretic systems. Nephrology. 1997;3(4):297-308. Excluded because not a report of a primary study.
Akashi Y, Musha H, Nakazawa K, Miyake F, Akashi Y, Musha H, et al. Plasma brain natriuretic peptide in takotsubo cardiomyopathy. Qjm. 2004;97(9):599-607. Excluded because this is a case report or series with 10 subjects. [pmid: 15317929].
Akashi Y, Nakazawa K, Sakakibara M, Miyake F, Sasaka K, Akashi YJ, et al. Reversible left ventricular dysfunction “takotsubo” cardiomyopathy related to catecholamine cardiotoxicity. Journal of Electrocardiology. 2002;35(4):351-356. Excluded because not a report of a primary study. [pmid: 12395363].
Akashi Y, Tejima T, Sakurada H, Matsuda H, Suzuki K, Kawasaki K, et al. Left ventricular rupture associated with takotsubo cardiomyopathy. Mayo Clinic Proceedings. 2004;79(6):821-824. Excluded because this is a case report or series with 10 subjects. [pmid: 15182100].
Akazawa H I. Too much Csx/Nkx2-5 is as bad as too little?. Journal of Molecular & Cellular Cardiology. 2003;35(3):227-229. Excluded because not a report of a primary study. [pmid: 12676537].
Akiba T, Tachibana K, Togashi K, Hiroe M, Marumo F, Akiba T, et al. Plasma human brain natriuretic peptide in chronic renal failure. Clinical Nephrology. 1995;44(Suppl 1):S61-S64. Excluded because BNP assay method is not an included one. [pmid: 8608666].
Ala-Kopsala M, Magga J, Peuhkurinen K, Leipala J, Ruskoaho H, Leppaluoto J, et al. Molecular heterogeneity has a major impact on the measurement of circulating N-terminal fragments of A- and B-type natriuretic peptides. Clinical Chemistry. 2004;50(9):1576-1588. Excluded because BNP assay method is not an included one. [pmid: 15265819].
Alehagen U, Lindstedt G, Eriksson H, Dahlstrom U, Alehagen ULGEHaDU. Utility of the amino-terminal fragment of pro-brain natriuretic peptide in plasma for the evaluation of cardiac dysfunction in elderly patients in primary health care. Clinical Chemistry. 2003;49(8):1337-1346. Excluded because BNP assay method is not an included one. [pmid: 12881450].
Almenar L, Hervas I, Martinez-Dolz L, Rueda J, Arnau M, Osa A, et al. The value of brain natriuretic peptide for the diagnosis of heart transplant rejection. Transplantation Proceedings. 2002;34(1):174-175. Excluded because not a report of a primary study. [pmid: 11959236].
Altemose G, Gritsus V, Jeevanandam V, Goldman B, Margulies K, Altemose G, et al. Altered myocardial phenotype after mechanical support in human beings with advanced cardiomyopathy. Journal of Heart & Lung Transplantation. 1997;16(7):765-773. Excluded because adult blood not measured. [pmid: 9257259].
Alvelos M, Ferreira A, Bettencourt P, Serrao P, Pestana M, Cerqueira-Gomes M, et al. The effect of dietary sodium restriction on neurohumoral activity and renal dopaminergic response in patients with heart failure. European Journal of Heart Failure. 2004;6(5):593-599. Excluded because adult blood not measured. [pmid: 15302007].
Anan F, Takahashi N, Ooie T, Hara M, Yoshimatsu H, Saikawa T, et al. Candesartan, an angiotensin II receptor blocker, improves left ventricular hypertrophy and insulin resistance. Metabolism: Clinical & Experimental. 2004;53(6):777-781. Excluded because this is a case report or series with 10 subjects. [pmid: 15164328].
Anderson H, Wang F, Gardner D, Anderson HD, Wang FaGDG. Role of the epidermal growth factor receptor in signaling strain-dependent activation of the brain natriuretic peptide gene. Journal of Biological Chemistry. 2004;279(10):9287-9297. Excluded because adult blood not measured. [pmid: 14645255].
Anderson T. The birth of love. Practising Midwife. 2000;3(3):4-5. Excluded because not a report of a primary study.
Andreassi M, Del Ry S, Palmieri C, Clerico A, Biagini A, Giannessi D. Up-regulation of ‘clearance’ receptors in patients with chronic heart failure: A possible explanation for the resistance to biological effects of cardiac natriuretic hormones. European Journal of Heart Failure. 2001;3(4):407-414. Excluded because BNP assay method is not an included one. [pmid: 11511425].
Anker S, Coats A, Anker S, Coats AJ. Plasma brain natriuretic peptide as an indicator of left ventricular systolic function and long-term survival after acute myocardial infarction. Circulation. 2001;95(2):538-539. Excluded because not a report of a primary study. [pmid: 9008480].
Anker SR. The syndrome of cardiac cachexia. International Journal of Cardiology. 2002;85(1):51-66. Excluded because not a report of a primary study. [pmid: 12163209].
Anker S, Steinborn W, Strassburg S. Cardiac cachexia. Annals of Medicine. 2004;36(7):518-529. Excluded because not a report of a primary study. [pmid: 15513302].
Apple F, Trinity E, Steen J, Prawer S, Wu A, Apple FS, et al. BNP test utilization for CHF in community hospital practice. Clinica Chimica Acta. 2003;328(12):191-193. Excluded because not a report of a primary study.
Arad M, Elazar E, Shotan A, Klein R, Rabinowitz B, Arad M, et al. Brain atrial natriuretic peptides in patients with ischemic heart disease with and without heart failure. Cardiology. 1996;87(1):12-17. Excluded because BNP assay method is not an included one. [pmid: 8631038].
Arai M, Matsui H, Periasamy M. Sarcoplasmic reticulum gene expression in cardiac hypertrophy and heart failure. Circulation Research. 1994;74(4):555-564. Excluded because not a report of a primary study. [pmid: 8137493].
Arakawa N, Nakamura M, Aoki H, Hiramori K, Arakawa N, Nakamura M, et al. Relationship between plasma level of brain natriuretic peptide and myocardial infarct size. Cardiology. 1994;85(5):334-340. Excluded because BNP assay method is not an included one. [pmid: 7850823].
Arakawa N, Nakamura M, Aoki H, Hiramori K, Arakawa N, Nakamura M, et al. Plasma brain natriuretic peptide concentrations predict survival after acute myocardial infarction. Journal of the American College of Cardiology. 1996;27(7):1656-1661. Excluded because BNP assay method is not an included one. [pmid: 8636550].
Arakawa N, Nakamura M, Endo H, Sugawara S, Suzuki T, Hiramori K, et al. Brain natriuretic peptide and cardiac rupture after acute myocardial infarction. Internal Medicine. 2001;40(3):232-236. Excluded because not a report of a primary study. [pmid: 11310490].
Arendt R, Schmoeckel M, Wilbert-Lampen U, Heucke L, Werdan K, Arendt R, et al. Neurohumoral regulation of endothelin release by opioid and natriuretic peptides. Transplantation Proceedings. 1995;27(3):2092-2096. Excluded because adult blood not measured. [pmid: 7792896].
Arjamaa O, Makinen T, Turunen L, Huttunen P, Leppaluoto J, Vuolteenaho O, et al. Are the blood pressure and endocrine responses of healthy subjects exposed to cold stress altered by an acutely increased sodium intake?. European Journal of Applied Physiology. 2001;84(1-2):48-53. Excluded because adult blood not measured. [pmid: 11394253].
Arjamaa O, Makinen T, Turunen L, Huttunen P, Leppaluoto J, Vuolteenaho O, et al. Blood pressure and endocrine responses of healthy subjects in cold pressor test after acutely increased dietary sodium intake. Journal of Physiological Anthropology & Applied Human Science. 2001;20(3):207-212. Excluded because BNP assay method is not an included one. [pmid: 11499168].
Aronson D, Burger A, Aronson DaBAJ. Intravenous nesiritide (human B-type natriuretic peptide) reduces plasma endothelin-1 levels in patients with decompensated congestive heart failure. American Journal of Cardiology. 1908;90(4):435-438. Excluded because BNP assay method is not an included one. [pmid: 12161240].
Aronson D, Burger A, Aronson DaBAJ. Neurohumoral activation and ventricular arrhythmias in patients with decompensated congestive heart failure: role of endothelin. Pacing & Clinical Electrophysiology. 2003;26(3):703-710. Excluded because BNP assay method is not an included one. [pmid: 12698670].
Aronson D, Burger A, Aronson DaBAJ. Prognosis assessment in patients with decompensated heart failure. Simple clinical parameters or neurohormonal factors. Italian Heart Journal: Official Journal of the Italian Federation of Cardiology. 2004;5(7):494-497. Excluded because not a report of a primary study. [pmid: 15487265].
Ationu A, Burch M, Elliott M, Carter N, Ationu A, Burch M, et al. Brain natriuretic peptide and fluid volume homeostasis--studies during cardiopulmonary bypass surgery. Clinical Autonomic Research. 1993;3(4):275-280. Excluded because BNP assay method is not an included one. [pmid: 8292884].
Ationu A, Burch M, Singer D, Littleton P, Carter N, Ationu A, et al. Cardiac transplantation affects ventricular expression of brain natriuretic peptide. Cardiovascular Research. 1993;27(2):188-191. Excluded because BNP assay method is not an included one. [pmid: 8472270].
Ationu A, Carter N, Ationu A, Carter ND. Brain and atrial natriuretic peptide plasma concentrations in normal healthy children. British Journal of Biomedical Science. 1993;50(2):92-95. Excluded because BNP assay method is not an included one. [pmid: 8219925].
Attenhofer Jost C, Oechslin E, Seifert B, Maly F, Fatio R, Turina J, et al. Remodelling after surgical repair of atrial septal defects within the oval fossa. Cardiology in the Young. 2002;12(6):506-512. Excluded because adult blood not measured. [pmid: 12635997].
Auvin-Guette C, Baraguey C, Blond A, Pousset J, Bodo B. Cyclogossine B, a cyclic octapeptide from Jatropha gossypifolia. Journal of Natural Products. Nov. 1997;60(11):1155-7. Excluded because adult blood not measured.
Baggish A, Cameron R, Anwaruddin S, Chen A, Krauser D, Tung R, et al. A clinical and biochemical critical pathway for the evaluation of patients with suspected acute congestive heart failure: The proBNP Investigation of Dyspnea in the Emergency Department (PRIDE) algorithm. Critical Pathways in Cardiology: A Journal of Evidence-Based Medicine. 2004;3(4):171-176. Excluded because not a report of a primary study.
Bail D, Kofler M, Ziemer G, Bail D, Kofler M, Ziemer G. Brain natriuretic peptide (BNP) in patients undergoing coronary artery bypass grafting. Thoracic & Cardiovascular Surgeon. 2004;52(3):135-140. Excluded because BNP assay method is not an included one. [pmid: 15192772].
Bank A, Shammas R, Mullen K, Chuang PP. Effects of short-term forearm exercise training on resistance vessel endothelial function in normal subjects and patients with heart failure. Journal of Cardiac Failure. 1998;4(3):193-201. Excluded because BNP assay method is not an included one. [pmid: 9754590].
Barclay T, Kim J, Lee AJ. Nesiritide for acute decompensated heart failure. Journal of Pharmacy Technology. 2002;18(6):295-304. Excluded because not a report of a primary study.
Barkoukis H, Fiedler K, Lerner E, Beyer PL. Solution center. A combined high-fiber, low-glycemic index diet normalizes glucose tolerance and reduces hyperglycemia and hyperinsulinemia in adults with hepatic cirrhosis. Journal of the American Dietetic Association. 2002;102(10):1503-1508. Excluded because BNP assay method is not an included one. [pmid: 12396175].
Barleta G, Lazzeri C, Del Bene R, Messeri G, Sbarba A, Mannella M, et al. Low-dose C-type natriuretic peptide does not affect cardiac and renal function in humans. Hypertension. 1998;31(3):802-808. Excluded because BNP assay method is not an included one. [pmid: 9495264].
Barletta G, Stefani L, Del Bene R, Fronzaroli C, Vecchiarino S, Lazzeri C, et al. Effects of exercise on natriuretic peptides and cardiac function in man. [see comment]. International Journal of Cardiology. 1998;65(3):217-225. Excluded because BNP assay method is not an included one. [pmid: 9740477].
Barlow J J.F. New rapid laboratory test for congestive heart failure B-type natriuretic peptide (BNP). South Dakota Journal of Medicine. 2002;55(11):467. Excluded because not a report of a primary study. [pmid: 12449586].
Baroletti S, Wahlstrom H, Baroletti SA, Wahlstrom HD. Interaction between nesiritide and a heparin coated pulmonary artery line during an infusion for decompensated heart failure. Pharmacotherapy. 2004;24(11):1634-1637. Excluded because this is a case report or series with 10 subjects. [pmid: 15537565].
Barst R, McGoon M, Torbicki A, Sitbon O, Krowka M, Olschewski H, et al. Diagnosis and differential assessment of pulmonary arterial hypertension. Journal of the American College of Cardiology. 2004;43(12 SUPPL.):40S-47S. Excluded because not a report of a primary study. [pmid: 15194177].
Baughman KL. B-type natriuretic peptide - A window to the heart. New England Journal of Medicine. 2002;347(3):158-159. Excluded because not a report of a primary study. [pmid: 12124403].
Bayerle-Eder M, Zangeneh M, Kreiner G, Raffesberg W, Nowotny P, Vierhapper H, et al. ANP but not BNP reflects early left diastolic dysfunction in type 1 diabetics with myocardial dysinnervation. Hormone & Metabolic Research. 2003;35(5):301-307. Excluded because BNP assay method is not an included one. [pmid: 12916000].
Bech J, Svendsen K, Nielsen C, Pedersen E, Bech J, Svendsen K, et al. The systemic and renal response to NO inhibition is not modified by angiotensin-II-receptor blockade in healthy humans. Nephrology Dialysis Transplantation. 1999;14(3):641-647. Excluded because BNP assay method is not an included one.
Belenky A, Smith A, Zhang B, Lin S, Despres N, Wu A, et al. The effect of class-specific protease inhibitors on the stabilization of B-type natriuretic peptide in human plasma. Clinica Chimica Acta. 2004;340(12):163-172. Excluded because adult blood not measured.
Bell DSH. Treatment of heart failure in patients with diabetes: Clinical update. Ethnicity & Disease 2002; 12(1). Excluded because not a report of a primary study
Bentzen H, Pedersen R, Nyvad O, Pedersen E, Bentzen H, Pedersen R, et al. Influence of training habits on exercise-induced changes in plasma atrial and brain natriuretic peptide and urinary excretion of aquaporin-2 in healthy man. Scandinavian Journal of Clinical & Laboratory Investigation. 2002;62(7):541-551. Excluded because BNP assay method is not an included one. [pmid: 12512745].
Bentzen H, Pedersen R, Pedersen H, Nyvad O, Pedersen E, Bentzen HPRS, et al. Abnormal rhythmic oscillations of atrial natriuretic peptide and brain natriuretic peptide in heart failure. Clinical Science. 2003;104(3):303-312. Excluded because BNP assay method is not an included one. [pmid: 12605591].
Bentzen H, Pedersen R, Nyvad O, Pedersen E, Bentzen HPRS, Nyvad OaPEB. Effect of exercise on natriuretic peptides in plasma and urine in chronic heart failure. International Journal of Cardiology. 2004;93(23):121-130. Excluded because BNP assay method is not an included one. [pmid: 14975537].
Berendes E, Schmidt C, Van Aken H, Hartlage M, Rothenburger M, Wirtz S et al. A-type and B-type natriuretic peptides in cardiac surgical procedures. Anesthesia & Analgesia 98(1):11–19. Excluded because BNP assay method is not an included one
Berendes E, Schmidt C, Van Aken H, Hartlage M, Wirtz S, Reinecke H, et al. Reversible cardiac sympathectomy by high thoracic epidural anesthesia improves regional left ventricular function in patients undergoing coronary artery bypass grafting: a randomized trial.[see comment]. Archives of Surgery. 2003;138(12):1283-1290. Excluded because BNP assay method is not an included one. [pmid: 14662525].
Berendes E, Van Aken H, Raufhake C, Schmidt C, Assmann G, Walter M, et al. Differential secretion of atrial and brain natriuretic peptide in critically ill patients. Anesthesia & Analgesia. 2001;93(3):676-682. Excluded because BNP assay method is not an included one. [pmid: 11524340].
Berendes E, Walter M, Cullen P, Prien T, Van Aken H, Horsthemke J, et al. Secretion of brain natriuretic peptide in patients with aneurysmal subarachnoid haemorrhage. Lancet. 2001;349(9047):245-249. Excluded because BNP assay method is not an included one. [pmid: 9014912].
Berger R, Huelsman M, Strecker K, Bojic A, Moser P, Stanek B, et al. B-type natriuretic peptide predicts sudden death in patients with chronic heart failure.[see comment]. Circulation. 2005;105(20):2392-2397. Excluded because BNP assay method is not an included one. [pmid: 12021226].
Berton GP. Risk stratification after acute myocardial infarction: Role of neurohormones inflammatory markers and albumin excretion rate. Italian Heart Journal: Official Journal of the Italian Federation of Cardiology. 2003;4(5):295-304. Excluded because not a report of a primary study. [pmid: 12848085].
Bettencourt P Paulo. NT-proBNP and BNP: biomarkers for heart failure management. European Journal of Heart Failure. 2003;6(3):359-363. Excluded because not a report of a primary study. [pmid: 14987589].
Bevilacqua M, Vago T, Baldi G, Norbiato G, Masson S, Latini R, et al. Analytical agreement and clinical correlates of plasma brain natriuretic peptide measured by three immunoassays in patients with heart failure. Clinical Chemistry. 1997;43(12):2439-2440. Excluded because not a report of a primary study. [pmid: 9439475].
Bhalla S, Robitaille L, Nemer M, Bhalla S, Robitaille L, Nemer M. Cooperative activation by GATA-4 and YY1 of the cardiac B-type natriuretic peptide promoter. Journal of Biological Chemistry. 2001;276(14):11439-11445. Excluded because adult blood not measured. [pmid: 11279028].
Bhat G, Costea A, Bhat GaCA. Reversibility of medically unresponsive pulmonary hypertension with nesiritide in a cardiac transplant recipient. ASAIO Journal. 2003;49(5):608-610. Excluded because adult blood not measured. [pmid: 14524574].
Bilkovski R, Kulstad E, Bilkovski RN, Kulstad EB. Elevations of B-type natriuretic peptide in pulmonary embolism: a case series. Journal of Emergency Medicine. 2003;25(4):415-420. Excluded because this is a case report or series with 10 subjects. [pmid: 14654183].
Billiot E, Macossay J, Thibodeaux S, Shamsi S, Warner I, Billiot E, et al. Chiral separations using dipeptide polymerized surfactants: effect of amino acid order. Analytical Chemistry. 1998;70(7):1375-1381. Excluded because adult blood not measured. [pmid: 9553495].
Billiot F, Billiot E, Warner I, Billiot FHBEJ, Warner IM. Depth of penetration of binaphthyl derivatives into the micellar core of sodium undecenoyl leucyl-leucinate surfactants. Journal of Chromatography. 2003;A.. 950(12):233-239. Excluded because adult blood not measured.
Birney M D.G. Atrial natriuretic peptide: a hormone with implications for clinical practice. Heart & Lung: Journal of Critical Care. 1990;19(2):174-185. Excluded because not a report of a primary study.
Bittner V. Exercise testing in heart failure: Maximal, submaximal, or both?. Journal of the American College of Cardiology. 2003;42(1):123-125. Excluded because not a report of a primary study. [pmid: 12849671].
Blom J, 't Hof A, Henriques J, Hans GJ, Slingerland R, Hoorntje J, et al. NT-proBNP: a marker for successful myocardial reperfusion in AMI patients treated with primary percutaneous coronary intervention. European Journal of Heart Failure. 2004;6(6):749-752. Excluded because BNP assay method is not an included one. [pmid: 15542411].
Blommendahl J, Janas M, Laine S, Miettinen A, Ashorn P. Comparison of procalcitonin with CRP and differential white blood cell count for diagnosis of culture-proven neonatal sepsis. Scandinavian Journal of Infectious Diseases. 2002;34(8):620-622. Excluded because adult blood not measured. [pmid: 12238581].
Bobadilla R, Oppelt T, Hirshy T, Bobadilla RV, Oppelt TF, Hirshy TC. Nesiritide treatment of noncardiogenic pulmonary edema. Annals of Pharmacotherapy. 2003;37(4):530-533. Excluded because adult blood not measured. [pmid: 12659610].
Bock JL. Test strategies for the detection of myocardial damage. Clinics in Laboratory Medicine. 2002;22(2):357-375. Excluded because not a report of a primary study. [pmid: 12134465].
Boehm M E.G. Clinical implications of basic research. Angiotensin-converting enzyme 2 -- a new cardiac regulator. New England Journal of Medicine. 1920;347(22):1795-1797. Excluded because not a report of a primary study. [pmid: 12456857].
Bokesch H, Pannell L, Cochran P, Sowder R, McKee T, Boyd MR. A novel anti-HIV macrocyclic peotide from Palicourea condensata. Journal of Natural Products. Feb. 2001;64(2):249-50. Excluded because adult blood not measured. [pmid: 11430013].
Bonatti J, Dichtl W, Lercher A, Puschendorf B, Bonatti J, Dichtl W, et al. Natriuretic peptides stimulate cyclic guanosine monophosphate production in human saphenous vein and internal mammary artery. European Journal of Cardio-Thoracic Surgery. 2000;17(2):175-181. Excluded because adult blood not measured. [pmid: 10731654].
Boonen S, Broos P, Verbeke G, Aerssens J, Van Herck E, Jans I, et al. Calciotropic hormones and markers of bone remodeling in age-related (type II) femoral neck osteoporosis: alterations consistent with secondary hyperparathyroidism-induced bone resorption. Journals of Gerontology. 1997;Series A(5):M286-M293. Excluded because BNP assay method is not an included one. [pmid: 9310082].
Borghi C, Esposti D, Immordino V, Cassani A, Boschi S, Bovicelli L, et al. Relationship of systemic hemodynamics, left ventricular structure and function, and plasma natriuretic peptide concentrations during pregnancy complicated by preeclampsia. American Journal of Obstetrics & Gynecology. 2000;183(1):140-147. Excluded because BNP assay method is not an included one. [pmid: 10920322].
Boxer R, Yang S, Hager WD. Congestive heart failure and the elderly. Connecticut Medicine. 2003;67(8):497-503. Excluded because not a report of a primary study. [pmid: 14587131].
Braddock MR. Chronic stress and stress disorders: the effects of stress system malfunction. Surgical Technologist. 2002;34(11):18-25. Excluded because not a report of a primary study.
Braunschweig F, Linde C, Eriksson M, Hofman-Bang C, Ryden L, Braunschweig F, et al. Continuous haemodynamic monitoring during withdrawal of diuretics in patients with congestive heart failure.[see comment]. European Heart Journal. 2002;23(1):59-69. Excluded because this is a case report or series with 10 subjects. [pmid: 11741363].
Braunschweig F, Sorensen J, Von Bibra H, Olsson A, Ryden L, Langstrom B, et al. Effects of biventricular pacing on myocardial blood flow and oxygen consumption using carbon-11 acetate positron emission tomography in patients with heart failure. American Journal of Cardiology. 2003;92(1):95-99. Excluded because this is a case report or series with 10 subjects. [pmid: 12842260].
Briest W. Do we have a new early marker of chronic transplant dysfunction now?. Cardiovascular Research. 2002;54(3):492-494. Excluded because not a report of a primary study. [pmid: 12031693].
Briguori C, Betocchi S, Manganelli F, Gigante B, Losi M, Ciampi Q, et al. Determinants and clinical significance of natriuretic peptides and hypertrophic cardiomyopathy.[see comment]. European Heart Journal. 2001;22(15):1328-1336. Excluded because BNP assay method is not an included one. [pmid: 11465965].
Brookes C, Kemp M, Hooper J, Oldershaw P, Moat N, Brookes C, et al. Plasma brain natriuretic peptide concentrations in patients with chronic mitral regurgitation. Journal of Heart Valve Disease. 1997;6(6):608-612. Excluded because BNP assay method is not an included one. [pmid: 9427129].
Brooks D S.D. From mechanisms and targets to risk assessment and treatment of cardiovascular and renal diseases. Current Opinion in Pharmacology. 2002;2(2):119-120. Excluded because not a report of a primary study.
Brueckmann M, Bertsch T, Hoffmann U, Lang S, Kaden J, Wolpert C, et al. N-terminal pro-atrial natriuretic peptide as a biochemical marker of long-term interventional success after radiofrequency catheter ablation of paroxysmal supraventricular tachyarrhythmias. Clinical Chemistry & Laboratory Medicine. 2004;42(8):896-902. Excluded because BNP assay method is not an included one. [pmid: 15387439].
Brunner-La Rocca H, Kaye D, Woods R, Hastings J, Esler M, Brunner-La Rocca H, et al. Effects of intravenous brain natriuretic peptide on regional sympathetic activity in patients with chronic heart failure as compared with healthy control subjects. Journal of the American College of Cardiology. 2001;37(5):1221-1227. Excluded because BNP used as treatment. [pmid: 11300426].
Brunner-La Rocca H, Woods R, Kaye D, Hastings J, Thomas C, Lambert E, et al. Divergent effects of ANP and BNP in acute heart failure: evidence for a putative BNP-selective receptor?. Journal of Hypertension. 2002;20(6):1195-1201. Excluded because adult blood not measured. [pmid: 12023691].
Bruun E C. The effect of Buserelin versus conventional antiandrogenic treatment in patients with T2-4NXM1 prostatic cancer. A prospective randomized multicentre phase III trial. The ‘Danish Buserelin Study Group’. Scand J Urol Nephrol. Aug. 1996;30(4):291-7. Excluded because adult blood not measured. [pmid: 8908651].
Buckley M, Marcus N, Yacoub M, Singer D, Buckley M, Marcus N, et al. Prolonged stability of brain natriuretic peptide: importance for non-invasive assessment of cardiac function in clinical practice. Clinical Science. 1998;95(3):235-239. Excluded because BNP assay method is not an included one. [pmid: 9730841].
Buckley M, Marcus N, Yacoub M, Buckley M, Marcus N, Yacoub MH. Cardiac peptide stability, aprotinin and room temperature: importance for assessing cardiac function in clinical practice. Clinical Science. 1999;97(6):689-695. Excluded because BNP assay method is not an included one. [pmid: 10585896].
Buckley M, Markandu N, Miller M, Sagnella G, MacGregor G, Buckley M, et al. Plasma concentrations and comparisons of brain and atrial natriuretic peptide in normal subjects and in patients with essential hypertension. Journal of Human Hypertension. 1993;7(3):245-250. Excluded because BNP assay method is not an included one. [pmid: 8345491].
Buckley M, Markandu N, Sagnella G, MacGregor G, Buckley M, Markandu N, et al. Brain and atrial natriuretic peptides: a dual peptide system of potential importance in sodium balance and blood pressure regulation in patients with essential hypertension. Journal of Hypertension. 1994;12(7):809-813. Excluded because BNP assay method is not an included one. [pmid: 7963510].
Buckley M, Saggar-Malik A, Markandu N, Sagnella G, MacGregor G, Buckley M, et al. Effects of changes in dietary sodium intake on plasma brain natriuretic peptide levels in patients with autosomal dominant polycystic kidney disease. Journal of Human Hypertension. 1996;10(6):415-416. Excluded because BNP assay method is not an included one. [pmid: 8872808].
Buckley M, Sethi D, Markandu N, Sagnella G, Singer D, MacGregor G, et al. Plasma concentrations and comparisons of brain natriuretic peptide and atrial natriuretic peptide in normal subjects, cardiac transplant recipients and patients with dialysis-independent or dialysis-dependent chronic renal failure. Clinical Science. 1992;83(4):437-444. Excluded because BNP assay method is not an included one. [pmid: 1330406].
Buckley M, Yacoub M, Singer D, Buckley M, Yacoub M, Singer DR. Investigation of the plasma concentrations and circulating forms of BNP and ANP in orthotopic cardiac transplant recipients. Journal of Human Hypertension. 1998;12(12):825-826. Excluded because BNP assay method is not an included one. [pmid: 9883703].
Burger A, Aronson D, Horton D, Burger M, Burger AJ, Aronson DHDP, et al. Comparison of the effects of dobutamine and nesiritide (B-type natriuretic peptide) on ventricular ectopy in acutely decompensated ischemic versus nonischemic cardiomyopathy. American Journal of Cardiology. 2003;91(11):1370-1372. Excluded because adult blood not measured. [pmid: 12767439].
Burger A D. Effect of vasoactive therapy on heart rate variability in patients with acutely decompensated congestive heart failure. American Journal of Cardiology. 1999;84(4):476-478. Excluded because adult blood not measured. [pmid: 10468094].
Burger A, Elkayam U, Neibaur M, Haught H, Ghali J, Horton D, et al. Comparison of the occurrence of ventricular arrhythmias in patients with acutely decompensated congestive heart failure receiving dobutamine versus nesiritide therapy. American Journal of Cardiology. 2001;88(1):35-39. Excluded because BNP assay method is not an included one. [pmid: 11423055].
Burger A, Horton D, LeJemtel T, Ghali J, Torre G, Dennish G, et al. Effect of nesiritide (B-type natriuretic peptide) and dobutamine on ventricular arrhythmias in the treatment of patients with acutely decompensated congestive heart failure: the PRECEDENT study. American Heart Journal. 2002;144(6):1102-1108. Excluded because BNP assay method is not an included one. [pmid: 12486437].
Burgher A, Aslan D, Laudi N, Bowman R, Burgher AH, Aslan DLNaBRJ. Use of brain natriuretic peptide to evaluate transfusion-related acute lung injury. Transfusion. 2004;44(10):1533-1534. Excluded because adult blood not measured. [pmid: 15383030].
Butler J, Emerman C, Peacock W, Mathur V, Young J, VMAC siBJECPW, et al. The efficacy and safety of B-type natriuretic peptide (nesiritide) in patients with renal insufficiency and acutely decompensated congestive heart failure. Nephrology Dialysis Transplantation. 2004;19(2):391-399. Excluded because adult blood not measured.
Califf RM. Cardiac markers in acute coronary syndromes - Refining our knowledge. European Heart Journal. 2003;24(2):136-137. Excluded because not a report of a primary study. [pmid: 12573270].
Campbell D, Aggarwal A, Esler M, Kaye D. Beta-blockers, angiotensin II, and ACE inhibitors in patients with heart failure. Lancet. 1920;358(9293):1609-1610. Excluded because not a report of a primary study. [pmid: 11716889].
Campbell D, Mitchelhill K, Schlicht S, Booth R, Campbell D, Mitchelhill K, et al. Plasma amino-terminal pro-brain natriuretic peptide: a novel approach to the diagnosis of cardiac dysfunction. Journal of Cardiac Failure. 2000;6(2):130-139. Excluded because BNP assay method is not an included one. [pmid: 10908087].
Campbell D, Munir V, Hennessy O, Dent A, Campbell D, Munir V, et al. Plasma amino-terminal pro-brain natriuretic peptide levels in subjects presenting to the Emergency Department with suspected acute coronary syndrome: possible role in selecting patients for follow up?. Internal Medicine Journal. 2001;31(4):211-219. Excluded because BNP assay method is not an included one. [pmid: 11456034].
Campbell D, Woodward M, Chalmers J, Colman S, Jenkins A, Kemp B, et al. Prediction of heart failure by amino terminal-pro-B-type natriuretic peptide and C-reactive protein in subjects with cerebrovascular disease. Hypertension. 2005;45(1):69-74. Excluded because BNP assay method is not an included one. [pmid: 15569851].
Campbell R, Ruggenenti P, Remuzzi G. Halting the progression of chronic nephropathy. Journal of the American Society of Nephrology. 2002;13(SUPPL. 3):S190-S195. Excluded because not a report of a primary study. [pmid: 12466313].
Canaan-Kuhl S, Jamison R, Myers B, Pratt R, Canaan-Kuhl S, Jamison R, et al. Identification of “B” receptor for natriuretic peptide in human kidney. [erratum appears in Endocrinology1992 Apr;130(4):2283]. Endocrinology. 1992;130(1):550-552. Excluded because adult blood not measured. [pmid: 1309350].
Cappellin E, Gatti R, Spinella P, De Palo C, Woloszczuk W, Maragno I, et al. Plasma atrial natriuretic peptide (ANP) fragments proANP (1-30) and proANP (31-67) measurements in chronic heart failure: a useful index for heart transplantation?. Clinica Chimica Acta. 2001;310(1):49-52. Excluded because BNP assay method is not an included one.
Cargill R, Barr C, Coutie W, Struthers A, Lipworth B, Cargill R, et al. C-type natriuretic peptide levels in cor pulmonale and in congestive heart failure. Thorax. 1994;49(12):1247-1249. Excluded because BNP assay method is not an included one. [pmid: 7878562]. [pmcid: 475334].
Cargill R, Clarkson P, MacDonald T, Lipworth B, Cargill R, Clarkson P, et al. Profound vagal reactions to brain natriuretic peptide. Journal of Molecular Medicine. 1995;73(3):149-150. Excluded because not a report of a primary study. [pmid: 7633953].
Cargill R, Coutie W, Lipworth B, Cargill R, Coutie W, Lipworth BJ. The effects of angiotensin II on circulating levels of natriuretic peptides. British Journal of Clinical Pharmacology. 1994;38(2):139-142. Excluded because BNP assay method is not an included one. [pmid: 7981014]. [pmcid: 1364859].
Cargill R, Lipworth B, Cargill R, Lipworth BJ. Pulmonary vasorelaxant activity of atrial natriuretic peptide and brain natriuretic peptide in humans. Thorax. 1995;50(2):183-185. Excluded because BNP assay method is not an included one. [pmid: 7701460]. [pmcid: 473921].
Cargill R, Lipworth B, Cargill R, Lipworth BJ. Acute effects of ANP and BNP on hypoxic pulmonary vasoconstriction in humans. British Journal of Clinical Pharmacology. 1995;40(6):585-590. Excluded because BNP assay method is not an included one. [pmid: 8703666]. [pmcid: 1365215].
Cargill R, Lipworth B, Cargill R, Lipworth BJ. Atrial natriuretic peptide and brain natriuretic peptide in cor pulmonale. Hemodynamic and endocrine effects. [see comment]. Chest. 1996;110(5):1220-1225. Excluded because BNP assay method is not an included one. [pmid: 8915224].
Cargill R, McFarlane L, Coutie W, Lipworth B, Cargill R, McFarlane L, et al. Acute neurohormonal responses to hypoxaemia in man. European Journal of Applied Physiology & Occupational Physiology. 1996;72(3):256-260. Excluded because BNP assay method is not an included one. [pmid: 8820895].
Cargill R, Struthers A, Lipworth B, Cargill R, Struthers A, Lipworth BJ. Comparative effects of atrial natriuretic peptide and brain natriuretic peptide on the aldosterone and pressor responses to angiotensin II in man. Clinical Science. 1995;88(1):81-86. Excluded because BNP assay method is not an included one. [pmid: 7705006].
Carrillo-Jimenez R, Treadwell T, Goldfine H, Buenano A, Lamas G, Hennekens C et al. Brain natriuretic peptide and HIV-related cardiomyopathy. AIDS Reader 50 A.D.; 12(11):501–503. Excluded because this is a case report or series with 10 subjects
Carson RJ. Clinical: the mechanisms involved in the initiation of term labour. Modern Midwife. 1997;7(7):12-16. Excluded because not a report of a primary study. [pmid: 9287666].
Carstens J, Jensen K, Pedersen EB. Effect of urodilatin infusion on renal haemodynamics, tubular function and vasoactive hormones. Clinical Science. 1997;92(4):397-407. Excluded because BNP assay method is not an included one. [pmid: 9176040].
Casco V, Veinot J, Kuroski de Bold M, Masters R, Stevenson M, de Bold A, et al. Natriuretic peptide system gene expression in human coronary arteries. Journal of Histochemistry & Cytochemistry. 2002;50(6):799-809. Excluded because adult blood not measured. [pmid: 12019296].
Casulari L, Costa K, Albuquerque R, Naves L, Suzuki K, Domingues L. Differential diagnosis and treatment of hyponatremia following pituitary surgery. Journal of Neurosurgical Sciences. 2004;48(1):11-18. Excluded because not a report of a primary study. [pmid: 15257260].
Cataliotti A, Malatino L, Jougasaki M, Zoccali C, Castellino P, Giacone G, et al. Circulating natriuretic peptide concentrations in patients with end-stage renal disease: role of brain natriuretic peptide as a biomarker for ventricular remodeling. Mayo Clinic Proceedings. 2001;76(11):1111-1119. Excluded because BNP assay method is not an included one. [pmid: 11702899].
Chaillous L, Lefevre H, Thivolet C, Boitard C, Lahlou N, Atlan-Gepner C, et al. Oral insulin administration and residual s-cell function in recent-onset type 1 diabetes: a multicentre randomised controlled trial. Lancet. 2000;356(9229):545-549. Excluded because BNP assay method is not an included one. [pmid: 10950231].
Chambers J, Francis D, Coats AJS. Recovery oxygen uptake and brain natriuretic peptide as markers of exercise capacity in chronic heart failure. Journal of Sports Sciences. 2000;18(7):490. Excluded because not a report of a primary study.
Chambers J J.S. Diagnosis and risk stratification of unstable angina and non ST-segment elevation myocardial infarction. Continuing Medical Education - Cardiology. 2002;2(1):15-29. Excluded because not a report of a primary study.
Chan R, Sealey J, Michelis M, Swan A, Pfaffle A, Devita M, et al. Renin-aldosterone system can respond to furosemide in patients with hyperkalemic hyporeninism. Journal of Laboratory and Clinical Medicine. 1998;132(3):229-235. Excluded because BNP assay method is not an included one. [pmid: 9735929].
Chanalaris A, Lawrence K, Townsend P, Davidson S, Jashmidi Y, Stephanou A, et al. Hypertrophic effects of urocortin homologous peptides are mediated via activation of the Akt pathway. Biochemical & Biophysical Research Communications. 2005;328(2):442-448. Excluded because adult blood not measured. [pmid: 15694367].
Chandar S, Pawsey C, Kritharides L. Diastolic heart failure: A clinical update. Medicine Today. 2001;2(10):22-30. Excluded because not a report of a primary study.
Chang R, Elatre W, Heywood J, Chang REWA, Heywood JT. Effect of nesiritide on length of hospital stay in patients with decompensated heart failure. Journal of Cardiovascular Pharmacology & Therapeutics. 2004;9(3):173-177. Excluded because BNP used as treatment. [pmid: 15378137].
Channick R, Simonneau G, Sitbon O, Robbins I, Frost A, Tapson V, et al. Effects of the dual endothelin-receptor antagonist bosentan in patients with pulmonary hypertension: a randomised placebo-controlled study. Lancet. 2001;358(9288):1119-1123. Excluded because adult blood not measured. [pmid: 11597664].
Charles C, Lainchbury J, Lewis L, Rademaker M, Richards A, Yandle T, et al. The role of adrenomedullin. American Journal of Hypertension. 1999;12(2 I):166-173. Excluded because adult blood not measured. [pmid: 10090344].
Chau W J Jr. Treatment of congestive heart failure in the elderly: Emphasis on renal functional changes and impact of therapy. Coronary Artery Disease. 1997;8(89):505-509. Excluded because not a report of a primary study. [pmid: 9431478].
Chello M, Mastroroberto P, Perticone F, Cirillo F, Bevacqua E, Olivito S, et al. Plasma levels of atrial and brain natriuretic peptides as indicators of recovery of left ventricular systolic function after coronary artery bypass. European Journal of Cardio-Thoracic Surgery. 2001;20(1):140-146. Excluded because BNP assay method is not an included one. [pmid: 11423287].
Chen H, Redfield M, Nordstrom L, Horton D, Burnett J Jr., et al. Subcutaneous administration of the cardiac hormone BNP in symptomatic human heart failure. Journal of Cardiac Failure. 2004;10(2):115-119. Excluded because adult blood not measured. [pmid: 15101022].
Cheung B B.M. Plasma concentration of brain natriuretic peptide is related to diastolic function in hypertension. Clinical & Experimental Pharmacology & Physiology. 1997;24(12):966-968. Excluded because not a report of a primary study. [pmid: 9406666].
Cheung B, Brown M, Cheung B, Brown MJ. Plasma brain natriuretic peptide and C-type natriuretic peptide in essential hypertension. Journal of Hypertension. 1994;12(4):449-454. Excluded because BNP assay method is not an included one. [pmid: 8064169].
Cheung B, Dickerson J, Ashby M, Brown M, Brown J, Cheung B, et al. Effects of physiological increments in human alpha-atrial natriuretic peptide and human brain natriuretic peptide in normal male subjects.[erratum appears in Clin Sci (Colch) 1994 Dec;87(6):following xxv]. Clinical Science. 1994;86(6):723-730. Excluded because BNP assay method is not an included one. [pmid: 8062508].
Cheung B, Kumana C, Cheung B, Kumana CR. Natriuretic peptides--relevance in cardiovascular disease. JAMA: Journal of the American Medical Association. 1919;280(23):1983-1984. Excluded because adult blood not measured.
Cheung B M.J. ‘New’ natriuretic peptides and blood pressure [1]. Lancet. 1993;342(8877):984. Excluded because not a report of a primary study. [pmid: 8105226].
Choy A, Darbar D, Lang C, Pringle T, McNeill G, Kennedy N, et al. Detection of left ventricular dysfunction after acute myocardial infarction: comparison of clinical, echocardiographic, and neurohormonal methods.[see comment]. British Heart Journal. 1994;72(1):16-22. Excluded because BNP assay method is not an included one. [pmid: 7741839]. [pmcid: 1025420].
Chua G, Kang-Hoe L, Chua GaK-HL. Marked elevations in N-terminal brain natriuretic peptide levels in septic shock. Critical care (London, England). 2004;8(4):R248-R250. Excluded because this is a case report or series with 10 subjects.
Chugh R. Management of pregnancy in patients with congenital heart disease and systemic ventricular failure. Progress in Pediatric Cardiology. 2004;19(1):47-60. Excluded because not a report of a primary study.
Cittadini A, Ines CL, Longobardi S, Rocco PVCC, Passamano L, Merola B, et al. A preliminary randomized study of growth hormone administration in Becker and Duchenne muscular dystrophies.[see comment]. European Heart Journal. 2003;24(7):664-672. Excluded because BNP assay method is not an included one. [pmid: 12657225].
Clark A J.G.F. Optimising delivery of care for chronic heart failure. Journal of Clinical Excellence. 2000;1(4):209-215. Excluded because not a report of a primary study.
Clarkson P, Wheeldon N, MacLeod C, Coutie W, MacDonald T, Clarkson P, et al. Brain natriuretic peptide: effect on left ventricular filling patterns in healthy subjects. Clinical Science. 1995;88(2):159-164. Excluded because BNP assay method is not an included one. [pmid: 7720339].
Clarkson P, Wheeldon N, MacFadyen R, Pringle S, MacDonald T, Clarkson P, et al. Effects of brain natriuretic peptide on exercise hemodynamics and neurohormones in isolated diastolic heart failure.[see comment]. Circulation. 1996;93(11):2037-2042. Excluded because BNP assay method is not an included one. [pmid: 8640980].
Cleland J, Cowburn P, and Struthers AD. Neutral endopeptidase inhibitors: Effects on peptide metabolism and potential therapeutic use in the treatment of heart failure. Heart Failure 1996; 12(2). Excluded because not a report of a primary study
Cleland J, Cowburn P, Morgan K. Neuroendocrine activation after myocardial infarction: Causes and consequences. Heart (British Cardiac Society). 1996;76(3 SUPPL. 3):53-59. Excluded because not a report of a primary study. [pmid: 8977365]. [pmcid: 484489].
Clemens L, Almirez R, Baudouin K, Mischak R, Grossbard E, Protter A, et al. Pharmacokinetics and biological actions of subcutaneously administered human brain natriuretic peptide. Journal of Pharmacology & Experimental Therapeutics. 1998;287(1):67-71. Excluded because adult blood not measured. [pmid: 9765323].
Clerico A, Emdin M, Clerico AaEM. Endocrine paradox in heart failure: resistance to biological effects of cardiac natriuretic hormones.[comment]. Clinical Chemistry. 2004;50(12):2465-2467. Excluded because adult blood not measured. [pmid: 15563503].
Clerico A, Iervasi G, Del Ry S, Giannessi D. Immunoassay methods for the measurement of natriuretic cardiac hormones - ANP, BNP, and related peptides - In humans. Journal of Clinical Ligand Assay. 1999;22(2):194-204. Excluded because not a report of a primary study.
Clough JD. BNP looks like a winner. Cleveland Clinic Journal of Medicine. 2002;69(3):179. Excluded because not a report of a primary study.
Cocco G, Kohn S, Sfrisi C. Comparison of the effects of cilazapril and of the combination of cilazapril plus valsartan in patients with advanced heart failure. Heartdrug. 2002;2(6):286-294. Excluded because BNP assay method is not an included one.
Cohn JN. New approaches to screening for vascular and cardiac risk. American Journal of Hypertension. 2001;14(6 II):218S-220S. Excluded because not a report of a primary study. [pmid: 11411760].
Cohn JN. Global structural ventricular remodeling: Summation. Journal of Cardiac Failure. 2002;8(6 SUPPL.):S269-S270. Excluded because not a report of a primary study. [pmid: 12555131].
Cohn JN. Valsartan attenuates heart failure progression. Cardiology Review 2002; 19(12 SUPPL.). Excluded because not a report of a primary study
Cohn JN. Lessons learned from the Valsartan- Heart Failure Trial (Val-HeFT): Angiotensin receptor blockers in heart failure. American Journal of Cardiology. 2002;90(9):992-993. Excluded because not a report of a primary study. [pmid: 12398968].
Cohn J J.N. Is there a common mechanism of benefit for effective treatment of heart failure?. European Journal of Heart Failure. 1999;1(1):31-34. Excluded because not a report of a primary study. [pmid: 10937976].
Cohn J, Quyyumi A, Hollenberg N, and Jamerson KA. Surrogate markers for cardiovascular disease:Functional markers. Circulation 2004; 109(25). Excluded because not a report of a primary study
Cohn PF. EECP - New data on possible mechanisms of action. European Heart Journal. 2001;22(16):1363-1364. Excluded because not a report of a primary study. [pmid: 11482912].
Collinson P G. Natriuretic peptides - Physiology and clinical application. Cpd Bulletin Clinical Biochemistry. 2003;5(2):48-52. Excluded because not a report of a primary study.
Colucci W, Elkayam U, Horton D, Abraham W, Bourge R, Johnson A, et al. Intravenous nesiritide, a natriuretic peptide, in the treatment of decompensated congestive heart failure. Nesiritide Study Group.[erratum appears in N Engl J Med 2000 Nov 16;343(20):1504]. New England Journal of Medicine. 1907;343(4):246-253. Excluded because adult blood not measured. [pmid: 10911006].
Conaway D, Sullivan R, McCullough P, Conaway DG, Sullivan RaMPA. Improved symptoms, physical limitation, and self-efficacy after resynchronization in a patient with heart failure and a prolonged QRS duration. Reviews in Cardiovascular Medicine. 2004;5(1):53-57. Excluded because this is a case report or series with 10 subjects. [pmid: 15029112].
Conraads V, Bosmans J, Vrints CJ. Chronic heart failure: An example of a systemic chronic inflammatory disease resulting in cachexia. International Journal of Cardiology. 2002;85(1):33-49. Excluded because not a report of a primary study. [pmid: 12163208].
Cooper A M. Clinical update. IV fluid therapy: part 1; water balance and hydration assessment. Australian Nursing Journal. 1999;7(5):insert -4. Excluded because not a report of a primary study.
Corboy J, Walker R, Simmonds M, Wilkins G, Richards A, Espiner E, et al. Plasma natriuretic peptides and cardiac volume during acute changes in intravascular volume in haemodialysis patients. Clinical Science. 1994;87(6):679-684. Excluded because BNP assay method is not an included one. [pmid: 7874859].
Corti R, Ruschitzka F, Hurlimann D, Luscher T, Noll G. Vasopeptidase inhibitors: A new class of drugs. Heartdrug. 2001;1(2):96-102. Excluded because not a report of a primary study.
Cossa F, Fabiani M, Farinato A, Laiacona M, Capitani E, Cossa F, et al. The ‘preliminary neuropsychological battery’. An instrument to grade the cognitive level of minimally responsive patients. Brain Injury. 1999;13(8):583-592. Excluded because adult blood not measured. [pmid: 10901687].
Cotter G, Kaluski E, Stangl K, Pacher R, Richter C, Milo-Cotter O, et al. The hemodynamic and neurohormonal effects of low doses of tezosentan (an endothelin A/B receptor antagonist) in patients with acute heart failure. European Journal of Heart Failure. 2004;6(5):601-609. Excluded because BNP assay method is not an included one. [pmid: 15302008].
Cowie MA. Recent developments: Management of chronic heart failure. British Medical Journal. 2002;325(7361):422-425. Excluded because not a report of a primary study. [pmid: 12193359]. [pmcid: 1123941].
Cowie M M.R. BNP: soon to become a routine measure in the care of patients with heart failure?[see comment]. Heart (British Cardiac Society). 2000;83(6):617-618. Excluded because not a report of a primary study. [pmid: 10814613]. [pmcid: 1760863].
Cowie M, Struthers A, Wood D, Coats A, Thompson S, Poole-Wilson P, et al. Value of natriuretic peptides in assessment of patients with possible new heart failure in primary care.[see comment]. Lancet. 1997;350(9088):1349-1353. Excluded because BNP assay method is not an included one. [pmid: 9365448].
Cowley C, Bradley J, Shaddy R, Cowley C, Bradley J, Shaddy RE. B-type natriuretic peptide levels in congenital heart disease. Pediatric Cardiology. 2004;25(4):336-340. Excluded because adult blood not measured. [pmid: 14735252].
Crilley J, Farrer M, Crilley J, Farrer M. Left ventricular remodelling and brain natriuretic peptide after first myocardial infarction.[see comment]. Heart (British Cardiac Society). 2001;86(6):638-642. Excluded because BNP assay method is not an included one. [pmid: 11711456]. [pmcid: 1730033].
Crook J F.A. Tech update. Rapidly identify CHF with POC advances. Nursing Management. 2003;34(1):48-49. Excluded because adult blood not measured. [pmid: 12544585].
Daggubati S, Parks J, Overton R, Cintron G, Schocken D, Vesely D, et al. Adrenomedullin, endothelin, neuropeptide Y, atrial, brain, and C-natriuretic prohormone peptides compared as early heart failure indicators.[erratum appears in Cardiovasc Res 1999 Nov;44(2):452-3]. Cardiovascular Research. 1997;36(2):246-255. Excluded because BNP assay method is not an included one. [pmid: 9463636].
Dastoor H, Bernieh B, Boobes Y, Abouchacra S, Eltayeb E, Elhuda M, et al. Plasma BNP in patients on maintenance haemodialysis: A guide to management?. Journal of Hypertension. 2005;23(1):23-28. Excluded because not a report of a primary study. [pmid: 15643118].
Daugaard G, Lassen U, Bie P, Pedersen E, Jensen K, Abildgaard U, et al. Natriuretic peptides in the monitoring of anthracycline induced reduction in left ventricular ejection fraction. European Journal of Heart Failure. 2005;7(1):87-93. Excluded because BNP assay method is not an included one. [pmid: 15642537].
Davidson N, Coutie W, Webb D, Struthers A, Davidson N, Coutie W, et al. Hormonal and renal differences between low dose and high dose angiotensin converting enzyme inhibitor treatment in patients with chronic heart failure. Heart (British Cardiac Society). 1996;75(6):576-581. Excluded because BNP assay method is not an included one. [pmid: 8697160]. [pmcid: 484380].
Davidson N, Coutie W, Struthers A, Davidson N, Coutie W, Struthers AD. N-terminal proatrial natriuretic peptide and brain natriuretic peptide are stable for up to 6 hours in whole blood in vitro. Circulation. 2002;91(4):1276-1277. Excluded because not a report of a primary study. [pmid: 7850974].
Davidson N, Naas A, Hanson J, Kennedy N, Coutie W, Struthers A, et al. Comparison of atrial natriuretic peptide B-type natriuretic peptide, and N-terminal proatrial natriuretic peptide as indicators of left ventricular systolic dysfunction. American Journal of Cardiology. 2004;77(10):828-831. Excluded because BNP assay method is not an included one. [pmid: 8623734].
Davidson N, Pringle S, Pringle T, McNeill G, Struthers A, Davidson N, et al. Right coronary artery stenosis is associated with impaired cardiac endocrine function during exercise. European Heart Journal. 1997;18(11):1749-1754. Excluded because BNP assay method is not an included one. [pmid: 9402449].
Davis M, Espiner E, Richards G, Billings J, Town I, Neill A, et al. Plasma brain natriuretic peptide in assessment of acute dyspnoea.[see comment]. Lancet. 1994;343(8895):440-444. Excluded because BNP assay method is not an included one. [pmid: 7905953].
de Boer R, Henning R, Suurmeijer A, Pinto Y, Olthof E, Kirkels J, et al. Early expression of natriuretic peptides and SERCA in mild heart failure: association with severity of the disease. International Journal of Cardiology. 2001;78(1):5-12. Excluded because adult blood not measured. [pmid: 11259807].
de Feo M, La Villa G, Lazzeri C, Tosti-Guerra C, Becorpi A, Pupilli C, et al. Urinary endothelin-1 excretion is enhanced by low-dose infusion of brain natriuretic peptide in normal humans. Hypertension. 1997;29(1 Pt 1):70-74. Excluded because adult blood not measured. [pmid: 9039083].
de Jong R, Blanksma P, Cornel J, Van den Heuvel A, Siebelink H, Vaalburg W, et al. Endothelial dysfunction and reduced myocardial perfusion reserve in heart failure secondary to coronary artery disease. American Journal of Cardiology. 2002;91(4):497-500. Excluded because BNP assay method is not an included one. [pmid: 12586279].
de Lemos J, McGuire D, Drazner M, de Lemos JA, McGuire DK, Drazner MH. B-type natriuretic peptide in cardiovascular disease.[see comment]. Lancet. 1907;362(9380):316-322. Excluded because not a report of a primary study. [pmid: 12892964].
de Lemos J, Morrow D, Bentley J, Omland T, Sabatine M, McCabe C, et al. The prognostic value of B-type natriuretic peptide in patients with acute coronary syndromes.[see comment]. New England Journal of Medicine. 2001;345(14):1014-1021. Excluded because BNP assay method is not an included one. [pmid: 11586953].
De Servi S, Mazzone A, James S, Wallentin L. Are levels of C-reactive protein and troponin T the best predictors of mortality after acute coronary syndrome? [5] (multiple letters). Journal of the American College of Cardiology. 2003;42(6):1144-1146. Excluded because not a report of a primary study. [pmid: 13678950].
Deary A, Schumann A, Murfet H, Haydock S, Foo R, Brown M, et al. Influence of drugs and gender on the arterial pulse wave and natriuretic peptide secretion in untreated patients with essential hypertension.[see comment]. Clinical Science. 2002;103(5):493-499. Excluded because BNP assay method is not an included one. [pmid: 12401122].
deBruin J, Schaefer M, Krohne H, Dreyer A. Preoperative anxiety, coping, and intraoperative adjustment: are there mediating effects of stress-induced analgesia?. Psychology and Health. 2001;16(3):253-271. Excluded because adult blood not measured.
Demetriou D C.S. Investigating the patient with cardiac failure. Medicine Today. 2002;3(8):55-63. Excluded because not a report of a primary study.
DeSantiago S, Alonso L, Halhali A, Larrea F, Isobard F, Bourges H. Negative calcium balance during lactation in rural Mexican women. American Journal of Clinical Nutrition. 2002;76(4):845-851. Excluded because adult blood not measured. [pmid: 12324299].
Diaz T, Alderman J, Diaz TaAJ. Nesiritide for the treatment of diastolic dysfunction. Congestive Heart Failure. 2004;10(3):154-157. Excluded because this is a case report or series with 10 subjects. [pmid: 15184731].
Dickerson RN. Hyponatremia in neurosurgical patients: Syndrome of inappropriate antidiuretic hormone or cerebral salt wasting syndrome?. Hospital Pharmacy. 2002;37(12):1336-1342. Excluded because not a report of a primary study.
Dickstein K. Natriuretic peptides in detection of heart failure. Lancet 1998; 351(9095). Excluded because not a report of a primary study
Dobrev D. Transcription factors for ion channels Active or passive players in cardiac remodeling?. Cardiovascular Research. 2003;60(2):226-227. Excluded because not a report of a primary study. [pmid: 14613850].
Doggrell SA. Is vasopressin-receptor antagonism an advancement in the treatment of heart failure?. Expert Opinion on Pharmacotherapy. 2004;5(10):2181-2184. Excluded because not a report of a primary study. [pmid: 15461553].
Dorner T, Gagelmann M, Hock D, Herbst F, Forssmann W, Dorner T, et al. Separation of synthetic cardiodilatin/atrial natriuretic factor and related peptides by reversed-phase high-performance liquid chromatography. Journal of Chromatography. 2005;A..490(2):411-417. Excluded because adult blood not measured.
Downie P, Talwar S, Squire I, Davies J, Barnett D, Ng L. Assessment of the stability of N-terminal pro-brain natriuretic peptide in vitro: implications for assessment of left ventricular dysfunction. Clinical Science. 1999;97(3):255-258. Excluded because BNP assay method is not an included one. [pmid: 10464049].
Doyama K, Fukumoto M, Takemura G, Tanaka M, Oda T, Hasegawa K, et al. Expression and distribution of brain natriuretic peptide in human right atria. Journal of the American College of Cardiology. 1998;32(7):1832-1838. Excluded because adult blood not measured. [pmid: 9857859].
Drazner M, McGuire D, de Lemos J, Drazner MMDK, de Lemos JA. Nesiritide in acute heart failure. Lancet. 1909;362(9388):998-999. Excluded because not a report of a primary study. [pmid: 14511940].
Drewnowski A. Why do we like fat?... Reducing dietary fat: putting theory into practice, December 10-11, 1996, New York, NY. Journal of the American Dietetic Association. 1997;97(7):S58-S62. Excluded because not a report of a primary study. [pmid: 9216570].
Drummer C, Heer M, Dressendorfer R, Strasburger C, Gerzer R. Reduced natriuresis during weightlessness. Clinical Investigator. 1993;71(9):678-686. Excluded because this is a case report or series with 10 subjects. [pmid: 8241716].
Dubin N, Monahan L, Yu-Yahiro J, Michael R, Zimmerman S, Hawkes W, et al. Serum concentrations of steroids, parathyroid hormone, and calcitonin in postmenopausal women during the year following hip fracture: effect of location of fracture and age. Journals of Gerontology. 1999;Series A(9):M467-M473. Excluded because BNP assay method is not an included one. [pmid: 10536650].
Dubrey S, T.C. Natriuretic peptides and heart failure: Diagnosis, prognosis and treatment. British Journalof Cardiology 2000; 7(4). Excluded because not a report of a primary study
Dudman N, Hunt D, MacMahon S, Neal B, Richards M, Simes J, et al. Effects of the vasopeptidase inhibitor, omapatrilat, in 723 patients with coronary heart disease. Journal of the Renin-Angiotensin-Aldosterone System. 2002;3(4):270-276. Excluded because BNP assay method is not an included one. [pmid: 12584671].
Dunn A, Chow M, Kluger J. Nesiritide: A natriuretic peptide with hemodynamic benefits in patients with acute decompensated CHF. Formulary. 1999;34(2):123-131. Excluded because not a report of a primary study.
Dzimiri N, Moorji A, Afrane B, Al Halees Z, Dzimiri N, Moorji A, et al. Differential regulation of atrial and brain natriuretic peptides and its implications for the management of left ventricular volume overload. European Journal of Clinical Investigation. 2002;32(8):563-569. Excluded because adult blood not measured. [pmid: 12190955].
Ebell M. Does elevated BNP predict adverse outcomes in pulmonary embolism?. Evidence-Based Practice. 2002;6(9):11. Excluded because not a report of a primary study.
Ebell M. Does pro-brain natriuretic peptide level predict the clinical course for pulmonary embolism?. Evidence-Based Practice. 2002;6(7):12. Excluded because not a report of a primary study.
Ebell M. Can B-natriuretic peptide distinguish patients with congestive heart failure from those with intrinsic lung disease?. Evidence-Based Practice. 2002;5(4):6. Excluded because not a report of a primary study.
Ebina T, Takahashi N, Mitani I, Sumita S, Ishigami T, Ashino K. Clinical implications of cardiac (123)I-meta-iodobenzylguanidine scintigraphy and cardiac natriuretic peptides in patients with heart disease. Nuclear Medicine Communications. 2002;23(8):795-801. Excluded because BNP assay method is not an included one. [pmid: 12124486].
Eguchi K, Kario K, Shimada K, Mori T, Nii T, Ibaragi K, et al. Circadian variation of blood pressure and neurohumoral factors during the acute phase of stroke. Clinical & Experimental Hypertension (New York). 2002;24(12):109-114. Excluded because BNP assay method is not an included one.
Ekman B, Ohman P, Arnqvist H, Lindstrom T, Nystrom F, Ekman BOPK, et al. Individualized growth hormone substitution with normalized IGF-I levels does not stimulate the renin-angiotensin-aldosterone system. Clinical Endocrinology. 2002;57(4):473-479. Excluded because BNP assay method is not an included one. [pmid: 12354129].
El Gamel A, Campbell C, Yonan N, Keevil B, Warbuton R, Woodcock A, et al. Atrial natriuretic peptide release after cardiac transplantation. Journal of Thoracic & Cardiovascular Surgery. 1996;112(4):1128-1129. Excluded because not a report of a primary study. [pmid: 8873749].
El Gamel A, Yonan N, Keevil B, Warbuton R, Kakadellis J, Woodcock A, et al. Significance of raised natriuretic peptides after bicaval and standard cardiac transplantation. Annals of Thoracic Surgery. 1997;63(4):1095-1100. Excluded because BNP assay method is not an included one. [pmid: 9124912].
Elin R, Winter W, Elin RJ, Winter WE. Laboratory and clinical aspects of B-type natriuretic peptides. Archives of Pathology & Laboratory Medicine. 2004;128(6):697-699. Excluded because not a report of a primary study. [pmid: 15163225].
Elkayam U, Akhter M, Singh H, Khan S, Usman A, Elkayam UAMW, et al. Comparison of effects on left ventricular filling pressure of intravenous nesiritide and high-dose nitroglycerin in patients with decompensated heart failure. American Journal of Cardiology. 2001;93(2):237-240. Excluded because adult blood not measured. [pmid: 14715359].
Elovic EP. Update on pharmacology. Anterior pituitary dysfunction after traumatic brain injury, part II. Journal of Head Trauma Rehabilitation. 2004;19(2):184-187. Excluded because not a report of a primary study. [pmid: 15247828].
Emdin M, Marini C, Passino C, Giuggioli D, Formichi B, Ferri C, et al. Right ventricular overload and cardiovascular neuroendocrine derangement in systemic sclerosis. European Heart Journal Supplements. 2004;6(SUPPL. 6):F68-F73. Excluded because BNP assay method is not an included one.
Emdin M, Passino C, Del Ry S, Prontera C, Galetta F, Clerico A, et al. Influence of gender on circulating cardiac natriuretic hormones in patients with heart failure. Clinical Chemistry & Laboratory Medicine. 2003;41(5):686-692. Excluded because BNP assay method is not an included one. [pmid: 12812268].
Enoch J. Misoprostol (Cytotec): a new method of inducing labor. Midwifery Today 1999;(49):22-30. Excluded because not a report of a primary study
Eskafi M, Mahmoud. Sleep apnoea in patients with stable congestive heart failure an intervention studywith a mandibular advancement device. Swedish Dental Journal - Supplement 2004;(168):1–56. Excluded because not a report of a primary study
Espiner E, Leikis R, Ferch R, MacFarlane M, Bonkowski J, Frampton C, et al. The neuro-cardio-endocrine response to acute subarachnoid haemorrhage. Clinical Endocrinology. 2002;56(5):629-635. Excluded because BNP assay method is not an included one. [pmid: 12030914].
Evans M, Livesey J, Ellis M, Yandle T, Evans M, Livesey J, et al. Effect of anticoagulants and storage temperatures on stability of plasma and serum hormones. Clinical Biochemistry. 2001;34(2):107-112. Excluded because BNP assay method is not an included one. [pmid: 11311219].
Ewald B. Abnormal laboratory results - B-type natriuretic peptide: A new diagnostic tool for congestive heart failure. Australian Prescriber. 2003;26(3):64-65. Excluded because not a report of a primary study.
Falcao L, Pinto F, Ravara L, van Zwieten P, Falcao LMPFRLavZPA. BNP and ANP as diagnostic and predictive markers in heart failure with left ventricular systolic dysfunction. Journal of the Renin-Angiotensin-Aldosterone System. 2004;5(3):121-129. Excluded because BNP assay method is not an included one. [pmid: 15526247].
Fang V, Juan C, Won J, Ho L, Fang V, Juan C, et al. Further study of aldosterone secretion-inhibitory factor and brain natriuretic peptide on cortisol production of guinea pig zona fasciculata cells. Chinese Journal of Physiology. 1920;43(4):141-147. Excluded because adult blood not measured. [pmid: 11292178].
Feldman D, Ikonomidis J, Uber W, Van Bakel A, Pereira N, Crumbley A, et al. Human B-natriuretic peptide improves hemodynamics and renal function in heart transplant patients immediately after surgery. Journal of Cardiac Failure. 2004;10(4):292-296. Excluded because this is a case report or series with 10 subjects. [pmid: 15309694].
Ferdinand KC. Advances in antihypertensive combination therapy: Benefits of low-dose thiazide diuretics in conjunction with omapatrilat, a vasopeptidase inhibitor. Journal of Clinical Hypertension. 2001;3(5):307-312. Excluded because not a report of a primary study. [pmid: 11588409].
Ferreira A, Bettencourt P, Dias P, Pestana M, Serrao P, Soares-Da-Silva P, et al. Neurohormonal activation, the renal dopaminergic system and sodium handling in patients with severe heart failure under vasodilator therapy. Clinical Science. 2001;100(5):557-566. Excluded because this is a case report or series with 10 subjects. [pmid: 11294697].
Fethiere J, De Lean A, Fethiere J, De Lean A. Pharmacological evidence for the heterogeneity of atrial natriuretic factor-R1 receptor subtype. Molecular Pharmacology. 1991;40(6):915-922. Excluded because adult blood not measured. [pmid: 1684636].
Fiedler B, Lohmann S, Smolenski A, Linnemuller S, Pieske B, Schroder F, et al. Inhibition of calcineurin-NFAT hypertrophy signaling by cGMP-dependent protein kinase type I in cardiac myocytes. Proceedings of the National Academy of Sciences of the United States of America. 1908;99(17):11363-11368. Excluded because adult blood not measured. [pmid: 12177418].
Figlewicz D, Schwartz M, Seeley R, Chavez M, Baskin D, Woods S, et al. Endocrine regulation of food intake and body weight. Journal of Laboratory and Clinical Medicine. 1996;127(4):328-332. Excluded because not a report of a primary study. [pmid: 8656034].
Fleischer D, Espiner E, Yandle T, Livesey J, Billings J, Town I, et al. Rapid assay of plasma brain natriuretic peptide in the assessment of acute dyspnoea. New Zealand Medical Journal. 2003;110(1039):71-74. Excluded because BNP assay method is not an included one. [pmid: 9137299].
Floras JS. Vasopeptidase inhibition: A novel approach to cardiovascular therapy. Canadian Journal of Cardiology. 2002;18(2):177-182. Excluded because not a report of a primary study. [pmid: 11875587].
Florkowski C, Hassan E, Yandle T, Livesey J, Espiner E, Donald RA. Growth hormone replacement increases cardiac muscle mass and reduces brain natriuretic peptide response to exercise in adults with growth hormone deficiency. Endocrinology & Metabolism, Supplement. 1997;4(3):167-171. Excluded because BNP assay method is not an included one.
Florkowski C, Richards A, Espiner E, Yandle T, Frampton C, Florkowski C, et al. Renal, endocrine, and hemodynamic interactions of atrial and brain natriuretic peptides in normal men. American Journal of Physiology. 1994;266(4 Pt 2):R1244-R1250. Excluded because BNP assay method is not an included one. [pmid: 8184968].
Florkowski C, Richards A, Espiner E, Yandle T, Sybertz E, Frampton C, et al. Low-dose brain natriuretic peptide infusion in normal men and the influence of endopeptidase inhibition. Clinical Science. 1997;92(3):255-260. Excluded because BNP assay method is not an included one. [pmid: 9093005].
Foex P. Pre-operative evaluation and risk assessment of patients undergoing vascular surgery. Bailliere's Best Practice in Clinical Anaesthesiology. 2000;14(1):1-16. Excluded because not a report of a primary study.
Fonarow GC. B-type natriuretic peptide: Spectrum of application. Nesiritide (recombinant BNP) for heart failure. Heart Failure Reviews. 2003;8(4):321-325. Excluded because not a report of a primary study. [pmid: 14574051].
Fonarow GC. Clinical update on the use of natriuretic peptides in the treatment of heart failure. Reviews in Cardiovascular Medicine. 2003;4(SUPPL. 7):S1-S2. Excluded because not a report of a primary study. [pmid: 14703686].
Fonarow G T.B. Prevention of heart failure: Effective strategies to combat the growing epidemic. Reviews in Cardiovascular Medicine. 2003;4(1):8-17. Excluded because not a report of a primary study. [pmid: 12684599].
Forssmann W, Magert H, Meyer M, Schulz-Knappe P. Cardiac peptides are also regulatory peptides in the autonomic nervous system and in paraneuronal systems. Journal of the Autonomic Nervous System. 1991;33(2):117-118. Excluded because not a report of a primary study.
Forssmann W, Meyer M, Forssmann K. The renal urodilatin system: Clinical implications. Cardiovascular Research. 2001;51(3):450-462. Excluded because not a report of a primary study. [pmid: 11476735].
Fox K. How to do it - Set up a heart failure clinic. Continuing Medical Education - Cardiology. 2003;2(3):160-165. Excluded because not a report of a primary study.
Foy S, Crozier I, Richards A, Nicholls M, Turner J, Frampton C, et al. Neurohormonal changes after acute myocardial infarction: Relationships with haemodynamic indices and effects of ACE inhibition. European Heart Journal. 1995;16(6):770-778. Excluded because BNP assay method is not an included one. [pmid: 7588920].
Frape D, Williams N, Scriven A, Palmer C, O'Sullivan K, Fletcher RJ. Diurnal trends in responses of blood plasma concentrations of glucose, insulin, and C-peptide following high- and low-fat meals and their relation to fat metabolism in healthy middle-aged volunteers. British Journal of Nutrition. 1997;77(4):523-535. Excluded because adult blood not measured. [pmid: 9155503].
Frape D, Williams N, Rajput-Williams J, Maitland B, Scriven A, Palmer C, et al. Effect of breakfast fat content on glucose tolerance and risk factors of atherosclerosis and thrombosis. British Journal of Nutrition. 1998;80(4):323-331. Excluded because BNP assay method is not an included one. [pmid: 9924274].
Frey N E.N. Modulating cardiac hypertrophy by manipulating myocardial lipid metabolism?. Circulation. 2002;105(10):1152-1154. Excluded because not a report of a primary study. [pmid: 11889005].
Friedl W, Mair J, Pichler M, Paulweber B, Sandhofer F, Puschendorf B, et al. Insertion/deletion polymorphism in the angiotensin-converting enzyme gene is associated with atrial natriuretic peptide activity after exercise. Clinica Chimica Acta. 2006;274(2):199-211. Excluded because BNP assay method is not an included one.
Friedl W, Mair J, Thomas S, Pichler M, Puschendorf B, Friedl W, et al. Natriuretic peptides and cyclic guanosine 3',5'-monophosphate in asymptomatic and symptomatic left ventricular dysfunction. Heart (British Cardiac Society). 1996;76(2):129-136. Excluded because BNP assay method is not an included one. [pmid: 8795474]. [pmcid: 484459].
Friedl W, Mair J, Thomas S, Pichler M, Puschendorf B, Friedl W, et al. Relationship between natriuretic peptides and hemodynamics in patients with heart failure at rest and after ergometric exercise. Clinica Chimica Acta. 1999;281(12):121-126. Excluded because BNP assay method is not an included one.
Fujii T, Otsuka T, Tanaka S, Kanazawa H, Hirata K, Kohno M, et al. Plasma endothelin-1 level in chronic obstructive pulmonary disease: relationship with natriuretic peptide.[comment]. Respiration. 1999;66(3):212-219. Excluded because BNP assay method is not an included one. [pmid: 10364736].
Fujita M, Miyamoto S, Tambara K, Budgell B. Trepopnea in patients with chronic heart failure. International Journal of Cardiology. 2002;84(23):115-118. Excluded because not a report of a primary study. [pmid: 12127363].
Fujiwara Y, Tatsumi T, Imai J, Nakagawa Y, Kimura T, Akaji K, et al. Syntheses and biological activities of several newly isolated natriuretic peptides. Journal of Pharmacobio-Dynamics. 1991;14(5):s-105. Excluded because not a report of a primary study.
Fukui S, Nawashiro H, Otani N, Ooigawa H, Toyooka T, Tsuzuki N, et al. Focal brain edema and natriuretic peptides in patients with subarachnoid hemorrhage. Acta Neurochirurgica - Supplement. 2003;86:489-491. Excluded because BNP assay method is not an included one. [pmid: 14753492].
Funder JW. Why Cardiovascular Endocrinology?. Endocrinology. 2003;144(6):i-ii. Excluded because not a report of a primary study.
Furst P. 2000 Jonathan E. Rhoads Lecture. A thirty-year odyssey in nitrogen metabolism: from ammonium to dipeptides. JPEN: Journal of Parenteral and Enteral Nutrition 2000; 24(4):197–209. Excluded because not a report of a primary study
Furuhashi N, Kimura H, Nagae H, Yajima A, Kimura C, Saito T, et al. Brain natriuretic peptide and atrial natriuretic peptide levels in normal pregnancy and preeclampsia. Gynecologic & Obstetric Investigation. 1994;38(2):73-77. Excluded because BNP assay method is not an included one. [pmid: 7959344].
Futterman L, Lemberg L, Futterman LG, Lemberg L. Novel markers in the acute coronary syndrome: BNP, IL-6, PAPP-A. American Journal of Critical Care. 2002;11(2):168-172. Excluded because not a report of a primary study. [pmid: 11888130].
Gackowski A, Isnard R, Golmard J, Pousset F, Carayon A, Montalescot G, et al. Comparison of echocardiography and plasma B-type natriuretic peptide for monitoring the response to treatment in acute heart failure. European Heart Journal. 2004;25(20):1788-1796. Excluded because BNP assay method is not an included one. [pmid: 15474693].
Gade W, Hainaut C, Gade J, Gade WHCaGJ. Accelerated cardiac protocols in emergency laboratory medicine: four case studies. Clinical Laboratory Science. 2003;16(3):180-187. Excluded because adult blood not measured. [pmid: 12875491].
Galatius S, Gustafsson F, Atar D, Hildebrandt PR. Tolerability of beta-blocker initiation and titration with bisoprolol and carvedilol in congestive heart failure - A randomized comparison. Cardiology. 2004;102(3):160-165. Excluded because not a report of a primary study. [pmid: 15334027].
Gardner DG. Molecular biology of the natriuretic peptides. Trends in Cardiovascular Medicine. 1994;4(4):159-165. Excluded because not a report of a primary study. [pmid: 21244881].
Garlichs C, Zhang H, Schmeisser A, Daniel W, Garlichs C, Zhang H, et al. Priming of superoxide anion in polymorphonuclear neutrophils by brain natriuretic peptide. Life Sciences. 1999;65(10):1027-1033. Excluded because adult blood not measured. [pmid: 10499870].
Gegenhuber A, Mueller T, Firlinger F, Lenz K, Poelz W, Haltmayer M, et al. Time course of B-type natriuretic peptide (BNP) and N-terminal proBNP changes in patients with decompensated heart failure. Clinical Chemistry. 2004;50(2):454-456. Excluded because not a report of a primary study. [pmid: 14752022].
Gempp E, Blatteau J, Louge P, Drouillard I, Galland F-M. N-Terminal pro brain natriuretic peptide increases after 1-h scuba dives at 10 m depth. Aviation Space & Environmental Medicine. 2005;76(2):114-116. Excluded because this is a case report or series with 10 subjects.
Geny B, Charloux A, Lampert E, Lonsdorfer J, Haberey P, Piquard F, et al. Enhanced brain natriuretic peptide response to peak exercise in heart transplant recipients. Journal of Applied Physiology. 1998;85(6):2270-2276. Excluded because BNP assay method is not an included one. [pmid: 9843552].
Geny B, Follenius M, Epailly E, Charpentier A, Brandenberger G, Eisenmann B, et al. Transient reduction without normalization of brain natriuretic peptide early after heart transplantation. Journal of Thoracic & Cardiovascular Surgery. 1998;115(2):473-475. Excluded because BNP assay method is not an included one. [pmid: 9475548].
Geny B, Hardy H, Lonsdorfer J, Eisenmann B, Haberey P, Piquard F, et al. Enhanced natriuretic response to neutral endopeptidase inhibition in heart-transplant recipients. Hypertension. 1999;33(4):969-974. Excluded because BNP assay method is not an included one. [pmid: 10205232].
Georges A, Forestier F, Valli N, Plogin A, Janvier G, Bordenave L, et al. Changes in type B natriuretic peptide (BNP) concentrations during cardiac valve replacement. European Journal of Cardio-Thoracic Surgery. 2004;25(6):941-945. Excluded because BNP assay method is not an included one. [pmid: 15144992].
Georgiadou P, Babu-Narayan S, Francis D, Kremastinos D, Gatzoulis MA. Periodic breathing as a feature of right heart failure in congenital heart disease. Heart (British Cardiac Society). 2004;90(9):1075-1076. Excluded because not a report of a primary study. [pmid: 15310713]. [pmcid: 1768429].
Gerbes A, Nemer M, Gerbes A, Nemer M. Detection of C-type natriuretic peptide compared with brain and atrial natriuretic peptide transcripts in human heart by the polymerase chain reaction. Clinical Investigator. 1993;71(8):672. Excluded because adult blood not measured. [pmid: 8219667].
Gerlach H, Dhainaut J, Harbarth S, Reinhart K, Marshall J, Levy M. The PIRO Concept: R is for response. Critical Care (London). 2003;7(3):256-259. Excluded because not a report of a primary study.
Gheorghiade M, Gattis W, Adams K Jr, Jaffe A, O'Connor C, et al. Rationale and design of the pilot randomized study of nesiritide versus dobutamine in heart failure (PRESERVD-HF). American Heart Journal. 2003;145(2 Suppl):S55-S57. Excluded because not a report of a primary study. [pmid: 12594453].
Ghitelman J, Krumerman D, Latif F, Le Jemtel T, Ghitelman JKDLFaLJTH. Serum brain natriuretic peptide level in a patient with chronic obstructive pulmonary disease and chronic heart failure. Congestive Heart Failure. 2004;10(2):106-108. Excluded because this is a case report or series with 10 subjects. [pmid: 15073457].
Gibbons G, Liew C, Goodarzi M, Rotter J, Hsueh W, Siragy H et al. Genetic markers: Progress and potential for cardiovascular disease. Circulation 2004; 109(25). Excluded because not a report of a primary study
Gibson N. B-natriuretic peptide levels had high sensitivity and specificity for detecting abnormal ventricular function. ACP Journal Club. 2002;v136(2):68. Excluded because not a report of a primary study. [pmid: 11874293].
Givertz M E. Neurohormones in heart failure: Predicting outcomes, optimizing care. European Heart Journal. 2004;25(4):281-282. Excluded because not a report of a primary study. [pmid: 14984914].
Gobinet-Georges A, Valli N, Filliatre H, Dubernet M, Dedeystere O, Bordenave L, et al. Stability of brain natriuretic peptide (BNP) in human whole blood and plasma. Clinical Chemistry & Laboratory Medicine. 2000;38(6):519-523. Excluded because BNP assay method is not an included one. [pmid: 10987200].
Goetze J, Christoffersen C, Perko M, Arendrup H, Rehfeld J, Kastrup J, et al. Increased cardiac BNP expression associated with myocardial ischemia. FASEB Journal. 2003;17(9):1105-1107. Excluded because adult blood not measured. [pmid: 12709407].
Goetze J, Gore A, Moller C, Steinbruchel D, Rehfeld J, Nielsen L, et al. Acute myocardial hypoxia increases BNP gene expression. FASEB Journal. 2004;18(15):1928-1930. Excluded because adult blood not measured. [pmid: 15576492].
Goetze J, Kastrup J, Pedersen F, Rehfeld J, Goetze JPKJPFaRJF. Quantification of pro-B-type natriuretic peptide and its products in human plasma by use of an analysis independent of precursor processing.[see comment]. Clinical Chemistry. 2002;48(7):1035-1042. Excluded because BNP assay method is not an included one. [pmid: 12089172].
Goetze J, Kastrup J, Rehfeld J, Goetze JPKJaRJF. The paradox of increased natriuretic hormones in congestive heart failure patients: does the endocrine heart also fail in heart failure?. European Heart Journal. 2003;24(16):1471-1472. Excluded because not a report of a primary study. [pmid: 12919769].
Goetze J, Videbaek R, Boesgaard S, Aldershvile J, Rehfeld J, Carlsen J, et al. Pro-brain natriuretic peptide as marker of cardiovascular or pulmonary causes of dyspnea in patients with terminal parenchymal lung disease. Journal of Heart & Lung Transplantation. 2004;23(1):80-87. Excluded because BNP assay method is not an included one. [pmid: 14734131].
Gohlke P. Role of neutral endopeptidase and angiotensin-converting enzyme in deoxycorticosterone acetate-salt hypertension. Journal of Hypertension. 2002;20(5):821-823. Excluded because not a report of a primary study. [pmid: 12011635].
Goldman D C.S. Clinical implications of basic research. Restoring the addicted brain. New England Journal of Medicine. 2002;347(11):843-845. Excluded because adult blood not measured. [pmid: 12226158].
Goldsmith SR. Vasopressin antagonists in CHF: Ready for clinical trials?. Cardiovascular Research. 2002;54(1):13-15. Excluded because not a report of a primary study. [pmid: 12062356].
Gomes M R.E. B-type (brain) natriuretic peptide: A new therapeutic agent for the treatment of heart failure. Prevention & Management of Congestive Heart Failure. 1998;4(3):15-21. Excluded because not a report of a primary study.
Goswami K, Maisel A, and Wanner EC. Brain-type (B-type) natriuretic peptide (BNP) levels: Truly costeffective in diagnosis of congestive heart failure (CHF)? Journal of Critical Illness 2003; 18(1). Excluded because not a report of a primary study
Grammatopoulos D E.W. Role of corticotropin-releasing hormone in onset of labour. Lancet. 1919;354(9189):1546-1549. Excluded because not a report of a primary study. [pmid: 10551516].
Grauer K. Clinical viewpoint. How I use BNP. Family Practice Recertification. 2004;26(1):20-22. Excluded because not a report of a primary study.
Gremmler B, Kisters K, Funke C, Schleiting H, Kunert M, Ulbricht LJ. The role of electrolytes and NT-proBNP determination in cases of severe heart failure drug treatment. Trace Elements & Electrolytes. 2004;21(3):206. Excluded because not a report of a primary study.
Gremmler B, Ulbricht L, Kosch M, Hausberg M, Kisters K. Combined antihypertensive therapy improves moderate heart failure [1]. Journal of Hypertension. 2003;21(11):2195. Excluded because not a report of a primary study. [pmid: 14597865].
Groenning B, Nilsson J, Sondergaard L, Kjaer A, Larsson H, Hildebrandt P, et al. Evaluation of impaired left ventricular ejection fraction and increased dimensions by multiple neurohumoral plasma concentrations. European Journal of Heart Failure. 2001;3(6):699-708. Excluded because adult blood not measured. [pmid: 11738222].
Groenning B, Nilsson J, Hildebrandt P, Kjaer A, Fritz-Hansen T, Larsson H, et al. Neurohumoral prediction of left-ventricular morphologic response to beta-blockade with metoprolol in chronic left-ventricular systolic heart failure. European Journal of Heart Failure. 2002;4(5):635-646. Excluded because BNP assay method is not an included one. [pmid: 12413508].
Groop P M.C. Brain-natriuretic peptide: Microalbuminuria for cardiac disease and diabetes?. Diabetologia. 2005;48(1):3-5. Excluded because not a report of a primary study. [pmid: 15624097].
Gutierrez C D.G. Diastolic heart failure: Challenges of diagnosis and treatment. American Family Physician. 2004;69(11):2609-2616. Excluded because not a report of a primary study. [pmid: 15202695].
Hachey D, Smith T, Hachey DM, Smith T. Use of nesiritide to treat acute decompensated heart failure. Critical Care Nurse. 2003;23(1):53-55. Excluded because not a report of a primary study. [pmid: 12640959].
Hachida M, Saitou S, Nonoyama M, Hoshi H, Hanayama N, Ohkado A, et al. Mechanisms of exercise response in the denervated heart after transplantation. Transplantation Proceedings. 1999;31(5):1966-1969. Excluded because BNP assay method is not an included one. [pmid: 10455938].
Hadase M, Azuma A, Zen K, Asada S, Kawasaki T, Kamitani T, et al. Very low frequency power of heart rate variability is a powerful predictor of clinical prognosis in patients with congestive heart failure. Circulation Journal. 2004;68(4):343-347. Excluded because BNP assay method is not an included one. [pmid: 15056832].
Hakala T, Hedman A, Turpeinen A, Kettunen R, Vuolteenaho O, Hippelainen M, et al. Prediction of atrial fibrillation after coronary artery bypass grafting by measuring atrial peptide levels and preoperative atrial dimensions. European Journal of Cardio-Thoracic Surgery. 2002;22(6):939-943. Excluded because BNP assay method is not an included one. [pmid: 12467817].
Halapas A, Tenta R, Pantos C, Cokkinos D, Koutsilieris M. Parathyroid hormone-related peptide and cardiovascular system. In Vivo. 2003;17(5):425-432. Excluded because not a report of a primary study. [pmid: 14598605].
Hall C. The value of natriuretic peptides for the management of heart failure: Current state of play. European Journal of Heart Failure. 2001;3(4):395-397. Excluded because not a report of a primary study. [pmid: 11511422].
Hama N, Itoh H, Shirakami G, Suga S, Komatsu Y, Yoshimasa T, et al. Detection of C-type natriuretic peptide in human circulation and marked increase of plasma CNP level in septic shock patients. Biochemical & Biophysical Research Communications. 2002;198(3):1177-1182. Excluded because BNP assay method is not an included one. [pmid: 8117275].
Hamad A, Clayton A, Islam B, Knox AJ. Guanylyl cyclases, nitric oxide, natriuretic peptides, and airway smooth muscle function. American Journal of Physiology - Lung Cellular & Molecular Physiology. 2003;285(5 295):L973-L983. Excluded because not a report of a primary study. [pmid: 14551038].
Hamberg O T.P. Effects of xylitol on urea synthesis in normal humans: relation to glucagon. JPEN: Journal of Parenteral and Enteral Nutrition. 1996;20(2):139-144. Excluded because adult blood not measured. [pmid: 8676533].
Hamid S G.F. Adrenomedullin: Regulator of systemic and cardiac homeostasis in acute myocardial infarction. Pharmacology & Therapeutics. 2005;105(2):95-112. Excluded because not a report of a primary study. [pmid: 15670621].
Hamrahian A, Oseni T, Arafah BM. Measurements of serum free cortisol in critically ill patients. New England Journal of Medicine. 2004;350(16):1629-1638. Excluded because adult blood not measured. [pmid: 15084695].
Handa S. Treatment of primary pulmonary hypertension. Internal Medicine. 2002;41(10):757-758. Excluded because not a report of a primary study. [pmid: 12412989].
Hansen-Schwartz J, Sviri G, Edvinsson L, Hansen-Schwartz J, Sviri G, Edvinsson L. Influence of brain natriuretic peptide on phenotypic change of cerebral vasculature. Acta Neurochirurgica - Supplement. 2001;77:37-40. Excluded because adult blood not measured. [pmid: 11563305].
Harada M, Itoh H, Nakagawa O, Ogawa Y, Miyamoto Y, Kuwahara K, et al. Significance of ventricular myocytes and nonmyocytes interaction during cardiocyte hypertrophy: evidence for endothelin-1 as a paracrine hypertrophic factor from cardiac nonmyocytes. Circulation. 1919;96(10):3737-3744. Excluded because adult blood not measured. [pmid: 9396478].
Harada T, Ohtaki E, Misu K, Sumiyoshi T, Hosoda S. Congestive heart failure caused by digitalis toxicity in an elderly man taking a licorice-containing Chinese herbal laxative [3]. Cardiology. 2002;98(4):218. Excluded because not a report of a primary study. [pmid: 12566654].
Harada T, Ohtaki E, Kitahara K, Sumiyoshi T, Hosoda S. Carvedilol-induced changes in cardiac diastolic performance in a patient with isolated noncompaction of the myocardium. Internal Medicine. 2002;41(8):642-647. Excluded because not a report of a primary study. [pmid: 12211534].
Haria M, Plosker G, Markham A. Felodipine/metoprolol: A review of the fixed dose controlled release formulation in the management of essential hypertension. Drugs. 2000;59(1):141-157. Excluded because not a report of a primary study. [pmid: 10718104].
Harrison A, Bhalla V, Gardetto N, Maisel A, Harrison ABVGNaMAS. Evolving use of B-type natriuretic peptide in clinical practice. Clinical Chemistry. 2004;50(9):1714-1715. Excluded because adult blood not measured. [pmid: 15331522].
Hartmann F, Kurowski V, Maghsoudi A, Kurz T, Schwarz M, Bonnemeier H, et al. Plasma catecholamines and N-terminal proBNP in patients with acute myocardial infarction undergoing primary angioplasty. Relation to left ventricular function and clinical outcome. Zeitschrift fur Kardiologie. 2003;92(1):73-81. Excluded because BNP assay method is not an included one. [pmid: 12545304].
Hasegawa K, Fujiwara H, Doyama K, Miyamae M, Fujiwara T, Suga S, et al. Ventricular expression of brain natriuretic peptide in hypertrophic cardiomyopathy. Circulation. 1993;88(2):372-380. Excluded because adult blood not measured. [pmid: 8339400].
Hasegawa K, Fujiwara H, Doyama K, Mukoyama M, Nakao K, Fujiwara T, et al. Ventricular expression of atrial and brain natriuretic peptides in dilated cardiomyopathy. An immunohistocytochemical study of the endomyocardial biopsy specimens using specific monoclonal antibodies. American Journal of Pathology. 1993;142(1):107-116. Excluded because BNP assay method is not an included one. [pmid: 8424448]. [pmcid: 1886835].
Haug C, Metzele A, Kochs M, Hombach V, Grunert A, Haug C, et al. Plasma brain natriuretic peptide and atrial natriuretic peptide concentrations correlate with left ventricular end-diastolic pressure. Clinical Cardiology. 1993;16(7):553-557. Excluded because BNP assay method is not an included one. [pmid: 8348764].
Haug C, Metzele A, Steffgen J, Kochs M, Hombach V, Grunert A, et al. Increased brain natriuretic peptide and atrial natriuretic peptide plasma concentrations in dialysis-dependent chronic renal failure and in patients with elevated left ventricular filling pressure. Clinical Investigator. 1994;72(6):430-434. Excluded because BNP assay method is not an included one. [pmid: 7950153].
Haug C, Metzele A, Steffgen J, Grunert A, Haug C, Metzele A, et al. Changes in brain natriuretic peptide and atrial natriuretic peptide plasma concentrations during hemodialysis in patients with chronic renal failure. Hormone & Metabolic Research. 1994;26(5):246-249. Excluded because BNP assay method is not an included one. [pmid: 8076909].
Hayabuchi Y, Matsuoka S, Kuroda Y, Hayabuchi Y, Matsuoka S, Kuroda Y. Plasma concentrations of atrial and brain natriuretic peptides and cyclic guanosine monophosphate in response to dobutamine infusion in patients with surgically repaired tetralogy of fallot. Pediatric Cardiology. 1999;20(5):343-350. Excluded because adult blood not measured. [pmid: 10441688].
Hayashi Y, Ohtani M, Sawa Y, Hiraishi T, Akedo H, Kobayashi Y, et al. Synthetic Human a-Atrial Natriuretic Peptide Improves the Management of Postoperative Hypertension and Renal Dysfunction after the Repair of Abdominal Aortic Aneurysm. Journal of Cardiovascular Pharmacology. 2003;42(5):636-641. Excluded because BNP assay method is not an included one. [pmid: 14576512].
Hayes DL. Cardiac arrhythmias and implantable devices. Journal of the American College of Cardiology. 2003;42(2):392-393. Excluded because not a report of a primary study. [pmid: 12875787].
He Q, Mendez M, LaPointe M, He QMMaLMC. Regulation of the human brain natriuretic peptide gene by GATA-4. American Journal of Physiology - Endocrinology & Metabolism. 2002;283(1):E50-E57. Excluded because adult blood not measured. [pmid: 12067842].
Heaney R, McCarron D, Dawson-Hughes B, Oparil S, Berga S, Stern J, et al. Dietary changes favorably affect bone remodeling in older adults. Journal of the American Dietetic Association. 1999;99(10):1228-1233. Excluded because BNP assay method is not an included one. [pmid: 10524386].
Heaney R, Rafferty K, Dowell MS. Effect of yogurt on a urinary marker of bone resorption in postmenopausal women. Journal of the American Dietetic Association. 2002;102(11):1672-1674. Excluded because adult blood not measured. [pmid: 12449294].
Heidenreich P, Gubens M, Fonarow G, Konstam M, Stevenson L, Shekelle P, et al. Cost-effectiveness of screening with B-type natriuretic peptide to identify patients with reduced left ventricular ejection fraction. Journal of the American College of Cardiology. 2003;43(6):1019-1026. Excluded because adult blood not measured. [pmid: 15028361].
Henriksen J S. Hypertension and liver disease. Current Hypertension Reports. 2004;6(6):453-461. Excluded because not a report of a primary study. [pmid: 15527691].
Heringlake M, Heide C, Bahlmann L, Eichler W, Pagel H, Schmucker P, et al. Effects of tilting and volume loading on plasma levels and urinary excretion of relaxin, NT-pro-ANP, and NT-pro-BNP in male volunteers. Journal of Applied Physiology. 2004;97(1):173-179. Excluded because adult blood not measured. [pmid: 14990550].
Hernandez A G.M. Using BNP levels in the assessment of dyspnea. Journal of Respiratory Diseases. 2004;25(10):402-403. Excluded because not a report of a primary study.
Herold K, Hagopian W, Auger J, Poumian-Ruiz E, Taylor L, Donaldson D, et al. Anti-CD3 monoclonal antibody in new-onset type 1 diabetes mellitus. New England Journal of Medicine. 2005;346(22):1692-1698. Excluded because adult blood not measured. [pmid: 12037148].
Herten M, Lenz W, Gerzer R, Drummer C, Herten M, Lenz W, et al. The renal natriuretic peptide urodilatin is present in human kidney. Nephrology Dialysis Transplantation. 1998;13(10):2529-2535. Excluded because adult blood not measured.
Herzog CA. How to manage the renal patient with coronary heart disease: The agony and the ecstasy of opinion-based medicine. Journal of the American Society of Nephrology. 2003;14(10):2556-2572. Excluded because not a report of a primary study. [pmid: 14514733].
Hetmanski D, Sparrow N, Curtis S, Cowley A, Hetmanski D, Sparrow N, et al. Failure of plasma brain natriuretic peptide to identify left ventricular systolic dysfunction in the community. Heart (British Cardiac Society). 2000;84(4):440-441. Excluded because not a report of a primary study. [pmid: 10995422]. [pmcid: 1729438].
Hickman P J.M. Abnormal laboratory results: New cardiac markers. Australian Prescriber. 2003;26(4):88-90. Excluded because not a report of a primary study.
Hill J, Hsu K, Pauly D, Schofield R, Aranda J Jr, et al. Sustained use of nesiritide to aid in bridging to heart transplant. Clinical Cardiology. 2003;26(5):211-214. Excluded because this is a case report or series with 10 subjects. [pmid: 12769247].
Hjortdal V, Stenbog E, Ravn H, Emmertsen K, Jensen K, Pedersen E, et al. Neurohormonal activation late after cavopulmonary connection. Heart (British Cardiac Society). 2000;83(4):439-443. Excluded because adult blood not measured. [pmid: 10722548]. [pmcid: 1729373].
Hobbs F, Davis R, Lip GYH. Heart failure in general practice. British Medical Journal. 2000;320(7235):626-629. Excluded because not a report of a primary study. [pmid: 10698886]. [pmcid: 1117656].
Hobbs F E. Heart failure and venous thromboembolism: A major hidden risk. British Journal of Cardiology. 2004;11(1):27-32. Excluded because not a report of a primary study.
Hobbs R, Miller L, Bott-Silverman C, James K, Rincon G, Grossbard E, et al. Hemodynamic effects of a single intravenous injection of synthetic human brain natriuretic peptide in patients with heart failure secondary to ischemic or idiopathic dilated cardiomyopathy. American Journal of Cardiology. 1919;78(8):896-901. Excluded because adult blood not measured. [pmid: 8888662].
Hobbs R R.M. Therapeutic potential nesiritide (recombinant b-type natriuretic peptide) in the treatment of heart failure. Expert Opinion on Investigational Drugs. 1999;8(7):1063-1072. Excluded because not a report of a primary study. [pmid: 15992106].
Hocher B, Ziebig R, Krause R, Asmus G, Neumayer H, Liefeldt L, et al. Relaxin is an independent risk factor predicting death in male patients with end-stage kidney disease. Circulation. 2005;109(19):2266-2268. Excluded because BNP assay method is not an included one. [pmid: 15136497].
Holcberg G, Miodovnik M, Rosenn B, Kossenjans W, Myatt L, Holcberg G, et al. Interaction of angiotensin II and brain natriuretic peptide in the placentas of normal and diabetic women. Obstetrics & Gynecology. 1995;85(3):428-432. Excluded because adult blood not measured. [pmid: 7862385].
Hollien J. A hormone receptor springs into action. Nature Structural Biology. 2001;8(10):832. Excluded because not a report of a primary study.
Holmes S, Espiner E, Richards A, Yandle T, Frampton C, Holmes S, et al. Renal, endocrine, and hemodynamic effects of human brain natriuretic peptide in normal man. Journal of Clinical Endocrinology & Metabolism. 1993;76(1):91-96. Excluded because this is a case report or series with 10 subjects. [pmid: 8380606].
Holtzman E D.A. Nephrogenic diabetes insipidus: causes revealed. Hospital Practice. 1997;29(3):89-93. Excluded because not a report of a primary study. [pmid: 8132731].
Honisko M, Fink J, Militello M, Mauro V, Alexander K, Honisko ME, et al. Compatibility of argatroban with selected cardiovascular agents. American Journal of Health-System Pharmacy. 1920;61(22):2415-2418. Excluded because adult blood not measured. [pmid: 15581266].
Hopkins W, Chen Z, Fukagawa N, Hall C, Knot H, LeWinter M, et al. Increased atrial and brain natriuretic peptides in adults with cyanotic congenital heart disease: enhanced understanding of the relationship between hypoxia and natriuretic peptide secretion. Circulation. 2006;109(23):2872-2877. Excluded because adult blood not measured. [pmid: 15173030].
Horan D, Hill L, Schulkin J. Childhood sexual abuse and preterm labor in adulthood: an endocrinological hypothesis. Women's Health Issues. 2000;10(1):27-33. Excluded because not a report of a primary study. [pmid: 10697466].
Horio T, Shimada K, Kohno M, Yoshimura T, Kawarabayashi T, Yasunari K, et al. Serial changes in atrial and brain natriuretic peptides in patients with acute myocardial infarction treated with early coronary angioplasty. American Heart Journal. 1993;126(2):293-299. Excluded because BNP assay method is not an included one. [pmid: 8337997].
Hosoda K, Nakao K, Mukoyama M, Saito Y, Jougasaki M, Shirakami G, et al. Expression of brain natriuretic peptide gene in human heart. Production in the ventricle. Hypertension. 1991;17(6 Pt 2):1152-1155. Excluded because adult blood not measured. [pmid: 2045161].
Hughes D, Talwar S, Squire I, Davies J, Ng L, Hughes D, et al. An immunoluminometric assay for N-terminal pro-brain natriuretic peptide: development of a test for left ventricular dysfunction. Clinical Science. 1999;96(4):373-380. Excluded because adult blood not measured. [pmid: 10087244].
Hunt P, Espiner E, Nicholls M, Richards A, Yandle T, Hunt P, et al. Differing biological effects of equimolar atrial and brain natriuretic peptide infusions in normal man. Journal of Clinical Endocrinology & Metabolism. 1996;81(11):3871-3876. Excluded because this is a case report or series with 10 subjects. [pmid: 8923831].
Hunt P, Espiner E, Nicholls M, Richards A, Yandle T, Hunt P, et al. The role of the circulation in processing pro-brain natriuretic peptide (proBNP) to amino-terminal BNP and BNP-32. Peptides. 1997;18(10):1475-1481. Excluded because adult blood not measured. [pmid: 9437705].
Hunt P, Espiner E, Richards A, Yandle T, Frampton C, Nicholls M, et al. Interactions of atrial and brain natriuretic peptides at pathophysiological levels in normal men. American Journal of Physiology. 1995;269(6 Pt 2):R1397-R1403. Excluded because adult blood not measured. [pmid: 8594942].
Hunt P, Richards A, Espiner E, Nicholls M, Yandle T, Hunt P, et al. Bioactivity and metabolism of C-type natriuretic peptide in normal man. Journal of Clinical Endocrinology & Metabolism. 1994;78(6):1428-1435. Excluded because BNP assay method is not an included one. [pmid: 8200946].
Hunt P, Yandle T, Nicholls M, Richards A, Espiner E, Hunt P, et al. The amino-terminal portion of pro-brain natriuretic peptide (Pro-BNP) circulates in human plasma. Biochemical & Biophysical Research Communications. 1909;214(3):1175-1183. Excluded because adult blood not measured. [pmid: 7575527].
Hursting M, Slaughter T, Stead A, Szewczyk K, Witt D, Greenberg CS. Standardization of prothrombin fragment 1.2 measurement: effects of preanalytical variables and calibrator selection. Archives of Pathology & Laboratory Medicine. 1998;122(1):31-36. Excluded because BNP assay method is not an included one. [pmid: 9448013].
Hussey L S. Sex-related differences in heart failure. Heart & Lung: Journal of Acute & Critical Care. 2003;32(4):215-223. Excluded because not a report of a primary study.
Hussey S F.H. Shortness of breath in a 74-year old woman. Laboratory Medicine. 2004;35(7):408-412. Excluded because not a report of a primary study.
Hutcheon S, Gillespie N, Struthers A, McMurdo M, Hutcheon SD, Gillespie ND, et al. B-type natriuretic peptide in the diagnosis of cardiac disease in elderly day hospital patients. Age & Ageing. 2002;31(4):295-301. Excluded because BNP assay method is not an included one. [pmid: 12147568].
Iascone M, Vittorini S, Collavoli A, Cupelli A, Kraft G, Biagini A, et al. A rapid procedure for the quantitation of natriuretic peptide RNAs by competitive RT-PCR in congenital heart defects. Journal of Endocrinological Investigation. 1999;22(11):835-842. Excluded because adult blood not measured. [pmid: 10710270].
Igaki T, Itoh H, Suga S, Hama N, Ogawa Y, Komatsu Y, et al. C-type natriuretic peptide in chronic renal failure and its action in humans. Kidney International - Supplement. 1996;55:S144-S147. Excluded because BNP assay method is not an included one. [pmid: 8743538].
Ikeda T, Matsuda K, Itoh H, Shirakami G, Miyamoto Y, Yoshimasa T, et al. Plasma levels of brain and atrial natriuretic peptides elevate in proportion to left ventricular end-systolic wall stress in patients with aortic stenosis. American Heart Journal. 1997;133(3):307-314. Excluded because BNP assay method is not an included one. [pmid: 9060799].
Inagaki T, Yamamoto M, Tsubouchi K, Miyaoka T, Uegaki J, Maeda T, et al. Echocardiographic investigation of pericardial effusion in a case of anorexia nervosa. International Journal of Eating Disorders. 2003;33(3):364-366. Excluded because not a report of a primary study. [pmid: 12655635].
Inamura T, Ueno H, Nishiyama T, Nakamura M, Ikezaki K, Inoha S, et al. Severe hyponatremia in a case of severe spinal injury: Sequential examination of factors affecting water-electrolyte balance. Brain & Nerve. 2002;54(1):23-27. Excluded because this is a case report or series with 10 subjects. [pmid: 11868347].
Ishikawa S, Miyauchi T, Ueno M, Sagawa K, Sakai S, Ushinohama H, et al. Abnormal neurohumoral responses to exercise in patients with heart disease: inhibition of an increase in endothelin-1 production during exercise. Journal of Cardiovascular Pharmacology. 1998;31(Suppl 1):S406-S411. Excluded because BNP assay method is not an included one. [pmid: 9595498].
Ishikawa Y, Bach J, Minami R, Ishikawa Y, Bach J, Minami R. Cardioprotection for Duchenne's muscular dystrophy. American Heart Journal. 1999;137(5):895-902. Excluded because adult blood not measured. [pmid: 10220639].
Ishizaka Y, Yamamoto Y, Fukunaga T, Yokota N, Kida O, Kitamura K, et al. Plasma concentration of human brain natriuretic peptide in patients on hemodialysis. American Journal of Kidney Diseases. 1994;24(3):461-472. Excluded because BNP assay method is not an included one. [pmid: 8079971].
Ishizaka Y, Yamamoto Y, Tanaka M, Kato F, Ishizaka Y, Yokota N, et al. Molecular forms of human brain natriuretic peptide (BNP) in plasma of patients on hemodialysis (HD). Clinical Nephrology. 1995;43(4):237-242. Excluded because BNP assay method is not an included one. [pmid: 7606877].
Isnard R, Pousset F, Trochu J, Chafirovskaia O, Carayon A, Golmard J, et al. Prognostic value of neurohormonal activation and cardiopulmonary exercise testing in patients with chronic heart failure. American Journal of Cardiology. 1908;86(4):417-421. Excluded because BNP assay method is not an included one. [pmid: 10946035].
Isnard R, Pousset F, Chafirovskaia O, Carayon A, Hulot J, Thomas D, et al. Combination of B-type natriuretic peptide and peak oxygen consumption improves risk stratification in outpatients with chronic heart failure. American Heart Journal. 2003;146(4):729-735. Excluded because BNP assay method is not an included one. [pmid: 14564330].
Iso T, Arai M, Wada A, Kogure K, Suzuki T, Nagai R, et al. Humoral factor(s) produced by pressure overload enhance cardiac hypertrophy and natriuretic peptide expression. American Journal of Physiology. 1997;273(1 Pt 2):H113-H118. Excluded because adult blood not measured. [pmid: 9249481].
Isotani E, Suzuki R, Tomita K, Hokari M, Monma S, Marumo F, et al. Alterations in plasma concentrations of natriuretic peptides and antidiuretic hormone after subarachnoid hemorrhage. Stroke. 1994;25(11):2198-2203. Excluded because BNP assay method is not an included one. [pmid: 7974545].
Isotani H, Kameoka K, Sasaki I, Hida H, Kakutani S, Tasaki T, et al. Plasma brain natriuretic peptide levels in normotensive type 2 diabetic patients without cardiac disease. Diabetes Care. 2000;23(6):859-860. Excluded because not a report of a primary study. [pmid: 10841011].
Itoh H, Sagawa N, Hasegawa M, Nanno H, Kobayashi F, Ihara Y, et al. Expression of biologically active receptors for natriuretic peptides in the human uterus during pregnancy. Biochemical & Biophysical Research Communications. 1908;203(1):602-607. Excluded because adult blood not measured. [pmid: 7915521].
Itoh H, Sagawa N, Mori T, Mukoyama M, Nakao K, Imura H, et al. Plasma brain natriuretic peptide level in pregnant women with pregnancy-induced hypertension. Obstetrics & Gynecology. 1993;82(1):71-77. Excluded because BNP assay method is not an included one. [pmid: 8515929].
Itoh H, Sagawa N, Nanno H, Mori T, Mukoyama M, Itoh H, et al. Impaired guanosine 3',5'-cyclic phosphate production in severe pregnancy-induced hypertension with high plasma levels of atrial and brain natriuretic peptides. Endocrine Journal. 1997;44(3):389-393. Excluded because BNP assay method is not an included one. [pmid: 9279514].
Iwao T, Oho K, Nakano R, Sakai T, Sato M, Miyamoto Y, et al. High plasma cardiac natriuretic peptides associated with enhanced cyclic guanosine monophosphate production in preascitic cirrhosis. Journal of Hepatology. 2000;32(3):426-433. Excluded because BNP assay method is not an included one. [pmid: 10735612].
Jackson G, Gibbs C, Davies M, Lip GY. ABC of heart failure: pathophysiology. BMJ. 2001;320(7228):167-170. Excluded because not a report of a primary study. [pmid: 10634740].
Jackson K, Robertson M, Fielding B, Frayn K, Williams CM. Second meal effect: modified sham feeding does not provoke the release of stored triacylglycerol from a previous high-fat meal. British Journal of Nutrition. 2001;85(2):149-156. Excluded because BNP assay method is not an included one. [pmid: 11242482].
Jacoby D D.J. Renin-angiotensin system and atherothrombotic disease: from genes to treatment. Archives of Internal Medicine. 2005;163(10):1155-1164. Excluded because not a report of a primary study. [pmid: 12767951].
Jang T, Aubin C, Naunheim R, Char D. Ultrasonography of the internal jugular vein in patients with dyspnea without jugular venous distention on physical examination. Annals of Emergency Medicine. 2004;44(2):160-168. Excluded because this is a case report or series with 10 subjects. [pmid: 15278091].
Jensen K, Carstens J, Ivarsen P, Pedersen E, Jensen K, Carstens J, et al. A new, fast and reliable radioimmunoassay of brain natriuretic peptide in human plasma. Reference values in healthy subjects and in patients with different diseases. Scandinavian Journal of Clinical & Laboratory Investigation. 1997;57(6):529-540. Excluded because not a report of a primary study. [pmid: 9350073].
Jensen K, Carstens J, Pedersen E, Jensen K, Carstens J, Pedersen EB. Effect of BNP on renal hemodynamics, tubular function and vasoactive hormones in humans. American Journal of Physiology. 1998;274(1 Pt 2):F63-F72. Excluded because BNP assay method is not an included one. [pmid: 9458824].
Jensen K, Eiskjaer H, Carstens J, Pedersen E, Jensen K, Eiskjaer H, et al. Renal effects of brain natriuretic peptide in patients with congestive heart failure. Clinical Science. 1999;96(1):5-15. Excluded because BNP assay method is not an included one. [pmid: 9857101].
Jernberg T, James S, Lindahl B, Stridsberg M, Venge P, Wallentin L, et al. NT-proBNP in unstable coronary artery disease--experiences from the FAST, GUSTO IV and FRISC II trials. European Journal of Heart Failure. 2003;6(3):319-325. Excluded because not a report of a primary study. [pmid: 14987583].
Jimenez C, Koulmann N, Mischler I, Allevard A, Launay J, Savourey G, et al. Plasma compartment filling after exercise or heat exposure. Medicine and Science in Sports and Exercise. 2002;34(10):1624-1631. Excluded because this is a case report or series with 10 subjects. [pmid: 12370564].
Johannsson G, Sverrisdottir Y, Ellegard L, Lundberg P, Herlitz H, Johannsson GSYBELLPAaHH. GH increases extracellular volume by stimulating sodium reabsorption in the distal nephron and preventing pressure natriuresis. Journal of Clinical Endocrinology & Metabolism. 2002;87(4):1743-1749. Excluded because this is a case report or series with 10 subjects. [pmid: 11932310].
John JP. Vasopeptide inhibition: A novel approach to blood pressure management. P & T. 2000;25(5):217-224. Excluded because not a report of a primary study.
Johnson M, McDonagh T, Harkness A, McKay S, Dargie HJ. Morphine for the relief of breathlessness in patients with chronic heart failure - A pilot study. European Journal of Heart Failure. 2002;4(6):753-756. Excluded because BNP assay method is not an included one. [pmid: 12453546].
Jones A, Kline J, Jones AE, Kline JA. Elevated brain natriuretic peptide in septic patients without heart failure. Annals of Emergency Medicine. 2003;42(5):714-715. Excluded because not a report of a primary study. [pmid: 14596247].
Jones C, Goodfellow J, Bleasdale R, Frenneaux MP. Modulation of interaction between left ventricular ejection and the arterial compartment: Assessment of aortic wave travel. Heart & Vessels. 2000;15(6):247-255. Excluded because not a report of a primary study. [pmid: 11766061].
Jorgensen M, Pedersen M, Siggaard C, Sorensen T, Mulvad G, Hansen J, et al. Ethnic, geographic and dietary influences upon vasoactive hormones and blood pressure among Greenland Inuit and Danes. Blood Pressure. 2003;12(56):298-306. Excluded because BNP assay method is not an included one. [pmid: 14763661].
Jortani S, Prabhu S, Valdes JR. Strategies for Developing Biomarkers of Heart Failure. Clinical Chemistry. 2004;50(2):265-278. Excluded because adult blood not measured. [pmid: 14656906].
Josephson S, Barnett P, Josephson SaBPP. Nesiritide: practical approach and benefits in the outpatient setting. Journal of Cardiovascular Nursing. 2004;19(5):358-363. Excluded because BNP used as treatment. [pmid: 15495897].
Kaaja R, Moore M, Yandle T, Ylikorkala O, Frampton C, Nicholls M, et al. Blood pressure and vasoactive hormones in mild preeclampsia and normal pregnancy. Hypertension in Pregnancy. 1999;18(2):173-187. Excluded because BNP assay method is not an included one. [pmid: 10476619].
Kagaya Y, Otani H, Tanikawa T, Namiuchi S, Isoyama S, Shirato K, et al. Concentrations of angiotensin II, endothelin-1, and BNP in the coronary sinus and ascending aorta of patients with heart disease. Heart (British Cardiac Society). 1999;81(1):102-103. Excluded because not a report of a primary study. [pmid: 10328668]. [pmcid: 1728897].
Kajita M, Ezura Y, Iwasaki H, Ishida R, Yoshida H, Kodaira M, et al. Association of the -381T/C promoter variation of the brain natriuretic peptide gene with low bone-mineral density and rapid postmenopausal bone loss. Journal of Human Genetics. 2003;48(2):77-81. Excluded because BNP assay method is not an included one. [pmid: 12601551].
Kalra P A.D. More evidence for bedside BNP in heart failure assessment. International Journal of Cardiology. 2002;86(23):149-152. Excluded because not a report of a primary study.
Kalra P, A.J.S. Therapeutic potential of the natriuretic peptide system. British Journal of Cardiology 2002; 9(5). Excluded because not a report of a primary study
Kalra P, Clague J, Bolger A, Anker S, Poole-Wilson P, Struthers A, et al. Myocardial production of C-type natriuretic peptide in chronic heart failure. Circulation. 2003;107(4):571-573. Excluded because BNP assay method is not an included one. [pmid: 12566368].
Kalra P S. Regulation of lipolysis: Natriuretic peptides and the development of cachexia. International Journal of Cardiology. 2002;85(1):125-132. Excluded because adult blood not measured. [pmid: 12163217].
Kambayashi Y, Nakao K, Mukoyama M, Saito Y, Ogawa Y, Shiono S, et al. Isolation and sequence determination of human brain natriuretic peptide in human atrium. FEBS Letters. 1990;259(2):341-345. Excluded because adult blood not measured. [pmid: 2136732].
Kammula U, Marincola F, Rosenberg SA. Real-time quantitative polymerase chain reaction assessment of immune reactivity in melanoma patients after tumor peptide vaccination. Journal of the National Cancer Institute. 1908;92(16):1336-1344. Excluded because adult blood not measured. [pmid: 10944556].
Kanda T, Inoue M, Kotajima N, Fujimaki S, Hoshino Y, Kurabayashi M, et al. Circulating interleukin-6 and interleukin-6 receptors in patients with acute and recent myocardial infarction. Cardiology. 2000;93(3):191-196. Excluded because BNP assay method is not an included one. [pmid: 10965091].
Kanegae K, Hiroshige K, Suda T, Iwamoto M, Ohta T, Nakashima Y, et al. Pharmacokinetics of bisoprolol and its effect on dialysis refractory hypertension. International Journal of Artificial Organs. 1999;22(12):798-804. Excluded because BNP assay method is not an included one. [pmid: 10654875].
Kaneko T, Shirakami G, Nakao K, Nagata I, Nakagawa O, Hama N, et al. C-type natriuretic peptide (CNP) is the major natriuretic peptide in human cerebrospinal fluid. Brain Research. 2005;612(12):104-109. Excluded because BNP assay method is not an included one. [pmid: 8330189].
Kang YJ. Molecular and cellular mechanisms of cardiotoxicity. Environmental Health Perspectives. 2001;109(SUPPL. 1):27-34. Excluded because adult blood not measured. [pmid: 11250803].
Karagiannis A, Tziomalos K, Zamboulis C. Plasma B-type natriuretic peptide is related to left ventricular mass in hypertensive patients [4]. European Heart Journal. 2004;25(21):1967. Excluded because not a report of a primary study. [pmid: 15522477].
Karjalainen A, Ruskoaho H, Vuolteenaho O, Heikkinen J, Backstrom A, Savolainen M, et al. Effects of estrogen replacement therapy on natriuretic peptides and blood pressure. Maturitas. 2003;47(3):201-208. Excluded because BNP assay method is not an included one. [pmid: 15036490].
Karmazyn M. Inhibitors of sodium-hydrogen exchange as therapeutic agents for the treatment of heart disease. Expert Opinion on Therapeutic Patents. 2003;13(9):1411-1425. Excluded because not a report of a primary study.
Kasama S, Toyama T, Kumakura H, Takayama Y, Ichikawa S, Tange S, et al. Dobutamine stress 99mTc-tetrofosmin quantitative gated SPECT predicts improvement of cardiac function after carvedilol treatment in patients with dilated cardiomyopathy. Journal of Nuclear Medicine. 2004;45(11):1878-1884. Excluded because BNP assay method is not an included one. [pmid: 15534058].
Kasuya H, Onda H, Yoneyama T, Sasaki T, Hori T. Bedside monitoring of circulating blood volume after subarachnoid hemorrhage. Stroke. 2003;34(4):956-960. Excluded because BNP assay method is not an included one. [pmid: 12649506].
Katayama T, Nakashima H, Furudono S, Honda Y, Suzuki S, Yano K, et al. Evaluation of neurohumoral activation (adrenomedullin, BNP catecholamines, etc.) in patients with acute myocardial infarction. Internal Medicine. 2004;43(11):1015-1022. Excluded because BNP assay method is not an included one. [pmid: 15609694].
Katayama T, Nakashima H, Takagi C, Honda Y, Suzuki S, Yano K, et al. Predictors of mortality in patients with acute myocardial infarction and cardiogenic shock. Circulation Journal. 2005;69(1):83-88. Excluded because BNP assay method is not an included one. [pmid: 15635209].
Kato H, Katori T, Nakamura Y, Kawarasaki H. Moderate-term effect of epoprostenol on severe portopulmonary hypertension. Pediatric Cardiology. 2003;24(1):50-53. Excluded because BNP assay method is not an included one. [pmid: 12574979].
Kato H, Yasue H, Yoshimura M, Tanaka H, Miyao Y, Okumura K, et al. Suppression of hyperventilation-induced attacks with infusion of B-type (brain) natriuretic peptide in patients with variant angina. American Heart Journal. 1994;128(6 Pt 1):1098-1104. Excluded because BNP assay method is not an included one. [pmid: 7985589].
Kato M, Kinugawa T, Omodani H, Osaki S, Ogino K, Hisatome I, et al. Augmented response in plasma atrial natriuretic peptide to dynamic exercise in patients with congestive heart failure. Japanese Circulation Journal. 1996;60(12):909-916. Excluded because BNP assay method is not an included one. [pmid: 8996680].
Katz SD. Nesiritide (hBNP): A new class of therapeutic peptide for the treatment of decompensated congestive heart failure. Prevention & Management of Congestive Heart Failure. 2001;7(2):78-87. Excluded because not a report of a primary study.
Kawakami R, Saito Y, Kishimoto I, Harada M, Kuwahara K, Takahashi N, et al. Overexpression of brain natriuretic peptide facilitates neutrophil infiltration and cardiac matrix metalloproteinase-9 expression after acute myocardial infarction. Circulation. 1920;110(21):3306-3312. Excluded because adult blood not measured. [pmid: 15545516].
Kawamura T, Wago M, Kawaguchi H, Tahara M, Yuge M, Kawamura T, et al. Plasma brain natriuretic peptide concentrations in patients with Kawasaki disease. Pediatrics International. 2000;42(3):241-248. Excluded because adult blood not measured. [pmid: 10881579].
Kawamura T, Wago M, Kawamura TaWM. Brain natriuretic peptide can be a useful biochemical marker for myocarditis in patients with Kawasaki disease. Cardiology in the Young. 2002;12(2):153-158. Excluded because adult blood not measured. [pmid: 12018720].
Kawut S H.I. New answers raise new questions in pulmonary arterial hypertension. European Respiratory Journal. 2004;23(6):799-801. Excluded because not a report of a primary study. [pmid: 15218988].
Kelley WS. Therapeutic peptides: The devil is in the details. Bio-Technology. 1996;14(1):28. Excluded because not a report of a primary study. [pmid: 9636310].
Kellner M, Yassouridis A, Hua Y, Wendrich M, Jahn H, Wiedemann K, et al. Intravenous C type natriuretic peptide augments behavioral and endocrine effects of cholecystokinin tetrapeptide in healthy men. Journal of Psychiatric Research. 2002;36(1):1-6. Excluded because BNP assay method is not an included one. [pmid: 11755455].
Kelly C, Newby D, McDonagh T, Mackay T, Barr J, Boon N, et al. Randomised controlled trial of continuous positive airway pressure and standard oxygen therapy in acute pulmonary oedema; effects on plasma brain natriuretic peptide concentrations.[see comment]. European Heart Journal. 2002;23(17):1379-1386. Excluded because BNP assay method is not an included one. [pmid: 12191749].
Kelly P, MacAulay-Hunter E, Astridge P, Lowry P, Perrins E, Kaye GC. Failure of plasma atrial natriuretic peptide levels to increase during exercise in patients with chronic atrial fibrillation. Pacing and Clinical Electrophysiology. 1997;20(1 part 1):10-16. Excluded because BNP assay method is not an included one. [pmid: 9121953].
Kemp M, Donovan J, Higham H, Hooper J. Biochemical markers of myocardial injury. British Journal of Anaesthesia. 2004;93(1):63-73. Excluded because not a report of a primary study. [pmid: 15096441].
Kerkela R, Pikkarainen S, Majalahti-Palviainen T, Tokola H, Ruskoaho H, Kerkela RPSM-PTTHaRH. Distinct roles of mitogen-activated protein kinase pathways in GATA-4 transcription factor-mediated regulation of B-type natriuretic peptide gene. Journal of Biological Chemistry. 2002;277(16):13752-13760. Excluded because adult blood not measured. [pmid: 11827958].
Kerzner R M.W. Management of heart failure in the elderly. Current Cardiology Reports. 2003;5(3):223-228. Excluded because not a report of a primary study. [pmid: 12691641].
Kihara T, Biro S, Ikeda Y, Fukudome T, Shinsato T, Masuda A, et al. Effects of repeated sauna treatment on ventricular arrhythmias in patients with chronic heart failure. Circulation Journal. 2004;68(12):1146-1151. Excluded because BNP assay method is not an included one. [pmid: 15564698].
Kihara T, Biro S, Imamura M, Yoshifuku S, Takasaki K, Ikeda Y, et al. Repeated sauna treatment improves vascular endothelial and cardiac function in patients with chronic heart failure. Journal of the American College of Cardiology. 2002;39(5):754-759. Excluded because BNP assay method is not an included one. [pmid: 11869837].
Kinoshita M, Tsutamoto T, Kinoshita M, Tsutamoto T. Roles of neurohumoral factors in the progression of heart failure. Internal Medicine. 1996;35(1):58-59. Excluded because not a report of a primary study. [pmid: 8652940].
Kinugawa T, Kato M, Ogino K, Osaki S, Igawa O, Hisatome I, et al. Effects of Angiotensin II Type 1 Receptor Antagonist, Losartan, on Ventilatory Response to Exercise and Neurohormonal Profiles in Patients with Chronic Heart Failure. Japanese Journal of Physiology. 2004;54(1):15-21. Excluded because BNP assay method is not an included one. [pmid: 15040844].
Kirchhoff W, Gradaus R, Stypmann J, Deng M, Tian T, Scheld H, et al. Vasoactive peptides during long-term follow-up of patients after cardiac transplantation. Journal of Heart & Lung Transplantation. 2004;23(3):284-288. Excluded because BNP assay method is not an included one. [pmid: 15019637].
Kirsch J, Muro J, Stansbury D, Fischer C, Monfore R, Light RW. Effect of naloxone on maximal exercise performance and control of ventilation in COPD. Chest. 1989;96(4):761-766. Excluded because adult blood not measured. [pmid: 2676390].
Kita H, Ohi M, Chin K, Noguchi T, Otsuka N, Tsuboi T, et al. The nocturnal secretion of cardiac natriuretic peptides during obstructive sleep apnoea and its response to therapy with nasal continuous positive airway pressure. Journal of Sleep Research. 1998;7(3):199-207. Excluded because BNP assay method is not an included one. [pmid: 9785275].
Kitzman D, Little W, Brubaker P, Anderson R, Hundley W, Marburger C, et al. Pathophysiological characterization of isolated diastolic heart failure in comparison to systolic heart failure. JAMA: Journal of the American Medical Association. 2002;288(17):2144-2150. Excluded because BNP assay method is not an included one.
Kjaer A, Appel J, Hildebrandt P, Petersen C, Kjaer AAJHPaPCL. Basal and exercise-induced neuroendocrine activation in patients with heart failure and in normal subjects. European Journal of Heart Failure. 2004;6(1):29-39. Excluded because BNP assay method is not an included one. [pmid: 15012916].
Klein L M. Therapeutic strategies for patients hospitalized with worsening heart failure. Italian Heart Journal: Official Journal of the Italian Federation of Cardiology. 2003;4(2):71-74. Excluded because not a report of a primary study. [pmid: 12762267].
Klemola R, Tikkanen I, Vuolteenaho O, Toivonen L, Laine M, Klemola R, et al. Plasma and pericardial fluid natriuretic peptide levels in postinfarction ventricular dysfunction. European Journal of Heart Failure. 2001;3(1):21-26. Excluded because BNP assay method is not an included one. [pmid: 11163731].
Knight E, Fish L, Kiely D, Marcantonio E, Davis K, Minaker KL. Atrial natriuretic peptide and the development of congestive heart failure in the oldest old: a seven-year prospective study. Journal of the American Geriatrics Society. 1999;47(4):407-411. Excluded because BNP assay method is not an included one. [pmid: 10203114].
Knudsen C, Omland T, Clapton P, Henriksson P. Chest radiographs and BNP levels provided complementary information beyond clinical findings for diagnosing heart failure. Evidence Based Medicine. 2004;9(5):152. Excluded because not a report of a primary study.
Kodama-Takahashi K, Kurata A, Ohshima K, Yamamoto K, Uemura S, Watanabe S, et al. Effect of cilostazol on the ventricular escape rate and neurohumoral factors in patients with third-degree atrioventricular block.[see comment]. Chest. 2003;123(4):1161-1169. Excluded because BNP assay method is not an included one. [pmid: 12684307].
Koerner M, Loebe M, Lisman K, Stetson S, Lafuente J, Noon G, et al. New strategies for the management of acute decompensated heart failure. Current Opinion in Cardiology. 2001;16(3):164-173. Excluded because not a report of a primary study. [pmid: 11357011].
Kohno M, Horio T, Toda I, Akioka K, Tahara A, Teragaki M, et al. Cosecretion of atrial and brain natriuretic peptides during supraventricular tachyarrhythmias. American Heart Journal. 1992;123(5):1382-1384. Excluded because BNP assay method is not an included one. [pmid: 1533489].
Kohno M, Horio T, Yasunari K, Yokokawa K, Ikeda M, Kurihara N, et al. Stimulation of brain natriuretic peptide release from the heart by thyroid hormone. Metabolism: Clinical & Experimental. 1993;42(8):1059-1064. Excluded because BNP assay method is not an included one. [pmid: 8345811].
Kohno M, Horio T, Yokokawa K, Murakawa K, Yasunari K, Akioka K, et al. Brain natriuretic peptide as a cardiac hormone in essential hypertension. American Journal of Medicine. 1992;92(1):29-34. Excluded because BNP assay method is not an included one. [pmid: 1530996].
Kohno M, Horio T, Yokokawa K, Akioka K, Ikeda M, Takeda T, et al. Pulmonary arterial brain natriuretic peptide concentration and cardiopulmonary hemodynamics during exercise in patients with essential hypertension. Metabolism: Clinical & Experimental. 1992;41(12):1273-1275. Excluded because BNP assay method is not an included one. [pmid: 1461132].
Kohno M, Horio T, Yokokawa K, Murakawa K, Yasunari K, Kurihara N, et al. Atrial and brain natriuretic peptides: secretion during exercise in patients with essential hypertension and modulation by acute angiotensin-converting enzyme inhibition. Clinical & Experimental Pharmacology & Physiology. 1992;19(3):193-200. Excluded because BNP assay method is not an included one. [pmid: 1387838].
Kohno M, Horio T, Yokokawa K, Yasunari K, Ikeda M, Minami M, et al. Brain natriuretic peptide as a marker for hypertensive left ventricular hypertrophy: changes during 1-year antihypertensive therapy with angiotensin-converting enzyme inhibitor. American Journal of Medicine. 1995;98(3):257-265. Excluded because BNP assay method is not an included one. [pmid: 7872342].
Kohno M, Minami M, Kano H, Yasunari K, Maeda K, Hanehira T, et al. Effect of angiotensin-converting enzyme inhibitor on left ventricular parameters and circulating brain natriuretic peptide in elderly hypertensives with left venticular hypertrophy. Metabolism: Clinical & Experimental. 2000;49(10):1356-1360. Excluded because BNP assay method is not an included one. [pmid: 11079829].
Kohno M, Yasunari K, Yokokawa K, Horio T, Kano H, Minami M, et al. Plasma brain natriuretic peptide during ergometric exercise in hypertensive patients with left ventricular hypertrophy. Metabolism: Clinical & Experimental. 1996;45(11):1326-1329. Excluded because BNP assay method is not an included one. [pmid: 8931634].
Kohno M, Yokokawa K, Yasunari K, Kano H, Minami M, Hanehira T, et al. Changes in plasma cardiac natriuretic peptides concentrations during 1 year treatment with angiotensin-converting enzyme inhibitor in elderly hypertensive patients with left ventricular hypertrophy. International Journal of Clinical Pharmacology & Therapeutics. 1997;35(1):38-42. Excluded because BNP assay method is not an included one. [pmid: 9021441].
Kohno M, Yokokawa K, Minami M, Kano H, Yasunari K, Hanehira T, et al. Association between angiotensin-converting enzyme gene polymorphisms and regression of left ventricular hypertrophy in patients treated with angiotensin-converting enzyme inhibitors. American Journal of Medicine. 1999;106(5):544-549. Excluded because BNP assay method is not an included one. [pmid: 10335726].
Kohse K, Feifel K, Mayer-Wehrstein R, Kohse K, Feifel K, Mayer-Wehrstein R. Differential regulation of brain and atrial natriuretic peptides in hemodialysis patients. Clinical Nephrology. 1993;40(2):83-90. Excluded because BNP assay method is not an included one. [pmid: 8222377].
Koller K, Lowe D, Bennett G, Minamino N, Kangawa K, Matsuo H, et al. Selective activation of the B natriuretic peptide receptor by C-type natriuretic peptide (CNP). Science. 1991;252(5002):120-123. Excluded because adult blood not measured. [pmid: 1672777].
Komarek M, Bernheim A, Schindler R, Steden R, Kiowski W, Brunner-La Rocca H, et al. Vascular effects of natriuretic peptides in healthy men. Journal of Cardiovascular Pharmacology & Therapeutics. 2004;9(4):263-270. Excluded because BNP assay method is not an included one. [pmid: 15678245].
Konishi C, Shiraishi J, Muraguchi N, Ohtsuki K, Inoue M, Tatsumi T, et al. Beneficial effect of cibenzoline on left ventricular pressure gradient with sigmoid septum. Circulation Journal. 2004;68(10):968-971. Excluded because this is a case report or series with 10 subjects. [pmid: 15459474].
Konstantinides S. Should thrombolytic therapy be used in patients with pulmonary embolism?. American Journal of Cardiovascular Drugs. 2004;4(2):69-74. Excluded because not a report of a primary study. [pmid: 15049719].
Koseki Y, Watanabe J, Shinozaki T, Sakuma M, Komaru T, Fukuchi M, et al. Characteristics and 1-year prognosis of medically treated patients with chronic heart failure in Japan. Circulation Journal. 2003;67(5):431-436. Excluded because not a report of a primary study. [pmid: 12736483].
Koshkina N, Waldrep J, Knight V. Camptothecins and lung cancer: Improved delivery systems by aerosol. Current Cancer Drug Targets. 2003;3(4):251-264. Excluded because not a report of a primary study. [pmid: 12871056].
Kosmala W, Kucharski W, Przewlocka-Kosmala M, Mazurek W. Comparison of left ventricular function by tissue Doppler imaging in patients with diabetes mellitus without systemic hypertension versus diabetes mellitus with systemic hypertension. American Journal of Cardiology. 2004;94(3):395-399. Excluded because BNP assay method is not an included one. [pmid: 15276118].
Kosmala W, Spring A, Zysko D, Halawa B, Witkowska M. Effects of exercise on left ventricular diastolic dysfunction and neurohormonal activity in patients with essential hypertension. Kardiologia Polska. 1999;50(3):217-224. Excluded because BNP assay method is not an included one.
Kotajima N, Kimura T, Kanda T, Kuwabara A, Fukumura Y, Murakami M, et al. Reciprocal increase of circulating interleukin-10 and interleukin-6 in patients with acute myocardial infarction. Heart (British Cardiac Society). 2001;86(6):704. Excluded because BNP assay method is not an included one. [pmid: 11711475]. [pmcid: 1730005].
Kraemer W, Fleck S, Maresh C, Ratamess N, Gordon S, Goetz K, et al. Acute hormonal responses to a single bout of heavy resistance exercise in trained power lifters and untrained men. Canadian Journal of Applied Physiology. 1999;24(6):524-537. Excluded because BNP assay method is not an included one. [pmid: 10638340].
Krause A, Liepke C, Meyer M, Adermann K, Forssmann W, Maronde E, et al. Human natriuretic peptides exhibit antimicrobial activity. European Journal of Medical Research. 2005;6(5):215-218. Excluded because adult blood not measured. [pmid: 11410403].
Kucher N S.Z. Clinician update Cardiac biomarkers for risk stratification of patients with acute pulmonary embolism. Circulation. 2003;108(18):2191-2194. Excluded because adult blood not measured. [pmid: 14597581].
Kuhn M, Voss M, Mitko D, Stypmann J, Schmid C, Kawaguchi N, et al. Left ventricular assist device support reverses altered cardiac expression and function of natriuretic peptides and receptors in end-stage heart failure. Cardiovascular Research. 2004;64(2):308-314. Excluded because adult blood not measured. [pmid: 15485690].
Kumagai J, Yorioka N, Kawanishi H, Moriishi M, Komiya Y, Asakimori Y, et al. Relationship between erythropoietin and chronic heart failure in patients on chronic hemodialysis. Journal of the American Society of Nephrology. 1999;10(11):2407-2411. Excluded because BNP assay method is not an included one. [pmid: 10541302].
Kuntzen C, Gulberg V, Gerbes A, Kuntzen CGVaGAL. Use of a mixed endothelin receptor antagonist in portopulmonary hypertension: a safe and effective therapy?. Gastroenterology. 2005;128(1):164-168. Excluded because adult blood not measured. [pmid: 15633133].
Kurabayashi H, Tamura K, Tamura J, Kubota K, Kurabayashi H, Tamura K, et al. The effects of hydraulic pressure on atrial natriuretic peptide during rehabilitative head-out water immersion. Life Sciences. 1907;69(9):1017-1021. Excluded because BNP assay method is not an included one. [pmid: 11508643].
Kurian D, Wagner I, Klapholz M, Kurian DC, Wagner IJ, Klapholz M. Nesiritide in pulmonary hypertension. Chest. 2004;126(1):302-305. Excluded because not a report of a primary study. [pmid: 15249476].
Kurosaki H, Tawada T, Kawasoe S, Ohashi Y, Goto M, Kurosaki H, et al. A model for ZnII-containing-beta-lactamase: synthesis, X-ray crystal structure of a zinc(II) complex bearing thiol group and hydrolysis of phosphate diester. Bioorganic & Medicinal Chemistry Letters. 2000;10(12):1333-1337. Excluded because adult blood not measured. [pmid: 10890158].
Kurose M, Yoshimura M, Yasue H, Kurose M, Yoshimura M, Yasue H. Raised plasma BNP in a patient with acute pulmonary thromboembolism. Heart (British Cardiac Society). 1997;78(3):320-321. Excluded because not a report of a primary study. [pmid: 9391303].
Kuznar W. Admissions, BNP levels drop with valsartan. Cardiology Review 2002; 19(3). Excluded because not a report of a primary study
Kyriakides Z, Markianos M, Michalis L, Antoniadis A, Nikolaou N, Kremastinos D, et al. Brain natriuretic peptide increases acutely and much more prominently than atrial natriuretic peptide during coronary angioplasty.[see comment]. Clinical Cardiology. 2000;23(4):285-288. Excluded because BNP assay method is not an included one. [pmid: 10763077].
La Villa G, Bisi G, Lazzeri C, Fronzaroli C, Stefani L, Barletta G, et al. Cardiovascular effects of brain natriuretic peptide in essential hypertension. Hypertension. 1995;25(5):1053-1057. Excluded because BNP assay method is not an included one. [pmid: 7737716].
La Villa G, Fronzaroli C, Lazzeri C, Porciani C, Bandinelli R, Vena S, et al. Cardiovascular and renal effects of low dose brain natriuretic peptide infusion in man. Journal of Clinical Endocrinology & Metabolism. 1994;78(5):1166-1171. Excluded because adult blood not measured. [pmid: 8175974].
La Villa G, Mannelli M, Lazzeri C, Vecchiarino S, de Feo M, Tosti GC, et al. Different effects of atrial and C-type natriuretic peptide on the urinary excretion of endothelin-1 in man. Clinical Science. 1998;95(5):595-602. Excluded because adult blood not measured. [pmid: 9791046].
La Villa G, Padeletti L, Lazzeri C, Salvi S, Michelucci A, Fronzaroli C, et al. Plasma levels of natriuretic peptides during ventricular pacing in patients with a dual chamber pacemaker. Pacing & Clinical Electrophysiology. 1994;17(5 Pt 1):953-958. Excluded because BNP assay method is not an included one. [pmid: 7517530].
La Villa G, Riccardi D, Lazzeri C, Casini RVDSA, Tosti GC, Fronzaroli C, et al. Blunted natriuretic response to low-dose brain natriuretic peptide infusion in nonazotemic cirrhotic patients with ascites and avid sodium retention. Hepatology. 1995;22(6):1745-1750. Excluded because BNP assay method is not an included one. [pmid: 7489983].
La Villa G, Romanelli R, Casini RVT-GC, de Feo M, Marra F, Laffi G, et al. Plasma levels of brain natriuretic peptide in patients with cirrhosis. Hepatology. 1992;16(1):156-161. Excluded because BNP assay method is not an included one. [pmid: 1618467].
La Villa G, Stefani L, Lazzeri C, Zurli C, Guerra C, Barletta G, et al. Acute effects of physiological increments of brain natriuretic peptide in humans. Hypertension. 1995;26(4):628-633. Excluded because BNP assay method is not an included one. [pmid: 7558223].
La Villa G, Vena S, Conti A, Fronzaroli C, Brat A, Lazzeri C, et al. Plasma levels of brain natriuretic peptide in healthy subjects and patients with essential hypertension: response to posture. Clinical Science. 1993;85(4):411-416. Excluded because BNP assay method is not an included one. [pmid: 8222505].
Lader E. Doppler echocardiography was more accurate than B-type natriuretic peptide assay for detecting CHF in acute dyspnea. ACP Journal Club. 2003;v139(1):22. Excluded because not a report of a primary study. [pmid: 12841726].
Lainchbury J A.M. Exercise testing in the assessment of chronic congestive heart failure. Heart (British Cardiac Society). 2002;88(5):538-543. Excluded because not a report of a primary study. [pmid: 12381653]. [pmcid: 1767430].
Lainchbury J, Nicholls M, Espiner E, Ikram H, Yandle T, Richards A, et al. Regional plasma levels of cardiac peptides and their response to acute neutral endopeptidase inhibition in man. Clinical Science. 1998;95(5):547-555. Excluded because BNP assay method is not an included one. [pmid: 9791040].
Lainchbury J, Nicholls M, Espiner E, Yandle T, Lewis L, Richards A, et al. Bioactivity and interactions of adrenomedullin and brain natriuretic peptide in patients with heart failure. Hypertension. 1999;34(1):70-75. Excluded because BNP assay method is not an included one. [pmid: 10406826].
Lainchbury J, Richards A, Nicholls M, Hunt P, Ikram H, Espiner E, et al. The effects of pathophysiological increments in brain natriuretic peptide in left ventricular systolic dysfunction. Hypertension. 1997;30(3 Pt 1):398-404. Excluded because BNP assay method is not an included one. [pmid: 9314423].
Lainchbury J, Richards A, Nicholls M, Espiner E, Yandle T, Lainchbury J, et al. Brain natriuretic peptide and neutral endopeptidase inhibition in left ventricular impairment. Journal of Clinical Endocrinology & Metabolism. 1999;84(2):723-729. Excluded because this is a case report or series with 10 subjects. [pmid: 10022444].
Lainchbury J, Troughton R, Lewis L, Yandle T, Richards A, Nicholls MG. Hemodynamic, hormonal, and renal effects of short-term adrenomedullin infusion in healthy volunteers. Journal of Clinical Endocrinology & Metabolism. 2000;85(3):1016-1020. Excluded because this is a case report or series with 10 subjects. [pmid: 10720032].
Lan Y, Chang R, Alejos J, Burch C, Wetzel G, Lan YTCRKAJC, et al. B-type natriuretic peptide in children after cardiac transplantation. Journal of Heart & Lung Transplantation. 2004;23(5):558-563. Excluded because adult blood not measured. [pmid: 15135371].
Lang C, Choy A, Henderson I, Coutie W, Struthers A, Lang C, et al. Effect of haemodialysis on plasma levels of brain natriuretic peptide in patients with chronic renal failure. Clinical Science. 1992;82(2):127-131. Excluded because BNP assay method is not an included one. [pmid: 1311649].
Lang C, Choy A, Struthers A, Lang C, Choy A, Struthers AD. Atrial and brain natriuretic peptides: a dual natriuretic peptide system potentially involved in circulatory homeostasis. Clinical Science. 1992;83(5):519-527. Excluded because not a report of a primary study. [pmid: 1335386].
Lang C, Choy A, Turner K, Tobin R, Coutie W, Struthers A, et al. The effect of intravenous saline loading on plasma levels of brain natriuretic peptide in man. Journal of Hypertension. 1993;11(7):737-741. Excluded because BNP assay method is not an included one. [pmid: 8228193].
Lang C, Coutie W, Khong T, Choy A, Struthers A, Lang C, et al. Dietary sodium loading increases plasma brain natriuretic peptide levels in man. Journal of Hypertension. 1991;9(9):779-782. Excluded because BNP assay method is not an included one. [pmid: 1663977].
Lang C, Coutie W, Struthers A, Dhillon D, Winter J, Lipworth B, et al. Elevated levels of brain natriuretic peptide in acute hypoxaemic chronic obstructive pulmonary disease. Clinical Science. 1992;83(5):529-533. Excluded because BNP assay method is not an included one. [pmid: 1335387].
Lang C, McAlpine H, Choy A, Pringle T, Coutie W, Struthers A, et al. Effect of pericardiocentesis on plasma levels of brain natriuretic peptide in cardiac tamponade. American Journal of Cardiology. 1919;70(20):1628-1629. Excluded because BNP assay method is not an included one. [pmid: 1466341].
Lang C, Motwani J, Coutie W, Struthers A, Lang C, Motwani J, et al. Influence of candoxatril on plasma brain natriuretic peptide in heart failure.[erratum appears in Lancet 1991 Aug 10;338(8763):394]. Lancet. 1907;338(8761):255. Excluded because not a report of a primary study. [pmid: 1676808].
Lang C, Motwani J, Coutie W, Struthers A, Lang C, Motwani J, et al. Clearance of brain natriuretic peptide in patients with chronic heart failure: indirect evidence for a neutral endopeptidase mechanism but against an atrial natriuretic peptide clearance receptor mechanism. Clinical Science. 1992;82(6):619-623. Excluded because adult blood not measured. [pmid: 1320540].
Lang C, Motwani J, Rahman A, Coutie W, Struthers A, Lang C, et al. Effect of angiotensin-converting enzyme inhibition on plasma brain natriuretic peptide levels in patients with heart failure. Clinical Science. 1992;83(2):143-147. Excluded because BNP assay method is not an included one. [pmid: 1327628].
Lang C, Prasad N, McAlpine H, MacLeod C, Lipworth B, MacDonald T, et al. Increased plasma levels of brain natriuretic peptide in patients with isolated diastolic dysfunction. American Heart Journal. 1994;127(6):1635-1636. Excluded because BNP assay method is not an included one. [pmid: 8197998].
Langenickel T, Buttgereit J, Pagel I, Dietz R, Willenbrock R, Bader M. Forced Homodimerization Site-Directed Mutagenesis Alters Guanylyl Cyclase Activity of Natriuretic Peptide Receptor B. Hypertension. 2004;43(2 II):460-465. Excluded because adult blood not measured. [pmid: 14691198].
Lapp H, Boerrigter G, Costello-Boerrigter L, Jaekel K, Scheffold T, Krakau I, et al. Elevated plasma human urotensin-II-like immunoreactivity in ischemic cardiomyopathy. International Journal of Cardiology. 2004;94(1):93-97. Excluded because BNP assay method is not an included one. [pmid: 14996481].
Latini R, Masson S, Staszewsky L, Maggioni AP. Valsartan for the treatment of heart failure. Expert Opinion on Pharmacotherapy. 2004;5(1):181-193. Excluded because not a report of a primary study. [pmid: 14680446].
Lauria M, Standley C, Sorokin Y, Todt J, Bottoms S, Yelian F, et al. Brain natriuretic peptide and cyclic guanosine-3',5' monophosphate in pre-eclampsia. Journal of Maternal-Fetal Medicine. 1996;5(3):128-131. Excluded because BNP assay method is not an included one. [pmid: 8796782].
Lauria M, Standley C, Sorokin Y, Yelian F, Cotton DB. Adrenomedullin levels in normal and preeclamptic pregnancy at term. Journal of the Society for Gynecologic Investigation. 1999;6(6):318-321. Excluded because BNP assay method is not an included one. [pmid: 10643585].
Law Y, Keller B, Feingold B, Boyle G, Law YM, Keller BB, et al. Usefulness of plasma B-type natriuretic peptide to identify ventricular dysfunction in pediatric and adult patients with congenital heart disease. American Journal of Cardiology. 2002;95(4):474-478. Excluded because adult blood not measured. [pmid: 15695131].
Lazzeri C, Franchi F, Porciani C, Fronzaroli C, Casini RVdFM, Mannelli M, et al. Systemic hemodynamics and renal function during brain natriuretic peptide infusion in patients with essential hypertension. American Journal of Hypertension. 1995;8(8):799-807. Excluded because BNP assay method is not an included one. [pmid: 7576396].
Lazzeri C, La Villa G, Bisi G, Boddi V, Messeri G, Strazzulla G, et al. Cardiovascular function during brain natriuretic peptide infusion in man. Cardiology. 1995;86(5):396-401. Excluded because BNP assay method is not an included one. [pmid: 7585742].
Le B, Addo T, de Lemos JA. The endocrine heart: B-type natriuretic peptide as a diagnostic and therapeutic agent in cardiovascular disease. Endocrinologist. 2003;13(2):97-105. Excluded because not a report of a primary study.
Lebech A, Gerstoft J, Hesse B, Petersen C, Kjaer A, Lebech AMGJHBPCLaKA. Right and left ventricular cardiac function in a developed world population with human immunodeficiency virus studied with radionuclide ventriculography.[see comment]. American Heart Journal. 2004;147(3):482-488. Excluded because BNP assay method is not an included one. [pmid: 14999198].
Lee Y, Lin S, Shin S, Lai Y, Lin Y, Tsai J, et al. Brain natriuretic peptide is synthesized in the human adrenal medulla and its messenger ribonucleic acid expression along with that of atrial natriuretic peptide are enhanced in patients with primary aldosteronism. Journal of Clinical Endocrinology & Metabolism. 1994;79(5):1476-1482. Excluded because adult blood not measured. [pmid: 7962346].
Lenz T, Foral P, Malesker M, Hunter C, Hilleman D, Lenz TL, et al. Impact of nesiritide on health care resource utilization and complications in patients with decompensated heart failure. Pharmacotherapy. 2004;24(9):1137-1146. Excluded because adult blood not measured. [pmid: 15460174].
Leuchte H, Baumgartner R, Behr J. Treatment of Severe Pulmonary Hypertension with Inhaled Iloprost [5]. Annals of Internal Medicine. 2003;139(4):306. Excluded because not a report of a primary study. [pmid: 12965995].
Levy T, Jenkins G, Walker S, Grieve L, Webb C, Buckley M, et al. Does the mechanism of action of biatrial pacing for atrial fibrillation involve changes in cardiac haemodynamics? Assessment by Doppler echocardiography and natriuretic peptide measurements. Europace. 2000;2(2):127-135. Excluded because BNP assay method is not an included one. [pmid: 11225939].
Lewis D, Gurram N, Abraham W, Akers W, Lewis DA, Gurram NR, et al. Effect of nesiritide versus milrinone in the treatment of acute decompensated heart failure. American Journal of Health-System Pharmacy. 1908;60(Suppl 4):S16-S20. Excluded because BNP used as treatment. [pmid: 12966902].
Liang F, Kovacic-Milivojevic B, Chen S, Cui J, Roediger F, Intengan H, et al. Signaling mechanisms underlying strain-dependent brain natriuretic peptide gene transcription. Canadian Journal of Physiology & Pharmacology. 2001;79(8):640-645. Excluded because adult blood not measured. [pmid: 11558672].
Liang F, Webb P, Marimuthu A, Zhang S, Gardner D, Liang FWPMAZSaGDG. Triiodothyronine increases brain natriuretic peptide (BNP) gene transcription and amplifies endothelin-dependent BNP gene transcription and hypertrophy in neonatal rat ventricular myocytes. Journal of Biological Chemistry. 2004;278(17):15073-15083. Excluded because adult blood not measured. [pmid: 12562779].
Lim P, Donnan P, Struthers A, MacDonald T, Lim PO, Donnan PT, et al. Exercise capacity and brain natruiretic peptide in hypertension. Journal of Cardiovascular Pharmacology. 2002;40(4):519-527. Excluded because BNP assay method is not an included one. [pmid: 12352313].
Lim P, Morris-Thurgood J, Frenneaux MP. Vascular mechanisms of sudden death in hypertrophic cardiomyopathy, including blood pressure responses to exercise. Cardiology in Review. 2002;10(1):15-23. Excluded because not a report of a primary study. [pmid: 11790265].
Lindaman C. S.I.A.D.H.: is your patient at risk?. Nursing. 1992;22(6):60-63. Excluded because not a report of a primary study. [pmid: 1614657].
Lindstedt G. Multifactorial regulation of plasma natriuretic peptides calls for supplementary measurements. Scandinavian Cardiovascular Journal. 2001;35(6):355-358. Excluded because not a report of a primary study. [pmid: 11837513].
Lipshultz S, Fisher S, Lai W, Miller TL. Cardiovascular monitoring and therapy for HIV-infected patients. Annals of the New York Academy of Sciences. 2001;946(pp 236273):236-273. Excluded because not a report of a primary study. [pmid: 11762991].
Lipshultz S, Fisher S, Lai W, Miller TL. Cardiovascular risk factors, monitoring, and therapy for HIV-infected patients. AIDS. 2003;17(SUPPL. 1):S96-S122. Excluded because not a report of a primary study. [pmid: 12870537].
Lok B, Mukerjee D, Timms P, Ashrafian H, Coghlan JG. Natriuretic peptides, respiratory disease, and the right heart. Chest. 2004;126(4):1330-1336. Excluded because not a report of a primary study. [pmid: 15486400].
Loke I, Squire I, Davies J, Ng L, Loke ISIB, Davies JE, et al. Reference ranges for natriuretic peptides for diagnostic use are dependent on age, gender and heart rate. European Journal of Heart Failure. 2003;5(5):599-606. Excluded because BNP assay method is not an included one. [pmid: 14607197].
Lombardi F. Sympathetic activation and sub-clinical inflammation: A new combination to identify high risk subjects. European Heart Journal. 2004;25(5):359-360. Excluded because not a report of a primary study. [pmid: 15033245].
Loureiro Soares LG. Brain natriuretic peptide: A marker for dyspnea? [3]. Journal of Pain & Symptom Management. 2002;24(5):457-458. Excluded because not a report of a primary study. [pmid: 12547045].
Luckey A, Parsa C, Harken AH. Reversible Cardiac Sympathectomy by High Thoracic Epidural Anesthesia Improves Regional Left Ventricular Function in Patients Undergoing Coronary Artery Bypass Grafting, A Randomized Trial: Invited critique. Archives of Surgery. 2003;138(12):1291. Excluded because not a report of a primary study.
Luft FC. Escalator driven. Journal of Molecular Medicine. 2004;82(5):275-277. Excluded because not a report of a primary study. [pmid: 15060783].
Luscher T, Ruschitzka F, Anand I, Konstam M, McMurray J, Notter T, et al. EARTH: EndothelinA receptor antagonist trial in heart failure. Heartdrug. 2001;1(6):294-298. Excluded because not a report of a primary study.
Macdonald J, Kennedy N, Struthers A, Macdonald J, Kennedy N, Struthers AD. Effects of spironolactone on endothelial function, vascular angiotensin converting enzyme activity, and other prognostic markers in patients with mild heart failure already taking optimal treatment. Heart (British Cardiac Society). 2004;90(7):765-770. Excluded because BNP assay method is not an included one. [pmid: 15201246]. [pmcid: 1768327].
Maeder M, Ammann P, Rickli H, Diethelm M, Maeder MAPRHaDM. Elevation of B-type natriuretic peptide levels in acute respiratory distress syndrome. Swiss Medical Weekly. 1909;133(3738):515-518. Excluded because this is a case report or series with 10 subjects. [pmid: 14652800].
Magga J, Puhakka M, Hietakorpi S, Punnonen K, Uusimaa P, Risteli J, et al. Atrial natriuretic peptide, B-type natriuretic peptide, and serum collagen markers after acute myocardial infarction. Journal of Applied Physiology. 2004;96(4):1306-1311. Excluded because BNP assay method is not an included one. [pmid: 14607848].
Maggioni A R. RAAS inhibitors in the cardiovascular continuum: What is still missing. Cardiovascular Drugs & Therapy. 2004;18(4):311-320. Excluded because not a report of a primary study. [pmid: 15367829].
Mair P, Mair J, Bleier J, Hormann C, Balogh D, Puschendorf B, et al. Augmented release of brain natriuretic peptide during reperfusion of the human heart after cardioplegic cardiac arrest. Clinica Chimica Acta. 1997;261(1):57-68. Excluded because BNP assay method is not an included one.
Maisel A. B-type natriuretic peptide levels: Diagnostic and prognostic in congestive heart failure: What's next?. Circulation. 2002;105(20):2328-2331. Excluded because not a report of a primary study. [pmid: 12021215].
Maisel A A.S. B-type natriuretic peptide (BNP) levels: diagnostic and therapeutic potential. [Review] [10 refs]. Reviews in Cardiovascular Medicine. 2001;2 Suppl 2:S13-S18. Excluded because not a report of a primary study. [pmid: 12439357].
Maisel A E.C. Measuring BNP levels in the diagnosis and treatment of CHF. Journal of Critical Illness. 2002;17(11):434-442. Excluded because not a report of a primary study.
Maisel A, Krishnaswamy P, Nowak R, Lader E. B type natriuretic peptide levels had high sensitivity but moderate specificity for detecting CHF in the emergency department. Evidence Based Medicine. 2003;8(1):28. Excluded because not a report of a primary study.
Maki N, Yoshiyama M, Omura T, Yoshimura T, Kawarabayashi T, Sakamoto K, et al. Effect of diltiazem on cardiac function assessed by echocardiography and neurohumoral factors after reperfused myocardial infarction without congestive heart failure. Cardiovascular Drugs & Therapy. 2001;15(6):493-499. Excluded because BNP assay method is not an included one. [pmid: 11916358].
Mallamaci F, Zoccali C, Tripepi G, Benedetto F, Parlongo S, Cataliotti A, et al. Diagnostic potential of cardiac natriuretic peptides in dialysis patients. Kidney International. 2001;59(4):1559-1566. Excluded because BNP assay method is not an included one. [pmid: 11260421].
Mallat Z, Heymes C, Corbaz A, Logeart D, Alouani S, Cohen-Solal A, et al. Evidence for altered interleukin 18 (IL)-18 pathway in human heart failure. FASEB Journal. 2004;18(14):1752-1754. Excluded because not a report of a primary study. [pmid: 15371332].
Marantz P, Kuwabara Y, Derby C, Tobin J, Cohen MV. Plasma atrial natriuretic peptide factor is elevated in elderly patients with occult valvular insufficiency. Cardiology in the Elderly. 1993;1(3):195-201. Excluded because BNP assay method is not an included one.
Marcus L, Hart D, Packer M, Yushak M, Medina N, Danziger R, et al. Hemodynamic and renal excretory effects of human brain natriuretic peptide infusion in patients with congestive heart failure A double-blind, placebo-controlled, randomized crossover trial. Circulation. 1919;94(12):3184-3189. Excluded because BNP assay method is not an included one. [pmid: 8989127].
Margulies K J.C. Neutral endopeptidase 24.11: A modulator of natriuretic peptides. Seminars in Nephrology. 1993;13(1):71-77. Excluded because not a report of a primary study. [pmid: 8434188].
Margulies K, Jaffer S, Pollack P, Ennis K, Margulies K, Jaffer S, et al. Physiological significance of early deceleration time prolongation in asymptomatic elderly subjects. Journal of Cardiac Failure. 1999;5(2):92-99. Excluded because BNP assay method is not an included one. [pmid: 10404348].
Marian A V. Biomarkers of cardiac disease. Expert Review of Molecular Diagnostics. 2004;4(6):805-820. Excluded because not a report of a primary study. [pmid: 15525223].
Marschall KE. Natriuretic peptides in the diagnosis and treatment of heart failure: An overview. Seminars in Anesthesia Perioperative Medicine & Pain. 2004;23(4):302-311. Excluded because not a report of a primary study.
Martin J H. Eplerenone GD Searle & Co. Current Opinion in Investigational Drugs. 2001;2(4):521-524. Excluded because not a report of a primary study. [pmid: 11566010].
Marumoto K, Hamada M, Aburaya M, Hiwada K, Marumoto K, Hamada M, et al. Augmented secretion of atrial and brain natriuretic peptides during dynamic exercise in patients with old myocardial infarction. Japanese Circulation Journal. 1995;59(11):715-724. Excluded because BNP assay method is not an included one. [pmid: 8747761].
Marumoto K, Hamada M, Hiwada K, Marumoto K, Hamada M, Hiwada K. Increased secretion of atrial and brain natriuretic peptides during acute myocardial ischaemia induced by dynamic exercise in patients with angina pectoris. Clinical Science. 1995;88(5):551-556. Excluded because BNP assay method is not an included one. [pmid: 7614814].
Marwick TH. Techniques for comprehensive two dimensional echocardiographic assessment of left ventricular systolic function. Heart (British Cardiac Society). 2003;89(SUPPL. 3):iii2-iii8. Excluded because not a report of a primary study. [pmid: 12482775]. [pmcid: 1767505].
Masters R, Davies R, Veinot J, Hendry P, Smith S, de Bold A, et al. Discoordinate modulation of natriuretic peptides during acute cardiac allograft rejection in humans. Circulation. 1907;100(3):287-291. Excluded because BNP assay method is not an included one. [pmid: 10411854].
Matsumoto A, Hirata Y, Kakoki M, Nagata D, Momomura S, Sugimoto T, et al. Increased excretion of nitric oxide in exhaled air of patients with chronic renal failure. Clinical Science. 1999;96(1):67-74. Excluded because BNP assay method is not an included one. [pmid: 9857108].
Matsuo S, Nakae I, Takada M, Murata K, Nakamura Y. Noninvasive identification of myocardial sympathetic and metabolic abnormalities in a patient with restrictive cardiomyopathy - In comparison with perfusion imaging. Annals of Nuclear Medicine. 2002;16(8):569-572. Excluded because this is a case report or series with 10 subjects. [pmid: 12593423].
McBride B C.M. Levosimendan: Implications for clinicians. Journal of Clinical Pharmacology. 2003;43(10):1071-1081. Excluded because not a report of a primary study. [pmid: 14517189].
McClean D, Ikram H, Garlick A, Richards A, Nicholls M, Crozier I, et al. The clinical, cardiac, renal, arterial and neurohormonal effects of omapatrilat, a vasopeptidase inhibitor, in patients with chronic heart failure. Journal of the American College of Cardiology. 2000;36(2):479-486. Excluded because BNP assay method is not an included one. [pmid: 10933361].
McClure S, Caruana L, Davie A, Goldthorp S, McMurray JJV. Cohort study of plasma natriuretic peptides for identifying left ventricular systolic dysfunction in primary care. British Medical Journal. 1998;317(7157):516-519. Excluded because BNP assay method is not an included one. [pmid: 9712601].
McClure S J.J.V. Natriuretic peptides for assessment of left ventricular systolic dysfunction in primary care. Cardiovascular Reviews & Reports. 2000;21(4):193-199. Excluded because not a report of a primary study.
McCord JK. The future of cardiac markers in the emergency department. Critical Pathways in Cardiology: A Journal of Evidence-Based Medicine. 2004;3(3):107-109. Excluded because not a report of a primary study.
McCullough PA. B-type natriuretic peptides: A diagnostic breakthrough in heart failure. Minerva Cardioangiologica. 2003;51(2):121-129. Excluded because not a report of a primary study. [pmid: 12783068].
McCullough PA. Clinical applications of B-type natriuretic peptide levels in the care of cardiovascular patients. Minerva Cardioangiologica. 2004;52(6):479-489. Excluded because not a report of a primary study. [pmid: 15729209].
McDonagh TA. Use of natriuretic peptides to identify heart failure. Hospital Practice (Office Edition). 1998;33(4):26. Excluded because not a report of a primary study.
McDonagh T, Cunningham A, Morrison C, McMurray J, Ford I, Morton J, et al. Left ventricular dysfunction, natriuretic peptides, and mortality in an urban population. Heart (British Cardiac Society). 2001;86(1):21-26. Excluded because BNP assay method is not an included one. [pmid: 11410555]. [pmcid: 1729832].
McDonagh T, Holmer S, Raymond I, Luchner A, Hildebrant P, Dargie H, et al. NT-proBNP and the diagnosis of heart failure: a pooled analysis of three European epidemiological studies. European Journal of Heart Failure. 2003;6(3):269-273. Excluded because not a report of a primary study. [pmid: 14987575].
McDonagh T, Robb S, Murdoch D, Morton J, Ford I, Morrison C, et al. Biochemical detection of left-ventricular systolic dysfunction.[see comment]. Lancet. 1998;351(9095):9-13. Excluded because BNP assay method is not an included one. [pmid: 9433422].
McDougall J N.A. Natriuresis and inhibition of Na+/K+-ATPase: Modulation of response by physiological manipulation. Clinical & Experimental Pharmacology & Physiology. 1998;25(SUPPL.):S57-S60. Excluded because adult blood not measured.
McDowell G, Coutie W, Shaw C, Buchanan K, Struthers A, Nicholls D, et al. The effect of the neutral endopeptidase inhibitor drug, candoxatril, on circulating levels of two of the most potent vasoactive peptides. British Journal of Clinical Pharmacology. 1997;43(3):329-332. Excluded because adult blood not measured. [pmid: 9088591]. [pmcid: 2042739].
McGeoch G, Lainchbury J, Town G, Toop L, Espiner E, Richards A, et al. Plasma brain natriuretic peptide after long-term treatment for heart failure in general practice. European Journal of Heart Failure. 2002;4(4):479-483. Excluded because BNP assay method is not an included one. [pmid: 12167387].
McGregor A, Richards M, Espiner E, Yandle T, Ikram H, McGregor A, et al. Brain natriuretic peptide administered to man: actions and metabolism. Journal of Clinical Endocrinology & Metabolism. 1990;70(4):1103-1107. Excluded because BNP assay method is not an included one. [pmid: 2156886].
McGregor D, Buttimore A, Lynn K, Yandle T, Nicholls M, McGregor DO, et al. Effects of long and short hemodialysis on endothelial function: a short-term study. Kidney International. 2003;63(2):709-715. Excluded because this is a case report or series with 10 subjects. [pmid: 12631138].
McKelvie RS. The therapeutic potential of angiotensin II receptor blockers in the treatment of heart failure. Expert Opinion on Investigational Drugs. 2004;13(3):245-253. Excluded because not a report of a primary study. [pmid: 15013943].
McKelvie R, Yusuf S, Pericak D. Comparison of candesartan, enalapril, and their combination in congestive heart failure: Randomized evaluation of strategies for left ventricular dysfunction (RESOLVD) pilot study. Prevention & Management of Congestive Heart Failure. 1999;5(6):286-287. Excluded because adult blood not measured.
McKelvie R, Yusuf S, Pericak D, Avezum A, Burns R, Probstfield J, et al. Comparison of candesartan, enalapril, and their combination in congestive heart failure: Randomized evaluation of strategies for left ventricular dysfunction (RESOLVD) pilot study: The RESOLVD pilot study investigators. Circulation. 1999;100(10):1056-1064. Excluded because BNP assay method is not an included one. [pmid: 10477530].
McKenna K, Smith D, Tormey W, Thompson C, McKenna K, Smith D, et al. Acute hyperglycaemia causes elevation in plasma atrial natriuretic peptide concentrations in Type 1 diabetes mellitus. Diabetic Medicine. 2000;17(7):512-517. Excluded because this is a case report or series with 10 subjects. [pmid: 10972580].
McKenna K, Smith D, Moore K, Glen A, Tormey W, Thompson C, et al. Brain natriuretic peptide increases urinary albumin and alpha-1 microglobulin excretion in Type 1 diabetes mellitus. Diabetic Medicine. 2001;18(12):973-978. Excluded because this is a case report or series with 10 subjects. [pmid: 11903396].
McLean A, Huang S, Ting I. B-type natriuretic peptide: Is there a place in the critical care setting?. Critical Care & Shock. 2004;7(3):117-124. Excluded because not a report of a primary study.
McMahon EG. Eplerenone, a new selective aldosterone blocker. Current Pharmaceutical Design. 2003;9(13):1065-1075. Excluded because not a report of a primary study. [pmid: 12678858].
Mead M. GP use of beta blockers in heart failure. British Journal of Cardiology 2002; 9(8). Excluded because not a report of a primary study
Medeiros MS, Balmforth A, Vaughan P, Kenny A, Turner A, Medeiros M, et al. Hydrolysis of natriuretic peptides by the human astrocytoma clone D384. Biochemical Society Transactions. 1990;18(5):888-889. Excluded because adult blood not measured. [pmid: 2150654].
Medeiros MS, Balmforth A, Vaughan P, Turner A, Medeiros M, Balmforth A, et al. Hydrolysis of atrial and brain natriuretic peptides by the human astrocytoma clone D384 and the neuroblastoma line SH-SY5Y. Neuroendocrinology. 1991;54(3):295-302. Excluded because adult blood not measured. [pmid: 1682834].
Mehrotra S, Ather S, Chandra M. Brain natriuretic peptide - A cardiologist's blood count. Journal of Internal Medicine of India. 2004;7(1):167-171. Excluded because not a report of a primary study.
Melzi dG, Tagnochetti T, Nauti A, Klersy C, Papalia A, Vadacca G, et al. Biological variation of N-terminal pro-brain natriuretic peptide in healthy individuals [3]. Clinical Chemistry. 2003;49(9):1554-1555. Excluded because not a report of a primary study. [pmid: 12928248].
Meng F, Yoshikawa T, Baba A, Moritani K, Suzuki M, Satoh T, et al. beta-Blockers Are Effective in Congestive Heart Failure Patients With Atrial Fibrillation. Journal of Cardiac Failure. 2003;9(5):398-403. Excluded because BNP assay method is not an included one. [pmid: 14583902].
Meschia JF. Not so accidental outcomes following cerebrovascular accidents. Current Neurology & Neuroscience Reports. 2004;4(5):341-342. Excluded because not a report of a primary study. [pmid: 15324598].
Messaoudi L, Donckier J, Stoffel M, Ketelslegers J, Kolanowski J, Messaoudi L, et al. Changes in blood pressure and in vasoactive and volume regulatory hormones during semistarvation in obese subjects. Metabolism: Clinical & Experimental. 1998;47(5):592-597. Excluded because BNP assay method is not an included one. [pmid: 9591752].
Meyer G, Roy P, Sors H, Sanchez O. Laboratory tests in the diagnosis of pulmonary embolism. Respiration. 2003;70(2):125-132. Excluded because not a report of a primary study. [pmid: 12740506].
Michaels A, Klein A, Madden J, Chatterjee K, Michaels AD, Klein AMJA, et al. Effects of intravenous nesiritide on human coronary vasomotor regulation and myocardial oxygen uptake. Circulation. 2003;107(21):2697-2701. Excluded because this is a case report or series with 10 subjects. [pmid: 12742984].
Miliotis T, Marko-Varga G, Nilsson J, Laurell T. An automated and integrated protein workstation interfacing capillary HPLC with MALDI-TOF mass spectrometry using piezoelectric microdispensing. JALA: Journal of the Association for Laboratory Automation. 2000;5(6):93-95. Excluded because not a report of a primary study.
Militello MA. Role of nesiritide in decompensated heart failure. Journal of Pharmacy Practice. 2002;15(4):326-333. Excluded because not a report of a primary study.
Miller W J.C. Circulating paracrine and autocrine mechanisms in heart failure. Current Opinion in Cardiology. 1993;8(3):376-382. Excluded because not a report of a primary study.
Mills R, LeJemtel T, Horton D, Liang C, Lang R, Silver M, et al. Sustained hemodynamic effects of an infusion of nesiritide (human b-type natriuretic peptide) in heart failure: a randomized, double-blind, placebo-controlled clinical trial. Natrecor Study Group. Journal of the American College of Cardiology. 1999;34(1):155-162. Excluded because BNP assay method is not an included one. [pmid: 10400005].
Milner S M.R. Reduced antimicrobial peptide expression in human burn wounds. Burns. 1999;25(5):411-413. Excluded because adult blood not measured. [pmid: 10439149].
Milo O, Cotter G, Kaluski E, Brill A, Blatt A, Krakover R, et al. Comparison of inflammatory and neurohormonal activation in cardiogenic pulmonary edema secondary to ischemic versus nonischemic causes. American Journal of Cardiology. 1907;92(2):222-226. Excluded because BNP assay method is not an included one. [pmid: 12860231].
Milting H, EL Banayosy A, Kassner A, Fey O, Sarnowski P, Arusoglu L, et al. The time course of natriuretic hormones as plasma markers of myocardial recovery in heart transplant candidates during ventricular assist device support reveals differences among device types. Journal of Heart & Lung Transplantation. 2001;20(9):949-955. Excluded because BNP assay method is not an included one. [pmid: 11557189].
Minamino N, Makino Y, Tateyama H, Kangawa K, Matsuo H, Minamino N, et al. Characterization of immunoreactive human C-type natriuretic peptide in brain and heart. Biochemical & Biophysical Research Communications. 1908;179(1):535-542. Excluded because adult blood not measured. [pmid: 1831979].
Missouris C, Grouzmann E, Buckley M, Barron J, MacGregor G, Singer D, et al. How does treatment influence endocrine mechanisms in acute severe heart failure? Effects on cardiac natriuretic peptides, the renin system, neuropeptide Y and catecholamines. Clinical Science. 1998;94(6):591-599. Excluded because BNP assay method is not an included one. [pmid: 9854456].
Missouris C, Varma C, Ward D, MacGregor G, Missouris C, Varma C, et al. Cardiac peptides and plasma renin activity in acute dilated cardiomyopathy. European Journal of Heart Failure. 2001;3(1):109-111. Excluded because not a report of a primary study. [pmid: 11163744].
Mistry S, Hawksworth G, Struthers A, McLay J, Mistry S, Hawksworth G, et al. Differential expression and synthesis of natriuretic peptides determines natriuretic peptide receptor expression in primary cultures of human proximal tubular cells. Journal of Hypertension. 2001;19(2):255-262. Excluded because adult blood not measured. [pmid: 11212968].
Mitaka C, Hirata Y, Nagura T, Tsunoda Y, Itoh M, Amaha K, et al. Increased plasma concentrations of brain natriuretic peptide in patients with acute lung injury. Journal of Critical Care. 1997;12(2):66-71. Excluded because BNP assay method is not an included one. [pmid: 9165414].
Mitaka C, Hirata Y, Nagura T, Tsunoda Y, Amaha K. Beneficial effect of atrial natriuretic peptide on pulmonary gas exchange in patients with acute lung injury. Chest. 1998;114(1):223-228. Excluded because BNP assay method is not an included one. [pmid: 9674473].
Mitka M Mike. Peptides prove predictive for heart failure patients. JAMA: Journal of the American Medical Association. 2004;287(15):1926. Excluded because not a report of a primary study.
Miyagawa S, Sawa Y, Fukushima N, Nishimura M, Matsumiya G, Taketani S, et al. Analysis of sympathetic nerve activity in end-stage cardiomyopathy patients receiving left ventricular support. Journal of Heart & Lung Transplantation. 2001;20(11):1181-1187. Excluded because this is a case report or series with 10 subjects. [pmid: 11704478].
Miyamoto S, Tambara K, Tamaki S, Nagaya N, Hasegawa K, Nohara R, et al. Effects of right lateral decubitus position on plasma norepinephrine and plasma atrial natriuretic peptide levels in patients with chronic congestive heart failure. American Journal of Cardiology. 2002;89(2):240-242. Excluded because BNP assay method is not an included one. [pmid: 11792354].
Mizuno T, Katafuchi T, Hagiwara H, Ito T, Kangawa K, Matsuo H, et al. Human adrenal tumor cell line SW-13 contains a natriuretic peptide receptor system that responds preferentially to ANP among various natriuretic peptides. Biochemical & Biophysical Research Communications. 1919;173(3):886-893. Excluded because adult blood not measured. [pmid: 2176493].
Moazami N, Damiano R, Bailey M, Hess R, Lawton J, Moon M, et al. Nesiritide (BNP) in the management of postoperative cardiac patients. Annals of Thoracic Surgery. 2003;75(6):1974-1976. Excluded because adult blood not measured. [pmid: 12822655].
Moazemi K, Chana J, Willard A, Kocheril AG. Intravenous vasodilator therapy in congestive heart failure. Drugs & Aging. 2003;20(7):485-508. Excluded because not a report of a primary study. [pmid: 12749747].
Modesti P, Cecioni I, Costoli A, Poggesi L, Galanti G, Serneri G, et al. Renal endothelin in heart failure and its relation to sodium excretion. American Heart Journal. 2000;140(4):617-622. Excluded because BNP assay method is not an included one. [pmid: 11011335].
Mohapatra S, Lockey R, Vesely D, Gower WR Jr. Natriuretic peptides and genesis of asthma: An emerging paradigm?. Journal of Allergy & Clinical Immunology. 2004;114(3):520-526. Excluded because not a report of a primary study. [pmid: 15356551].
Mohideen M M.R. Brain natriuretic peptide is more than a marker. Ceylon Medical Journal. 2002;47(3):81-82. Excluded because not a report of a primary study. [pmid: 12449771].
Molkentin JD. A friend within the heart: Natriuretic peptide receptor signaling. Journal of Clinical Investigation. 2003;111(9):1275-1277. Excluded because not a report of a primary study. [pmid: 12727915]. [pmcid: 154452].
Moller D, Lind P, Strunge B, Pedersen EB. Abnormal vasoactive hormones and 24-hour blood pressure in obstructive sleep apnea. American Journal of Hypertension. 2003;16(4):274-280. Excluded because BNP assay method is not an included one. [pmid: 12670743].
Montgomery H, Clarkson P, Dollery C, Prasad K, Losi M, Hemingway H, et al. Association of angiotensin-converting enzyme gene I/D polymorphism with change in left ventricular mass in response to physical training. Circulation. 1997;96(3):741-747. Excluded because BNP assay method is not an included one. [pmid: 9264477].
Mori K, Manabe T, Nii M, Hayabuchi Y, Kuroda Y, Tatara K, et al. Plasma levels of natriuretic peptide and echocardiographic parameters in patients with Duchenne's progressive muscular dystrophy. Pediatric Cardiology. 2002;23(2):160-166. Excluded because adult blood not measured. [pmid: 11889527].
Mori M, Kinugawa T, Endo A, Kato M, Kato T, Osaki S, et al. Effects of hypoxic exercise conditioning on work capacity, lactate, hypoxanthine and hormonal factors in men. Clinical & Experimental Pharmacology & Physiology. 1999;26(4):309-314. Excluded because this is a case report or series with 10 subjects. [pmid: 10225141].
Morimoto T, Hayashino Y, Shimbo T, Izumi T, Fukui T, Morimoto THYSTITaFT. Is B-type natriuretic peptide-guided heart failure management cost-effective?. International Journal of Cardiology. 2004;96(2):177-181. Excluded because adult blood not measured. [pmid: 15262031].
Morita E, Yasue H, Yoshimura M, Ogawa H, Jougasaki M, Matsumura T, et al. Increased plasma levels of brain natriuretic peptide in patients with acute myocardial infarction. Circulation. 1993;88(1):82-91. Excluded because BNP assay method is not an included one. [pmid: 8319360].
Morita T, Tei Y, Inoue S, Suga A, Chihara S, Morita TTYISSAaCS. Fluid status of terminally ill cancer patients with intestinal obstruction: an exploratory observational study. Supportive Care in Cancer. 2002;10(6):474-479. Excluded because this is a case report or series with 10 subjects. [pmid: 12353126].
Moser DK. Pathophysiology of heart failure update: the role of neurohumoral activation in the progression of heart failure. AACN Clinical Issues: Advanced Practice in Acute and Critical Care. 1998;9(2):157-171. Excluded because not a report of a primary study.
Motwani J, McAlpine H, Kennedy N, Struthers A, Motwani J, McAlpine H, et al. Plasma brain natriuretic peptide as an indicator for angiotensin-converting-enzyme inhibition after myocardial infarction.[see comment]. Lancet. 1993;341(8853):1109-1113. Excluded because BNP assay method is not an included one. [pmid: 8097802].
Mudambo K, Coutie W, Rennie M, Mudambo K, Coutie W, Rennie MJ. Plasma arginine vasopressin, atrial natriuretic peptide and brain natriuretic peptide responses to long-term field training in the heat: effects of fluid ingestion and acclimatization. European Journal of Applied Physiology & Occupational Physiology. 1997;75(3):219-225. Excluded because BNP assay method is not an included one. [pmid: 9088840].
Muders F, Kromer E, Griese D, Pfeifer M, Hense H, Riegger G, et al. Evaluation of plasma natriuretic peptides as markers for left ventricular dysfunction. American Heart Journal. 1997;134(3):442-449. Excluded because BNP assay method is not an included one. [pmid: 9327700].
Mueller C, Scholer A, Laule-Kilian K. BNP testing improves outcomes in evaluation of dyspnea. Journal of Family Practice. 2004;53(5):354. Excluded because not a report of a primary study.
Mueller T, Gegenhuber A, Poelz W, Haltmayer M, Mueller TGAPWaHM. Preliminary evaluation of the AxSYM B type natriuretic peptide (BNP) assay and comparison with the ADVIA Centaur BNP assay. Clinical Chemistry. 2004;50(6):1104-1106. Excluded because not a report of a primary study. [pmid: 15161739].
Mukoyama M, Nakao K, Saito Y, Ogawa Y, Hosoda K, Suga S, et al. Increased human brain natriuretic peptide in congestive heart failure. New England Journal of Medicine. 1909;323(11):757-758. Excluded because not a report of a primary study. [pmid: 2143809].
Mukoyama M, Nakao K, Obata K, Jougasaki M, Yoshimura M, Morita E, et al. Augmented secretion of brain natriuretic peptide in acute myocardial infarction. Biochemical & Biophysical Research Communications. 1919;180(1):431-436. Excluded because BNP assay method is not an included one. [pmid: 1834057].
Mukoyama M, Nakao K, Hosoda K, Suga S, Saito Y, Ogawa Y, et al. Brain natriuretic peptide as a novel cardiac hormone in humans. Evidence for an exquisite dual natriuretic peptide system, atrial natriuretic peptide and brain natriuretic peptide. Journal of Clinical Investigation. 1991;87(4):1402-1412. Excluded because BNP assay method is not an included one. [pmid: 1849149]. [pmcid: 295184].
Mukoyama M, Nakao K, Saito Y, Ogawa Y, Hosoda K, Suga S, et al. Human brain natriuretic peptide, a novel cardiac hormone. Lancet. 2003;335(8692):801-802. Excluded because not a report of a primary study. [pmid: 1969551].
Murchie P, Mendez G, Campbell N, Patterson Y, Reid J, Cowie MR. Left ventricular dysfunction in the diabetic population. British Journal of General Practice. 2002;52(475):153-154. Excluded because not a report of a primary study. [pmid: 11885826]. [pmcid: 1314223].
Murdoch D, Byrne J, Farmer R, Morton J, Murdoch D, Byrne J, et al. Disparity between studies of the stability of BNP in blood: comparison of endogenous and exogenous peptide. Heart (British Cardiac Society). 1999;81(2):212-213. Excluded because BNP assay method is not an included one. [pmid: 9922362].
Murray M, Young J, Morrow D, Weiner M, Tu W, Hoke S, et al. Methodology of an ongoing, randomized, controlled trial to improve drug use for elderly patients with chronic heart failure. American Journal Geriatric Pharmacotherapy. 2004;2(1):53-65. Excluded because BNP assay method is not an included one.
Mussalo H, Vanninen E, Ikaheimo R, Hartikainen J, Mussalo HVEIRaHJ. NT-proANP and BNP in renovascular and in severe and mild essential hypertension. Kidney & Blood Pressure Research. 2003;26(1):34-41. Excluded because BNP assay method is not an included one. [pmid: 12697975].
Muta H, Ishii M, Maeno Y, Akagi T, Kato H, Muta H, et al. Quantitative evaluation of the changes in plasma concentrations of cardiac natriuretic peptide before and after transcatheter closure of atrial septal defect. Acta Paediatrica. 2002;91(6):649-652. Excluded because adult blood not measured. [pmid: 12162595].
Nagaya N. Drug therapy of primary pulmonary hypertension. American Journal of Cardiovascular Drugs. 2004;4(2):75-85. Excluded because not a report of a primary study. [pmid: 15049720].
Nakagawa K, Yamaguchi T, Seida M, Tanaka Y, Yoshino M, Nakagawa KYTSMTYaYM. Plasma concentrations of atrial and brain natriuretic peptides in a case with hypertensive encephalopathy. Neurological Research. 2002;24(6):627-630. Excluded because this is a case report or series with 10 subjects. [pmid: 12238633].
Nakamura M, Kawata Y, Yoshida H, Arakawa N, Koeda T, Ichikawa T, et al. Relationship between plasma atrial and brain natriuretic peptide concentration and hemodynamic parameters during percutaneous transvenous mitral valvulotomy in patients with mitral stenosis. American Heart Journal. 1992;124(5):1283-1288. Excluded because BNP assay method is not an included one. [pmid: 1442497].
Nakamura S, Isaji M, Ishimori M. Plasma adrenomedullin concentration in patients with Graves' disease. Internal Medicine. 2004;43(7):628-629. Excluded because BNP assay method is not an included one. [pmid: 15335196].
Nakamura S, Ishimori M, Nakamura S, Ishimori M. Plasma brain natriuretic peptide concentration in patients with Graves' disease. Endocrine Journal. 2001;48(3):403-404. Excluded because not a report of a primary study. [pmid: 11523914].
Nakamura S, Naruse M, Naruse K, Kawana M, Nishikawa T, Hosoda S, et al. Atrial natriuretic peptide and brain natriuretic peptide coexist in the secretory granules of human cardiac myocytes. American Journal of Hypertension. 1991;4(11):909-912. Excluded because adult blood not measured. [pmid: 1838692].
Nakamura S, Yoshimura M, Nakayama M, Ito T, Mizuno Y, Harada E, et al. Possible association of heart failure status with synthetic balance between aldosterone and dehydroepiandrosterone in human heart. Circulation. 1909;110(13):1787-1793. Excluded because adult blood not measured. [pmid: 15364798].
Nakanishi T, Tomita K, Nonoguchi H, Marumo F, Nakanishi T, Tomita K, et al. Heterogeneity of glomerular cGMP production by atrial natriuretic peptide and brain natriuretic peptide. Contributions to Nephrology. 1991;95:71-75. Excluded because adult blood not measured. [pmid: 1666993].
Nakao K, Mukoyama M, Hosoda K, Suga S, Ogawa Y, Saito Y, et al. Biosynthesis, secretion, and receptor selectivity of human brain natriuretic peptide. Canadian Journal of Physiology & Pharmacology. 1991;69(10):1500-1506. Excluded because BNP assay method is not an included one. [pmid: 1723349].
Nakao K, Ogawa Y, Suga -i S aIH. Molecular biology and biochemistry of the natriuretic peptide system. II: Natriuretic peptide receptors. Journal of Hypertension. 1992;10(10):1111-1114. Excluded because not a report of a primary study. [pmid: 1334991].
Nakao K, Saito Y, Itoh H, Ogawa Y, Nakagawa O, Harada M, et al. Roles of natriuretic peptides in heart failure. Journal of Cardiac Failure. 1996;2(4 Suppl):S129-S133. Excluded because not a report of a primary study. [pmid: 8951570].
Nakaoka Y, Nishida K, Fujio Y, Izumi M, Terai K, Oshima Y, et al. Activation of gp130 transduces hypertrophic signal through interaction of scaffolding/docking protein Gab1 with tyrosine phosphatase SHP2 in cardiomyocytes.[see comment]. Circulation Research. 2003;93(3):221-229. Excluded because adult blood not measured. [pmid: 12855672].
Nakayama T, Nomura M, Fujinaga H, Ikefuji H, Kimura M, Chikamori K, et al. Does coronary artery stenting for acute myocardial infarction improve left ventricular overloading at the chronic stage?. Japanese Heart Journal. 2004;45(2):217-229. Excluded because BNP assay method is not an included one. [pmid: 15090698].
Nakazato M. Guanylin family: new intestinal peptides regulating electrolyte and water homeostasis. Journal of Gastroenterology. 2001;36(4):219-225. Excluded because not a report of a primary study. [pmid: 11324723].
Naruse M, Takeyama Y, Tanabe A, Hiroshige J, Naruse K, Yoshimoto T, et al. Atrial and brain natriuretic peptides in cardiovascular diseases. Hypertension. 1994;23(1 Suppl):I231-I234. Excluded because BNP assay method is not an included one. [pmid: 8282365].
Nawata H, Ohashi M, Haji M, Takayanagi R, Higuchi K, Fujio N, et al. Atrial and brain natriuretic peptide in adrenal steroidogenesis. Journal of Steroid Biochemistry & Molecular Biology. 1991;40(13):367-379. Excluded because adult blood not measured. [pmid: 1659877].
Nexo E. Reflections of the jury. Scandinavian Journal of Clinical & Laboratory Investigation. 2004;64(5):478. Excluded because not a report of a primary study.
Ng L, Geeranavar S, Jennings S, Loke I, O'Brien R, Ng L, et al. Diagnosis of heart failure using urinary natriuretic peptides.[see comment]. Clinical Science. 2004;106(2):129-133. Excluded because BNP assay method is not an included one. [pmid: 13678415].
Ng L L.L. Brain naturetic peptide (BNP) and diabetes mellitus. Diabetic Medicine. 2004;21(Suppl 3):8-10. Excluded because not a report of a primary study. [pmid: 15089779].
Ng L, Loke I, Davies J, Khunti K, Stone M, Abrams K, et al. Identification of previously undiagnosed left ventricular systolic dysfunction: community screening using natriuretic peptides and electrocardiography. European Journal of Heart Failure. 2003;5(6):775-782. Excluded because BNP assay method is not an included one. [pmid: 14675856].
Ng L, Loke I, O'Brien R, Squire I, Davies J, Ng LL, et al. Plasma urocortin in human systolic heart failure. Clinical Science. 2004;106(4):383-388. Excluded because BNP assay method is not an included one. [pmid: 14651473].
Nicholls MG. Calorie-restricted weight reduction blood pressure, and atrial natriuretic peptides. Nutrition. 1993;9(4):381-382. Excluded because not a report of a primary study. [pmid: 8292146].
Nicholls M, Charles C, Lainchbury J, Lewis L, Rademaker M, Richards A, et al. Adrenomedullin in heart failure. Hypertension Research. 2003;26(SUPPL.):S135-S140. Excluded because not a report of a primary study. [pmid: 12630824].
Nicholls M, Lainchbury J, Richards A, Troughton R, Yandle T, Nicholls M, et al. Brain natriuretic peptide-guided therapy for heart failure. Annals of Medicine. 2001;33(6):422-427. Excluded because not a report of a primary study. [pmid: 11585103].
Nicholls M, Richards A, Crozier I, Espiner R, Ikram H. Cardiac natriuretic peptides in heart failure. Annals of Medicine. 1993;25(6):503-505. Excluded because not a report of a primary study. [pmid: 8292296].
Nicholson S, Richards M, Espiner E, Nicholls G, Yandle T, Nicholson S, et al. Atrial and brain natriuretic peptide response to exercise in patients with ischaemic heart disease. Clinical & Experimental Pharmacology & Physiology. 1993;20(78):535-540. Excluded because BNP assay method is not an included one. [pmid: 8403535].
Nielsen O, McDonagh T, Robb S, Dargie H, Nielsen OW, McDonagh TA, et al. Retrospective analysis of the cost-effectiveness of using plasma brain natriuretic peptide in screening for left ventricular systolic dysfunction in the general population. Journal of the American College of Cardiology. 2003;41(1):113-120. Excluded because BNP assay method is not an included one. [pmid: 12570953].
Nielsen O, Rasmussen V, Christensen N, Hansen J, Nielsen O, Rasmussen V, et al. Neuroendocrine testing in community patients with heart disease: plasma N-terminal proatrial natriuretic peptide predicts morbidity and mortality stronger than catecholamines and heart rate variability. Scandinavian Journal of Clinical & Laboratory Investigation. 2004;64(7):619-628. Excluded because BNP assay method is not an included one. [pmid: 15513318].
Nishigaki K, Tomita M, Kagawa K, Noda T, Minatoguchi S, Oda H, et al. Marked expression of plasma brain natriuretic peptide is a special feature of hypertrophic obstructive cardiomyopathy. Journal of the American College of Cardiology. 1996;28(5):1234-1242. Excluded because BNP assay method is not an included one. [pmid: 8890821].
Nishikimi T, Matsuoka H, Ishikawa K, Yoshihara F, Kawano Y, Kitamura K, et al. Antihypertensive therapy reduces increased plasma levels of adrenomedullin and brain natriuretic peptide concomitant with regression of left ventricular hypertrophy in a patient with malignant hypertension. Hypertension Research - Clinical & Experimental. 1996;19(2):97-101. Excluded because BNP assay method is not an included one.
Nishino M, Kimura T, Kanda T, Kotajima N, Yoshida A, Kuwabara A, et al. Circulating interleukin-6 significantly correlates to thyroid hormone in acute myocardial infarction but not in chronic heart failure. Journal of Endocrinological Investigation. 2000;23(8):509-514. Excluded because BNP assay method is not an included one. [pmid: 11021766].
Nitta K, Kawashima A, Yumura W, Naruse M, Oba T, Kabaya T, et al. Plasma concentration of brain natriuretic peptide as an indicator of cardiac ventricular function in patients on hemodialysis. American Journal of Nephrology. 1998;18(5):411-415. Excluded because BNP assay method is not an included one. [pmid: 9730565].
Node K, Fujita M, Kitakaze M, Hori M, Liao JK. Short-term statin therapy improves cardiac function and symptoms in patients with idiopathic dilated cardiomyopathy. Circulation. 2003;108(7):839-843. Excluded because BNP assay method is not an included one. [pmid: 12885745].
Noll B, Goke B, Simon B, Maisch B, Noll B, Goke B, et al. Cardiac natriuretic peptide hormones during artificial cardiac pacemaker stimulation and left heart catheterization. Clinical Investigator. 1992;70(12):1057-1060. Excluded because BNP assay method is not an included one. [pmid: 1467628].
Nordmeyer J, Eder S, Mahmoodzadeh S, Martus P, Fielitz J, Bass J, et al. Upregulation of myocardial estrogen receptors in human aortic stenosis. Circulation. 1920;110(20):3270-3275. Excluded because adult blood not measured. [pmid: 15533858].
Norman J, Little D, Bolgar M, Di Donato G, Norman J, Little D, et al. Degradation of brain natriuretic peptide by neutral endopeptidase: species specific sites of proteolysis determined by mass spectrometry. Biochemical & Biophysical Research Communications. 2002;175(1):22-30. Excluded because adult blood not measured. [pmid: 1998506].
not found in reference. New B-type natriuretic peptide test (pro-BNP) for heart failure. Cardiovascular Journal of Southern Africa 13(5):272-Oct. Excluded because not a report of a primary study
not found in reference. Glutathione, reduced (GSH). Alternative Medicine Review 2001 Dec;6(6):601–7. Excluded because not a report of a primary study
not found in reference. Pain and beta-endorphins. BackLetter 1999; 14(7):74. Excluded because not a report of a primary study
not found in reference. ... And assay of brain natriuretic peptide. Hospital Practice (Office Edition) 2000; 35(6):30. Excluded because not a report of a primary study
not found in reference. Rapid BNP blood test useful for diagnosing heart failure. British Journal of Cardiology 2000; 7(5):267. Excluded because not a report of a primary study
not found in reference. Aha pearls. Formulary 2001; 36(1):60–67. Excluded because adult blood not measured
not found in reference. Detecting asymptomatic left ventricular dysfunction. Medicine Today 2001; 2(10):10. Excluded because not a report of a primary study
not found in reference. Trauma technology. Diagnosing acute venous thrombosis. International Journal of Trauma Nursing 2001; 6(1):30-Mar. Excluded because not a report of a primary study
not found in reference. Brain natriuretic peptide (BNP): A diagnostic tool. Medicine Today 2002; 3(4):8–9. Excluded because not a report of a primary study
not found in reference. Case report: Tracking a growing epidemic. Cardiology Review 2002; 19(9):36. Excluded because this is a case report or series with 10 subjects
not found in reference. BNP better than clinician judgment for chronic heart failure assessment. Cardiology Review 2003; 20(12):12. Excluded because not a report of a primary study
not found in reference. Use of plasma brain natriuretic peptide concentration to aid in the diagnosis of heart failure. Prevention & Management of Congestive Heart Failure 2003; 9(3):180. Excluded because not a report of a primary study
not found in reference. Rising to the challenge of heart failure in the UK. Care of the Critically Ill 2003; 19(4):139. Excluded because not a report of a primary study
not found in reference. Nesiritide shortens hospital stay in heart failure. Pharmaceutical Journal 2003; 270(7244):506. Excluded because not a report of a primary study
not found in reference. Post-test. Cardiology Review 2003; 20(4 SUPPL.). Excluded because not a report of a primary study
not found in reference. New aid to diagnosis of congestive heart failure: a bedside blood test for B-type natriuretic peptide provides both diagnostic and prognostic information in acute dyspnea. Emergency Medicine 2003; 35(1):11–12. Excluded because not a report of a primary study
not found in reference. A is for... Natriuretic peptides. Science & Medicine 2003; 9(2):120. Excluded because not a report of a primary study
not found in reference. Elevated plasma natriuretic peptide levels were associated with cardiovascular events. ACP Journal Club 2004; v141(2):50. Excluded because not a report of a primary study
not found in reference. Rapid measurement of B-type natriuretic peptides reduced time to discharge and treatment costs in patients with acute dyspnea. ACP Journal Club 2004; v141(2):35. Excluded because not a report of a primary study
not found in reference. Primary results of the rapid emergency department heart failure outpatient trial. Indian Heart Journal 2004; 56(4):360. Excluded because not a report of a primary study
not found in reference. Community echocardiography for heart failure. British Journal of Cardiology 2004; 11(5):399–402. Excluded because not a report of a primary study
not found in reference. Natriuretic peptide understanding prompts development of new drugs. South African Medical Journal 2004; 94(5):353. Excluded because not a report of a primary study
not found in reference. Heart failure beyond maximum medical management. British Journal of Cardiology 2004; 11(1):22–23. Excluded because not a report of a primary study
not found in reference. RCT of BNP. Bandolier 2004; 11(8):7–8. Excluded because not a report of a primary study
not found in reference. BNP for CHF. Bandolier 2004; 11(3):7–8. Excluded because not a report of a primary study
not found in reference. FDA grants clearance to NT-proBNP for prognosis of congestive heart failure. Medical Letter on the CDC & FDA 2004;19–20. Excluded because not a report of a primary study
not found in reference. New CHF drug shown to ease breathing distress among hospitalized patients. Clinical Resource Management 2005; 3(5):68–70. Excluded because BNP used as treatment
Nousiainen T, Jantunen E, Vanninen E, Remes J, Puustinen J, Rantala A, et al. Acute neurohumoral and cardiovascular effects of idarubicin in leukemia patients. European Journal of Haematology. 1998;61(5):347-353. Excluded because BNP assay method is not an included one. [pmid: 9855251].
Nousiainen T, Jantunen E, Vanninen E, Remes J, Vuolteenaho O, Hartikainen J, et al. Natriuretic peptides as markers of cardiotoxicity during doxorubicin treatment for non-Hodgkin's lymphoma. European Journal of Haematology. 1999;62(2):135-141. Excluded because BNP assay method is not an included one. [pmid: 10052718].
Nousiainen T, Vanninen E, Jantunen E, Remes J, Ritanen E, Vuolteenaho O, et al. Neuroendocrine changes during the evolution of doxorubicin-induced left ventricular dysfunction in adult lymphoma patients. Clinical Science. 2001;101(6):601-607. Excluded because BNP assay method is not an included one. [pmid: 11724646].
Nousiainen T, Vanninen E, Jantunen E, Puustinen J, Remes J, Rantala A, et al. Natriuretic peptides during the development of doxorubicin-induced left ventricular diastolic dysfunction. Journal of Internal Medicine. 2002;251(3):228-234. Excluded because BNP assay method is not an included one. [pmid: 11886482].
Nowatzke W T.G. Stability of N-terminal pro-brain natriuretic peptide after storage frozen for one year and after multiple freeze-thaw cycles [8]. Clinical Chemistry. 2003;49(9):1560-1562. Excluded because not a report of a primary study. [pmid: 12928253].
Nunes J, es D, Dias P, Faria DB. Troponin I elevation after pericardiocentesis for cardiac tamponade: A role for myocardial strain? [4]. International Journal of Cardiology. 2001;81(23):277-278. Excluded because not a report of a primary study. [pmid: 11744150].
O'Connor J L.N. B-type natriuretic peptide is an accurate predictor of heart failure in the emergency department. Journal of Family Practice. 2002;51(10):816. Excluded because not a report of a primary study. [pmid: 12401145].
Obi T, Takatsu M, Konishi T, Mizoguchi K, Nishimura Y, Obi T, et al. Secretion of natriuretic peptides caused by an epileptic attack. Acta Neurologica Scandinavica. 2002;106(4):225-228. Excluded because not a report of a primary study. [pmid: 12225320].
Odent M. Why labouring women don't need “support”... reprinted with permission. Copyright Mothering, 1996. MIDIRS Midwifery Digest. 1997;7(1):61-64. Excluded because not a report of a primary study.
Ogawa A, Iwase T, Yamamoto T, Nishiyama S, Narui K, Momomura S. Improvement of Cheyne-Stokes respiration, central sleep apnea and congestive heart failure by noninvasive bilevel positive pressure and medical treatment. Circulation Journal. 2004;68(9):878-882. Excluded because this is a case report or series with 10 subjects. [pmid: 15329513].
Ogawa E, Saito Y, Harada M, Kamitani S, Kuwahara K, Miyamoto Y, et al. Outside-in signalling of fibronectin stimulates cardiomyocyte hypertrophy in cultured neonatal rat ventricular myocytes. Journal of Molecular & Cellular Cardiology. 2000;32(5):765-776. Excluded because adult blood not measured. [pmid: 10775482].
Ogawa M, Hirose N, Ogimoto M, Matsuki H, Miki K, Kinoshita M, et al. Chronic beneficial effects of type 1 angiotensin II receptor antagonist in patients with chronic hypoxemic pulmonary diseases. Cardiology. 2002;97(2):111-112. Excluded because not a report of a primary study. [pmid: 11978959].
Ogawa S, Matsumura S, Yoshikawa T, Satoh T, Kumagai H, Mitamura H, et al. A case of dilated cardiomyopathy with end-stage heart failure treated by prolonged continuous hemodiafiltration. Keio Journal of Medicine. 2002;51(3):165-177. Excluded because this is a case report or series with 10 subjects. [pmid: 12371648].
Ogawa S, Takeuchi K, Ito S, Ogawa STKaIS. Plasma BNP levels in the treatment of type 2 diabetes with pioglitazone. Journal of Clinical Endocrinology & Metabolism. 2003;88(8):3993-3996. Excluded because BNP assay method is not an included one. [pmid: 12915698].
Ogawa T, Vatta M, Bruneau B, de Bold A, Ogawa T, Vatta M, et al. Characterization of natriuretic peptide production by adult heart atria. American Journal of Physiology. 1999;276(6 Pt 2):H1977-H1986. Excluded because adult blood not measured. [pmid: 10362678].
Ogawa Y, Itoh H, Nakao K. Molecular biology of brain natriuretic peptide. Japanese Heart Journal. 1994;35(4):496-497. Excluded because adult blood not measured.
Ogimoto A, Hamada M, Nakura J, Miki T, Hiwada K, Ogimoto AHMNJMTaHK. Relation between angiotensin-converting enzyme II genotype and atrial fibrillation in Japanese patients with hypertrophic cardiomyopathy. Journal of Human Genetics. 2002;47(4):184-189. Excluded because BNP assay method is not an included one. [pmid: 12166654].
Ohata T, Sakakibara T, Takano H, Izutani H, Ohata TSTTHaIH. Plasma brain natriuretic peptide reflects left ventricular function during percutaneous cardiopulmonary support. Annals of Thoracic Surgery. 2004;77(1):164-167. Excluded because this is a case report or series with 10 subjects. [pmid: 14726055].
Ohba H, Takada H, Musha H, Nagashima J, Mori N, Awaya T, et al. Effects of prolonged strenuous exercise on plasma levels of atrial natriuretic peptide and brain natriuretic peptide in healthy men. American Heart Journal. 2001;141(5):751-758. Excluded because this is a case report or series with 10 subjects. [pmid: 11320362].
Ohbayashi Y, Tsutamoto T, Sakaguchi T, Tanaka T, Kanamori T, Yokohama H, et al. Effect of an angiotensin II type 1 receptor blocker, valsartan, on neurohumoral factors in patients with hypertension: comparison with a long-acting calcium channel antagonist, amlodipine. Journal of Cardiovascular Pharmacology. 2003;42(Suppl 1):S71-S74. Excluded because BNP assay method is not an included one. [pmid: 14871033].
Ohkusa T, Noma T, Ueyama T, Hismatsu Y, Yano M, Kensuke E, et al. Differences in sarcoplasmic reticulum gene expression in myocardium from patients undergoing cardiac surgery. Quantification of steady-state levels of messenger RNA using the reverse transcription-polymerase chain reaction. Heart & Vessels. 1997;12(1):1-9. Excluded because adult blood not measured. [pmid: 9288554].
Ohmichi N, Iwai N, Kinoshita M, Ohmichi N, Iwai N, Kinoshita M. Expression of angiotensin converting enzyme and chymase in human atria. Journal of Hypertension. 1997;15(9):935-943. Excluded because adult blood not measured. [pmid: 9321740].
Ohsaki Y, Gross A, Le P, Oie H, Johnson B, Ohsaki Y, et al. Human small cell lung cancer cells produce brain natriuretic peptide. Oncology. 1999;56(2):155-159. Excluded because adult blood not measured. [pmid: 9949302].
Ohtsuka T, Hamada M, Saeki H, Ogimoto A, Hara Y, Shigematsu Y, et al. Serum levels of matrix metalloproteinases and tumor necrosis factor-a in patients with idiopathic dilated cardiomyopathy and effect of carvedilol on these levels. American Journal of Cardiology. 2003;91(8):1024-1027. Excluded because BNP assay method is not an included one. [pmid: 12686357].
Ohuchi H, Suzuki H, Toyohara K, Tatsumi K, Ono Y, Arakaki Y, et al. Abnormal cardiac autonomic nervous activity after right ventricular outflow tract reconstruction. Circulation. 1920;102(22):2732-2738. Excluded because BNP assay method is not an included one. [pmid: 11094040].
Okada K, Minamino T, Tsukamoto Y, Liao Y, Tsukamoto O, Takashima S, et al. Prolonged endoplasmic reticulum stress in hypertrophic and failing heart after aortic constriction: possible contribution of endoplasmic reticulum stress to cardiac myocyte apoptosis. Circulation. 2004;110(6):705-712. Excluded because adult blood not measured. [pmid: 15289376].
Okumura K, Yasue H, Fujii H, Kugiyama K, Matsuyama K, Yoshimura M, et al. Effects of brain (B-type) natriuretic peptide on coronary artery diameter and coronary hemodynamic variables in humans: comparison with effects on systemic hemodynamic variables. Journal of the American College of Cardiology. 1995;25(2):342-348. Excluded because BNP assay method is not an included one. [pmid: 7829786].
Okuno S, Hamada H, Yasuoka M, Watanabe H, Fujiki Y, Yamada N, et al. Brain natriuretic peptide (BNP) and cyclic guanosine monophosphate (cGMP) levels in normal pregnancy and preeclampsia. Journal of Obstetrics & Gynaecology Research. 1999;25(6):407-410. Excluded because BNP assay method is not an included one. [pmid: 10680338].
Omland T. N-terminal proBNP: Marker of systolic dysfunction or nonspecific indicator of cardiac disease?. Heartdrug. 2003;3(3):122-124. Excluded because BNP assay method is not an included one.
Omland T, Richards A, Wergeland R, Vik-Mo H, Omland TRA, Wergeland RaV-MH. B-type natriuretic peptide and long-term survival in patients with stable coronary artery disease. American Journal of Cardiology. 2005;95(1):24-28. Excluded because BNP assay method is not an included one. [pmid: 15619389].
Onuoha G, Nicholls D, Patterson A, Beringer T, Onuoha G, Nicholls D, et al. Neuropeptide secretion in exercise. Neuropeptides. 1998;32(4):319-325. Excluded because BNP assay method is not an included one. [pmid: 10102676].
Onuoha G, Nugent A, Hunter S, Alpar E, McEneaney D, Campbell N, et al. Neuropeptide variability in man.[see comment]. European Journal of Clinical Investigation. 2000;30(7):570-577. Excluded because adult blood not measured. [pmid: 10886296].
Ootaki Y, Yamaguchi M, Yoshimura N, Oka S, Yoshida M, Hasegawa T, et al. Secretion of A-type and B-type natriuretic peptides into the bloodstream and pericardial space in children with congenital heart disease. Journal of Thoracic & Cardiovascular Surgery. 2003;126(5):1411-1416. Excluded because adult blood not measured. [pmid: 14666013].
Owen A. NICE try but a long way to go in heart failure. British Journal of Cardiology. 2004;11(5):339-341. Excluded because not a report of a primary study.
Ozawa T, Tanaka H, Nakano R, Sato M, Inuzuka T, Soma Y, et al. Nocturnal decrease in vasopressin secretion into plasma in patients with multiple system atrophy. Journal of Neurology, Neurosurgery and Psychiatry. 1999;67(4):542-545. Excluded because BNP assay method is not an included one.
Papp A, Uusaro A, Parviainen I, Hartikainen J, Ruokonen E, Papp A, et al. Myocardial function and haemodynamics in extensive burn trauma: evaluation by clinical signs, invasive monitoring, echocardiography and cytokine concentrations. A prospective clinical study. Acta Anaesthesiologica Scandinavica. 2003;47(10):1257-1263. Excluded because this is a case report or series with 10 subjects. [pmid: 14616324].
Park M, Scott R, Uber P, Mehra M, Park MH, Scott RL, et al. Bedside b-type natriuretic peptide and acute non-cellular cardiac allograft rejection. Journal of Heart & Lung Transplantation. 2002;21(5):613-614. Excluded because adult blood not measured. [pmid: 11983556].
Patel A M.A. Recent advances in the treatment of heart failure. Circulation Journal. 2002;66(2):117-121. Excluded because not a report of a primary study. [pmid: 11999634].
Patel D, Bailey S, Patel DN, Bailey SR. Role of BNP in patients with severe asymptomatic aortic stenosis. European Heart Journal. 2004;25(22):1972-1973. Excluded because not a report of a primary study. [pmid: 15541831].
Patel J J.A. Immunosuppression diagnosis, and treatment of cardiac allograft rejection. Seminars in Thoracic & Cardiovascular Surgery. 2004;16(4):378-385. Excluded because not a report of a primary study. [pmid: 15635544].
Paulus W W.J. Natriuretic peptides to probe haemodynamic overload in hypertrophic cardiomyopathy.[comment]. European Heart Journal. 2001;22(15):1249-1251. Excluded because not a report of a primary study. [pmid: 11465958].
Pearl A, Wright S, Gamble G, Doughty R, Sharpe N, Pearl AWSGGDRaSN. Randomised trials in general practice--a New Zealand experience in recruitment.[see comment]. New Zealand Medical Journal. 1920;116(1186):U681. Excluded because not a report of a primary study. [pmid: 14657964].
Pedersen E, Pedersen H, Jensen K, Pedersen E, Pedersen H, Jensen KT. Pulsatile secretion of atrial natriuretic peptide and brain natriuretic peptide in healthy humans. Clinical Science. 1999;97(2):201-206. Excluded because BNP assay method is not an included one. [pmid: 10409475].
Pei Y, Chan C, Cattran D, Cardella C, Zaltzman J, Lopez M, et al. Sustained vasoconstriction associated with daily cyclosporine dose in heart and lung transplant recipients: potential pathophysiologic role of endothelin. Journal of Laboratory and Clinical Medicine. 1995;125(1):113-119. Excluded because BNP assay method is not an included one. [pmid: 7822939].
Pepperell J, Maskell N, Jones D, Langford-Wiley B, Crosthwaite N, Stradling J, et al. A randomized controlled trial of adaptive ventilation for Cheyne-Stokes breathing in heart failure. American Journal of Respiratory & Critical Care Medicine. 2003;168(9):1109-1114. Excluded because BNP assay method is not an included one. [pmid: 12928310].
Perin E, Dohmann H, Borojevic R, Silva S, Sousa A, Mesquita C, et al. Transendocardial, autologous bone marrow cell transplantation for severe, chronic ischemic heart failure. Circulation. 2003;107(18):2294-2302. Excluded because BNP assay method is not an included one. [pmid: 12707230].
Petrie M, McClure S, Love M, McMurray J, Petrie M, McClure S, et al. Novel neuropeptides in the pathophysiology of heart failure: adrenomedullin and endothelin-1. European Journal of Heart Failure. 1999;1(1):25-29. Excluded because not a report of a primary study. [pmid: 10937975].
Philipp S, Monti J, Pagel I, Langenickel T, Notter T, Ruschitzka F, et al. Treatment with darusentan over 21 days improved cGMP generation in patients with chronic heart failure. Clinical Science. 2002;103(Suppl 48):249S-253S. Excluded because BNP assay method is not an included one. [pmid: 12193097].
Piccini J, Klein L, Gheorghiade M, Bonow RO. New insights into diastolic heart failure: Role of diabetes mellitus. American Journal of Medicine. 2004;116(5 SUPPL. 1):64S-75S. Excluded because not a report of a primary study. [pmid: 15019864].
Pidgeon G, Richards A, Nicholls M, Bailey R, Lynn K, Lewis L, et al. Effect of ouabain on pressor responsiveness in normal man. American Journal of Physiology - Endocrinology & Metabolism. 1994;267(5 305):E642-E647. Excluded because this is a case report or series with 10 subjects.
Pidgeon G, Richards A, Nicholls M, Lewis L, Yandle TG. Acute effects of intravenous ouabain in healthy volunteers. Clinical Science. 1994;86(4):391-397. Excluded because this is a case report or series with 10 subjects. [pmid: 8168332].
Pidgeon G, Richards A, Nicholls M, Espiner E, Yandle T, Frampton C, et al. Differing metabolism and bioactivity of atrial and brain natriuretic peptides in essential hypertension. Hypertension. 1996;27(4):906-913. Excluded because BNP assay method is not an included one. [pmid: 8613267].
Piquard F, Geny B, Elero B, Canguilhem B, Mettauer B, Epailly E, et al. Role of immunosuppressive therapy in neuroendocrine activation after human heart, renal, and liver transplantation. Transplantation Proceedings. 1998;30(5):2124-2126. Excluded because BNP assay method is not an included one. [pmid: 9723414].
Poole-Wilson PA. Tailored treatment for heart failure: An emerging concept. American Heart Journal. 1999;138(6 I):1005-1006. Excluded because not a report of a primary study. [pmid: 10577424].
Poole-Wilson P S.-R. New therapies for the management of acute heart failure. Current Cardiology Reports. 2003;5(3):229-236. Excluded because not a report of a primary study. [pmid: 12691642].
Porcel J, Vives M, Cao G, Esquerda A, Rubio M, Rivas M, et al. Measurement of pro-brain natriuretic peptide in pleural fluid for the diagnosis of pleural effusions due to heart failure.[see comment]. American Journal of Medicine. 2003;116(6):417-420. Excluded because adult blood not measured. [pmid: 15006591].
Potter LR. CNP, cardiac natriuretic peptide?. Endocrinology. 2004;145(5):2129-2130. Excluded because not a report of a primary study. [pmid: 15087437].
Prandota J. Furosemide: progress in understanding its diuretic, anti-inflammatory, and bronchodilating mechanism of action, and use in the treatment of respiratory tract diseases. American Journal of Therapeutics. 2002;9(4):317-328. Excluded because not a report of a primary study. [pmid: 12115021].
Prasad K, Fredericks S, Holt D, Prasad K, Fredericks S, Holt DW. Measuring brain natriuretic peptide.[see comment]. Lancet. 1908;348(9027):626. Excluded because not a report of a primary study. [pmid: 8774612].
Prasad N, Bridges A, Lang C, Clarkson P, MacLeod C, Pringle T, et al. Brain natriuretic peptide concentrations in patients with aortic stenosis. American Heart Journal. 1997;133(4):477-479. Excluded because BNP assay method is not an included one. [pmid: 9124176].
Prasad N, Lang C, McAlpine H, Choy A, MacDonald T, Struthers A, et al. Raised plasma concentrations of brain natriuretic peptide in pulmonary arterial hypertension.[see comment]. Respiratory Medicine. 1995;89(6):445-447. Excluded because BNP assay method is not an included one. [pmid: 7644777].
Prasun MA. The effects of a diuretic titration protocol on clinical outcomes in heart failure patients. University of Illinois at Chicago, Health Sciences Center ** Ph D.(142 p):2002. Excluded because not a report of a primary study
Prasun M, Kocheril A, Klass P, Dunlap S, Piano M, Prasun MA, et al. The effects of a sliding scale diuretic titration protocol in patients with heart failure. Journal of Cardiovascular Nursing. 2005;20(1):62-70. Excluded because BNP assay method is not an included one. [pmid: 15632815].
Prestle J, Dieterich S, Preuss M, Bieligk U, Hasenfuss G, Prestle J, et al. Heterogeneous transmural gene expression of calcium-handling proteins and natriuretic peptides in the failing human heart.[see comment]. Cardiovascular Research. 1999;43(2):323-331. Excluded because adult blood not measured. [pmid: 10536662].
Pritchett A D.L. Neurohormonal therapy for congestive heart failure. Current Treatment Options in Cardiovascular Medicine. 2004;6(6):499-507. Excluded because not a report of a primary study. [pmid: 15496267].
Prontera C, Emdin M, Zucchelli G, Ripoli A, Passino C, Clerico A, et al. Natriuretic peptides (NPs): Automated electrochemiluminescent immunoassay for N-terminal pro-BNP compared with IRMAs for ANP and BNP in heart failure patients and healthy individuals. Clinical Chemistry. 2003;49(9):1552-1554. Excluded because not a report of a primary study. [pmid: 12928247].
Pu W S. Transcription factors and heart failure: Does the stressed heart need a hand?. Journal of Molecular & Cellular Cardiology. 2001;33(10):1765-1767. Excluded because not a report of a primary study. [pmid: 11603918].
Pucci A, Wharton J, Arbustini E, Grasso M, Diegoli M, Needleman P, et al. Atrial amyloid deposits in the failing human heart display both atrial and brain natriuretic peptide-like immunoreactivity. Journal of Pathology. 1991;165(3):235-241. Excluded because adult blood not measured. [pmid: 1837051].
Puschendorf B B. Strategies for cardiac marker measurement. Clinical Chemistry & Laboratory Medicine. 1999;37(1112):997-999. Excluded because not a report of a primary study. [pmid: 10726807].
Putsep K, Carlsson G, Boman H, Andersson M. Mechanisms of disease. Deficiency of antibacterial peptides in patients with morbus Kostmann: an observation study. Lancet. 1920;360(9340):1144-1149. Excluded because adult blood not measured. [pmid: 12387964].
Qi W, Mathisen P, Kjekshus J, Simonsen S, Endresen K, Bjornerheim R, et al. The effect of aortic valve replacement on N-terminal natriuretic propeptides in patients with aortic stenosis. Clinical Cardiology. 2002;25(4):174-180. Excluded because BNP assay method is not an included one. [pmid: 12000075].
Rabinstein A E.F.M. Hyponatremia in Critically III Neurological Patients. Neurologist. 2003;9(6):290-300. Excluded because not a report of a primary study. [pmid: 14629783].
Rahimtoola SH. The year in valvular heart disease. Journal of the American College of Cardiology. 2005;45(1):111-122. Excluded because not a report of a primary study. [pmid: 15629384].
Rahmutula D, Nakayama T, Soma M, Takahashi Y, Uwabo J, Sato M, et al. A C2077T polymorphism of the type B human natriuretic peptide receptor gene is not associated with myocardial infarction. Medical Science Monitor. 2000;6(6):1056-1060. Excluded because adult blood not measured. [pmid: 11208455].
Rahmutula D, Nakayama T, Soma M, Sato M, Izumi Y, Kanmatsuse K, et al. Systematic screening of type B human natriuretic peptide receptor gene polymorphisms and association with essential hypertension. Journal of Human Hypertension. 2001;15(7):471-474. Excluded because adult blood not measured. [pmid: 11464256].
Rao G. What is an ROC curve?. Journal of Family Practice. 2003;52(9):695. Excluded because not a report of a primary study. [pmid: 12967540].
Ravnan S P.C. The rational use of diuretics in heart failure. Current Cardiology Reports. 2003;5(3):237-242. Excluded because not a report of a primary study. [pmid: 12691643].
Redfield M, Margaret M. The Breathing Not Proper trial: enough evidence to change heart failure guidelines?. Journal of Cardiac Failure. 2002;8(3):120-123. Excluded because not a report of a primary study. [pmid: 12140802].
Ribeiro A, Dos Reis A, Barros M, de Sousa M, Rocha A, Perez A, et al. Brain natriuretic peptide and left ventricular dysfunction in Chagas' disease. Lancet. 2002;360(9331):461-462. Excluded because not a report of a primary study. [pmid: 12241721].
Ribeiro A, Dos Reis A, Barros M, de Sousa M, Rocha A, Perez A, et al. Brain natriuretic peptide and left ventricular dysfunction in Chagas' disease.[see comment]. Lancet. 2002;360(9331):461-462. Excluded because BNP assay method is not an included one. [pmid: 12241721].
Ribeiro A, Reis A, Teixeira M, and Rocha MOC. Brain natriuretic peptide in Chagas' disease: further insights... Walther T, Heringer-Walther S, Wessel N et al. Brain natriuretic peptide as a predictor of cardiomyopathy in Chagas' disease. Lancet 2003; 361:1567. Lancet 1907; 362(9380):333. Excluded because not a report of a primary study
Richards AM. Vasopeptidase inhibitors for heart failure: Where do we go from here?. European Journal of Heart Failure. 2003;5(4):411-413. Excluded because not a report of a primary study. [pmid: 12921800].
Richards A, Crozier I, Espiner E, Yandle T, Nicholls M, Richards A, et al. Plasma brain natriuretic peptide and endopeptidase 24.11 inhibition in hypertension. Hypertension. 1993;22(2):231-236. Excluded because BNP assay method is not an included one. [pmid: 8340158].
Richards A, Crozier I, Yandle T, Espiner E, Ikram H, Nicholls M, et al. Brain natriuretic factor: regional plasma concentrations and correlations with haemodynamic state in cardiac disease. British Heart Journal. 1993;69(5):414-417. Excluded because BNP assay method is not an included one. [pmid: 8390847]. [pmcid: 1025104].
Richards A, Crozier I, Holmes S, Espiner E, Yandle T, Frampton C, et al. Brain natriuretic peptide: natriuretic and endocrine effects in essential hypertension. Journal of Hypertension. 1993;11(2):163-170. Excluded because this is a case report or series with 10 subjects. [pmid: 8385176].
Richards A, Doughty R, Nicholls M, MacMahon S, Ikram H, Sharpe N, et al. Neurohumoral prediction of benefit from carvedilol in ischemic left ventricular dysfunction. Australia-New Zealand Heart Failure Group. Circulation. 2002;99(6):786-792. Excluded because BNP assay method is not an included one. [pmid: 9989964].
Richards A, Nicholls M, Yandle T, Ikram H, Espiner E, Turner J, et al. Neuroendocrine prediction of left ventricular function and heart failure after acute myocardial infarction. The Christchurch Cardioendocrine Research Group. Heart (British Cardiac Society). 1999;81(2):114-120. Excluded because BNP assay method is not an included one. [pmid: 9922344]. [pmcid: 1728940].
Roberts A. The adrenal gland 2. Nursing Times. 1919;91(50):31-33. Excluded because not a report of a primary study. [pmid: 8559680].
Roberts A. Systems of life. The pituitary... part 1. Nursing Times. 1995;91(19):35-37. Excluded because not a report of a primary study.
Robertson M, Livesey G, Hampton S, Mathers JC. Evidence for altered control of glucose disposal after total colectomy. British Journal of Nutrition. 2000;84(6):813-819. Excluded because BNP assay method is not an included one. [pmid: 11177197].
Robson J. What happened to evidence in NICE guidance on heart failure? [7]. British Medical Journal. 2003;327(7420):932. Excluded because not a report of a primary study. [pmid: 14563774].
Rodeheffer R, Richard J. Epidemiology and screening of asymptomatic left ventricular dysfunction. Journal of Cardiac Failure. 2002;8(6 Suppl):S253-S257. Excluded because not a report of a primary study. [pmid: 12555128].
Rosen S, Taneja A, Coats A, Flather M. Assessment of the patient with heart failure. Continuing Medical Education - Cardiology. 2002;2(2):95-105. Excluded because not a report of a primary study.
Rosenberg K. BNP assay for assessing cardiac function. Cardiology Review. 2001;18(6):15. Excluded because not a report of a primary study.
Rosenkranz S, Diet F, Karasch T, Weihrauch J, Wassermann K, Erdmann E, et al. Sildenafil improved pulmonary hypertension and peripheral blood flow in a patient with scleroderma-associated lung fibrosis and the raynaud phenomenon. Annals of Internal Medicine. 1920;139(10):871-873. Excluded because not a report of a primary study. [pmid: 14623635].
Ross J Jr. Thematic review series IX: New therapeutic targets for the treatment of heart failure: Introduction. Proceedings of the Association of American Physicians. 1999;111(5):396-398. Excluded because not a report of a primary study. [pmid: 10519159].
Rossi A, Enriquez-Sarano M, Burnett J Jr, Lerman A, Abel M, et al. Natriuretic peptide levels in atrial fibrillation: a prospective hormonal and Doppler-echocardiographic study. Journal of the American College of Cardiology. 2000;35(5):1256-1262. Excluded because BNP assay method is not an included one. [pmid: 10758968].
Rouleau J, Pfeffer M, Stewart D, Isaac D, Sestier F, Kerut E, et al. Comparison of vasopeptidase inhibitor, omapatrilat, and lisinopril on exercise tolerance and morbidity in patients with heart failure: IMPRESS randomised trial. Lancet. 2000;356(9230):615-620. Excluded because BNP assay method is not an included one. [pmid: 10968433].
Rousseau M, Gurne O, Duprez D, Van Mieghem W, Robert A, Ahn S, et al. Beneficial neurohormonal profile of spironolactone in severe congestive heart failure: results from the RALES neurohormonal substudy.[erratum appears in J Am Coll Cardiol. 2003 Nov 19;42(10):1865]. Journal of the American College of Cardiology. 2002;40(9):1596-1601. Excluded because BNP assay method is not an included one. [pmid: 12427411].
Roy B, Dauphin M, Kelly TM. Idiotypic and anti-idiotypic antibodies interfere in a standard radioimmunoassay for beta-endorphin. Journal of Laboratory and Clinical Medicine. 1995;125(1):79-85. Excluded because BNP assay method is not an included one. [pmid: 7822949].
Rubinstein I D. Circulating natriuretic peptides: A biologic marker of tissue injury?. Chest. 1999;115(1):7-8. Excluded because not a report of a primary study. [pmid: 9925055].
Ruck A, Gustafsson T, Norrbom J, Nowak J, Kallner G, Soderberg M, et al. ANP and BNP but not VEGF are regionally overexpressed in ischemic human myocardium. Biochemical & Biophysical Research Communications. 2004;322(1):287-291. Excluded because adult blood not measured. [pmid: 15313204].
Ruschitzka F, Corti R, Quaschning T, Hermann M, Luscher TF. Vasopeptidase inhibitors-Concepts and evidence. Nephrology Dialysis Transplantation. 2001;16(8):1532-1535. Excluded because not a report of a primary study.
Ruskoaho H. Atrial natriuretic peptide: Synthesis, release, and metabolism. Pharmacological Reviews. 1992;44(4):481-602. Excluded because not a report of a primary study.
Ruskoaho H, Hall C, Holmstrom H, McDonagh TA. S-10. New analyses in the evaluation of heart failure. Scandinavian Journal of Clinical and Laboratory Investigation Supplement. 2000;60(232):44-45. Excluded because not a report of a primary study.
Russell S T. Vasopressin receptor antagonists: Therapeutic potential in the management of acute and chronic heart failure. American Journal of Cardiovascular Drugs. 2003;3(1):13-20. Excluded because not a report of a primary study. [pmid: 14727942].
Ry S, Andreassi M, Clerico A, Biagini A, Giannessi D, Ry S, et al. Endothelin-1, endothelin-1 receptors and cardiac natriuretic peptides in failing human heart. Life Sciences. 2001;68(24):2715-2730. Excluded because adult blood not measured. [pmid: 11400914].
Sabbah HN. Biologic rationale for the use of beta-blockers in the treatment of heart failure. Heart Failure Reviews. 2004;9(2):91-97. Excluded because not a report of a primary study. [pmid: 15516856].
Saijo M, Takemura G, Koda M, Okada H, Miyata S, Ohno Y, et al. Cardiomyopathy with prominent autophagic degeneration, accompanied by an elevated plasma brain natriuretic peptide level despite the lack of overt heart failure. Internal Medicine. 2004;43(8):700-703. Excluded because BNP assay method is not an included one. [pmid: 15468969].
Sakamoto T, Mizuno Y, Ogawa H, Yoshimura M, Kugiyama K, Yasue H. B-type natriuretic peptide after percutaneous transluminal septal myocardial ablation. International Journal of Cardiology. 2002;83(2):151-158. Excluded because this is a case report or series with 10 subjects. [pmid: 12007687].
Sakurai S, Adachi H, Hasegawa A, Hoshizaki H, Oshima S, Taniguchi K, et al. Brain natriuretic peptide facilitates severity classification of stable chronic heart failure with left ventricular dysfunction. Heart (British Cardiac Society). 2003;89(6):661-662. Excluded because not a report of a primary study. [pmid: 12748228]. [pmcid: 1767693].
Salo J, Jimenez W, Kuhn M, Gines A, Gines P, Fernandez-Esparrach G, et al. Urinary excretion of urodilatin in patients with cirrhosis. Hepatology. 1996;24(6):1428-1432. Excluded because adult blood not measured. [pmid: 8938175].
Salzmann J, Flitcroft D, Bunce C, Gordon D, Wormald R, Migdal C, et al. Brain natriuretic peptide: identification of a second natriuretic peptide in human aqueous humour. British Journal of Ophthalmology. 1998;82(7):830-834. Excluded because adult blood not measured. [pmid: 9924382]. [pmcid: 1722682].
Samson WK. Natriuretic peptides: A family of hormones. Trends in Endocrinology & Metabolism. 1992;3(3):86-90. Excluded because not a report of a primary study. [pmid: 18407084].
Sanderson J, Chan W, Hung Y, Chan S, Shum I, Raymond K, et al. Effect of low dose beta blockers on atrial and ventricular (B type) natriuretic factor in heart failure: a double blind, randomised comparison of metoprolol and a third generation vasodilating beta blocker. British Heart Journal. 1995;74(5):502-507. Excluded because BNP assay method is not an included one. [pmid: 8562234]. [pmcid: 484069].
Sanderson J, John E. BNP or echocardiography for monitoring heart failure?. European Heart Journal. 2004;25(20):1763-1764. Excluded because not a report of a primary study. [pmid: 15474688].
Sankaralingam A. Increase in circulating levels of cardiac natriuretic peptides after hormone replacement therapy in postmenopausal women (S Maffei, S Del Ry, C Clerico. Clin Scie 2001; 101: 447–53). Cpd Bulletin Clinical Biochemistry. 2002;4(3):81. Excluded because not a report of a primary study.
Saper C C.B. Of hearts and minds: natriuretic peptides in the brain. Journal of Comparative Neurology. 2005;356(2):166-167. Excluded because not a report of a primary study. [pmid: 7629312].
Saribulbul O, Alat I, Coskun S, Apaydin A, Yagdi T, Kiliccioglu M, et al. The role of brain natriuretic peptide in the prediction of cardiac performance in coronary artery bypass grafting. Texas Heart Institute Journal. 2003;30(4):298-304. Excluded because BNP assay method is not an included one. [pmid: 14677740]. [pmcid: 307715].
Sasaki T, Kubo T, Komamura K, Nishikimi T, Sasaki T, Kubo T, et al. Effects of long-term treatment with pimobendan on neurohumoral factors in patients with non-ischemic chronic moderate heart failure. Journal of Cardiology. 1999;33(6):317-325. Excluded because BNP assay method is not an included one. [pmid: 10396705].
Sato Y, Kita T, Takatsu Y, Kimura T. Biochemical markers of myocyte injury in heart failure. Heart (British Cardiac Society). 2004;90(10):1110-1113. Excluded because not a report of a primary study. [pmid: 15367501]. [pmcid: 1768497].
Sato Y, Taniguchi R, Makiyama T, Nagai K, Okada H, Yamada T, et al. Serum cardiac troponin T and plasma brain natriuretic peptide in patients with cardiac decompensation. Heart (British Cardiac Society). 2002;88(6):647-648. Excluded because not a report of a primary study. [pmid: 12433908]. [pmcid: 1767451].
Savoia C E.L. Significance of recently identified peptides in hypertension: Endothelin, natriuretic, peptides, adrenomedullin, leptin. Medical Clinics of North America. 2004;88(1):39-62. Excluded because not a report of a primary study. [pmid: 14871050].
Schaufelberger M, Bergh C, Caidahl K, Eggertsen R, Furenas E, Lindstedt G, et al. Can brain natriuretic peptide (BNP) be used as a screening tool in general practice?. Scandinavian Journal of Primary Health Care. 2004;22(3):187-190. Excluded because BNP assay method is not an included one. [pmid: 15370797].
Schenk S, McCarthy P, Starling R, Hoercher K, Hail M, Ootaki Y, et al. Neurohormonal response to left ventricular reconstruction surgery in ischemic cardiomyopathy.[see comment]. Journal of Thoracic & Cardiovascular Surgery. 2004;128(1):38-43. Excluded because BNP assay method is not an included one. [pmid: 15224019].
Schmitt M, Gunaruwan P, Payne N, Taylor J, Lee L, Broadley A, et al. Effects of exogenous and endogenous natriuretic peptides on forearm vascular function in chronic heart failure. Arteriosclerosis, Thrombosis & Vascular Biology. 2004;24(5):911-917. Excluded because BNP assay method is not an included one.
Schmitt M, Qasem A, McEniery C, Wilkinson I, Tatarinoff V, Noble K, et al. Role of natriuretic peptides in regulation of conduit artery distensibility.[erratum appears in Am J Physiol Heart Circ Physiol 2004 Nov;56(5):H2367]. American Journal of Physiology - Heart & Circulatory Physiology. 2004;287(3):H1167-H1171. Excluded because adult blood not measured. [pmid: 15317675].
Schoenfeld J, Tom J, Lowe D, Schoenfeld J, Tom J, Lowe DG. Mutations in B-type natriuretic peptide mediating receptor-A selectivity. FEBS Letters. 1997;414(2):263-267. Excluded because adult blood not measured. [pmid: 9315698].
Schrier R, Gurevich A, Cadnapaphornchai MA. Pathogenesis and management of sodium and water retention in cardiac failure and cirrhosis. Seminars in Nephrology. 2001;21(2):157-172. Excluded because not a report of a primary study. [pmid: 11245778].
Schulz H, Langvik T, Lund SE, Smith J, Ahmadi N, Hall C, et al. Radioimmunoassay for N-terminal probrain natriuretic peptide in human plasma. Scandinavian Journal of Clinical & Laboratory Investigation. 2001;61(1):33-42. Excluded because BNP assay method is not an included one. [pmid: 11300609].
Schunemann HJM. Rapid measurement of B-type natriuretic peptides reduced time to discharge and treatment costs in patients with acute dyspnea. ACP Journal Club. 2005;v142(1):A14. Excluded because not a report of a primary study. [pmid: 15656555].
Schwam E. Eric B-type natriuretic peptide for diagnosis of heart failure in emergency department patients: a critical appraisal. Academic Emergency Medicine. 2004;11(6):686-691. Excluded because not a report of a primary study. [pmid: 15175210].
Schwartz M R.J. The new biology of body weight regulation. Journal of the American Dietetic Association. 1997;97(1):54-60. Excluded because not a report of a primary study. [pmid: 8990418].
Scotland R, Ahluwalia A, Hobbs A, Scotland RS, Ahluwalia AaHAJ. C-type natriuretic peptide in vascular physiology and disease. Pharmacology & Therapeutics. 2005;105(2):85-93. Excluded because adult blood not measured. [pmid: 15670620].
Segev, G J.F. B-type natriuretic peptide: a novel clinical tool for diagnosis and management of heart failure. Hospital Physician. 2003;39(9):19-24. Excluded because not a report of a primary study.
Seidler T, Pemberton C, Yandle T, Espiner E, Nicholls G, Richards M, et al. The amino terminal regions of proBNP and proANP oligomerise through leucine zipper-like coiled-coil motifs. Biochemical & Biophysical Research Communications. 2002;255(2):495-501. Excluded because adult blood not measured. [pmid: 10049737].
Sekiguchi K, Kanda T, Ono Z, Tanaka T, Yokoyama T, Aihara Y, et al. Augmented responses of angiotensin I and II in patients with ischemic heart disease: relation to left ventricular function. Japanese Heart Journal. 2000;41(3):269-278. Excluded because BNP assay method is not an included one. [pmid: 10987347].
Selvais P, Donckier J, Robert A, Laloux O, Van Linden F, Ahn S, et al. Cardiac natriuretic peptides for diagnosis and risk stratification in heart failure: influences of left ventricular dysfunction and coronary artery disease on cardiac hormonal activation. European Journal of Clinical Investigation. 1998;28(8):636-642. Excluded because BNP assay method is not an included one. [pmid: 9767358].
Selvais P, Robert A, Ahn S, Van Linden F, Ketelslegers J, Pouleur H, et al. Direct comparison between endothelin-1, N-terminal proatrial natriuretic factor, and brain natriuretic peptide as prognostic markers of survival in congestive heart failure. Journal of Cardiac Failure. 2000;6(3):201-207. Excluded because BNP assay method is not an included one. [pmid: 10997745].
Selvais P, Rousseau L, Ahn S, Van Linden F, Ketelslegers J, Rousseau M, et al. Usefulness of the supine-rest maneuver before neurohormonal sampling. American Journal of Cardiology. 2003;89(6):772-774. Excluded because BNP assay method is not an included one. [pmid: 11897225].
Sengenes C, Berlan M, De GILM, Galitzky J, Sengenes C, Berlan M, et al. Natriuretic peptides: a new lipolytic pathway in human adipocytes. FASEB Journal. 2000;14(10):1345-1351. Excluded because adult blood not measured. [pmid: 10877827].
Sengenes C, Stich V, Berlan M, Hejnova J, Lafontan M, Pariskova Z, et al. Increased lipolysis in adipose tissue and lipid mobilization to natriuretic peptides during low-calorie diet in obese women. International Journal of Obesity & Related Metabolic Disorders: Journal of the International Association for the Study of Obesity. 2002;26(1):24-32. Excluded because adult blood not measured. [pmid: 11791143].
Setsuta K, Seino Y, Ogawa T, Arao M, Miyatake Y, Takano T. Use of cytosolic and myofibril markers in the detection of ongoing myocardial damage in patients with chronic heart failure. American Journal of Medicine. 2002;113(9):717-722. Excluded because BNP assay method is not an included one. [pmid: 12517360].
Seymour AA. The pharmacology of SQ 28,603, an inhibitor of neutral endopeptidase 3.4.24.11. Cardiovascular Drug Reviews. 1991;9(3):285-298. Excluded because not a report of a primary study.
Shand B, Gilchrist N, Nicholls M, Caesar M. Effect of lacidipine on blood pressure, vasoactive hormones, and haemorheology in elderly patients with essential hypertension. Journal of Human Hypertension. 2000;14(7):473-475. Excluded because not a report of a primary study. [pmid: 10918554].
Sharabi Y, Dagan Y, Grossman E. Sleep apnea as a risk factor for hypertension. Current Opinion in Nephrology & Hypertension. 2004;13(3):359-364. Excluded because not a report of a primary study. [pmid: 15073496].
Sharp R, Gregory A, Mowdy M, Sirajuddin R, Sharp RP, Gregory AMMH, et al. Nesiritide for treatment of heart failure due to right ventricular dysfunction. Pharmacotherapy. 2004;24(9):1236-1240. Excluded because this is a case report or series with 10 subjects. [pmid: 15460186].
Sheedy W, Stewart A, Morice A, Sheedy W, Stewart A, Morice AH. Plasma levels of atrial natriuretic peptide and brain natriuretic peptide following intravenous saline infusion in oedematous chronic obstructive pulmonary disease and non-oedematous chronic obstructive pulmonary disease. Respiration. 1996;63(6):376-380. Excluded because BNP assay method is not an included one. [pmid: 8933657].
Shehab A, MacFadyen R, McLaren M, Tavendale R, Belch J, Struthers AD. Sudden unexpected death in heart failure may be preceded by short term, intraindividual increases in inflammation and in autonomic dysfunction: A pilot study. Heart (British Cardiac Society). 2004;90(11):1263-1268. Excluded because BNP assay method is not an included one. [pmid: 15486117]. [pmcid: 1768533].
Shenker Y. Natriuretic peptides and adrenal cortex. Endocrinologist. 2000;10(4):219-224. Excluded because not a report of a primary study.
Shephard RJ. Exercise under hot conditions: a major threat to the immune response?. Journal of Sports Medicine and Physical Fitness. 2002;42(3):368-378. Excluded because adult blood not measured. [pmid: 12094129].
Sheth T, Parker T, Block A, Hall C, Adam A, Pfeffer M, et al. Comparison of the effects of omapatrilat and lisinopril on circulating neurohormones and cytokines in patients with chronic heart failure. American Journal of Cardiology. 2002;90(5):496-500. Excluded because BNP assay method is not an included one. [pmid: 12208409].
Shiba N, Watanabe J, Shinozaki T, Koseki Y, Sakuma M, Kagaya Y, et al. Analysis of chronic heart failure registry in the Tohoku district: third year follow-up. Circulation Journal. 2004;68(5):427-434. Excluded because not a report of a primary study. [pmid: 15118283].
Shih W, Romero R, Timothy M, Milan PP. 99mTc-depreotide chest SPECT demonstrates pulmonary metastases from renal cell carcinoma. Journal of Nuclear Medicine Technology. 2004;32(1):19-21. Excluded because adult blood not measured. [pmid: 14990670].
Shimizu H, Aono K, Masuta K, Asada H, Misaki A, Teraoka H, et al. Stability of brain natriuretic peptide (BNP) in human blood samples. Clinica Chimica Acta. 1999;285(1-2):169-172. Excluded because this is a case report or series with 10 subjects.
Shimizu H, Masuta K, Asada H, Sugita K, Sairenji T, Shimizu HMKAHSKaST. Characterization of molecular forms of probrain natriuretic peptide in human plasma. Clinica Chimica Acta. 2003;334(1-2):233-239. Excluded because adult blood not measured.
Shimoyama M, Murata Y, Sumi K, Hamazoe R, Komuro I. Docetaxel induced cardiotoxicity. Heart (British Cardiac Society). 2001;86(2):219. Excluded because not a report of a primary study. [pmid: 11454849].
Shimoyama M, Ochi H, Takeda S, Doi T, Kinugasa Y, Endoh A, et al. Effect of controlled release nifedipine on left ventricular hypertrophy in Japanese patients with hypertension: An open-label, uncontrolled study. Current Therapeutic Research, Clinical & Experimental. 2001;62(11):773-782. Excluded because BNP assay method is not an included one.
Shinohara H, Fukuda N, Soeki T, Sakabe K, Onose Y, Tamura Y, et al. Effects of angiotensin II receptor antagonists on [(123)I]metaiodobenzylguanidine myocardial imaging findings and neurohumoral factors in chronic heart failure. Heart & Vessels. 2002;17(2):47-52. Excluded because BNP assay method is not an included one. [pmid: 12541093].
Shirakami G, Magaribuchi T, Shingu K, Suga S, Tamai S, Nakao K, et al. Positive end-expiratory pressure ventilation decreases plasma atrial and brain natriuretic peptide levels in humans. Anesthesia & Analgesia. 1993;77(6):1116-1121. Excluded because BNP assay method is not an included one. [pmid: 8250300].
Shirakami G, Murakawa M, Shingu K, Mashima S, Suga S, Magaribuchi T, et al. Perioperative plasma concentrations of endothelin and natriuretic peptides in children undergoing living-related liver transplantation. Anesthesia & Analgesia. 1996;82(2):235-240. Excluded because adult blood not measured. [pmid: 8561319].
Shirakami G, Shingu K, Tamai S, Ando A, Suga S, Nakao K, et al. A case of “stunned myocardium” after noncardiac surgery: increased concentration of plasma brain natriuretic peptide. Anesthesia & Analgesia. 1994;79(1):175-179. Excluded because not a report of a primary study. [pmid: 8010432].
Sica D, Liao W, Gehr T, Khan S, Jemal M, Delaney C, et al. Disposition and safety of omapatrilat in subjects with renal impairment. Clinical Pharmacology & Therapeutics. 2000;68(3):261-269. Excluded because adult blood not measured. [pmid: 11014407].
Sica D, Midha M, Aronoff G, Bergen G. Atrial natriuretic factor in spinal cord injury. Archives of Physical Medicine and Rehabilitation. 1993;74(9):969-972. Excluded because adult blood not measured. [pmid: 8379845].
Sica D P. Pharmacotherapy in congestive heart failure: Vasopeptidase inhibition and its role in congestive heart failure. Prevention & Management of Congestive Heart Failure. 2000;6(3):158-163. Excluded because not a report of a primary study.
Sigurdsson A, Eriksson S, Hall C, Kahan T, Swedberg K. Early neurohormonal effects of trandolapril in patients with left ventricular dysfunction and a recent acute myocardial infarction: A double-blind, randomized, placebo-controlled multicentre study. European Journal of Heart Failure. 2001;3(1):69-78. Excluded because BNP assay method is not an included one. [pmid: 11163738].
Silver MA. Are you ready for another paradigm shift?. Prevention & Management of Congestive Heart Failur. 2001;7(5):242-243. Excluded because not a report of a primary study.
Silver M, Horton D, Ghali J, Elkayam U, Silver MA, Horton DP, et al. Effect of nesiritide versus dobutamine on short-term outcomes in the treatment of patients with acutely decompensated heart failure. Journal of the American College of Cardiology. 2002;39(5):798-803. Excluded because BNP assay method is not an included one. [pmid: 11869844].
Silverberg D, Wexler D, Blum M, Wollman Y, Iaina A. The cardio-renal anaemia syndrome: Does it exist?. Nephrology Dialysis Transplantation. 2003;18(SUPPL. 8):viii7-viii12. Excluded because not a report of a primary study.
Silverberg D, Wexler D, Blum M, Schwartz D, Wollman Y, Iaina A. Erythropoietin should be part of congestive heart failure management. Kidney International - Supplement. 2003;64(87):S40-S47. Excluded because not a report of a primary study. [pmid: 14531772].
Sim V, Hampton D, Phillips C, Lo S, Vasishta S, Davies J, et al. The use of brain natriuretic peptide as a screening test for left ventricular systolic dysfunction- cost-effectiveness in relation to open access echocardiography. Family Practice. 2003;20(5):570-574. Excluded because BNP assay method is not an included one. [pmid: 14507800].
Smith H, Pickering R, Struthers A, Simpson I, Mant D, Smith H, et al. Biochemical diagnosis of ventricular dysfunction in elderly patients in general practice: observational study.[see comment]. BMJ. 2000;320(7239):906-908. Excluded because BNP assay method is not an included one. [pmid: 10741999]. [pmcid: 27331].
Smith M, Espiner E, Yandle T, Charles C, Richards A, Smith M, et al. Delayed metabolism of human brain natriuretic peptide reflects resistance to neutral endopeptidase. Journal of Endocrinology. 2000;167(2):239-246. Excluded because adult blood not measured. [pmid: 11054637].
Smith T, Rosen D, Russo P, Berkenbosch J, Gustafson R, Siu B, et al. Nesiritide during extracorporeal membrane oxygenation. Paediatric Anaesthesia. 2005;15(2):152-157. Excluded because adult blood not measured. [pmid: 15675934].
Snowden J, Hill G, Hunt P, Carnoutsos S, Spearing R, Espiner E, et al. Assessment of cardiotoxicity during haemopoietic stem cell transplantation with plasma brain natriuretic peptide. Bone Marrow Transplantation. 2000;26(3):309-313. Excluded because BNP assay method is not an included one. [pmid: 10967571].
Soares L, Luis Guilherme Loureiro. Brain natriuretic peptide: a marker for dyspnea?. Journal of Pain & Symptom Management. 2002;24(5):457-458. Excluded because not a report of a primary study. [pmid: 12547045].
Sodian R, Loebe M, Schmitt C, Potapov E, Siniawski H, Muller J, et al. Decreased plasma concentration of brain natriuretic peptide as a potential indicator of cardiac recovery in patients supported by mechanical circulatory assist systems. Journal of the American College of Cardiology. 2001;38(7):1942-1949. Excluded because BNP assay method is not an included one. [pmid: 11738298].
Song S, Kamath S, Mosquera D, Zigova T, Sanberg P, Vesely D, et al. Expression of brain natriuretic peptide by human bone marrow stromal cells. Experimental Neurology. 2004;185(1):191-197. Excluded because adult blood not measured. [pmid: 14697330].
Sonoda K, Ikeda S, Miyahara Y, Kohno S, Sonoda KISMYaKS. Successful treatment of chronic pulmonary thromboembolism by long-term intermittent administration of milrinone, a phosphodiesterase-ill inhibitor. Internal Medicine. 2002;41(11):961-966. Excluded because not a report of a primary study. [pmid: 12487168].
SoRelle R. R. Cardiovascular news. VMAC. Circulation. 2000;102(25):E9050-E9051. Excluded because not a report of a primary study.
Sowers JR. Hypertension angiotensin II oxidative stress. New England Journal of Medicine. 2006;346(25):1999-2001. Excluded because not a report of a primary study. [pmid: 12075063].
Sparrow N, Adlam D, Cowley A, Hampton J, Sparrow NADCAaHJR. The diagnosis of heart failure in general practice: implications for the UK National Service Framework. European Journal of Heart Failure. 2003;5(3):349-354. Excluded because BNP assay method is not an included one. [pmid: 12798834].
Spevack D, Matros T, Shah A, Dweck E, Tunick P, Spevack DM, et al. Clinical improvement with repeated courses of intravenous B-type natriuretic peptide in refractory heart failure. European Journal of Heart Failure. 2004;6(5):611-613. Excluded because this is a case report or series with 10 subjects. [pmid: 15302009].
Squire I, Evans J, Ng L, Loftus I, Thompson M, Squire IB, et al. Plasma MMP-9 and MMP-2 following acute myocardial infarction in man: correlation with echocardiographic and neurohumoral parameters of left ventricular dysfunction. Journal of Cardiac Failure. 2004;10(4):328-333. Excluded because BNP assay method is not an included one. [pmid: 15309700].
Stambler BS. Atrial tachycardia and congestive heart failure: New insights from an old experimental model. Journal of Cardiovascular Electrophysiology. 2004;15(8):933-935. Excluded because adult blood not measured. [pmid: 15333090].
Stanek B. BNP Testing in Heart Failure - One Fits All?. Journal of Clinical & Basic Cardiology. 2003;6(14):15-18. Excluded because not a report of a primary study.
Steele I, McDowell G, Moore A, Campbell N, Shaw C, Buchanan K, et al. Responses of atrial natriuretic peptide and brain natriuretic peptide to exercise in patients with chronic heart failure and normal control subjects. European Journal of Clinical Investigation. 1997;27(4):270-276. Excluded because BNP assay method is not an included one. [pmid: 9134374].
Stenvinkel P, Pecoits-Filho R, Lindholm B. Leptin, ghrelin, and proinflammatory cytokines: compounds with nutritional impact in chronic kidney disease?. Advances in Renal Replacement Therapy. 2003;10(4):332-345. Excluded because adult blood not measured. [pmid: 14681862].
Stepan H, Walther T, Walther D, Faber R. Detection of C-type natriuretic peptide in normal pregnancy. Journal of Perinatal Medicine. 1998;26(1):56-58. Excluded because BNP assay method is not an included one. [pmid: 9595369].
Stevens T, Rasmussen T, Wei C, Kinoshita M, Matsuda Y, Burnett J, et al. Renal role of the endogenous natriuretic peptide system in acute congestive heart failure. Journal of Cardiac Failure. 1996;2(2):119-125. Excluded because adult blood not measured. [pmid: 8798113].
Stevenson LW. Clinical use of inotropic therapy for heart failure: Looking backward or forward? Part I: Inotropic infusions during hospitalization. Circulation. 2003;108(3):367-372. Excluded because not a report of a primary study. [pmid: 12876135].
Stompor TP. Can we ask the lab how much extra fluid patients carry?. Nephron Clinical Practice. 2004;97(4):c123-c124. Excluded because not a report of a primary study. [pmid: 15331940].
Storti S, Prontera C, Emdin M, Passino C, Prati P, Fontani G, et al. Analytical performance and clinical results of a fully automated MEIA system for brain natriuretic peptide assay: comparison with a point of care testing method. Clinical Chemistry & Laboratory Medicine. 2004;42(10):1178-1185. Excluded because adult blood not measured. [pmid: 15552278].
Strain WD. The use of recombinant human B-type natriuretic peptide (nesiritide) in the management of acute decompensated heart failure. International Journal of Clinical Practice. 2004;58(11):1081-1087. Excluded because not a report of a primary study. [pmid: 15605677].
Strametz-Juranek J, Pacher R, Kos T, Woloszczuk W, Grimm M, Zuckermann A, et al. Sequential big endothelin plasma levels in heart transplant recipients during bridging therapy and after successful heart transplantation. Journal of Heart & Lung Transplantation. 2003;22(7):731-737. Excluded because BNP assay method is not an included one. [pmid: 12873540].
Struthers AD. The effect of ACE inhibitors and atrial natriuretic factor on the cardiorenal axis in man. British Journal of Clinical Pharmacology. 1992;34(1):21-24. Excluded because not a report of a primary study. [pmid: 1385970]. [pmcid: 1381370].
Struthers AD. Careful screening to target interventions to prevent sudden cardiac death. Clinical & Experimental Pharmacology & Physiology. 2001;28(3):219-222. Excluded because not a report of a primary study. [pmid: 11236129].
Struthers A A.D. Plasma concentrations of brain natriuretic peptide: will this new test reduce the need for cardiac investigations?. British Heart Journal. 1993;70(5):397-398. Excluded because not a report of a primary study. [pmid: 8260266]. [pmcid: 1025346].
Struthers A A.D. The diagnosis of heart failure. Heart (British Cardiac Society). 2000;84(3):334-338. Excluded because not a report of a primary study. [pmid: 10956303]. [pmcid: 1760946].
Suda M, Komatsu Y, Tanaka K, Yasoda A, Sakuma Y, Tamura N, et al. C-Type natriuretic peptide/guanylate cyclase B system in rat osteogenic ROB-C26 cells and its down-regulation by dexamethazone. Calcified Tissue International. 1999;65(6):472-478. Excluded because adult blood not measured. [pmid: 10594167].
Suguta M, Hara K, Nakano A, Amano A, Hasegawa A, Kurabayashi M, et al. Serum atrial natriuretic peptide concentration is a useful predictor of atrial standstill in patients with heart failure. Japanese Circulation Journal. 2000;64(7):537-540. Excluded because this is a case report or series with 10 subjects. [pmid: 10929785].
Sundell J, Engblom E, Koistinen J, Ylitalo A, Naum A, Stolen K, et al. The effects of cardiac resynchronization therapy on left ventricular function, myocardial energetics, and metabolic reserve in patients with dilated cardiomyopathy and heart failure. Journal of the American College of Cardiology. 2004;43(6):1027-1033. Excluded because this is a case report or series with 10 subjects. [pmid: 15028362].
Sundqvist P, Feuk U, Haggman M, Persson A, Stridsberg M, Wadstrom J, et al. Hand-assisted retroperitoneoscopic live donor nephrectomy in comparison to open and laparoscopic procedures: a prospective study on donor morbidity and kidney function. Transplantation. 1907;78(1):147-153. Excluded because adult blood not measured. [pmid: 15257054].
Suo M, Hautala N, Foldes G, Szokodi I, Toth M, Leskinen H, et al. Posttranscriptional control of BNP gene expression in angiotensin II-induced hypertension. Hypertension. 2002;39(3):803-808. Excluded because adult blood not measured. [pmid: 11897768].
Suter T B. Detection of anthracycline-induced cardiotoxicity: Is there light at the end of the tunnel?. Annals of Oncology. 2002;13(5):647-649. Excluded because not a report of a primary study. [pmid: 12075731].
Sutovsky I, Katoh T, Ohno T, Honma H, Takayama H, Takano T, et al. Relationship between brain natriuretic peptide, myocardial wall stress, and ventricular arrhythmia severity. Japanese Heart Journal. 2004;45(5):771-777. Excluded because BNP assay method is not an included one. [pmid: 15557718].
Suzuki T, Hayashi D, Yamazaki T, Mizuno T, Kanda Y, Komuro I, et al. Elevated B-type natriuretic peptide levels after anthracycline administration.[comment]. American Heart Journal. 1998;136(2):362-363. Excluded because adult blood not measured. [pmid: 9704703].
Svitil K. Needlepoint. Arthritis Today. 1997;11(3):32-37. Excluded because not a report of a primary study.
Tabrizchi R. Dual ACE and Neutral Endopeptidase Inhibitors: Novel Therapy for Patients with Cardiovascular Disorders. Drugs. 2003;63(20):2185-2202. Excluded because not a report of a primary study. [pmid: 14498755].
Taguchi I, Ogawa K, Kanaya T, Matsuda R, Kuga H, Nakatsugawa M, et al. Effects of enhanced external counterpulsation on hemodynamics and its mechanism. Circulation Journal. 2004;68(11):1030-1034. Excluded because BNP assay method is not an included one. [pmid: 15502384].
Takahashi K, Ashizawa N, Minami T, Suzuki S, Sakamoto I, Hayashi K, et al. Malignant pheochromocytoma with multiple hepatic metastases treated by chemotherapy and transcatheter arterial embolization. Internal Medicine. 1999;38(4):349-354. Excluded because not a report of a primary study. [pmid: 10361908].
Takahashi K, Sone M, Totsune K, Satoh F, Murakami O, Ohneda M, et al. Immunoreactive endothelin in the human kidney: comparison with natriuretic peptides. Journal of Cardiovascular Pharmacology. 1995;26 Suppl 3:S510-S512. Excluded because adult blood not measured. [pmid: 8587463].
Takahashi K, Totsune K, Sone M, Ohneda M, Murakami O, Itoi K, et al. Human brain natriuretic peptide-like immunoreactivity in human brain. Peptides. 1992;13(1):121-123. Excluded because adult blood not measured. [pmid: 1535705].
Takahashi T, Allen P, Izumo S, Takahashi T, Allen P, Izumo S. Expression of A-, B-, and C-type natriuretic peptide genes in failing and developing human ventricles Correlation with expression of the Ca(2+)-ATPase gene. Circulation Research. 1992;71(1):9-17. Excluded because adult blood not measured. [pmid: 1535030].
Takahashi T, Anzai T, Yoshikawa T, Maekawa Y, Asakura Y, Satoh T, et al. Serum C-reactive protein elevation in left ventricular remodeling after acute myocardial infarction - Role of neurohormones and cytokines. International Journal of Cardiology. 2003;88(23):257-265. Excluded because BNP assay method is not an included one. [pmid: 12714206].
Takahashi T, Sakuma M, Ikeda J, Nawata J, Demachi J, Kitamukai O, et al. Effects and problems of continuous infusion of epoprostenol for patients with primary pulmonary hypertension. Internal Medicine. 2002;41(10):784-788. Excluded because BNP assay method is not an included one. [pmid: 12412996].
Takano H I. beta-blockers have beneficial effects even on unclassified cardiomyopathy such as isolated ventricular noncompaction. Internal Medicine. 2002;41(8):601-602. Excluded because not a report of a primary study. [pmid: 12211522].
Takemura G, Fujiwara H, Takatsu Y, Fujiwara T, Nakao K, Takemura G, et al. Venticular expression of atrial and brain natriuretic peptides in patients with myocarditis. International Journal of Cardiology. 1995;52(3):213-222. Excluded because adult blood not measured. [pmid: 8789180].
Takemura G, Takatsu Y, Doyama K, Itoh H, Saito Y, Koshiji M, et al. Expression of atrial and brain natriuretic peptides and their genes in hearts of patients with cardiac amyloidosis. Journal of the American College of Cardiology. 2003;31(4):754-765. Excluded because BNP assay method is not an included one. [pmid: 9525543].
Takemura K, Yasumura Y, Hirooka K, Hanatani A, Nakatani S, Komamura K, et al. Low-dose amiodarone for patients with advanced heart failure who are intolerant of beta-blockers. Circulation Journal. 2002;66(5):441-444. Excluded because BNP assay method is not an included one. [pmid: 12030336].
Talwar S, Downie P, Squire I, Davies J, Barnett D, Ng L, et al. Plasma N-terminal pro BNP and cardiotrophin-1 are elevated in aortic stenosis. European Journal of Heart Failure. 2001;3(1):15-19. Excluded because BNP assay method is not an included one. [pmid: 11163730].
Talwar S, Siebenhofer A, Williams B, Ng L, Talwar S, Siebenhofer A, et al. Influence of hypertension, left ventricular hypertrophy, and left ventricular systolic dysfunction on plasma N terminal proBNP. Heart (British Cardiac Society). 2000;83(3):278-282. Excluded because BNP assay method is not an included one. [pmid: 10677405]. [pmcid: 1729338].
Talwar S, Squire I, Davies J, Barnett D, Ng LL. Plasma N-terminal pro-brain natriuretic peptide and the ECG in the assessment of left-ventricular systolic dysfunction in a high risk population. European Heart Journal. 1999;20(23):1736-1744. Excluded because BNP assay method is not an included one. [pmid: 10562482].
Talwar S, Squire I, Downie P, Davies J, Ng L, Talwar S, et al. Plasma N terminal pro-brain natriuretic peptide and cardiotrophin 1 are raised in unstable angina. Heart (British Cardiac Society). 2000;84(4):421-424. Excluded because BNP assay method is not an included one. [pmid: 10995414]. [pmcid: 1729429].
Talwar S, Squire I, Downie P, Mccullough A, Campton M, Davies J, et al. Profile of plasma N-terminal proBNP following acute myocardial infarction; correlation with left ventricular systolic dysfunction.[see comment]. European Heart Journal. 2000;21(18):1514-1521. Excluded because BNP assay method is not an included one. [pmid: 10973765].
Tamura N, Ogawa Y, Yasoda A, Itoh H, Saito Y, Nakao K, et al. Two cardiac natriuretic peptide genes (atrial natriuretic peptide and brain natriuretic peptide) are organized in tandem in the mouse and human genomes. Journal of Molecular & Cellular Cardiology. 1996;28(8):1811-1815. Excluded because adult blood not measured. [pmid: 8877790].
Tan F, Moravec C, Li J, Apperson-Hansen C, McCarthy P, Young J, et al. The gene expression fingerprint of human heart failure. Proceedings of the National Academy of Sciences of the United States of America. 2002;99(17):11387-11392. Excluded because adult blood not measured. [pmid: 12177426]. [pmcid: 123266].
Tan L, Schlosshan D, Williams SG. The benefits of valsartan in the treatment of heart failure: Results from Val-HeFT. International Journal of Clinical Practice. 2004;58(2):184-191. Excluded because not a report of a primary study. [pmid: 15055867].
Tanabe A, Naruse M, Wasada T, Naruse K, Yoshimoto T, Omori Y, et al. Effects of acute hyperinsulinemia on plasma atrial and brain natriuretic peptide concentrations. European Journal of Endocrinology. 1995;132(6):693-698. Excluded because BNP assay method is not an included one. [pmid: 7788008].
Tanabe K, Yamamoto A, Suzuki N, Akashi Y, Seki A, Samejima H, et al. Exercise-induced changes in plasma atrial natriuretic peptide and brain natriuretic peptide concentrations in healthy subjects with chronic sleep deprivation. Japanese Circulation Journal. 1999;63(6):447-452. Excluded because this is a case report or series with 10 subjects. [pmid: 10406584].
Tanaka M, Hiroe M, Nishikawa T, Sato T, Marumo F, Tanaka M, et al. Cellular localization and structural characterization of natriuretic peptide-expressing ventricular myocytes from patients with dilated cardiomyopathy. Journal of Histochemistry & Cytochemistry. 1994;42(9):1207-1214. Excluded because adult blood not measured. [pmid: 8064128].
Tanaka M, Ishizaka Y, Ishiyama Y, Kato J, Kida O, Kitamura K, et al. Exercise-induced secretion of brain natriuretic peptide in essential hypertension and normal subjects. Hypertension Research - Clinical & Experimental. 1995;18(2):159-166. Excluded because BNP assay method is not an included one.
Tanaka M, Ishizaka Y, Ishiyama Y, Kato J, Kida O, Kitamura K, et al. Chronic effect of beta-adrenoceptor blockade on plasma levels of brain natriuretic peptide during exercise in essential hypertension. Hypertension Research - Clinical & Experimental. 1996;19(4):239-245. Excluded because BNP assay method is not an included one.
Tanaka T, Hasegawa K, Fujita M, Tamaki S, Yamazato A, Kihara Y, et al. Marked elevation of brain natriuretic peptide levels in pericardial fluid is closely associated with left ventricular dysfunction. Journal of the American College of Cardiology. 1998;31(2):399-403. Excluded because BNP assay method is not an included one. [pmid: 9462585].
Tang W G.S. Chronic heart failure: 10 Questions physicians often ask. Consultant. 2002;42(6):678-686. Excluded because not a report of a primary study.
Tang W G.S. Evolving concepts in left ventricular systolic and diastolic remodeling: Implications for therapy. Current Cardiology Reports. 2004;6(3):200-204. Excluded because not a report of a primary study. [pmid: 15075056].
Tapanainen J, Lindgren K, Makikallio T, Vuolteenaho O, Leppaluoto J, Huikuri H, et al. Natriuretic peptides as predictors of non-sudden and sudden cardiac death after acute myocardial infarction in the beta-blocking era.[see comment]. Journal of the American College of Cardiology. 2004;43(5):757-763. Excluded because BNP assay method is not an included one. [pmid: 14998613].
Tateyama H, Hino J, Minamino N, Kangawa K, Minamino T, Sakai K, et al. Concentrations and molecular forms of human brain natriuretic peptide in plasma. Biochemical & Biophysical Research Communications. 2006;185(2):760-767. Excluded because BNP assay method is not an included one. [pmid: 1610367].
Tavi P, Laine M, Weckstrom M, Ruskoaho H. Cardiac mechanotransduction: From sensing to disease and treatment. Trends in Pharmacological Sciences. 2001;22(5):254-260. Excluded because not a report of a primary study. [pmid: 11339977].
Tayama K, Takamori S, Mitsuoka M, Hayashi A, Tamura K, Mifune H, et al. Natriuretic peptides after pulmonary resection. Annals of Thoracic Surgery. 2002;73(5):1582-1586. Excluded because BNP assay method is not an included one. [pmid: 12022554].
Tendera M. The epidemiology of heart failure. Journal of the Renin-Angiotensin-Aldosterone System. 2004;5(SUPPL. 1):S2-S6. Excluded because not a report of a primary study. [pmid: 15526238].
Terasako K K. Perioperative plasma concentrations of atrial and brain natriuretic peptides in patients undergoing hip arthroplasty. Anaesthesia & Intensive Care. 2002;30(5):588-590. Excluded because BNP assay method is not an included one. [pmid: 12413257].
Tharaux P, Dussaule J, Hubert-Brierre J, Vahanian A, Acar J, Ardaillou R, et al. Plasma atrial and brain natriuretic peptides in mitral stenosis treated by valvulotomy. Clinical Science. 1994;87(6):671-677. Excluded because BNP assay method is not an included one. [pmid: 7874858].
Theorell T H. Endocrinological and immunological variables sensitive to psychosocial factors of possible relevance to work-related musculoskeletal disorders. Work & Stress. 2002;16(2):154-165. Excluded because not a report of a primary study.
Therapondos G, Flapan A, Dollinger M, Garden O, Plevris J, Hayes P, et al. Cardiac function after orthotopic liver transplantation and the effects of immunosuppression: a prospective randomized trial comparing cyclosporin (Neoral) and tacrolimus. Liver Transplantation. 2002;8(8):690-700. Excluded because BNP assay method is not an included one. [pmid: 12149762].
Thiriet N, Esteve L, Aunis D, Zwiller J, Thiriet N, Esteve L, et al. Immediate early gene induction by natriuretic peptides in PC12 phaeochromocytoma and C6 glioma cells. Neuroreport. 2001;8(2):399-402. Excluded because adult blood not measured. [pmid: 9080415].
Thorens J, Ritz M, Reynard C, Righetti A, Vallotton M, Favre H, et al. Haemodynamic and endocrinological effects of noninvasive mechanical ventilation in respiratory failure. European Respiratory Journal. 1997;10(11):2553-2559. Excluded because BNP assay method is not an included one. [pmid: 9426094].
Tiret L, Mallet C, Poirier O, Nicaud V, Millaire A, Bouhour J, et al. Lack of association between polymorphisms of eight candidate genes and idiopathic dilated cardiomyopathy: the CARDIGENE study. Journal of the American College of Cardiology. 2000;35(1):29-35. Excluded because adult blood not measured. [pmid: 10636255].
Tjeerdsma G, van Wijk L, Molhoek G, Boomsma F, Haaksma J, van Veldhuisen DJ. Autonomic and hemodynamic effects of a new selective dopamine agonist, CHF1035, in patients with chronic heart failure. Cardiovascular Drugs & Therapy. 2001;15(2):139-145. Excluded because BNP assay method is not an included one. [pmid: 11669407].
Togashi K, Ando K, Hasegawa N, Kawakami M, Marumo F, Togashi K, et al. Concentrations of brain natriuretic peptide in treated congestive heart failure. Clinical Chemistry. 1991;37(5):765. Excluded because not a report of a primary study. [pmid: 1827759].
Togashi K, Fujita S, Kawakami M, Togashi K, Fujita S, Kawakami M. Presence of brain natriuretic peptide in urine. Clinical Chemistry. 1992;38(2):322-323. Excluded because adult blood not measured. [pmid: 1541029].
Togashi K, Hirata Y, Ando K, Takei Y, Kawakami M, Marumo F, et al. Brain natriuretic peptide-like immunoreactivity is present in human plasma. FEBS Letters. 1989;250(2):235-237. Excluded because adult blood not measured. [pmid: 2526749].
Togashi K, Kameya T, Ando K, Marumo F, Kawakami M, Togashi K, et al. Brain natriuretic peptides in human plasma, spinal cord and cerebrospinal fluid. Clinica Chimica Acta. 1909;201(3):193-200. Excluded because adult blood not measured.
Tomiyama H, Kushiro T, Imai S, Suzuki Y, Akutsu N, Ebuchi T, et al. Changes in the E/A ratio induced by handgrip-exercise are related to changes in the plasma atrial natriuretic peptide level, but not to changes in brain natriuretic peptide in mild essential hypertension. Japanese Circulation Journal. 1995;59(9):617-623. Excluded because BNP assay method is not an included one. [pmid: 7500545].
Totsuka N, Awata N, Takahashi K, Yamamura H, Nakamura J, Tsuchikane E, et al. A single-center, open-label, randomized, parallel-group study assessing the differences between an angiotensin II receptor antagonist and an angiotensin-converting enzyme inhibitor in hypertensive patients with congestive heart failure: The research for efficacy of angiotensin II receptor antagonist in hypertensive patients with congestive heart failure study. Current Therapeutic Research, Clinical & Experimental. 2003;64(2):81-94. Excluded because BNP assay method is not an included one.
Totsune K, Takahashi K, Murakami O, Satoh F, Sone M, Mouri T. Elevated plasma C-type natriuretic peptide concentrations in patients with chronic renal failure. Clinical Science. 1994;87(3):319-322. Excluded because BNP assay method is not an included one. [pmid: 7955908].
Totsune K, Takahashi K, Satoh F, Sone M, Ohneda M, Satoh C, et al. Urinary immunoreactive brain natriuretic peptide in patients with renal disease. Regulatory Peptides. 1996;63(23):141-147. Excluded because adult blood not measured. [pmid: 8837222].
Totsune K, Takahashi K, Murakami O, Satoh F, Sone M, Ohneda M, et al. Immunoreactive brain natriuretic peptide in human adrenal glands and adrenal tumors. European Journal of Endocrinology. 1996;135(3):352-356. Excluded because adult blood not measured. [pmid: 8890728].
Trinity E F.S. Brain natriuretic peptide in the diagnosis and management of congestive heart failure. Laboratory Medicine. 2002;33(10):793-796. Excluded because not a report of a primary study.
Troughton R, Prior D, Pereira J, Martin M, Fogarty A, Morehead A, et al. Plasma B-type natriuretic peptide levels in systolic heart failure: importance of left ventricular diastolic function and right ventricular systolic function. Journal of the American College of Cardiology. 2004;43(3):416-422. Excluded because BNP assay method is not an included one. [pmid: 15013124].
Troughton R, Richards A, Nicholls M, Troughton R, Richards A, Nicholls MG. Individualized treatment of heart failure. Internal Medicine Journal. 2001;31(3):138-141. Excluded because not a report of a primary study. [pmid: 11478341].
Tsaioun KI. Vitamin K-dependent proteins in the developing and aging nervous system. Nutrition Reviews. 1999;57(8):231-240. Excluded because adult blood not measured. [pmid: 10518409].
Tsubokawa T, Shiokawa Y, Kurita H, Kaneko N. High plasma concentration of brain natriuretic peptide in patients with ruptured anterior communicating artery aneurysm. Neurological Research. 2004;26(8):893-896. Excluded because BNP assay method is not an included one. [pmid: 15727273].
Tsuji T, Imagawa K, Masuda H, Haraikawa M, Shibata K, Kono M, et al. Stabilization of human brain natriuretic peptide in blood samples. Clinical Chemistry. 1994;40(4):672-673. Excluded because not a report of a primary study. [pmid: 8149626].
Tsutamoto T, Wada A, Maeda K, Hayashi M, Tsutsui T, Ohnishi M, et al. Transcardiac gradient of aldosterone before and after spironolactone in patients with congestive heart failure. Journal of Cardiovascular Pharmacology. 2003;41(Suppl 1):S19-S22. Excluded because this is a case report or series with 10 subjects. [pmid: 12688391].
Tsutsumi Y, Matsubara H, Ohkubo N, Mori Y, Nozawa Y, Murasawa S, et al. Angiotensin II type 2 receptor is upregulated in human heart with interstitial fibrosis, and cardiac fibroblasts are the major cell type for its expression. Circulation Research. 1998;83(10):1035-1046. Excluded because adult blood not measured. [pmid: 9815151].
Tuinenburg A, Brundel B, Van Gelder I, Henning R, van den Berg M, Driessen C, et al. Gene expression of the natriuretic peptide system in atrial tissue of patients with paroxysmal and persistent atrial fibrillation. Journal of Cardiovascular Electrophysiology. 1999;10(6):827-835. Excluded because adult blood not measured. [pmid: 10376920].
Twickler MT. Cardiovascular endocrinology. Seminars in Vascular Medicine. 2004;4(2):105-106. Excluded because not a report of a primary study.
Ueda R, Yokouchi M, Suzuki T, Otomo E, Katagiri T, Ueda RYMSTOEaKT. Plasma brain natriuretic peptide levels increase in proportion to changes in pulmonary artery pressure in old-old persons. Journal of the American Geriatrics Society. 2003;51(6):891-893. Excluded because not a report of a primary study. [pmid: 12757592].
Ueki R, Okutani R, Fukushima A, Tsuji T, Ohata H, Tashiro C. Perioperative endocrinological findings in a patient with Bartter's syndrome and living-related renal transplantation. Journal of Anesthesia. 2000;14(2):105-108. Excluded because BNP assay method is not an included one. [pmid: 14564600].
Ueno S, Ikeda U, Hojo Y, Arakawa H, Nonaka M, Yamamoto K, et al. Serum hepatocyte growth factor levels are increased in patients with congestive heart failure. Journal of Cardiac Failure. 2001;7(4):329-334. Excluded because BNP assay method is not an included one. [pmid: 11782856].
Usuki S, Nakauchi T, Higa S, Someya K. The improvement of luteal insufficiency in fecund women by Tokishakuyakusan treatment. American Journal of Chinese Medicine. 2002;30(2/3):327-338. Excluded because adult blood not measured. [pmid: 12230021].
Uusimaa P, Ruskoaho H, Vuolteenaho O, Niemela M, Lumme J, Ikaheimo M, et al. Plasma vasoactive peptides after acute myocardial infarction in relation to left ventricular dysfunction. International Journal of Cardiology. 2004;69(1):5-14. Excluded because BNP assay method is not an included one. [pmid: 10362366].
Uusimaa P, Tokola H, Ylitalo A, Vuolteenaho O, Ruskoaho H, Risteli J, et al. Plasma B-type natriuretic peptide reflects left ventricular hypertrophy and diastolic function in hypertension. International Journal of Cardiology. 2004;97(2):251-256. Excluded because BNP assay method is not an included one. [pmid: 15458692].
Valli N, Georges A, Corcuff J, Barat J, Bordenave L, Valli N, et al. Assessment of brain natriuretic peptide in patients with suspected heart failure: comparison with radionuclide ventriculography data. Clinica Chimica Acta. 2001;306(12):19-26. Excluded because BNP assay method is not an included one.
van den Berg M, Tjeerdsma G, Lefrandt J, Smit A, van den Meiracker A, Van Roon A, et al. Effect of lower body negative pressure in patients with mild congestive heart failure. American Journal of Cardiology. 2003;91(6):759-762. Excluded because BNP assay method is not an included one. [pmid: 12633820].
Van den Berghe GHA. The neuroendocrine stress response and modern intensive care: the concept revisited. Burns. 1999;25(1):7-16. Excluded because not a report of a primary study. [pmid: 10090378].
van der Merwe D, Henley R, Lane G, Field R, Frenneaux M, Dunstan F, et al. Effect of different sample types and stability after blood collection of N-terminal pro-B-type natriuretic peptide as measured with Roche Elecsys system. Clinical Chemistry. 2004;50(4):779-780. Excluded because not a report of a primary study. [pmid: 15044344].
van der ZK, Houben A, Kroon A, de Leeuw P, van der Zander K, Houben A, et al. Effects of brain natriuretic peptide on forearm vasculature: comparison with atrial natriuretic peptide. Cardiovascular Research. 1999;44(3):595-600. Excluded because BNP assay method is not an included one. [pmid: 10690292].
van der ZK, Houben A, Kroon A, De Mey J, Smits P, de Leeuw P, et al. Nitric oxide and potassium channels are involved in brain natriuretic peptide induced vasodilatation in man. Journal of Hypertension. 2002;20(3):493-499. Excluded because adult blood not measured. [pmid: 11875317].
van der ZK, Houben A, Hofstra L, Kroon A, de Leeuw P, van der Zander KHAJ, et al. Hemodynamic and renal effects of low-dose brain natriuretic peptide infusion in humans: a randomized, placebo-controlled crossover study. American Journal of Physiology - Heart & Circulatory Physiology. 2003;285(3):H1206-H1212. Excluded because adult blood not measured. [pmid: 12738624].
van der ZK, Houben A, Kroon A, Wierema T, Fuss-Lejeune M, Koster D, et al. Does brain natriuretic peptide have a direct renal effect in human hypertensives?. Hypertension. 2003;41(1):119-123. Excluded because BNP assay method is not an included one. [pmid: 12511540].
van Veldhuisen D, Genth-Zotz S, Brouwer J, Boomsma F, Netzer T, Man in 't Veld AJ PY et al. High-versus low-dose ACE inhibition in chronic heart failure: a double-blind, placebo-controlled study of imidapril. Journal of the American College of Cardiology 1998; 32(7):1811–1818. Excluded because BNP assay method is not an included one
van Veldhuisen D W.H. Vasopeptidase inhibition in heart failure [8]. Lancet. 2000;356(9240):1526. Excluded because not a report of a primary study. [pmid: 11081561].
Vasan RS. Diastolic heart failure. British Medical Journal. 2003;327(7425):1181-1182. Excluded because not a report of a primary study. [pmid: 14630731]. [pmcid: 274046].
Vesely DL. Congestive heart failure update: new cardiac peptides in diagnosis and treatment. Consultant 259; 40(2):253–256. Excluded because not a report of a primary study
Vesely DL. Atrial natriuretic peptides in the diagnosis and treatment of congestive heart failure. Prevention & Management of Congestive Heart Failure 1999; 5(4). Excluded because not a report of a primary study
Villarreal D, Freeman R, Reams GP. Natriuretic peptides and salt sensitivity: Endocrine cardiorenal integration in heart failure. Prevention & Management of Congestive Heart Failure. 2002;8(1):29-36. Excluded because not a report of a primary study.
Vincent SR. The ascending reticular activating system - From aminergic neurons to nitric oxide. Journal of Chemical Neuroanatomy. 2000;18(12):23-30. Excluded because not a report of a primary study. [pmid: 10708916].
Von Kaisenberg C, Huggon I, Hyett J, Farzaneh F, Nicolaides K, Von Kaisenberg C, et al. Cardiac gene expression of GATA-4 transcription factor in human trisomy 21 fetuses with increased nuchal translucency. Prenatal Diagnosis. 1998;18(3):267-271. Excluded because adult blood not measured. [pmid: 9556043].
Wagoner L W.T. The use of B-type natriuretic peptide (BNP nesiritide) for the treatment of congestive heart failure. Today's Therapeutic Trends. 1999;17(2):113-131. Excluded because not a report of a primary study.
Wakaumi M, Shiga T, Nozaki K, Fujiu K, Shimaya K, Ishizuka N, et al. Plasma brain natriuretic peptide as a parameter to assess efficacy of continuous intravenous infusion of prostacyclin (epoprostenol) to treat severe primary pulmonary hypertension: a case report. Heart & Vessels. 2000;15(3):144-146. Excluded because BNP assay method is not an included one. [pmid: 11289503].
Wakaumi M, Shiga T, Naganuma M, Matsuda N, Tatami S, Kasanuki H, et al. Plasma concentration profile of orally administered pimobendan and plasma brain natriuretic peptide level in patients with severe heart failure. Cardiovascular Drugs & Therapy. 2003;17(3):291-293. Excluded because not a report of a primary study. [pmid: 14669747].
Wallbridge D, MacIntyre H, Gray C, Oldroyd K, Rae A, Cobbe S, et al. Role of endogenous opioids and catecholamines in vasovagal syncope.[see comment]. European Heart Journal. 1996;17(11):1729-1736. Excluded because BNP assay method is not an included one. [pmid: 8922923].
Walter M, Berendes E, Claviez A, Suttorp M, Walter M, Berendes E, et al. Inappropriate secretion of natriuretic peptides in a patient with a cerebral tumor. JAMA: Journal of the American Medical Association. 1999;282(1):27-28. Excluded because not a report of a primary study.
Walther T, Heringer-Walther S, Wessel N, Schultheiss H, Moreira MC, Walther TH-WSWNSHPaMMdC. Brain natriuretic peptide as a predictor of cardiomyopathy in Chagas' disease.[see comment][comment]. Lancet. 2003;361(9368):1567. Excluded because not a report of a primary study. [pmid: 12737906].
Walther T, Stepan H, Pankow K, Gembardt F, Faber R, Schultheiss H, et al. Relation of ANP and BNP to their N-terminal fragments in fetal circulation: evidence for enhanced neutral endopeptidase activity and resistance of BNP to neutral endopeptidase in the fetus. BJOG: an International Journal of Obstetrics & Gynaecology. 2004;111(5):452-455. Excluded because adult blood not measured. [pmid: 15104609].
Wambach G, Koch J, Wambach G, Koch J. BNP plasma levels during acute volume expansion and chronic sodium loading in normal men. Clinical & Experimental Hypertension (New York). 1995;17(4):619-629. Excluded because BNP assay method is not an included one.
Wang C, Cherng W, Chen F, Lee N. Short-term hormone replacement therapy in postmenopausal women improves Doppler-derived aortic flow parameters and aortic root function. Journal of Medical Ultrasound. 2000;8(1):22-28. Excluded because BNP assay method is not an included one.
Wang D, Dowling T, Meadows D, Ayala T, Marshall J, Minshall S, et al. Nesiritide does not improve renal function in patients with chronic heart failure and worsening serum creatinine. Circulation. 2004;110(12):1620-1625. Excluded because BNP assay method is not an included one. [pmid: 15337695].
Wang T H. Intravenous morphine reduces plasma endothelin 1 concentration through activation of neutral endopeptidase 24.11 in patients with myocardial infarction. Annals of Emergency Medicine. 2001;37(5):445-449. Excluded because BNP assay method is not an included one. [pmid: 11326179].
Wang W, Ou Y, Shi Y, Wang WOYaSY. AlbuBNP, a recombinant B-type natriuretic peptide and human serum albumin fusion hormone, as a long-term therapy of congestive heart failure. Pharmaceutical Research. 2004;21(11):2105-2111. Excluded because adult blood not measured. [pmid: 15587934].
Watanabe H, Lau D, Guyn H, Wong N, Watanabe H, Lau D, et al. Effect of progesterone therapy on arginine vasopressin and atrial natriuretic factor in premenstrual syndrome. Clinical & Investigative Medicine - Medecine Clinique et Experimentale. 1997;20(4):211-223. Excluded because BNP assay method is not an included one. [pmid: 9258576].
Watanabe Y, Nakajima K, Shimamori Y, Fujimoto Y, Watanabe Y, Nakajima K, et al. Comparison of the hydrolysis of the three types of natriuretic peptides by human kidney neutral endopeptidase 24.11. Biochemical & Molecular Medicine. 1997;61(1):47-51. Excluded because adult blood not measured. [pmid: 9232196].
Wei C, Heublein D, Perrella M, Lerman A, Rodeheffer R, McGregor C, et al. Natriuretic peptide system in human heart failure. Circulation. 1993;88(3):1004-1009. Excluded because BNP assay method is not an included one. [pmid: 8353861].
Wei T, Zeng C, Chen L, Chen Q, Zhao R, Lu G, et al. Bedside tests of B-type natriuretic peptide in the diagnosis of left ventricular diastolic dysfunction in hypertensive patients. European Journal of Heart Failure. 2005;7(1):75-79. Excluded because BNP assay method is not an included one. [pmid: 15642535].
Weinberg E, Shimpo M, Hurwitz S, Tominaga S, Rouleau J, Lee R, et al. Identification of serum soluble ST2 receptor as a novel heart failure biomarker. Circulation. 2003;107(5):721-726. Excluded because BNP assay method is not an included one. [pmid: 12578875].
White M, Rouleau J, Hall C, Arnold M, Harel F, Sirois P, et al. Changes in vasoconstrictive hormones, natriuretic peptides, and left ventricular remodeling soon after anterior myocardial infarction. American Heart Journal. 2001;142(6):1056-1064. Excluded because BNP assay method is not an included one. [pmid: 11717612].
Wians F Jr, Wilson B, Grant A, Bailey J, Gheorghiu I, et al. Evaluation of the analytical performance characteristics of the Bayer ACS:180(R) B-type natriuretic peptide (BNP) assay. Clinica Chimica Acta. 2005;353(12):147-155. Excluded because BNP assay method is not an included one.
Wijdicks E, Heublein D, Burnett J Jr, Wijdicks E, Heublein D, et al. Increase and uncoupling of adrenomedullin from the natriuretic peptide system in aneurysmal subarachnoid hemorrhage. Journal of Neurosurgery. 2001;94(2):252-256. Excluded because BNP assay method is not an included one. [pmid: 11213962].
Wijdicks E, Schievink W, Burnett J Jr, Wijdicks E, Schievink W, et al. Natriuretic peptide system and endothelin in aneurysmal subarachnoid hemorrhage. Journal of Neurosurgery. 1997;87(2):275-280. Excluded because BNP assay method is not an included one. [pmid: 9254093].
Wijeysundera H, Hansen M, Stanton E, Cropp A, Hall C, Dhalla N, et al. Neurohormones and oxidative stress in nonischemic cardiomyopathy: relationship to survival and the effect of treatment with amlodipine. American Heart Journal. 2003;146(2):291-297. Excluded because BNP assay method is not an included one. [pmid: 12891198].
Wiley K, Davenport A, Wiley K, Davenport AP. Physiological antagonism of endothelin-1 in human conductance and resistance coronary artery. British Journal of Pharmacology. 2001;133(4):568-574. Excluded because adult blood not measured. [pmid: 11399674]. [pmcid: 1572818].
Wilkins MR. Clinical potential of endopeptidase-24.11 inhibitors in cardiovascular disease. Biochemical Society Transactions. 1993;21(3):673-678. Excluded because not a report of a primary study. [pmid: 8224488].
Wilkins M, Redondo J, Brown LA. The natriuretic-peptide family. Lancet. 1997;349(9061):1307-1310. Excluded because not a report of a primary study. [pmid: 9142076].
Wilkins M, Su X, Palayew M, Yamashiro Y, Rolli P, McKenzie J, et al. The effects of posture change and continuous positive airway pressure on cardiac natriuretic peptides in congestive heart failure. Chest. 1995;107(4):909-915. Excluded because BNP assay method is not an included one. [pmid: 7705152].
Williams DG. New “wheys” to raise glutathione levels. ALTERNATIVES. 1997;7(6):41-44. Excluded because adult blood not measured.
Williams S L.B. Aldosterone antagonists: Current and future perspectives. Current Opinion in Cardiovascular, Pulmonary & Renal Investigational Drugs. 2000;2(4):310-315. Excluded because not a report of a primary study.
Williams S Ng L, O'Brien R, Taylor S, Wright D, Tan L, et al. Is plasma N-BNP a good indicator of the functional reserve of failing hearts? The FRESH-BNP study. European Journal of Heart Failure. 2004;6(7):891-900. Excluded because BNP assay method is not an included one. [pmid: 15556051].
Williams S Ng L, O'Brien R, Taylor S, Li Y, Tan L, et al. Comparison of plasma N-brain natriuretic peptide, peak oxygen consumption, and left ventricular ejection fraction for severity of chronic heart failure. American Journal of Cardiology. 2006;93(12):1560-1561. Excluded because BNP assay method is not an included one. [pmid: 15194038].
Winter R, Laurent G, Gauldie J, Lever J, Peacock A, Reeves J, et al. Attenuation of pulmonary vascular remodelling by natriuretic peptides. European Respiratory Review. 1993;3(16):576-580. Excluded because adult blood not measured.
Winter W R.J. The role and assessment of ventricular peptides in heart failure. Clinics in Laboratory Medicine. 2004;24(1):235-274. Excluded because not a report of a primary study. [pmid: 15157565].
Witteles R, Matsuda K, Fowler M, Witteles RMKaFMB. B-type natriuretic peptide is effective therapy before care. Annals of Internal Medicine. 2004;141(11):895. Excluded because not a report of a primary study. [pmid: 15583244].
Witthaut R, Busch C, Fraunberger P, Walli A, Seidel D, Pilz G, et al. Plasma atrial natriuretic peptide and brain natriuretic peptide are increased in septic shock: impact of interleukin-6 and sepsis-associated left ventricular dysfunction. Intensive Care Medicine. 2003;29(10):1696-1702. Excluded because BNP assay method is not an included one. [pmid: 12915939].
Witzel K. Effects of emergency ambulance transportation on heart rate, blood pressure, corticotropin, and cortisol. Annals of Emergency Medicine. 1999;33(5):598-599. Excluded because not a report of a primary study. [pmid: 10216340].
Wong F, Siu S, Liu P, Blendis L, Wong F, Siu S, et al. Brain natriuretic peptide: is it a predictor of cardiomyopathy in cirrhosis?. Clinical Science. 2001;101(6):621-628. Excluded because BNP assay method is not an included one. [pmid: 11724649].
Woo M P.B. Fludrocortisone in the treatment of subarachnoid hemorrhage-induced hyponatremia. Annals of Pharmacotherapy. 1997;31(5):637-639. Excluded because not a report of a primary study. [pmid: 9161663].
Worthley M, Corti R, Worthley SG. Vasopeptidase inhibitors: Will they have a role in clinical practice?. British Journal of Clinical Pharmacology. 2004;57(1):27-36. Excluded because not a report of a primary study. [pmid: 14678337]. [pmcid: 1884420].
Wozakowska-Kaplon B. Beata. Effect of sinus rhythm restoration on plasma brain natriuretic peptide in patients with atrial fibrillation. American Journal of Cardiology. 2006;93(12):1555-1558. Excluded because BNP assay method is not an included one. [pmid: 15194036].
Wu AHB. Analytical and clinical evaluation of new diagnostic tests for myocardial damage. Clinica Chimica Acta. 1998;272(1):11-21. Excluded because not a report of a primary study.
Wu AHB. B-type natriuretic peptide for congestive heart failure. Journal of Clinical Ligand Assay. 2002;25(2):155-159. Excluded because not a report of a primary study.
Wu A, Smith A, Wu AH, Smith A. Biological variation of the natriuretic peptides and their role in monitoring patients with heart failure [Review] [9 refs]. European Journal of Heart Failure. 2003;6(3):355-358. Excluded because not a report of a primary study. [pmid: 14987588].
Yakubo S, Yagi H, Yamaoka K, Hanakawa K, Ariga H, Takase H, et al. A case with heart failure improved by Moku-boi-to of Chinese origin by decreased blood concentration of brain natriuretic peptide. Nihon University Journal of Medicine. 1998;40(5):309-314. Excluded because BNP assay method is not an included one.
Yamahara K, Itoh H, Yamamoto A, Sasano H, Masatsugu K, Sawada N, et al. New diagnostic procedure for primary aldosteronism: Adrenal venous sampling under adrenocorticotropic hormone and angiotensin II receptor blocker - Application to a case of bilateral multiple adrenal microadenomas. Hypertension Research. 2002;25(2):145-152. Excluded because not a report of a primary study. [pmid: 12047027].
Yamamoto K, Dang Q, Maeda Y, Huang H, Kelly R, Lee R, et al. Regulation of cardiomyocyte mechanotransduction by the cardiac cycle.[see comment]. Circulation. 2003;103(10):1459-1464. Excluded because adult blood not measured. [pmid: 11245653].
Yamazaki H, Senju Y, Kinoshita N, Katsukawa F, Onishi S, Yamazaki H, et al. Plasma brain natriuretic peptide in athletes. American Journal of Cardiology. 2000;85(11):1393-1394. Excluded because not a report of a primary study. [pmid: 10831966].
Yancy C, Saltzberg M, Berkowitz R, Bertolet B, Vijayaraghavan K, Burnham K, et al. Safety and feasibility of using serial infusions of nesiritide for heart failure in an outpatient setting (from the FUSION I trial). American Journal of Cardiology. 2004;94(5):595-601. Excluded because adult blood not measured. [pmid: 15342289].
Yandle T, Fisher S, Livesey J, Espiner E, Richards M, Nicholls G, et al. Exponential increase in clinical use of plasma brain natriuretic peptide (BNP) assays. New Zealand Medical Journal. 2004;117(1197):U956. Excluded because adult blood not measured. [pmid: 15326509].
Yandle T, Richards A, Gilbert A, Fisher S, Holmes S, Espiner E, et al. Assay of brain natriuretic peptide (BNP) in human plasma: evidence for high molecular weight BNP as a major plasma component in heart failure. Journal of Clinical Endocrinology & Metabolism. 1993;76(4):832-838. Excluded because BNP assay method is not an included one. [pmid: 8473392].
Yano Y, Gabazza E, Katsuki A, Furuta M, Tanaka T, Araki-Sasaki R, et al. Plasma levels of natriuretic peptides are correlated with renin activity in normotensive type 2 diabetic patients. Diabetes Care. 2000;23(12):1853-1855. Excluded because not a report of a primary study. [pmid: 11128368].
Yarabe H, Rugutt J, McCarroll M, Warner I, Yarabe H, Rugutt J, et al. Capillary electrophoretic separation of binaphthyl enantiomers with two polymeric chiral surfactants: 1H-nuclear magnetic resonance and fluorescence spectroscopy study. Electrophoresis. 2000;21(10):2025-2032. Excluded because adult blood not measured. [pmid: 10879962].
Yasue H, Yoshimura M, Yasue H, Yoshimura M. Natriuretic peptides in the treatment of heart failure. Journal of Cardiac Failure. 1996;2(4 Suppl):S277-S285. Excluded because BNP used as treatment. [pmid: 8951590].
Yasumoto K, Takata M, Ueno H, Tomita S, Tomoda F, Inoue H, et al. Relation of plasma brain and atrial natriuretic peptides to left ventricular geometric patterns in essential hypertension. American Journal of Hypertension. 1999;12(9 Pt 1):921-924. Excluded because BNP assay method is not an included one. [pmid: 10509551].
Yasumura Y, Miyatake K, Okamoto H, Miyauchi T, Kawana M, Tsutamoto T, et al. Rationale for the use of combination angiotensin-converting enzyme inhibitor and angiotensin II receptor blocker therapy in heart failure. Circulation Journal. 2004;68(4):361-366. Excluded because BNP assay method is not an included one. [pmid: 15056835].
Yasumura Y, Takemura K, Sakamoto A, Kitakaze M, Miyatake K, Yasumura YTKSAKMaMK. Changes in myocardial gene expression associated with beta-blocker therapy in patients with chronic heart failure. Journal of Cardiac Failure. 2003;9(6):469-474. Excluded because this is a case report or series with 10 subjects. [pmid: 14966788].
Yeo K, Wu A, Apple F, Kroll M, Christenson R, Lewandrowski K, et al. Multicenter evaluation of the Roche NT-proBNP assay and comparison to the Biosite Triage BNP assay. Clinica Chimica Acta. 2003;338(12):107-115. Excluded because BNP assay method is not an included one.
Ylitalo K, Uusimaa P, Vuolteenaho O, Ruskoaho H, Peuhkurinen K, Ylitalo K, et al. Vasoactive peptide release in relation to hemodynamic and metabolic changes during rapid ventricular pacing. Pacing & Clinical Electrophysiology. 1999;22(7):1064-1070. Excluded because BNP assay method is not an included one. [pmid: 10456635].
Yoshibayashi M, Kamiya T, Saito Y, Matsuo H, Yoshibayashi M, Kamiya T, et al. Increased plasma levels of brain natriuretic peptide in hypertrophic cardiomyopathy. New England Journal of Medicine. 1993;329(6):433-434. Excluded because not a report of a primary study. [pmid: 8326985].
Yoshimura M, Yasue H, Morita E, Sakaino N, Jougasaki M, Kurose M, et al. Hemodynamic, renal, and hormonal responses to brain natriuretic peptide infusion in patients with congestive heart failure. Circulation. 1991;84(4):1581-1588. Excluded because BNP assay method is not an included one. [pmid: 1914098].
Yoshimura M, Yasue H, Okumura K, Ogawa H, Jougasaki M, Mukoyama M, et al. Different secretion patterns of atrial natriuretic peptide and brain natriuretic peptide in patients with congestive heart failure. Circulation. 1993;87(2):464-469. Excluded because BNP assay method is not an included one. [pmid: 8425293].
Yoshimura M, Yasue H, Tanaka H, Kikuta K, Sumida H, Kato H, et al. Responses of plasma concentrations of A type natriuretic peptide and B type natriuretic peptide to alacepril, an angiotensin-converting enzyme inhibitor, in patients with congestive heart failure.[see comment]. British Heart Journal. 1994;72(6):528-533. Excluded because BNP assay method is not an included one. [pmid: 7857734]. [pmcid: 1025637].
Yoshimura N, Yamaguchi M, Oshima Y, Oka S, Ootaki Y, Hasegawa T, et al. Suppression of the secretion of atrial and brain natriuretic peptide after total cavopulmonary connection. Journal of Thoracic & Cardiovascular Surgery. 2000;120(4):764-769. Excluded because adult blood not measured. [pmid: 11003760].
Yoshimura T, Yoshimura M, Yasue H, Ito M, Okamura H, Mukoyama M, et al. Plasma concentration of atrial natriuretic peptide and brain natriuretic peptide during normal human pregnancy and the postpartum period. Journal of Endocrinology. 1994;140(3):393-397. Excluded because BNP assay method is not an included one. [pmid: 8182366].
Young J, Correia N, Francis G, Maisel A, Michota F, Young JB, et al. Testing for B-type natriuretic peptide in the diagnosis and assessment of heart failure: what are the nuances?. Cleveland Clinic Journal of Medicine. 2004;71(Suppl 5):S1-17. Excluded because not a report of a primary study. [pmid: 15462123].
Yu C, Sanderson J, Shum I, Chan S, Yeung L, Hung Y, et al. Diastolic dysfunction and natriuretic peptides in systolic heart failure. Higher ANP and BNP levels are associated with the restrictive filling pattern.[see comment]. European Heart Journal. 1996;17(11):1694-1702. Excluded because BNP assay method is not an included one. [pmid: 8922918].
Yu C, Sanderson J, Yu C, Sanderson JE. Plasma brain natriuretic peptide--an independent predictor of cardiovascular mortality in acute heart failure. European Journal of Heart Failure. 1999;1(1):59-65. Excluded because BNP assay method is not an included one. [pmid: 10937981].
Zheng B, Wen J, Han M, Zhou A, Zheng BWJKHMaZAR. hhLIM protein is involved in cardiac hypertrophy. Biochimica et Biophysica Acta. 2004;1690(1):1-10. Excluded because adult blood not measured. [pmid: 15337165].
Zinchuk V. Histology and histochemistry of heart muscle: Toward function with structure in mind. Microscopy Research & Technique. 2002;58(5):377. Excluded because not a report of a primary study. [pmid: 12226806].
Zoccali C, Mallamaci F, Benedetto F, Tripepi G, Parlongo S, Cataliotti A, et al. Cardiac natriuretic peptides are related to left ventricular mass and function and predict mortality in dialysis patients. Journal of the American Society of Nephrology. 2001;12(7):1508-1515. Excluded because BNP assay method is not an included one. [pmid: 11423580].
Zolle O, Lawrie A, Simpson A, Zolle O, Lawrie A, Simpson AW. Activation of the particulate and not the soluble guanylate cyclase leads to the inhibition of Ca2+ extrusion through localized elevation of cGMP. Journal of Biological Chemistry. 1908;275(34):25892-25899. Excluded because adult blood not measured. [pmid: 10851228].