# Appendix C: Evidence Tables

Table 1 Evidence Table. Effect of clinical determinants on BNP and NT-proBNP listed by study

Study | Determinant Name | Control or comparison group for categorical assocations | Effect | Method
Palmer, 2003 | ACE genotype DD | | increase | NT-proBNP -Christchurch
Schnabel, 2005 | ACS | No ACS | increase | NT-proBNP - Elecsys
Ueda, 2003 | Activities of daily living score | | increase | BNP - Shionogi
Ray, 2004 | Acute right heart failure (no CPE group) | No acute right HF (no CPE group) | none | BNP - Triage
Richards, 1998 | Adrenomedullin | | increase | NT-proBNP - Christchurch
Maisel, 2004a | African-American | Caucasian | none | BNP - Triage
Bettencourt, 2000a | Age | | increase | BNP - Shionogi
Grabowski, 2004 | Age | | increase | BNP - Triage
James, 2003 | Age | | increase | NT-proBNP - Elecsys
Lainchbury, 2003 | Age | | increase | NT-proBNP -Christchurch
Lindahl, 2005 | Age | | increase | NT-proBNP - Elecsys
Olsen, 2004 | Age | | increase | NT-proBNP - Elecsys
Omland, 1996 | Age | | increase | BNP - Shionogi
Redfield, 2004 | Age | | increase | BNP - Triage
Redfield, 2004 | Age | | increase | BNP - Triage
Suzuki, 2002 | Age | | increase | BNP - Shionogi
Tsutamoto, 1997 | Age | | increase | BNP - Shionogi
Ueda, 2003 | Age | | increase | BNP - Shionogi
Tarnow, 2005 | Age (DN) | | increase | NT-proBNP - Elecsys
Latini, 2004a | Aldosterone | | none | BNP - Shionogi
Shiga, 2003 | Amiodarone | No Amiodarone | decrease | BNP - Shionogi
Shiga, 2003 | Amiodarone | Baseline | decrease | BNP - Shionogi
James, 2003 | Angina, stable | | increase | NT-proBNP - Elecsys
Olsen, 2004 | Angina, stable | without CV risk | none | NT-proBNP - Elecsys
Bertinchant, 2005 | ANP | | increase | BNP - Shionogi
Omland, 1996 | ANP | | increase | BNP - Shionogi
Richards, 1998 | ANP | | increase | NT-proBNP - Christchurch
Tsutamoto, 1997 | ANP | | increase | BNP - Shionogi
Weber, 2004 | Aortic stenosis, mild | Normal LVF | increase | NT-proBNP - Elecsys
Weber, 2004 | Aortic stenosis, moderate | Normal LVF | increase | NT-proBNP - Elecsys
Weber, 2004 | Aortic stenosis, severe | Normal LVF | increase | NT-proBNP - Elecsys
Nielsen, L.S., 2004 | Arrhythmia | Non-cardiac dyspnoea | increase | NT-proBNP - Roche (manual)
Stanek, 2001 | Atenolol | Baseline | decrease | BNP - Shionogi
Dias, 2001 | Atrial fibrillation | Sinus Rhythym | none | BNP - Shionogi
Fung, 2003 | Beta-blocker (carvedilol, metoprolol) | Baseline | decrease | NT-proBNP - Roche (manual)
Yoshizawa, 2004 | Beta-blocker (carvedilol, metoprolol) | Baseline | none | BNP - Shionogi
Latini, 2004a | Big endothelin-1 | | increase | BNP - Shionogi
Stanek, 2001 | Big endothelin-1 | | increase | BNP - Shionogi
Bettencourt, 1999 | Blood pressure | (hypertension group) | none | BNP - Shionogi
Tsutamoto, 1997 | Blood pressure | | none | BNP - Shionogi
Ueda, 2003 | Blood pressure | | none | BNP - Shionogi
Kawai, 2001 | Blood pressure, systolic | Baseline | none | BNP - Shionogi
Olsen, 2004 | Blood pressure, systolic | | increase | NT-proBNP - Elecsys
Suzuki, 2002 | Blood pressure, systolic | | none | BNP - Shionogi
Tarnow, 2005 | Blood pressure, systolic (DN) | | increase | NT-proBNP - Elecsys
Suzuki, 2002 | BMI | | none | BNP - Shionogi
Ueda, 2003 | BMI | | none | BNP - Shionogi
Taniguchi, 2004 | Cardiac decompensation | No cardiac decompensation | increase | NT-proBNP - Roche (commercial)
Tsutamoto, 1997 | Cardiac index | | none | BNP - Shionogi
Ray, 2004 | Cardiogenic pulmonary edema (CPE) | Obstructive lung disease | increase | BNP - Triage
Bettencourt, 2004 | Carvedilol | No beta-blocker | decrease | BNP - Shionogi
Hartmann, 2004a | Carvedilol | Placebo | none | NT-proBNP - Roche (manual)
Kawai, 2001 | Carvedilol | No carvedilol | none | BNP - Shionogi
Sliwa, 2004 | Carvedilol | Perindopril | decrease | NT-proBNP - Roche (commercial)
Sliwa, 2004 | Carvedilol | Baseline | decrease | NT-proBNP - Roche (commercial)
Yoshizawa, 2004 | Carvedilol | Baseline | none | BNP - Shionogi
Sliwa, 2004 | Carvedilol + Perindopril (6 months later) | Perindopril + Carvedilol (6 months later) | decrease | NT-proBNP - Roche (commercial)
Olsen, 2004 | Cerebrovascular disease (stroke or TIA) | without CV risk | none | NT-proBNP - Elecsys
Richards, 1998 | cGMP | | increase | NT-proBNP - Christchurch
Tsutamoto, 1997 | cGMP | | increase | BNP - Shionogi
Tarnow, 2005 | Cholesterol | | none | NT-proBNP - Elecsys
Ueda, 2003 | Cholesterol | | none | BNP - Shionogi
Bazzino, 2004 | C-reactive protein | | increase | NT-proBNP - E170
James, 2003 | C-reactive protein | | increase | NT-proBNP - Elecsys
Lindahl, 2005 | C-reactive protein | | increase | NT-proBNP - Elecsys
Bettencourt, 2004 | Creatinine | | increase | BNP - Shionogi
Bettencourt, 1999 | Creatinine | (hypertension group) | none | BNP - Shionogi
Galvani, 2004 | Creatinine | | increase | NT-proBNP - Elecsys
James, 2003 | Creatinine | | increase | NT-proBNP - Elecsys
Omland, 1996 | Creatinine | | increase | BNP - Shionogi
Panteghini, 2003 | Creatinine | | none | BNP - Triage
Ueda, 2003 | Creatinine | | increase | BNP - Shionogi
Zeller, 2004 | Creatinine | | increase | NT-proBNP - Elecsys
Wallen, 1997 | Creatinine clearance | | none | BNP - Shionogi
Taniguchi, 2004 | Creatinine kinase | | none | NT-proBNP - Roche (commercial)
Bazzino, 2004 | Creatinine kinase, CK-MB | | increase | NT-proBNP - E170
Mega, 2004 | Creatinine kinase, CK-MB | | none | BNP - Centaur
Morrow, 2003 | Creatinine kinase, CK-MB | | increase | BNP - Triage
Panteghini, 2003 | Creatinine kinase, CK-MB | | increase | BNP - Triage
James, 2003 | Diabetes | | increase | NT-proBNP - Elecsys
Lindahl, 2005 | Diabetes | No diabetes | none | NT-proBNP - Elecsys
Olsen, 2004 | Diabetes | without CV risk | none | NT-proBNP - Elecsys
Schnabel, 2005 | Diabetes | No diabetes | none | NT-proBNP - Elecsys
Tarnow, 2005 | Diabetic nephropathy | Normoalbuminuric | increase | NT-proBNP - Elecsys
Tarnow, 2005 | Diabetic retinopathy | | none | NT-proBNP - Elecsys
Suzuki, 2002 | Diastolic blood pressure | | none | BNP - Shionogi
Bayes-Genis, 2004 | Diastolic failure | Systolic LV dysfunction | decrease | NT-proBNP - Elecsys
Bettencourt, 2000c | Diastolic failure | Systolic dysfunction | decrease | BNP - Shionogi
Bettencourt, 2000c | Diastolic failure | Normal ventricular function | increase | BNP - Shionogi
Bettencourt, 2000a | Diastolic failure | Systolic heart failure | decrease | BNP - Shionogi
Bettencourt, 1999 | Diastolic failure | (hypertension group) | increase | BNP - Shionogi
Nielsen, L.S., 2004 | Diastolic failure | Non-cardiac dyspnoea | increase | NT-proBNP - Roche (manual)
Redfield, 2004 | Diastolic failure | | increase | BNP - Triage
Hamada, 2005 | Dilated cardiomyopathy | Old myocardial infarction | none | BNP - Shionogi
Bayes-Genis, 2004 | Dyspnoea, non-cardiac | Control | increase | NT-proBNP - Elecsys
Logeart, 2002 | Dyspnoea, non-cardiac | Control | increase | BNP - Triage
Maisel, 2002. | Dyspnoea, non-cardiac | No CHF | increase | BNP - Triage
Morrison, 2002 | Dyspnoea, non-cardiac | CHF | decrease | BNP - Triage
Akioka, 2000 | E/A ratio | | none | BNP - Shionogi
Suzuki, 2002 | E/A ratio | | none | BNP - Shionogi
Yoshimura, 2002 | Enalapril | Baseline | decrease | BNP - Shionogi
Yoshimura, 2002 | Enalapril (15-mg) | Enalapril (5-mg) | decrease | BNP - Shionogi
Brunner-La Rocca, 1999 | Enalapril (40-mg) | Enalapril (10-mg) | decrease | BNP - Shionogi
Taniguchi, 2004 | End-diastolic dimension | | none | NT-proBNP - Roche (commercial)
Latini, 2004a | Endothelin-1 | | increase | BNP - Shionogi
Richards, 1998 | Epinephrine | | increase | NT-proBNP - Christchurch
Koglin, 2001 | Exercise | | decrease | BNP - Shionogi
James, 2003 | Female | | increase | NT-proBNP - Elecsys
Lindahl, 2005 | Female | Male | increase | NT-proBNP - Elecsys
Maisel, 2004a | Female | Male | none | BNP - Triage
Olsen, 2004 | Female | Male | none | NT-proBNP - Elecsys
Redfield, 2004 | Female | Male | increase | BNP - Triage
Schnabel, 2005 | Female | Male | increase | NT-proBNP - Elecsys
Ueda, 2003 | Female | Male | none | BNP - Shionogi
Weber, 2004 | Female | Male | none | NT-proBNP - Elecsys
Wiviott, 2004 | Female | Male | increase | BNP - Triage
Nielsen, O.W.,2004 | Female (>74) | Male (>74) | none | NT-proBNP - Elecsys
Nielsen, O.W.,2004 | Female (40–59) | Male (40–59) | none | NT-proBNP - Elecsys
Nielsen, O.W.,2004 | Female (60–74) | Male (60–74) | none | NT-proBNP - Elecsys
Tarnow, 2005 | Female (DN) | Male | none | NT-proBNP - Elecsys
Kawai, 2001 | Fibrosis | Baseline | none | BNP - Shionogi
Bettencourt, 1999 | Fractional shortening | (hypertension group) | none | BNP - Shionogi
Bettencourt, 2004 | Furosemide, dosage | | none | BNP - Shionogi
Tarnow, 2005 | Glomerular filtration rate (ND) | | decrease | NT-proBNP - Elecsys
Tarnow, 2005 | Glomerular filtration rate (No DN) | | decrease | NT-proBNP - Elecsys
Tarnow, 2005 | Glucose, fasting | | none | NT-proBNP - Elecsys
O'Brien, 2003 | Glucose, random | | increase | NT-proBNP - Roche (manual)
Tarnow, 2005 | HbA1c | | none | NT-proBNP - Elecsys
Ueda, 2003 | HbA1c | | none | BNP - Shionogi
Bettencourt, 1999 | Heart rate | | none | BNP - Shionogi
James, 2003 | Heart rate | | increase | NT-proBNP - Elecsys
Kawai, 2001 | Heart rate | Baseline | increase | BNP - Shionogi
Tsutamoto, 1997 | Heart rate | | increase | BNP - Shionogi
Ueda, 2003 | Heart rate | | none | BNP - Shionogi
Tarnow, 2005 | Hemoglobin (DN) | | decrease | NT-proBNP - Elecsys
Schnabel, 2005 | Hyperlipidemia | No hyperlipidemia | decrease | NT-proBNP - Elecsys
James, 2003 | Hyperlipidemia (hypercholesterolemia) | | none | NT-proBNP - Elecsys
James, 2003 | Hypertension | | increase | NT-proBNP - Elecsys
Schnabel, 2005 | Hypertension | No hypertension | none | NT-proBNP - Elecsys
Suzuki, 2002 | Hypertension, duration | | none | BNP - Shionogi
Suzuki, 2002 | Hypertension, left ventricular hypertrophy | Normotensive | increase | BNP - Shionogi
Suzuki, 2002 | Hypertension, normal left ventricular mass | Normotensive | increase | BNP - Shionogi
Bettencourt, 1999 | Hypertension, with diastolic dysfunction | Hypertension, without diastolic dysfunction | increase | BNP - Shionogi
Bettencourt, 1999 | Hypertension, with diastolic dysfunction | Control & hypertension without diastolic dysfunction | increase | BNP - Shionogi
Bettencourt, 1999 | Hypertension, without diastolic dysfunction | Control | increase | BNP - Shionogi
Richards, 2002 | Hypertensive (MI) | Normotensive (MI) | increase | NT-proBNP - Christchurch
Richards, 2002 | Hypertensive (OMI) | Normotensive (OMI) | increase | NT-proBNP - Christchurch
Jernberg, 2003 | Interleukin-6 | | increase | NT-proBNP - Elecsys
Koglin, 2001 | Ischemic heart disease | Nonischemic heart disease | none | BNP - Shionogi
Olsen, 2004 | Ischemic heart disease | without CV risk | increase | NT-proBNP - Elecsys
Sadanandan, 2004 | LAD culprit lesion | nonLAD culprit lesion | increase | BNP - Triage
Sadanandan, 2004 | LAD lesion, proximal vs mid | Mid LAD lesion | increase | BNP - Triage
Thompson, 2005 | Left ventricular assist device | Baseline | decrease | BNP - Triage
Kawai, 2001 | Left ventricular diastolic dimension | Baseline | increase | BNP - Shionogi
Kawai, 2001 | Left ventricular end-systolic diameter | Baseline | increase | BNP - Shionogi
Bettencourt, 2000c | Left ventricular mass index | | increase | BNP - Shionogi
Bettencourt, 2000a | Left ventricular mass index | | increase | BNP - Shionogi
Bettencourt, 1999 | Left ventricular mass index | (hypertension group) | increase | BNP - Shionogi
Bettencourt, 1999 | Left ventricular mass index | | increase | BNP - Shionogi
Kawai, 2001 | Left ventricular mass index | Baseline | increase | BNP - Shionogi
Suzuki, 2002 | Left ventricular mass index | | increase | BNP - Shionogi
Suzuki, 2002 | Left ventricular relative wall thickness | | none | BNP - Shionogi
Bettencourt, 2004 | Lisinopril, dosage | | decrease | BNP - Shionogi
Dao, 2001 | Lung disease | CHF | decrease | BNP - Triage
Nielsen, L.S., 2004 | Lung disease | CHF and CHF + lung disease | decrease | NT-proBNP - Roche (manual)
Sakatani, 2004 | Lymphocytes (HHD, MS, AF, HC) | | none | BNP - Shionogi
Sakatani, 2004 | Lymphocytes (IHD, DC, AS, AR, MR) | | decrease | BNP - Shionogi
Yoshizawa, 2004 | Metoprolol | Baseline | none | BNP - Shionogi
Kyuma, 2004 | MIBG activity | | decrease | BNP - Shionogi
Suzuki, 2002 | Mid-wall left ventricular fractional shortening | | none | BNP - Shionogi
Schnabel, 2005 | Multi-vessel disease | No multi-vessel disease | increase | NT-proBNP - Elecsys
James, 2003 | Myocardial infarction | | increase | NT-proBNP - Elecsys
Olsen, 2004 | Myocardial infarction | without CV risk | increase | NT-proBNP - Elecsys
Panteghini, 2003 | Myocardial infarction | | increase | BNP - Triage
Lindahl, 2005 | Myocardial infarction, history | No previous MI | increase | NT-proBNP - Elecsys
Schnabel, 2005 | Myocardial infarction, history | No myocardial infarction, history | increase | NT-proBNP - Elecsys
Bazzino, 2004 | Myoglobin | | increase | NT-proBNP - E170
Bertinchant, 2005 | Norepinephrine | | increase | BNP - Shionogi
Latini, 2004a | Norepinephrine | | increase | BNP - Shionogi
Latini, 2002 | Norepinephrine | | increase | BNP - Shionogi
Richards, 1998 | Norepinephrine | | increase | NT-proBNP - Christchurch
Stanek, 2001 | Norepinephrine | | increase | BNP - Shionogi
Tsutamoto, 1997 | Norepinephrine | | increase | BNP - Shionogi
Jarai, 2005 | NT-proANP | | increase | NT-proBNP - Biomedica
Omland, 1996 | NT-proANP | | increase | BNP - Shionogi
Richards, 1998 | NT-proANP | | increase | NT-proBNP - Christchurch
Stanek, 2001 | NT-proANP | | increase | BNP - Shionogi
Wang, 2004 | NT-proANP | | increase | BNP - Shionogi
Vasan, 2002 | NT-proANP (females) | | increase | BNP - Shionogi
Vasan, 2002 | NT-proANP (males) | | increase | BNP - Shionogi
Ueland, 2004 | Osteoprotegerin | | increase | NT-proBNP - Roche (manual)
Tsutamoto, 1997 | PCWP | | increase | BNP - Shionogi
Panteghini, 2003 | Perfusion defect size | | increase | BNP - Triage
Sliwa, 2004 | Perindopril | Baseline | none | NT-proBNP - Roche (commercial)
Olsen, 2004 | Peripheral vascular disease | without CV risk | none | NT-proBNP - Elecsys
Latini, 2004a | Plasma renin activity | | decrease | BNP - Shionogi
Lindahl, 2005 | Previous CHF | No previous CHF | increase | NT-proBNP - Elecsys
Tsutamoto, 1997 | Pulmonary arterial pressure | | increase | BNP - Shionogi
Suzuki, 2002 | Pulse pressure | | increase | BNP - Shionogi
Fisher, 2003 | Relaxin | | none | NT-proBNP - Roche (commercial)
Akioka, 2000 | Restrictive filling pattern of deceleration time (DcT) | | decrease | BNP - Shionogi
James, 2003 | Revascularization | | increase | NT-proBNP - Elecsys
Tsutamoto, 1997 | Right atrial pressure | | increase | BNP - Shionogi
Schnabel, 2005 | Smoker, current | Non-smoker | none | NT-proBNP - Elecsys
James, 2003 | Smoking, current | | none | NT-proBNP - Elecsys
Shimpo, 2004 | ST2, soluble receptor | | none | BNP - Shionogi
James, 2003 | Stroke | | increase | NT-proBNP - Elecsys
Lindahl, 2005 | ST-segment depression | No ST-segment depression | increase | NT-proBNP - Elecsys
James, 2003 | ST-segment depression > 5mm | | increase | NT-proBNP - Elecsys
Panteghini, 2003 | Telesystolic volume | | none | BNP - Triage
Ueda, 2003 | Total protein | | none | BNP - Shionogi
Grabowski, 2004 | Troponin-I | | increase | BNP - Triage
Jarai, 2005 | Troponin-I | | none | NT-proBNP - Biomedica
Dokainish, 2005 | Troponin-I (CAD) | Tn-I negative (CAD) | increase | BNP - Triage
Dokainish, 2005 | Troponin-I (No CAD) | Tn-I negative (No CAD) | increase | BNP - Triage
Bayes-Genis, 2004 | Troponin-T | | increase | NT-proBNP - Elecsys
Bazzino, 2004 | Troponin-T | | increase | NT-proBNP - E170
Bertinchant, 2005 | Troponin-T | | increase | BNP - Shionogi
Ishii, 2003 | Troponin-T | | increase | BNP - Shionogi
James, 2003 | Troponin-T | | increase | NT-proBNP - Elecsys
Jernberg, 2003 | Troponin-T | | increase | NT-proBNP - Elecsys
Jernberg, 2002 | Troponin-T | | increase | NT-proBNP - Elecsys
Lindahl, 2005 | Troponin-T | | increase | NT-proBNP - Elecsys
Taniguchi, 2004 | Troponin-T (> 0.01 ng/mL) | Troponin-T (≤ 0.01 ng/mL) | increase | NT-proBNP - Roche (commercial)
Krum, 2004 | Valsartan | Placebo | decrease | BNP - Shionogi
Latini, 2002 | Valsartan | Placebo | decrease | BNP - Shionogi
Maggioni, 2002 | Valsartan | Placebo | decrease | BNP - Shionogi
Krum, 2004 | Valsartan (ACEi < median) | Placebo (ACEi < median) | decrease | BNP - Shionogi
Krum, 2004 | Valsartan (ACEi > median) | Placebo (ACEi > median) | decrease | BNP - Shionogi
Baruch, 2004 | Valsartan (age < 65 y) | Placebo (age < 65 y) | decrease | BNP - Shionogi
Baruch, 2004 | Valsartan (age ≥ 65 y) | Placebo (age ≥ 65 y) | decrease | BNP - Shionogi
Krum, 2004 | Valsartan (no ACEi) | Placebo (no ACEi) | decrease | BNP - Shionogi
Nielsen, L.S., 2004 | Valvular disease | Non-cardiac dyspnoea | increase | NT-proBNP - Roche (manual)
James, 2003 | Weight | | decrease | NT-proBNP - Elecsys

Table 1-1 Evidence Table. Effect of clinical determinants on BNP and NT-proBNP listed by study

Study | n | Determinant n | Control or comparsion group n | Determinant Concentration | Control or comparison group concentration | Units | Statistical Method | p | r | Beta or chi-square
Palmer, 2003 | | 196 | 522 | 28.6 +/-21.7 | 24.2 +/-13.8 | pmol/L | Chi-square | 0.007
Schnabel, 2005 | 904 | | | 542.0 (161.43/1355.50) | 192.0 (88.67/487.90) | pg/mL | Wilcoxon rank sum | <0.001
Ueda, 2003 | 111 | | | | | pg/mL | Univariate / Multivariate | 0.0001/0.002 | 0.36
Ray, 2004 | | 52 | 115 | 125 (75 to 752) | 59 (41 to 88) | pg/mL | Mann-Whitney | | ns
Richards, 1998 | 100 | | | | | pmol/L | Pearson product moment | <0.001 | 0.4
Maisel, 2004a | | 715 | 773 | | | pg/mL | Kruskal-Wallis and Mann-Whitney U tests | <0.001
Bettencourt, 2000a | 85 | | | | | pg/mL | Multiple regression | 0.173 | 0.036
Grabowski, 2004 | 126 | | | | | pg/mL | Spearman correlation coefficient | 0.01 | 0.23
James, 2003 | 6809 | | | | | ng/L | Multiple linear regression | | 0.46 | 0.04
Lainchbury, 2003 | 205 | | | | | pmol/L | Pearson's correlation coefficient | <0.01
Lindahl, 2005 | 1352 / 999 | | | | | ng/L | not clear / Multiple linear mixed effects | <0.001 / <0.05
Olsen, 2004 | 183 | | | | | pmol/L | correlation, not specified | <0.001 | 0.4
Omland, 1996 | 131 | | | | | pmol/L | Linear regression analysis | <0.001 | 0.34
Redfield, 2004 | 726 | | | | | pg/mL | Least squares regression (controlled for diastolic dysfunction) | 0.0003
Redfield, 2004 | 2042 | | | | | pg/mL | Least squares regression (controlled for EF) | 0.0007
Suzuki, 2002 | 185 | | | | | pg/mL | Univariate/multivariate | 0.0001/0.0210 | 0.452/0.256
Tsutamoto, 1997 | 85 | | | | | pg/mL | Linear regression analysis | <0.0001 | 0.46
Ueda, 2003 | 111 | | | | | pg/mL | Univariate / Multivariate | 0.001/0.05 | 0.31
Tarnow, 2005 | 198 | | | | | ng/L | na | <0.0001 | 0.42
Latini, 2004a | 4223 | | | | | pg/mL | Spearman's coefficient | ns | 0.0072
Shiga, 2003 | | 42 | 18 | 180 +/-30 | 282 +/-71 | pg/mL | Mann-Whitney | <0.001
Shiga, 2003 | | 37 | 41 | 333 +/-107 | 146 +/-40 | pg/mL | Mann-Whitney | <0.05
James, 2003 | | 3181 | | | | ng/L | Multiple linear regression | | | 0.11
Olsen, 2004 | | 15 | 123 | 29.7 +/- 136 | 19.8 +/- 62.0 | pmol/L | Unpaired Student's t-test | ns
Bertinchant, 2005 | 63 | | | | | ug/L | Spearman rank correlation | <0.0001 | 0.85
Omland, 1996 | 131 | | | | | pmol/L | Linear regression analysis | <0.001 | 0.51
Richards, 1998 | 100 | | | | | pmol/L | Pearson product moment | <0.001 | 0.69
Tsutamoto, 1997 | 85 | | | | | pg/mL | Linear regression analysis | <0.0001 | 0.53
Weber, 2004 | | 26 | 32 | 612 +/- 151 | 140 +/- 27 | pg/mL | Kruskal Wallis | <0.001
Weber, 2004 | | 29 | 32 | 1441 +/- 32 | 140 +/- 27 | pg/mL | Kruskal Wallis | <0.001
Weber, 2004 | | 91 | 32 | 2579 +/- 13 | 140 +/- 27 | pg/mL | Kruskal Wallis | <0.001
Nielsen, L.S., 2004 | | 10 | 264 | | | pmol/L | t-test | <0.001
Stanek, 2001 | 51 | | | | | fmol/L | ANOVA | <0.01
Dias, 2001 | | 14 | 32 | 175.9 +/-39.5 | 215.3 +/-57.5 | pg/mL | na | 0.98
Fung, 2003 | | 43 | 43 | - 37.0 +/-14.5 | | pmol/L | Student's t-test | 0.015
Yoshizawa, 2004 | | 84 | 84 | 290 +/-384 | 177 +/-256 | pg/mL | t-test | ns
Latini, 2004a | 2312 | | | | | pg/mL | Spearman's coefficient | <0.001 | 0.4142
Stanek, 2001 | 100 | | | | | fmol/L | Spearman rank-correlation coefficient | 0.0001 | 0.47
Bettencourt, 1999 | 36 | | | | | pg/mL | Multiple linear regression | 0.445 | | 0.013
Tsutamoto, 1997 | 85 | | | | | pg/mL | Linear regression analysis | 0.044 | 0.018
Ueda, 2003 | 111 | | | | | pg/mL | Univariate / Multivariate | 0.99 | -0.001
Kawai, 2001 | 21 | | | | | pg/mL | Linear regression | 0.28 | 0.25
Olsen, 2004 | 183 | | | | | pmol/L | regression, method not specified | <0.001 | 0.25
Suzuki, 2002 | 185 | | | | | pg/mL | Univariate/multivariate | 0.1199 | 0.104
Tarnow, 2005 | 198 | | | | | ng/L | regression, method not specified | <0.0001 | 0.53
Suzuki, 2002 | 185 | | | | | pg/mL | Univariate/multivariate | 0.0002/0.0530 | 0.243/0.118
Ueda, 2003 | 111 | | | | | pg/mL | Univariate | 0.47 | -0.07
Taniguchi, 2004 | | 45 | 26 | 7233 +/-2369 | 1303 +/-291 | pg/mL | na | <0.05
Tsutamoto, 1997 | 85 | | | | | pg/mL | Linear regression analysis | ns | -0.11
Ray, 2004 | | 141 | 167 | 611 (370 to 709) | 56 (48 to 97) | pg/mL | Mann-Whitney | <0.001
Bettencourt, 2004 | | 57 | 27 | | | pg/mL | | 0.02
Hartmann, 2004a | 815 | unknown | unknown | 261.5 | 233.6 | pmol/L | not given | ns
Kawai, 2001 | | 21 | 9 | | | pg/mL | Repeated-measures analysis of variance | 0.18
Sliwa, 2004 | | 27 | 30 | -80 | | pg/mL | t-test | <0.01
Sliwa, 2004 | | 27 | 27 | -125 | | pg/mL | t-test | <0.0005
Yoshizawa, 2004 | | 58 | 58 | -44 | | pg/mL | t-test | ns
Sliwa, 2004 | | 27 | 30 | -75 | | pg/mL | t-test | <0.01
Olsen, 2004 | | 19 | 123 | 28.5 +/- 36 | 19.8 +/- 62.0 | pmol/L | Unpaired Student's t-test | ns
Richards, 1998 | 100 | | | | | pmol/L | Pearson product moment | <0.001 | 0.64
Tsutamoto, 1997 | 85 | | | | | pg/mL | Linear regression analysis | 0.0002 | 0.4
Tarnow, 2005 | 386 | | | | | ng/L | na | ns
Ueda, 2003 | 111 | | | | | pg/mL | Univariate / Multivariate | 0.72 | 0.03
Bazzino, 2004 | 1483 | | | | | pg/mL | Spearman correlation coefficient | 0.01 | 0.28
James, 2003 | 6809 | | | | | ng/L | Multiple linear regression | | 0.34 | 0.19
Lindahl, 2005 | 1352 / 999 | | | 787 (696 to 890) | 358 (327 to 390) | ng/L | Mann-Whitney / Multiple linear mixed effects | < 0.001 / 0.05
Bettencourt, 2004 | 84 | | | | | pg/mL | Spearman | 0.01 | 0.3
Bettencourt, 1999 | 36 | | | | | pg/mL | Multiple linear regression | 0.939 | | -0.004
Galvani, 2004 | 1756 | | | | | ng/L | Spearman correlation coefficient | 0.01 | 0.23
James, 2003 | 6809 | | | | | ng/L | Multiple linear regression | na | 0.2 | 0.0013
Omland, 1996 | 131 | | | | | pmol/L | Linear regression analysis | <0.01 | 0.25
Panteghini, 2003 | 64 | | | | | pg/mL | Standard Linear regression | 0.21 | 0.16
Ueda, 2003 | 111 | | | | | pg/mL | Univariate / Multivariate | 0.02/0.002 | 0.23
Zeller, 2004 | 101 | | | | | pmol/L | Logistic regression | <0.01 | 0.481
Wallen, 1997 | 200 | | | | | pg/mL | na | 0.126 | -0.079
Taniguchi, 2004 | 71 | | | | | pg/mL | na | ns
Bazzino, 2004 | 1483 | | | | | pg/mL | Spearman correlation coefficient | <0.001 | 0.07
Mega, 2004 | 436 | | | | | pg/mL | Spearman correlation coefficient | 0.19 | -0.065
Morrow, 2003 | 1676 | | | | | pg/mL | Spearman correlation | <0.001 | 0.27
Panteghini, 2003 | 64 | | | | | pg/mL | Standard Linear regression | 0.002 | 0.38
James, 2003 | | 1420 | | | | ng/L | Multiple linear regression | | | 0.08 (CI = 0.013 to 0.15)
Lindahl, 2005 | 1352 / 999 | | | 447 (366 to 546) | 474 (438 to 512) | ng/L | Mann-Whitney / Multiple linear mixed effects | 0.60 / ns
Olsen, 2004 | | 20 | 123 | 21 +/- 67 | 19.8 +/- 62.0 | pmol/L | Unpaired Student's t-test | ns
Schnabel, 2005 | 904 | 204 | 700 | 351.8 (107.35/875.00) | 231.5 (101.00/691.90) | pg/mL | Wilcoxon rank sum | ns
Tarnow, 2005 | | 198 | 188 | 110 (5 to 79640) | 27 (5 to 455) | ng/L | t-test | <0.0001
Tarnow, 2005 | | 320 | 66 | | | ng/L | t-test | ns
Suzuki, 2002 | 185 | | | | | pg/mL | Univariate/multivariate | 0.0558 | 0.128
Bayes-Genis, 2004 | | 28 | 33 | 848 +/-297 | 1118 +/-199 | pmol/L | Mann-Whitney | 0.054
Bettencourt, 2000c | | 31 | 36 | 168.0 +/-110.5 | 339.1 +/-249.9 | pg/mL | t-test | 0.001
Bettencourt, 2000c | | 36 | 33 | 339.1 +/-249.9 | 68.3 +/- 72.6 | pg/mL | t-test | <0.001
Bettencourt, 2000a | | 17 | 55 | 137.2 +/- 364.1 | 362 +/- 536.4 | pg/mL | Chi-square | <0.03
Bettencourt, 1999 | 36 | | | | | pg/mL | Multiple linear regression | 0.027 | | 0.622
Nielsen, L.S., 2004 | | 32 | 264 | | | pmol/L | t-test | <0.001
Redfield, 2004 | 726 | | | | | pg/mL | Pearson' correlation coefficient | <0.0001 | 0.308
Hamada, 2005 | | 21 | 31 | 784 +/-682 | 688 +/-487 | pg/mL | Chi-square | ns
Bayes-Genis, 2004 | | 15 | 86 | 50 +/-15 | 9 +/-3 | pmol/L | Mann-Whitney | <0.05
Logeart, 2002 | | 48 | 30 | 187 +/-158 | 44 +/-39 | pg/mL | t-test | <0.05
Maisel, 2002. | | 72 | 770 | 346 +/-390 | 110 +/-225 | pg/mL | t-test | <0.001
Morrison, 2002 | | 85 | 135 | 61 +/-92 | 759 +/-799 | pg/mL | t-test | <0.001
Akioka, 2000 | 33 | | | | | pg/mL | Linear regression | ns
Suzuki, 2002 | 185 | | | | | pg/mL | Univariate/multivariate | 0.7956 | 0.108
Yoshimura, 2002 | | 24 | 24 | | | pg/mL | t-test | 0.01
Yoshimura, 2002 | | 12 | 12 | 78 +/-58 | 139 +/-61 | pg/mL | t-test | 0.05
Brunner-La Rocca, 1999 | | 45 | 45 | 192 | 152 | pg/mL | | <0.005
Taniguchi, 2004 | 71 | | | | | pg/mL | na | ns
Latini, 2004a | 1929 | | | | | pg/mL | Spearman's coefficient | <0.001 | 0.1955
Richards, 1998 | 100 | | | | | pmol/L | Pearson product moment | <0.01 | 0.17
Koglin, 2001 | 78 | | | | | pg/mL | Logistic regression | <0.0001 | | 24.9
James, 2003 | | 2597 | | | | ng/L | Multiple linear regression | | | 0.26
Lindahl, 2005 | 1352 / 999 | | | 606 (529 to 693) | 426 (391 to 463) | ng/L | Mann-Whitney / Multiple linear mixed effects | <0.001 / <0.05
Maisel, 2004a | | 703 | 883 | | | pg/mL | Kruskal-Wallis and Mann-Whitney U tests | 0.756
Olsen, 2004 | 183 | | | | | pmol/L | | ns
Redfield, 2004 | | 1058 | 984 | | | pg/mL | Multivariate models | <0.0001
Schnabel, 2005 | | 208 | 696 | 354.5 (148.4/1288.0) | 231.5 (94.66/662.30) | pg/mL | Wilcoxon rank sum | <0.001
Ueda, 2003 | | 88 | 23 | | | pg/mL | Univariate / Multivariate | 0.98 | -0.003
Weber, 2004 | | 95 | 114 | 1852 | 1221.0 | pg/mL | Mann-Whitney | 0.59
Wiviott, 2004 | | 638 | 1227 | 68.4 +/-4.5 | 46.1 +/-2.4 | ng/mL | Student t test | <0.0001
Nielsen, O.W.,2004 | | 85 | 23 | | | pmol/L | t-test | 0.74
Nielsen, O.W.,2004 | | 89 | 75 | | | pmol/L | t-test | 0.59
Nielsen, O.W.,2004 | | 60 | 49 | | | pmol/L | t-test
Tarnow, 2005 | | 150 | 236 | | | ng/L | t-test | 0.28
Kawai, 2001 | 21 | | | | | pg/mL | Linear regression | 0.25 | -0.28
Bettencourt, 1999 | 36 | | | | | pg/mL | Multiple linear regression | 0.551 | | 0.011
Bettencourt, 2004 | 84 | | | | | pg/mL | Spearman | 0.48 | 0.08
Tarnow, 2005 | 198 | | | | | ng/L | na | <0.0001 | -0.6
Tarnow, 2005 | 188 | | | | | ng/L | na | 0.002 | -0.22
Tarnow, 2005 | 386 | | | | | ng/L | na | ns
O'Brien, 2003 | 96 | | | | | fmol/L | Pearson product moment correlation coefficient | 0.011 | 0.27
Tarnow, 2005 | 386 | | | | | ng/L | na | ns
Ueda, 2003 | 111 | | | | | pg/mL | Univariate / Multivariate | 0.87 | -0.02
Bettencourt, 1999 | 36 | | | | | pg/mL | Multiple linear regression | 0.825 | | -0.002
James, 2003 | 6809 | | | | | ng/L | Multiple linear regression | | 0.14 | 0.07
Kawai, 2001 | 21 | | | | | pg/mL | Linear regression | 0.012 | 0.54
Tsutamoto, 1997 | 85 | | | | | pg/mL | Linear regression analysis | <0.0001 | 0.26
Ueda, 2003 | 111 | | | | | pg/mL | Univariate / Multivariate | 0.46 | 0.07
Tarnow, 2005 | 198 | | | | | ng/L | na | <0.0001 | -0.52
Schnabel, 2005 | 904 | 645 | 259 | 214.5 (95.61/670.05) | 361.5 (137.13/1011.75) | pg/mL | Wilcoxon rank sum | <0.001
James, 2003 | | 1995 | | | | ng/L | Multiple linear regression | | | -0.098
James, 2003 | | 3515 | | | | ng/L | Multiple linear regression | | | 0.082
Schnabel, 2005 | 904 | 695 | 209 | 261.8 (103.75/261.8) | 213.8 (96.39/662.30) | pg/mL | Wilcoxon rank sum test | ns
Suzuki, 2002 | 185 | | | | | pg/mL | Univariate/multivariate | 0.0015/.1795 | 0.317/0.135
Suzuki, 2002 | | 89 | 44 | 57.3 +/-55.4 | 19.5 +/-24.0 | pg/mL | One-way ANOVA | 0.01
Suzuki, 2002 | | 96 | 44 | 29.7 +/-28.3 | 19.5 +/-24.0 | pg/mL | One-way ANOVA | 0.05
Bettencourt, 1999 | | 12 | 24 | | | pg/mL | t-test | 0.001
Bettencourt, 1999 | | 36 | 11 | 61.16 +/-45.38 | 31.27 +/-18.10 | pg/mL | t-test | 0.001
Bettencourt, 1999 | | 24 | 11 | | | pg/mL | t-test | 0.0003
Richards, 2002 | | 436 | 657 | 192 +/-175 | 160 +/-150 | pmol/L | Chi-square | 0.034
Richards, 2002 | | 436 | 657 | 111 +/-134 | 76 +/-80 | pmol/L | Chi-square | <0.001
Jernberg, 2003 | 2019 | | | | | ng/L | not found | <0.001 | 0.29
Koglin, 2001 | | 24 | 54 | 150.6 +/-25.7 | 158.9 +/-22.2 | pg/mL | na | ns
Olsen, 2004 | | 26 | 123 | 67.3 +/- 118 | 19.8 +/- 62.0 | pmol/L | Unpaired Student's t-test | < 0.05
Sadanandan, 2004 | | 88 | 188 | 40 | 24.0 | pg/mL | Wilcoxon rank-sum test | 0.005
Sadanandan, 2004 | | 83 | 6 | 41 | 10.0 | pg/mL | Wilcoxon rank-sum test | 0.03
Thompson, 2005 | 19 | | | 221.1 +/-124.2 | 754.1 +/-261.1 | pg/mL | t-test | <0.0001
Kawai, 2001 | 21 | | | | | pg/mL | Linear regression | <0.001 | 0.7
Kawai, 2001 | 21 | | | | | pg/mL | Linear regression | <0.001 | 0.86
Bettencourt, 2000c | | | | | | pg/mL | Pearson's correlation | 0.008 | 0.27
Bettencourt, 2000a | 85 | | | | | pg/mL | Multiple regression | <0.001 | 0.19
Bettencourt, 1999 | 36 | | | | | pg/mL | Multiple linear regression | 0.041 | | 0.006
Bettencourt, 1999 | 47 | | | | | pg/mL | Pearson's correlation coefficient | <0.001 | 0.53
Kawai, 2001 | 21 | | | | | pg/mL | Linear regression | 0.012 | 0.54
Suzuki, 2002 | 185 | | | | | pg/mL | Univariate/multivariate | 0.0001/0.0095 | 0.370/0.266
Suzuki, 2002 | 185 | | | | | pg/mL | Univariate/multivariate | 0.0159/0.4925 | 0.161/0.067
Bettencourt, 2004 | 84 | | | | | pg/mL | Spearman | <0.001 | -0.41
Dao, 2001 | | 56 | 94 | 86 +/- 39 | 1076 +/- 138 | pg/mL | t-test | <0.001
Nielsen, L.S., 2004 | | 136 | 81 | 2.19 +/- 0.97 | 4.39 +/- 1.31 | pmol/L | t-test | <0.001
Sakatani, 2004 | 30 | | | | | pg/mL | Linear regression | 0.393 | -0.17
Sakatani, 2004 | 40 | | | | | pg/mL | Linear regression | 0.011 | -0.43
Yoshizawa, 2004 | | 26 | 26 | -27 | | pg/mL | t-test | ns
Kyuma, 2004 | 158 | | | | | pg/mL | Linear regression | <0.0001 | 0.33
Suzuki, 2002 | 185 | | | | | pg/mL | Univariate/multivariate | 0.1014 | 0.109
Schnabel, 2005 | 904 | 393 | 511 | 290.4 (127.6/873.2) | 181.8 (86.91/659.6) | pg/mL | Wilcoxon rand sum | <0.001
James, 2003 | | 2067 | | | | ng/L | Multiple linear regression | | | 0.35
Olsen, 2004 | | 16 | 123 | 112.5 +/- 131 | 19.8 +/- 62.0 | pmol/L | Unpaired Student's t-test | < 0.01
Panteghini, 2003 | | 64 | 28 | 119.5 (5–730) | 6 (5–48) | pg/mL | Standard Linear regression | < 0.0001
Lindahl, 2005 | 1352 / 999 | | | 651 (569 to 744) | 414 (381 to 451) | ng/L | Mann-Whitney / Multiple linear mixed effects | < 0.001 / 0.05
Schnabel, 2005 | 904 | | | 301.5 (135.0/714.8) | 218.5 (90.38/727.95) | pg/mL | Wilcoxon rand sum | 0.03
Bazzino, 2004 | 1483 | | | | | pg/mL | Spearman correlation coefficient | 0.01 | 0.3
Bertinchant, 2005 | 63 | | | | | ug/L | Spearman rank correlation | <0.0001 | 0.62
Latini, 2004a | 4284 | | | | | pg/mL | Spearman's coefficient | <0.001 | 0.2216
Latini, 2002 | 4284 | | | | | pg/mL | na | <0.001 | 0.26
Richards, 1998 | 100 | | | | | pmol/L | Pearson product moment | <0.001 | 0.33
Stanek, 2001 | 100 | | | | | fmol/L | Spearman rank-correlation coefficient | <0.05 | 0.2
Tsutamoto, 1997 | 85 | | | | | pg/mL | Linear regression analysis | <0.0001 | 0.67
Jarai, 2005 | 120 | | | | | nmol/L | Spearman rank correlation | <0.0001 | 0.63
Omland, 1996 | 131 | | | | | pmol/L | Linear regression analysis | <0.001 | 0.61
Richards, 1998 | 100 | | | | | pmol/L | Pearson product moment | <0.001 | 0.52
Stanek, 2001 | 100 | | | | | fmol/L | Spearman rank-correlation coefficient | 0.0001 | 0.56
Wang, 2004 | 3346 | | | | | pg/mL | Spearman's coefficient | <0.001 | 0.67
Vasan, 2002 | 1707 | | | | | pg/mL | Spearman correlation coefficient | <0.001 | 0.62
Vasan, 2002 | 1470 | | | | | pg/mL | Spearman correlation coefficient | <0.001 | 0.7
Ueland, 2004 | 234 | | | | | pmol/L | na | <0.0001 | 0.51
Tsutamoto, 1997 | 85 | | | | | pg/mL | Linear regression analysis | 0.47 | 0.0045
Panteghini, 2003 | 64 | | | | | pg/mL | Standard Linear regression | 0.001 | 0.4
Sliwa, 2004 | | 30 | 30 | -45 | | pg/mL | t-test | ns
Olsen, 2004 | | 5 | 123 | 33.3 +/- 98 | 19.8 +/- 62.0 | pmol/L | Unpaired Student's t-test | ns
Latini, 2004a | 4274 | | | | | pg/mL | Spearman's coefficient | <0.001 | -0.192
Lindahl, 2005 | 1352 / 999 | | | 784 (552 to 1113) | 460 (427 to 495) | ng/L | Mann-Whitney | 0.004
Tsutamoto, 1997 | 85 | | | | | pg/mL | Linear regression analysis | <0.0001 | 0.45
Suzuki, 2002 | 185 | | | | | pg/mL | Univariate/multivariate | 0.0007/0.0176 | 0.224/0.231
Fisher, 2003 | 87 | | | | | pg/mL | NA | ns
Akioka, 2000 | 33 | | | | | pg/mL | Linear regression | 0.003 | -0.5
James, 2003 | | 1035 | | | | ng/L | Multiple linear regression | | | 0.099
Tsutamoto, 1997 | 85 | | | | | pg/mL | Linear regression analysis | 0.31 | ns
Schnabel, 2005 | | 592 | 312 | 252.9 (88.31/758.25) | 243.6 (100.7/767.85) | pg/mL | Wilcoxon rank sum | ns
James, 2003 | | 1536 | | | | ng/L | Multiple linear regression | | | 0.069 (CI = -0.001 to 0.14)
Shimpo, 2004 | 448 | | | | | pg/mL | Spearman's coefficient | 0.15 | 0.068
James, 2003 | | 153 | | | | ng/L | Multiple linear regression | | | 0.14
Lindahl, 2005 | 1352 / 999 | | | 651 (587 to 723) | 350 (318 to 385) | ng/L | Mann-Whitney / Multiple linear mixed effects | < 0.001 / 0.05
James, 2003 | 6809 | | | | | ng/L | Multiple linear regression | | | 0.06
Panteghini, 2003 | 64 | | | | | pg/mL | Standard Linear regression | 0.083 | 0.22
Ueda, 2003 | 111 | | | | | pg/mL | Univariate / Multivariate | 0.06/0.69 | -0.18
Grabowski, 2004 | 126 | | | | | pg/mL | Spearman | <0.0001 | 0.39
Jarai, 2005 | 120 | | | | | nmol/L | Spearman rank correlation | 0.246 | 0.1
Dokainish, 2005 | | 454 | 252 | 38 (8/81) | 16 (3/39) | pg/mL | Student t test | <0.0001
Dokainish, 2005 | | 29 | 65 | 19 (3/57) | 15 (0/37) | pg/mL | Student t test | <0.0001
Bayes-Genis, 2004 | 175 | | | | | pmol/L | Spearman's rank correlation | <0.0001 | 0.6
Bazzino, 2004 | 1483 | | | | | pg/mL | Spearman correlation coefficient | 0.01 | 0.23
Bertinchant, 2005 | 63 | | | | | ug/L | Spearman rank correlation | 0.002 | 0.4
Ishii, 2003 | 100 | | | | | ng/L | Linear regression | <0.05 | 0.24
James, 2003 | 6809 | | | | | ng/L | Multiple linear regression | | 0.48 | 0.35
Jernberg, 2003 | 2019 | | | | | ng/L | not found | <0.001 | 0.53
Jernberg, 2002 | | | | | | ng/L | Spearman rank-correlation coefficient | 0.01 | 0.49
Lindahl, 2005 | 1352 / 999 | | | 797 (719 to 883) | 293 (267 to 321) | ng/L | Mann-Whitney / Multiple linear mixed effects | < 0.001 / 0.05
Taniguchi, 2004 | | 20 | 51 | 13260 +/-5035 | 1847 +/-311 | pg/mL | na | <0.001
Krum, 2004 | | 1532 | 1502 | -21.56 | 27.2 | pg/mL | Least squares mean change | <0.00001
Latini, 2002 | | 1940 | 1979 | (-)21 | (+)23 | pg/mL | Least squares mean | <0.0001
Maggioni, 2002 | 123 | | | | | pg/mL | Least squares mean change | 0.005
Krum, 2004 | 1024 | | | | | pg/mL | Least squares mean change | 0.00006
Krum, 2004 | 1278 | | | | | pg/mL | Least squares mean change | 0.00003
Baruch, 2004 | 2112 | | | -36.4 | | pg/mL | Placebo-subtracted least-squares mean difference | <0.001
Baruch, 2004 | 1807 | | | -51.4 | | pg/mL | Placebo-subtracted least-squares mean difference | <0.001
Krum, 2004 | 169 | | | | | pg/mL | Least squares mean change | 0.05
Nielsen, L.S., 2004 | | 12 | 264 | | | pmol/L | t-test | <0.001
James, 2003 | 6809 | | | | | ng/L | Multiple linear regression | | -0.18 | -0.012

Table 2 Evidence Table. Summary of studies in patients with risk of CAD: BNP

Author | Sample Characteristics | Sample Size/Followup | Diagnostic Criteria | Outcomes | Quality: Consecutive Cohort / Outcome Blinding | Analysis/Model | BNP Method/Units | Measure of Association
Bhalla 2004 | Cohort: N/A | 482 | Subjects were either referred by physicians or nurse practitioner for echocardiography for clinical suspicion of cardiac dysfunction (referred group) or randomly selected and recruited from the diabetic clinic (not referred group). In this group of patients, there was no suspicion of cardiac dysfunction, no referrals to cardiologists, and no previous records of echocardiography with abnormalities of LV function (systolic or diastolic). | 1) Cardiac mortality; 2) All-cause mortality | NR/NR | 1) Unadjusted: initial BNP = mortality (referred group); 2) Adjusted (non-referred); 3) Other variables used in regression analyses, but not statistically significant (p<0.05), were gender, type of diabetes, LV function, and ejection fraction | Biosite Diagnostics - Triage | Likelihood ratio in non-referred group at BNP level of 120 pg/ml was 5.66.
USA | Age: Condition 1 mean age = 52 +/- 20 years (referred group) | Followup:; 1) Condition 1 (referred group) :827 +/- 384 days; 2) Condition 2 (non-referred group): 864 +/- 207 days | | | | | Cut-off points: 20, 40, 60, 80, 100, 120 pg/ml
| Condition 2 mean age =61 +/- 12 years (not referred group)
| % Male: 96
Kellett 2004 | Cohort: N/A | 646 | Patients with suspected heart disease who were admitted for acute medical emergencies. Cardiac function was assessed by clinical exam, ECG, and chest X-ray. | In-hospital mortality | Yes/NR | Mortality = systolic blood pressure </= 90 mmHg, hemoglobin level </= 100 g/l, white blood cell count > 13000, being unwell before the current illness, BNP >/= 700 pg/ml | Biosite Diagnostics - Triage | Adjusted odds ratio = 22.0
Ireland | Age: mean age = 73.7 +/- 11.9 (range 19–105) years | Followup:; 1) Until discharge 8.3 +/- 6.9 days; 2) Until death in hospital 12.2 +/- 9.9 days | | | | | 700 pg/ml (200 pg/ml increments from 0 to 1199 pg/ml then >/=1200 pg/ml)
| % Male: 57
Suzuki 2002 | Cohort: N/A | 229 | Hypertensive persons (systolic blood pressure >/= 140 mmHg or diastolic blood pressure >/= 90 mmHg). | Cardiovascular events (angina pectoris, myocardial infarction, arrhythmia, stroke, cardiovascular death, sudden death) | NR/NR | Univariate and multivariate analysis: age; systolic blood pressure; diastolic blood pressure; pulse pressure; left ventricular mass index ; left ventricular relative wall thickness; mid-wall left ventricular fractional shortening ; E/A ratio; ANP; BNP | Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Univariate analysis/Multivariate analysis (risk ratio [95% confidence interval]): BNP 1.015 (1.009–1.021)/1.011 (1.004–1.017)
Japan | Age: mean age = 66 +/- 11 years | Followup: 34.6 months | | | | | Cut-off point: 68pg/ml
| % Male: 50
Ueda 2003 | Cohort: N/A | 111 | Electrocardiographic abnormalities (presence of left bundle branch block, major Q waves according to the Minnesota code [Q111–Q128]; ST-J depression of 1mm or more or negative T waves in leads II, V2 to V6, AVL, and AVF; voltage criteria for left ventricular hypertrophy; or arrhythmias). Also, patients who had a clinical history of stroke or ischemic heart disease (without hospitalization) | 1) Cardiac event; 2) Death | NR/NR | Cox regression: plasma BNP = cardiac events, total mortality. | Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Plasma BNP was significantly associated with cardiac events and total mortality. Each 50-pg/mL increase in plasma BNP concentration increased the rate of cardiac events by 1.6-fold, i.e, hazard ratio 1.6 (95% confidence interval: 1.2–2.1) and the rate of total mortality by 1.4-fold, i.e., hazard ratio 1.4 (1.2–1.6).
Japan | Age: mean age = 85.5 +/- 5.2 years | Followup: 2 years | | | | Linear regression: plasma BNP = age, sex, body mass index, blood pressure, heart rate, serum total protein, serum creatinine, hemoglobin A1C, serum total cholesterol, ADL score. | 1) Cut-off point # 1: > 60 pg/ml (Kaplan-Meier); 2) Cut-off point # 2: >= 100 pg/ml (Cox regression) | Compared with subjects who had a normal BNP concentration (<18.4 pg/mL), those with BNP levels >=100pg/mL had a 2.1-fold (1.3–3.4) greater rate of cardiac events and a 1.6-fold (1.3–2.1) greater mortality
| % Male: 21 | | | | | | | .
Wang 2004 | Cohort: Framingham Offspring Study | 3346 | Readers are referred to another publication on the Framingham Study to obtain information on diagnostic criteria for cardiovascular events. | 1) Death; 2) Major cardiovascular events (myocardial infarction, coronary insufficiency,death from coronary heart disease, heart failure, stroke) | NR/Yes | Cox proportional hazards model | Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Adjusted Hazard Ratio per 1 SD Increment in Log BNP Values (95% confidence interval):
USA | Age: Condition 1 mean age = 59 +/- 10 years | Followup: 5.2 years | | | | | 1) 20.0 pg/ml (men); 2) 23.3 pg/ml (women) | 1) Death: 1.27 (1.06–1.52); 2) First major cardiovascular event: 1.28 (1.03–1.59); 3) Heart failure: 1.77 (1.31–2.41); 4) Atrial fibrillation: 1.66 (1.30–2.11); 5) Stroke or transient ischemic attack: 1.53 (1.16–2.02); 6) Coronary heart disease events: 1.10 (0.89–1.37)
| Condition 2 mean age = 58 +/- 10 years | | | | | | | Adjusted Hazard Ratio for BNP Values above 80th Percentile (95% confidence interval):
| % Male: 47 | | | | | | | 1) Death: 1.62 (1.08–2.42); 2) First major cardiovascular event: 1.76 (1.06–2.92); 3) Heart failure: 3.07 (1.51–6.26); 4) Atrial fibrillation: 1.91 (1.13–3.25); 5) Stroke or transient ischemic attack: 1.99 (1.09–3.62); 6) Coronary heart disease events: 1.30 (0.79–2.15)
Nagao 2004 | Cohort: N/A | 401 | Cardiac arrest prior to the arrival of emergency, with presumed cardiac origin of the arrest according to the Utstein Style. | Survival to hospital discharge | NR/NR | Survival to hospital discharge = cardiac arrest, age, gender, CPR, call-response interval, initial cardiac rhythm, ROSC | Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Adjusted odds ratios with condition 1 as reference group:
Japan | Age: Condition 1 mean age = 61.5 +/- 12.9 years | Followup: Until discharge (specific length of time not provided) | | | | | 1) Cut-off point: 100 pg/ml.; 2) Analysis based on quartiles of BNP: 2.0–33.8 pg/ml (condition 1); 33.9–152.0 pg/ml (condition 2); 152.1–392.0 pg/ml (condition 3); 392.1–2620.0 pg/ml (condition 4). | versus condition 2 = 0.13 (95% confidence interval: 0.04–0.46;
| Condition 2 mean age = 63.4 +/- 10.2 years | | | | | | | versus condition 3 = 0.10 (0.03–0.41);
| Condition 3age range = 64.9 +/- 13.4 years | | | | | | | versus condition 4 = 0.004 (0.00–0.16)
| Condition 4 age range = 65.4 +/- 10.6 years
| % Male: 80

Abbreviations: N/A=not applicable, NR=not reported, ADL=activities of daily living, LV=left ventricular, ECG=electrocardiograph, E/A=early/atrial, ANP=atrial natriuretic peptide, IRMA=immunoradiometric assay, SD=standard deviation, CPR=cardiopulmonary resuscitation, ROSC=return of spontaneous circulation

Table 3 Evidence Table: Summary of studies in patients with risk of CAD: NT-proBNP

Author | Sample Characteristics | Sample Size/Followup | Diagnosis criteria | Outcomes | Quality: Consecutive Cohort / Outcome Blinding | Analysis/Model | BNP Method/Units | Measure of Association
Gaede 2005 | Cohort: Steno-2 | 160 | Diabetic patients between 40–65 years of age. | Combined mortality endpoint for cardiovascular disease: cardiovascular mortality, nonfatal myocardial infarction, nonfatal stroke, percutaneous coronary interventions, coronary artery bypass graft, vascular surgery, amputations | NR/Yes | Model 1: CVD = diabetes duration, CVD, sex, age | Roche Diagnostics - Elecsys 1010, Elecsys 2010, E170 or Modular | Unadjusted hazard ratio: 4.4 (95% confidence interval: 2.3–8.4).
Denmark | study Age: mean age = 55.1 | Followup: 7.8 years | | | | Model 2: CVD = diabetes duration, CVD, sex, age, systolic blood pressure, diastolic blood pressure, HbA1c, fasting serum levels of total cholesterol, HDL cholesterol, LDL cholesterol, triglycerides, urinary AER | Cut-off point: 33.5 pg/ml | Unadjusted hazard ratio: (42 patients whose BNP did not reach below the median in the first 2 years) 0.45 (0.12–1.65).
| % Male: 74 | | | | | | | Adjusted hazard ratio (model 1): 3.3 (1.7–6.5)
| | | | | | | | Adjusted hazard ratio (model 2): 3.6 (1.7–7.5)
Jernberg 2002 | Cohort: N/A | 775 | History of chest pain or other symptoms suggestive of an acute coronary syndrome. | Death | Yes/NR | Model 1: death = age, diabetes, ECG changes, elevated cTnT, P-creatinine | Roche Diagnostics - Elecsys 1010, Elecsys 2010, E170 or Modular | Compared to condition 1 - adjusted rate ratios and 95% confidence intervals:
Sweden | Age: Condition 1 mean age 55 (range 48–64) years | Followup: Median 40 months (range 35 to 47 months) | | | | Model 2: death = BNP, age, diabetes, ECG changes, elevated cTnT, P-creatinine | Condition 1: </= 112 ng/l; | Condition 2: 1.85 (0.67–5.08)
| Condition 2 mean age 70 (range 59–76) years | | | | | | condition 2: 113–400 ng/l; | Condition 3: 2.96 (1.12–7.81)
| Condition 3 mean age 75 (range 68–80) years | | | | | | condition 3: 401–1653 ng/l; | Condition 4: 5.40 (2.02–14.4)
| Condition 4 mean age 77 (range 70–83) years | | | | | | condition 4: >/= 1654 ng/l
| % Male: 60
Olsen 2004 | Cohort: Losartan Intervention for Endpoint Reduction in Hypertension (LIFE) study | 183 | Electrocardiographic LV hypertrophy by the Cornell voltage-duration product or the Sokolow-Lyon voltage criterion | Composite endpoint: cardiovascular death, fatal/non-fatal myocardial infarction, fatal/non-fatal stroke | NR/Yes | Composite endpoint = NT-proBNP, NT-proANP, cardiovascular risk, LV midwall fractional shortening, body weight, smoking, age, LV mass | Roche Diagnostics - Elecsys 1010, Elecsys 2010, E170 or Modular | NT-proBNP > 21.8 pmol/l for incidence of composite endpoint (vs </= 21.8 pmol/l): unadjusted hazard ratio = 2.8 (1.19–5.70)
USA, Denmark, Norway | Age: Condition 1 mean age 66 +/- 7 years | Followup: 60 +/- 5 months (range 54 to 68 months) | | | | | Cut-off point: 21.8 pmol/l
| Condition 2 mean age 70 +/- 6 years
| % Male: 64
Tarnow 2005 | Cohort: N/A | 386 | Diabetic nephropathy: persistent macroalbuminuria (>300 mg 24 h) in at least two out of three consecutive 24-h urine collections, in the presence of diabetic retinopathy and the absence other kidney or urinary tract disease were recruited | All-cause mortality | Yes/NR | Mortality = BNP, smoking, antihypertensive medication, systolic blood pressure, serum cholesterol | Roche Diagnostics - Elecsys 1010, Elecsys 2010, E170 or Modular | NT-proBNP cutoff 125 pg/ml - adjusted hazard ratios and 95% confidence intervals:
Denmark | Age: Condition 1 (nephropathy) mean age 41 +/- 9.5 years | Followup: 9.3 years (range 0 to 9.5 years) | | | | | Cut-off point: 125 pg/l | All-cause mortality: 2.68 (1.24–5.79) CV death: 4.09 (1.61–10.41)
| Condition 2 (normoalbuminuria) mean age 42.5 +/-9.9 years | | | | | | | For each 10 fold increase in BNP as a continuous variable - adjusted hazard ratios and 95% confidence intervals:
| % Male: 61 | | | | | | | All-cause: 2.67 (1.62–4.42)
| | | | | | | | CV death: 3.32 (1.90–5.81)
Weber 2004 | Cohort: N/A | 209 | Degenerative aortic stenosis >/= 12 months. Aortic stenotic severity was assessed by the mean transvalvular pressure gradient obtained echocardiographically. | Severity of aortic stenosis | NR/Yes | Severity of aortic stenosis = NT-proBNP, NYHA class, left ventricular mass index, body mass index, ejection fraction (data in published report provided only for NT-proBNP and NYHA class) | Roche Diagnostics - Elecsys 1010, Elecsys 2010, E170 or Modular | Chi-square, p-values only
Germany | Age: 60 (range 46–75) years | Followup: N/A (cross-sectional) | | | | | Cut-off point: 550 pg/ml
| % Male: 55
Nielsen 2004 | Cohort: Copenhagen Hospital Heart Failure Study | 2224 | No obvious heart disease: sinus rhythm, LV ejection fraction > 0.55, no valvular heart disease or dilated or congenital heart disease at referral | Major adverse cardiac events (MACEs): as LV ejection fraction < 0.35, valvular heart disease, pulmonary congestion on the chest X-ray at the time of admission or development of one of the following incidents during a 90 day follow up period: symptoms of heart failure, myocardial infarction, valvular disease, sudden death or cardiac death. | Yes/Yes | N/A | Roche Diagnostics - Elecsys 1010, Elecsys 2010, E170 or Modular | No regression analysis
Denmark | Age range 40–75 years | Followup: 1 year | | | | | Cut-off points: 40–59 years = 43.5 pmol/l; 60–74 years = 99 pmol/l; >/= 75 years = 250 pmol/l
| % Male: not reported

Abbreviations: NR=not reported, N/A=not applicable, CVD=cardiovascular disease, HDL=high density lipoprotein, LDL=low density liporotein, AER=albumin excretion rate, ECG=electrocardiograph, cTnT=cardiac tropinin T, LV=left ventricular, CV=cardiovascular, NYHA=New York Heart Association

Table 4 Evidence Table. Summary of studies in patients with CAD with surgery: BNP

Study | Sample Characteristics | Sample Size/Followup | Diagnostic criteria | Outcomes | Consecutive Cohort / Outcome Blinding | Analysis/Model | BNP Method/Units | Measure of Association
Grabowski 2004 | Mean age: 58.8 +/- 10.7 | 126 | Admission with acute STEMI, | All-cause mortality | Yes/Yes | Simple and stepwise multiple logistic regression | Biosite Diagnostics - Triage | BNP > 100 pg/mL:
Poland | % Male: 45% | Followup: 42 days | Clinical symptoms of ACS, or ST elevation >= 1 mm on at least 2 ECG at admission. | | | | Threshold: 100 pg/mL | Unadj OR = 10.3(1.3–84.2)
| | | | | | | | Adj OR = 16.3(1.4–186.7)
Jiang 2004 | Condition 1 - mean age: 52.8 +/- 9.8 | 949 completed followup (960 enrolled) | Current chest pain and unstable angina developed within 24 hours of admission. Patients with acute MI and at least 2 of the following: a) persistent chest pain over 20 minutes, b) elevation of ST segment in at least 2 related leads or developed a branch bundle blockade, c) new abnormal regional wall movement on Echocardiogram, d) elevation of biomarker of myocardium. | 1) Mortality (1 and 6 months); 2) Heart failure; 3) Acute MI; 4) ACS; 5) Death (all cause/ 6 months); 6) Acute MI (newly developed) | Yes/NR | 1x1 variable comparisons using chi-square test Multiple logistic Regression (forward selection) | Biosite Diagnostics - Triage | Appears that only delayed PCI was statistically significant for BNP > 80 pg/ml:
China, Saudi Arabia | Condition 2 - mean age: 51.8 +/- 9.9 | Followup: 1 and 6 months | | | | | Threshold: 80 pg/mL | Unadjusted odds ratio = 2.94 (95% confidence interval = 1.17–7.42) for mortality at 6 months.
| % Male: 83% | | | | | | | Early PCI group at 1 month --> Unadjusted odds ratio = 3.53 (1.35–9.21)
| | | | | | | | Early PCI group at 6 month --> Unadjusted odds ratio = 2.96 (1.31–6.66)
Wiviott 2004 | TACTICS-TIMI 18 | 1,865 | Accelerated or prolonged angina, eligibility for PCI, and the presence of at least 1 objective marker of ischemia. | Combined incidence of death, myocardial infarction (MI), and rehospitalization for acute coronary syndrome (ACS) | NR/NR | Multiple logistic regression controlling for differences between genders | Biosite Diagnostics - Triage | BNP for 6 month mortality (including interaction between gender and BNP): odds ratio = 2.1 (95% confidence interval = 0.64–7.20).
USA | Condition 1 mean age 60.2 | Followup: 6 months | | | | | Threshold: 80 mg/dl | For death or MI: odds ratio = 1.6 (0.70–3.8).
| Condition 2 mean age 64.5,
| % Male: 66%
Morrow 2003 | Condition 1 - mean age: 60 | 1,676 | The index diagnosis was established by the investigator based on local electrocardiographic and laboratory data. | 1) All cause death; 2) New or recurrent MI; 3) Rehospitalization for acute coronary syndrome (ACS); 4) New or worsening congested heart failure | NR/Yes | Simple logistic regression | Biosite Diagnostics - Triage | For 6 month mortality:
USA | Condition 2 - mean age: 69 | Followup: 6 months | | | | | BNP dichotomized > 80 pg/ml based on previous literature. | Unadjusted odds ratio for BNP > 80 pg/ml = 3.7
| % Male: 62.7% | | | | | | | Adjusted odds ratio = 3.3 (95% confidence interval = 1.7 to 6.3)
Takase 2004 | Mean age: 67+/- 1, | 77 | Positive results on an exercise myocardial single-photon-emission computed tomography scan using 99m technetium-sestamibi, 99m technetium-tetrofosmin, or 201 thallium-chloride, and had an angiographically significant coronary stenosis (75% stenosis of coronary artery). | Recurrence of anginal attacks. | Yes/NR | Simple Cox proportional hazards | Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | The crude hazard ratio of incident anginal recurrence in patients with higher levels of BNP was 41.119 (95% confidence interval = 7.833–215.847).
Japan | % Male: 70% | Followup: 25.9 ± 1.4 months | | | | | Threshold: 68 pg/ml

Abbreviations: STEMI=ST-elevation myocardial infarction, ACS=acute coronary syndrome, ECG=electrocardiograph, UnAdj=unadjusted, Adj=adjusted, OR=odds ratio, MI=myocardial infarction, PCI=percutaneous coronary intervention, TIMI=thrombolysis in myocardial infarction, NR=not reported

Table 5 Evidence Table. Summary of studies in patients with CAD no surgery: BNP

Author | Sample Characteristics | Sample Size/ Followup | Diagnostic Criteria | Outcomes | Consecutive Cohort / Outcome Blinding | Analysis/Model | BNP Method/Units | Measure of Association
Mega 2004 | Age range: 21–75 years | 438 | ST segment elevation myocardial infarction | Mortality | NR/NR | Fisher's exact test and Chi Square test for simple comparisons between variables. Logistic regression | Bayer Healthcare - ADVIA Centaur | Adjusted odds ratio = 7.2 (95% confidence interval = 2.1–24.5)
USA | % Male: 77 | Followup: 30 days from angioplasty | | | | | Threshold: 80 pg/mL | No history of CHF: Adjusted odds ratio = 8.2, (2.3-to 28.4)
| | | | | | | | The prognostic association between BNP and mortality was even stronger using a cut-point of 40 pg/mL: Adjusted odds ratio = 15.9 (3.1–81).
Omland 1996 | Mean age: 67.8 | 131 | Unspecified | Mortality | NR/Yes | Simple and multiple Cox proportional hazards regression | Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Unadjusted odds ratio = 2.53 (2.14–2.92)
Scandanavia | % Male: 74.8 | Followup: Median = 1293 days | | | | | Threshold: 115.22 pg/mL | Adjusted odds ratio = 1.99 (1.56–2.42)
Wylie 2004 | No data reported in the publication - readers are referred to another reference. | 1124 | Ischemic discomfort at rest lasting >/= 5 minutes and associated with >/=1 of these features: new ST segment deviation >/= 0.5 mm, T-wave inversion >/= 3 mm in 3 leads or left bundle branch block, positive cardiac markers, or documented coronary artery disease. | Development of CHF or cardiogenic shock | NR/Yes | Backward selection logistic regression | Biosite Diagnostics - Triage | Adjusted odds ratio (30 days) = 1.85 (1.04–3.28)
USA | | Followup: periods at 30 days, 10 months | | | | | Threshold: 80 pg/mL | Adjusted odds ratio (10 months) = 3.03 (1.25–7.35)
Sabatine 2002 | No data reported in the publication - readers are referred to another reference. | 450 patients from OPUS-TIMI-16 trial | Non-ST elevation acute coronary syndromes (OPUS-TIMI-16) | 1) All cause mortality; 2) Non-fatal MI; 3) Development of congestive heart failure; 4) Composite of 1–3 | NR/NR | Multiple Cox proportional hazards regression | Biosite Diagnostics - Triage | For OPUS-TIMI 16 subjects at 10 months followup: Adjusted hazard ratio = 2.1, (p = 0.001) for composite endpoint (death, MI or CHF)
USA | | 1635 patients from TACTICS-TIMI 18 trial (as part of validation cohort) | | | | | Threshold: 80 pg/mL | For TACTIS-TIMI 18 through 6 months: BNP (OR 1.6, p = 0.019) for same endpoint
| | Followup: periods at 6 months, 10 months
Bettencourt 2000 | Mean age: 58.3 +/- 12.6 | 101 | Admission to cardiac unit with acute myocardial infarction as defined by the presence of typical cardiac ischemic symptoms, presence of ischemic changes on ECG in two or more leads, and peak elevation of plasma creatinine kinase to at least level twice of normal. | 1) Left ventricular dysfunction; 2) Heart failure; 3) Ischemia event | Yes/NR | Likelihood ratio-based forward stepwise logistic regression analysis | Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Adjusted odds ratio for outcome of left ventricular systolic dysfunction = 1.01 (p < 0.0001)Adjusted odds ratio for left ventricular dysfunction (systolic or isolated dyastolic) = 1.01 (p = 0.0002)
Portugal | % Male: 84.2 | Followup: 12 months | | | | | Threshold values: 142.3 pg/mL for systolic dysfunction; 93.8 pg/mL for isolated diastolic dysfunction or systolic dysfunction; 259.1 pg/mL for heart failure; 380.5 pg/mL for death.

Abbreviations: NR=not reported ADVIA= CHF=congestive heart failure, IRMA= immuno radiometric assay, OPUS=Orbofiban in Patients with Unstable Coronary Syndromes, TIMI= thrombolysis in myocardial infarction, MI=myocardial infarction, ECG=electrocardiograph

Table 6 Evidence Table: Summary of studies in patients with CAD not surgery: BNP

Study | Sample Characteristics | Sample Size /Followup | Diagnostic criteria | Outcomes | Consecutive Cohort / Outcome Blinding | Analysis/Model | BNP Method/Units | Measure of Association
de Winter 2004 | Condition 1-mean age: 68 +/- 10 years | 1172 | Consecutive patients undergoing PTCA | 1) Death; 2) Myocardial infarction | Yes/NR | Simple logisitic regression (highest quartile as decision threshold for increased NT proBNP), Stepwise multiple logistic regression, Cox survival analysis | Roche Diagnostics - Elecsys 1010, Elecsys 2010, E170 or Modular | Mortality or myocardial infarction: unadjusted odds ratio = 7.06 (95% confidence interval 3.30–15.08)
Netherlands | Condition 2-mean age: 60 +/- 11 years | Followup: 12 to 14 months | | | | | Threshold: 456 pg/mL | Mortality: unadjusted odds ratio = 13.47 (4.50–40.48)
| % Male: 70 | | | | | | | Myocardial infarction: unadjusted odds ratio = 2.53 (0.77–8.34)
| | | | | | | | Event-free survival: adjusted odds ratio = 4.96 (2.25–10.94)
Galvani 2004 | Condition 1 - mean age: 59 +/- 11 years | 1726 | Rest anginal pain lasting more than 10 minutes and occurring within 24 hours of admission to coronary care unit (angina was associated with ischemic ECG changes) | Mortality at 30 days | NR/NR | Simple and multiple logistic regression for 30 day mortality | Roche Diagnostics - Elecsys 1010, Elecsys 2010, E170 or | First quartile is reference category for predicting odds of 30 day mortality:
Italy | Condition 2 - mean age: 65 +/- 11 years | Followup: 30 days | | | | | Threshold: Modular/Quartiles: </= 107 pg/mL, 108–353 pg/mL, 354–1357 pg/mL, >/= 1358 pg/mL | 2nd quartile:
| % Male: 71 | | | | | | | Unadjusted odds ratio = 2.94 (1.15–7.52)
| | | | | | | | Adjusted odds ratio = 1.33 (0.79–2.24)
| | | | | | | | 3rd Quartile:
| | | | | | | | Unadjusted odds ratio = 5.32 (2.19–12.91)
| | | | | | | | Adjusted odds ratio = 1.89 (1.00–3.58)
| | | | | | | | 4th quartile:
| | | | | | | | Unadjusted odds ratio = 11.5 (4.90–26.87)
| | | | | | | | Adjusted odds ratio = 3.91 (1.51–10.13)
Bazzino 2004 | Mean age: 66+/- 12 years | 1483 | Resting chest pain within 24 hours of admission to coronary care unit | 1) Combined endpoint of mortality or or non-fatal MI.; 2) All cause mortality (in hospital and 180 day).; 3) New non-fatal myocardial infarction (MI). | Yes/Yes | Stepwise multiple logistic regression | Roche Diagnostics - Elecsys 1010, Elecsys 2010, E170 or Modular | For 180 day mortality, the strongest independent predictor after adjusting for cardiac markers (treated as categorical) was NT-proBNP: adjusted odds ratio = 3.42 (1.95–5.98).
Argentina | % Male: 63.6 | Followup: From hospital admission to 180 days or death (which came first) | | | | | Threshold: 586 pg/mL | After forward stepwise logistic regression, NT-proBNP remained in the model:
| | | | | | | | For 180 day mortality, adjusted odds ratio = 1.67 (1.41–1.99)
| | | | | | | | For 180 day mortlaity or new myocardial infarction, adjusted odds ratio = 1.43 (1.24–1.64)
| | | | | | | | For in-hospital mortality, adjusted odds ratio = 1.70 (1.31–2.20)
James 2003 | Mean age: 65 +/- 11 years | 6809 | One or more episodes of angina lasting >/= 5 minutes, within 24 hours of admission, | 1) Myocardial Infarction; 2) Mortality: 30 day and 12 month | NR/Yes | Multiple logistic regression | Roche Diagnostics - Elecsys 1010, Elecsys 2010, E170 or Modular | For the outcome of myocardial infarction at 30 days, the confidence intervals for all four quartiles overlap the null value of 1.00, thereby indicating that the adjusted odds ratios (depicted graphically) are not statistically significant at the 5% level.
Sweden | % Male: 61.9 | Followup:; 1) 30 days; 2) 12 months | and either a positive cardiac troponin test or >/= 0.5 mm of ST-segment depression | | | | Threshold: Quartiles: <= 237 pg/mL, 238–668 pg/mL, 669–1869 pg/mL, >1869 pg/mL | For mortality at 1 year, the adjusted odds ratios range from approximately 1.4 to 3.2 (depicted graphically). The odds ratios are statistically significant at the 5% level.
Richards 2003 | Mean age: 62.4 +/- 10.4 (range 26–80) years | 666 | Myocardial infarction: ischemic change (including ST elevation or depression or dynamic T-wave changes; i.e., includes ST-elevation, non-ST elevation, Q-wave, and non-Q-wave infarcts) in 2 or more ECG leads and peak elevation of plasma creatinine kinase to at least twice the upper limit of normal. | 1) Mortality; 2) Re-admission to hospital with heart failure; 3) New Myocardial Infarction; 4) All recurrent acute coronary syndromes (ACS) | NR/NR | Stepwise Cox proportional hazards regression | [NT-proBNP] New Zealand (Christchurch)-no instrument, manual assay | Death: adjusted rate ratio = 6.63 (3.72–11.79); interaction between N-BNP and ejection fraction < 40%: adjusted rate ratio = 3.26 (2.04–5.22)
New Zealand | % Male: 78.2 | Followup:3 years (mean) | | | | | Threshold: 1370 pg/mL | Death or heart failure: adjusted rate ratio = 2.70 (1.65–4.41)
| | | | | | | | Reinfarction: adjusted rate ratio = 3.51 (1.08–11.50); interaction between N-BNP and ejection fraction < 40%: adjusted rate ratio = 3.81 (1.01–13.52)
| | | | | | | | Death, heart failure, or reinfarction: adjsuted rate ratio = 2.27 (1.54–3.33); interaction between N-BNP and ejection fraction < 40%: adjusted rate ratio = 1.59 (1.12–2.27)
| | | | | | | | Death, heart failure, or acute coronary syndromes: adjusted rate ratio = 2.10 (1.57–2.83); interaction between N-BNP and ejection fraction < 40%: adjusted rate ratio = 1.57 (1.17–2.10)
Omland 2002 | Condition 1 - mean age: 62 | 609 | Clinical diagnosis not specified | All-cause mortality | Yes/NR | Multiple Cox proportional hazards regression | Manual method referencing - Carl J., Borgya A., Gallusser A. et al. Development of a novel, N-terminal-proBNP (NT-proBNP) assay with a low detection limit. Scand J Clin Lab Invest Suppl 1999; 230:177–81 | Unadjusted rate ratio = 3.9 (2.4–6.5)
Sweden | Condition 2 - mean age: 69 | Followup:Median: 51 months (range 19–72 months) | | | | | Threshold: 4609 pg/mL | Adjusted rate ratio = 2.1 (1.1–3.9) (after adjustment for age and ejection fraction, rate ratio = 2.4 [1.1–5.4])
| % Male (NT-proBNP <=545 pmol/L): 73
| % Male (NT-proBNP <545 pmol/L): 70

Abbreviations: PTCA= NR=not reported, ECG=electrocardiogram, MI=myocardial infarction, PCTA=percutaneous transluminal coronary angioplasty

Table 7 Evidence Table: Summary of studies in patients with CAD no surgery: NT-proBNP

Author | Sample Characteristics | Sample Size /Followup | Diagnostic criteria | Outcomes | Consecutive Cohort / Outcome Blinding | Analysis /Model | BNP Method /Units | Measure of Association
Squire 2004 | Mean age: 65 (range 32–95) years | 403 | AMI was defined as presentation with at least two of three standard criteria, i.e. appropriate symptoms, acute ECG changes of infarction (ST elevation, new left bundle branch block) and a rise in creatine kinase to at least twice the upper limit of normal, i.e. > 400 international units/(200 nmol) in 0.1 mol/l phosphate buffer, and the tracer purified on reversed-phase HPLC. | 1) Mortality <30 days; 2) Mortality > 30 days | Yes/NR | ANOVA, Cox proportional hazards (multiple), logisitic regression (multiple), Kaplan-Meier curves | Manual method referencing - Carl J., Borgya A., Gallusser A. et al. Development of a novel, N-terminal-proBNP (NT-proBNP) assay with a low detection limit. Scand J Clin Lab Invest Suppl 1999; 230:177–81 | Adjusted odds ratio = 5.5 (95% confidence interval = 2.2–13.5) for predicting hospitalization due to HF.
U.K. | % Male: 75 | Followup: Median = 462 (range 5–764) days | Acute MI pateints who presented with 2 or 3 criteria (i.e. appropriate symptoms, acute ECG changes [ST elevation, new left bundle branch block]) and a rise in creatine kinase to at least twice the upper limit of normal, i.e. >400 international units/l. | | | | Threshold: 7324 pg/mL | Adjusted odds ratio = 3.2 (1.7–6.2) for predicting outpaitent HF episodes.
| | | | | | | | Adjusted hazard ratio = 4.2 (2.1–8.4) for all cause mortality.
| | | | | | | | Adjusted odds ratio = 8.76 (2.48–30.90) for all-cause mortaliy < 30 days.
Jernberg 2003 | Age range: 40–84 years | 2019 | Myocardial ischemia had to be verified by an electrocardiogram (ST-segment depression =>0.10 mV or T-wave inversion =>0.10 mV) or by raised biochemical markers. | 1) Mortality; 2) Myocaridal infarction | NR/NR | Multiple logistic regression and multiple Cox proportional hazards | Roche Diagnostics - Elecsys 1010, Elecsys 2010, E170 or Modular | Adjusted rate ratio = 3.76 (1.95–7.25)
Sweden | % Male: Not reported | Followup:</= 2 years | | | | | Threshold: 535 pg/mL (men)
| | | | | | | 672 pg/mL (women)
Palmer 2003 | Mean age: 62.1 years | 978 | The presence of typical cardiac ischemic symptoms, ischemic change on the electrocardiogram in two or more contiguous leads, and peak elevation of plasma creatine kinase to at least twice normal (400 U/l). All patients were troponin T positive. | Mortality post-myocardial infarction | NR/Yes | Multiple Cox proportional hazards | New Zealand (Christchurch) - no instrument, manual assay | Nt-proBNP interacts with angiotensin-converting enzyme: adjusted hazard ratio = 1.01 (1.00–1.02)
New Zealand | % Male: 78 | Followup: Median = 2.4 (range 2–2119) days | | | | | Threshold: 186 pg/mL
Richards 1998 | Mean age:64 +/-10years | Control: 35 normal subjects not matched for age. | Acute myocardial infarction was defined by the presence of typical cardiac ischemic symptoms, the presence of ischemic changes on the ECG in two or more ECG leads, and peak elevation of plasma creatine kinase to at least twice normal (400 U/L). | 1) All-cause mortality; 2) Left ventricular ejection | Yes/NR | Multiple logistic regression | New Zealand (Christchurch) - no instrument, manual assay | Mortality: 254 pg/mL adjusted odds ratio = 5.9 (1.8–19.0) 1032 pg/mL adjusted odds ratio = 19.7 (2.7–142.0), p < 0.001 (20 deaths above the median and 1 death below the median)
New Zealand | % Male: 74 | Treatment: 121 patients with acute myocardial infarction. | | | | | Threshold: 254 pg/mL for death 1032 pg/mL for left ventricular failure | Left ventricular failure: 254 pg/ml = 5.5 (2.3–13.3) 1032 pg/mL adjusted odds ratio = 5.5 (2.3–13.3)
| | Followup: 24 months
Darbar 1996 | Mean age: 63.0 years | 75 | Patients were assessed by clinical, echocardiographic, and neurohormonal methods to identify left ventricular | 1) Cardiovascular death; 2) Development of symptomatic heart failure | NR/Yes | Stepwise logistic regression | New Zealand (Christchurch) -no instrument, manual assay | The estimated odds ratio for each 10 pmol/L increase in BNP concentrations was 7.33 (1.9–10.1).
USA | % Male: 70.7 | Followup: Median: 19.7 (range 14–31) months | dysfunction. | | | | Threshold: 169 pg/mL
Jarai 2005 | Mean age: 63 +/-13 years | 120 | Typical angina symptoms within the last 24 hours and signs of myocardial ischaemia in the 12 lead ECG (ST-depression of 0.1 mV in two continuous leads, T-wave inversion or both with concomitantly elevated TnI [>0.15 ng/mL] levels were diagnosed as non-ST-elevation myocardial infarction). Patients without TnI elevations were diagnosed with unstable angina. | Cardiovacular death | Yes/NR | Multiple logistic regression | Biomedica Grupe - No instrument, EIA (manual assay) | Adjusted odds ratio = 4.8 (2.84–6.76)
Austria | % Male: Not reported | Followup: 2 years | | | | | Threshold: 2791 pg/mL (upper limit or normal range)
Latini 2004 | Mean age: 31.9 | 724 | Clinical persistent ST-segment elevation, maximal CK value exceeding 2X upper limit of reference range during the first hours after the index event. | 1) All-cause mortality; 2) Episodes of heart failure; 3) Cardio residual ischemia; 4) Combined death and heart failure | NR/Yes | Multiple logistic regression | Roche Diagnostics-Elecsys 1010, Elecsys 2010, E170 or Modular | Not clearly reported in text.
Italy | % Male: 69 | Followup: 3 months | | | | | Threshold: 1300 pg/mL
James 2004 | Mean age: 65 | 1381 | 1 or more episodes of angina > 5 min and ST-depression > 5mm or Troponin or I test elevation. | 1) Mortality at 12 months; 2) Myocardial infarction; 3) Death or MI | NR/Yes | Multiple logistic regression | Roche Diagnostics-Elecsys 1010, Elecsys 2010, E170 or Modular | Graphical depiction of odds ratios shows that all odds ratios for myocardial infarction were not statistically significant at the 5% level. Graphical depiction shows that odds ratios for 3rd and 4th quartiles of NT-proBNP were statistically significant at the 5% level.
Europe, North America | % Male: 62 | Followup: 12 months | | | | | Threshold: Quartiles: <237 pg/mL, 237–669 pg/mL, 669–1869 pg/mL, and >1869 pg/mL
Ueland 2004 | Condition 1 - mean age: 63 +/- 8 years (osteoprotegerin<2.1) | Control: 15 age and gender matched healthy controls | Left ventricular dysfunction (i.e., left ventricular ejection fraction [LVEF] <35% or a left ventricular end-diastolic dimension >65 mm) and/or HF during the acute phase as suggested by one or more of the following: treatment with diuretic or intravenous vasodilator therapy for HF, pulmonary rales, third heart sound, persistent sinus tachycardia (=/> 100 beats/min), or radiographic evidence of pulmonary congestion. | 1) Non-fatal myocardial infarction; 2) Cardiovascular death; 3) Total mortality death | NR/NR | Simple Cox proportional hazards | Manual method referencing - Carl J., Borgya A., Gallusser A. et al. Development of a novel, N-terminal-proBNP (NT-proBNP) assay with a low detection limit. Scand J Clin Lab Invest Suppl 1999; 230:177–81/ | All cause mortality: unadjusted rate ratio = 2.1 (1.0–4.4)
U.K. | Condition 2 - mean age: 67 +/- 10 years (OPG<3.0) | Treatment: 234 patients with acute myocardial infarction complicated by heart failure | | | | | Threshold: 0537 pg/mL | Cardiovascular death: unadjusted rate ratio = 2.2 (1.0–5.0)
| Condition 3 - mean age: 69 +/- 10 years (OPG<4.1) | Followup: Median 2.7 years | | | | | | Composite end point (all events combined): unadjusted rate ratio = 1.4 (0.8–2.6)
| Condition 4 - mean age: 72 +/- 11 years (OPG>4.1)
| % Male: 70.2
Schnabel 2005 | Condition 1 - mean age: 60.7 +/- 9.7 years | 904 | Under coronary angiography: at least one stenosis >30% diagnosed in a major coronary artery, unstable angina classified by Braunwald classification (class B or C), acute myocardial infarction (ST-segment elevation in at least two corresponding leads plus troponin elevation - | Cardiovascular events | NR/NR | Multiple Cox proportional hazards | Roche Diagnostics - Elecsys 1010, Elecsys 2010, E170 or Modular | In patients with stable angina: quartile 1 (<86.7 pg/ml) adjusted hazard ratio=1.0 n=144 quartile 2 (86.7–192.0 pg/ml) adjusted hazard ratio=1.18, (0.30–4.58) quartile 3 (192.0–487.9 pg/ml) adjusted hazard ratio = 1.51 (0.40–5.64)quartile 4 (>487.9 pg/ml) adjusted hazard ratio = 3.96 (1.13–13.9). Hazard ratios according to quartiles of baseline NT-proBNP in patients with ACS: quartile 1 (<160.8 pg/ml) adjusted hazard ratio = 1.0 quartile 2 (160.8–538.1 pg/ml) adjusted hazard ratio = 0.64 (0.13–3.05)quartile 3 (538.1–1356.0 pg/ml) adjusted hazard ratio = 0.64 (0.14–2.95) quartile 4 (>156.0 pg/ml) adjusted hazard ratio = 1.2 (0.21–6.84)
Germany | Condition 2 - mean age: 62 +/- 11.2 years | Followup: Median 2 years (maximum 3.7 years) | LVEF was determined by LV-angiography and off-line analysis according to the area-length method). | | | | Threshold: In patients with stable angina: quartile 1 (<86.7 pg/ml) quartile 2 (86.7–192.0 pg/ml) quartile 3 (192.0–487.9 pg/ml) quartile 4 (>487.9 pg/ml)
| % Male: 77 | | | | | | Hazard ratios according to quartiles of baseline NT-proBNP in patients with ACS: quartile 1 (<160.8 pg/ml) quartile 2 (160.8–538.1 pg/ml) quartile 3 (538.1–1356.0 pg/ml) quartile 4 (>156.0 pg/ml)
Heeschen 2004 | Condition 1 - mean age: 59.9 +/- 10.9 years | 1791 | Chest pain at rest or accelerating chest pain within the previous 24 hours. All patients had evidence of coronary artery disease as described in another article. | 1) Mortality; 2) Myocardial infarction | NR/NR | Multiple logistic regression | Roche Diagnostics - Elecsys 1010, Elecsys 2010, E170 or Modular | Death or Nonfatal Myocardial Infarction During 30 Days of Followup: Adjusted odds ratio = 2.68 (1.66–4.34)
Germany, New Zealand | Condition 2 - mean age: 64.1 +/- 10.8 years | Followup: 30 days | | | | | Threshold: 246 pg/mL
| % Male: 67%

Abbreviations: LVEF=left ventricular ejection fraction, AMI=acute myocardial infarction, ECG=electrocardiogram, HPLC=high pressure liquid chromatography, MI=myocardial infarction, NR=not reported, HF=heart failure

Table 8 Evidence Table: Summary of studies in patients with CAD no regression analyses

Author | Sample Characteristics | Sample Size/Followup | Diagnostic criteria | Outcomes | Consecutive Cohort / Outcome Blinding | Analysis/Model | BNP Method/Units | Measure of Association
Dokainish 2005 | Condition 1 - mean age: 57.3 +/- 11.6 years | 895 | Angiographic CAD if >/= 50% stenosis in coronary artery | Death or Re-infarction | NR/Yes | Chi-square, Fisher exact test, t-test, Wilcoxon rank-sum, Kruskal-Wallis | [BNP] Biosite Diagnostics - Triage | Not Reported
USA | Condition 2 - mean age: 60.6 +/- 13.3 years | Followup:NR | | | | | Threshold: BNP 80 pg/mL
| % Male: 57
Lindahl 2005 | Mean age: 67 years% | 961 | Non-ST-segment elevation. Both chest pain and signs of ischemia (ST-segment depression =>0.10 mV or T-wave inversion =>.10 mV or raised biochemical markers. | 1) Changes in NT-proBNP after 5 serial measures expressed as; a) median values; b) mean rate of change per visit; Outcomes for the FRISC-II trial; 2) mortality; 3) MI | NR/NR | Multiple linear and logistic regression | [NT-proBNP] Roche Diagnostics - Elecsys 1010, Elecsys 2010, E170 or Modular | Not Reported
Sweden | Male: 71 | Followup: 2 years if randomized to invasive vs non-invasive surgery 6 months if randomized to daltperin vs placebo | | | | | Threshold: Baseline NT-proBNP median = 529 pg/mL, six months median = 238 pg/mL
Panteghini 2003 | All subjects mean age 52.5 years | Controls: 28 age-matched apparently healthy laboratory workers | Made by cardiologist | 1) All cause mortality; 2) Unstable angina or recurrrent MI | NR/Yes | Linear regression, Kaplan-Meier survival curve | [BNP] Biosite Diagnostics -Triage | Not Reported
Italy | All subjects age range 33–78, 89% | Treatment: 64 acute myocardial infarction patients | | | | | Threshold: BNP 83 pg/ml
| | Followup: 13 months median (range 4 to 23 months)
Richards 2002 | Mean age: 63.6 years | 747 | Patients were categorized as having antecedent hypertension if this diagnosis was known by the patient to have been made by their family physician or after specialist referral, if the acute admission note indicated a history of hypertension and/or they were receiving antihypertensive medication. | 1) Mortality; 2) Pre-discharge heart failure; 3) Re-admission for heart failure | NR/NR | Multiple Cox proportional hazards or logistic regression | NT-proBNP | Not Reported
New Zealand | % Male: 72.6 | Followup: 2 year mean (up to 1000 days) | | | | | Threshold: 1015 pg/mL
Sadanandan 2004 | Condition 1 - mean age: 61 years | 276 | Subjects from TACTICS-TIMI-18 trial. | Composite endpoint of death, non-fatal re-infarction, and repeat hospitalization for ACS (P) | NR/Yes | Chi square test | [BNP] Biosite Diagnostics - Triage | Not Reported
USA | Condition 2 - mean age: 67 years | Followup: 6 months | All patients had unstable angina, non-ST elevated myocardial infarction (UA/NSTEMI), and cardiac cathertization within 4–48 hrs and revascularization. | | | | Threshold: BNP 80 pg/m L
| % Male: 65%
Shimpo 2004 | Mean age: 58 years | 810 | Episode of ischemic discomfort of at least 30 minutes within 6 hours or 12 hours and exhibited at least 0.1-mV ST-segment elevation in 2 contiguous ECG leads. | 1) Congestive heart faliure; 2) Mortality 30 day; 3) Mortality | NR/NR | Multiple logistic regression | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Not Reported
USA | % Male: 79.2 | Followup: 30 days | | | | | Threshold: BNP 80 pg/ml
Suzuki 2004 | Condition 1 - mean age: 64.7 +/- 11.1 years | 145 | The diagnosis of AMI was made from clinical symptoms, including chest pain, ECG changes including ST elevation and ST depression, and an elevation of serum creatine kinase-MB isoenzyme to more than twice the normal upper level. | Cardiac related mortality | NR/NR | Cox proportional hazards regression | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Some chi-quare values for log BNP were given for Cox proportional hazards analysis: Log BNP univariate chi-square = 20.06, p<0.0001; multivairate chi-square = 7.003, p 0.008.
Japan | Condition 2 - mean age: 66.7 +/- 7.9 years | Followup: 58.6 month mean (range 1–158 months) | | | | | Threshold: BNP 180 pg/ml
| % Male: 73%
Zeller 2004 | Mean age: 69 (range 55–77) Years | 101 | All patients with a diagnosis of MI exceeding the decision limit increase in troponin I (10.1 ng/ml) associated with either typical ischemic symptoms or ECG signs (ST-segment depression or negative T waves). | 1) Death or recurrent MI; 2) Death or recurrent MI or heart failure | NR/NR | Multiple logistic regression | [NT-proBNP] Roche Diagnostics - Elecsys 1010, Elecsys 2010, E170 or Modular | Predictors of NT-proBNP > 136 pg/mL Univariate analysis (OR/95% CI): Age > 65 years5.46/2.27–13.08 Killip > I 4.50/1.51–13.41 PURSUIT score >/= 7 4.25/1.85–9.76 Hypertension 2.75/1.23–6.15 LVEF < 50% 2.69/1.13–6.41 Female 0.29/0.12–0.72 Current smoker 0.20/0.08–0.61 Multivariate analysis LVEF < 50% 0.91/0.85–0.96 Age > 65 years 1.12 1.05–1.19 Hypertension 3.78/1.03–13.83
France | % Male: 69 | Followup: NR | | | | | Threshold: NT-proBNP 136 pmol/L
Hutfless 2004 | Mean age: 63 +/- 9.1 years | 98 | CAD included: | Clinical end points included: | Yes/NR | None | [BNP] Biosite Diagnostics - Triage | Not Reported
USA | % Male: 100 | Followup: NR | 1) Myocardial infarction within 6 weeks preoperatively n=7.; 2) CHF NYHA functional class III or IV n=9.; 3) Insulin-dependent diabetes mellitus n=10.; 4) Past cerebrovascular accident n=10.; 5) Chronic renal insufficiency n=7.; 6) Previous percutaneous transluminal coronary angioplasty/stent n=19.; 7) Previous thoracotomy n=9.All male patients undergoing heart surgery at the VA hospital were eligible for inclusion | 1) intraoperative and postoperative cardiac events: significant STsegment change, significant arrhythmia, new Q-wave, or cardiac enzyme elevation;; 2) ventilator dependence >48 h postoperatively;; 3) intensive care unit stay longer than 5 days postoperatively;; 4) hospital stay longer than 10 days postoperatively;; 5) emergency reintubation other than for reoperation;; 6) cardiothoracic reoperation within 2 weeks of initial surgery;; 7) readmission within 30 days for cardiac reasons;; 8) requirement for intra-aortic balloon pump (IABP);; 9) mortality within 30 days and within 1 year postoperatively; and; 10) postoperative requirement for epinephrine, lidocaine, and/or pressor doses of dopamine. | | | Threshold: 3 BNP cut-points:120 pg/ml280 pg/ml385 pg/ml
Julier 2003 | Mean age: 63.5 years | 72 | Scheduled for elective CABG surgery on CPB circuit with cardiac arrest. | NT-proBNP levels in treated vs. placebo patients | NR/Yes | None | [NT-proBNP] Roche Diagnostics - Elecsys 1010, Elecsys 2010, E170 or Modular | Not Reported
Switzerland | % Male: 81.9 | Followup: 72 hours | | postoperative cardiovascular and renal adverse events. | | | Threshold: None
Kerbaul 2004 | Condition 1 - mean age: 68 +/- 10 years | 60 | 1) Recent MI: acute coronary syndrome with or without ST modification or and with Tropinin I level modifications occurring within 6 weeks of the operation.; 2) Unstable angina: associated with acute coronary sybdrome w/out modification in Tropinin I.; 3) Peripheral arteriosclerosis: history of claudication or peripheral vascular surgery. patients undergoing elective OPCAB who were free of active preoperative infection and inflammation | 1) Cardiovascular complications (myocardial infarction, cardiogenic shock, arrhythmias, CHF, and death occurring after the fourth postoperative hour) Abnormal post-operative cardiovascular course: ICU: (a) systolic arterial pressure < 90 mmHg with low cardiac output (cardiac index <2 l min⁁-1 m⁁-2) and signs of hypoperfusion such as oliguria; (b) need for catecholamines for cardiovascular support (dobutamine >5 ug kg⁁-1 min⁁-1 or any amount of epinephrine or norepinephrine >6 h); (c) postoperative myocardial infarction defined as a maximal creatine kinase MB fraction level >100 IU l⁁-1 associated electrocardiographic modifications and segmental hypokinesia at the echocardiography; (d) CHF defined by fluid retention and persistent chest infiltration; (e) atrial fibrillation >15 min with hemodynamic instability requiring electrical or pharmacological cardioversion; (f) ventricular fibrillation or tachycardia requiring electrical cardioversion; (f) operative mortality occurring within 30 days of the operation. | Yes/Yes | Unadjusted regression: BNP = preoperative left ventricular ejection fraction BNP = NYHA status | [NT-proBNP] Roche Diagnostics - Elecsys 1010, Elecsys 2010, E170 or Modular | Not Reported
| Condition 2 - mean age: 67+/- 9 years | Followup: Without complications: 2.6 +/- 0.9 days With complications: 6.9 +/- 3.8 days | | | | | Threshold: 0: 30 minutes after introduction of IV anesthesia before surgery --> 397 pg/ml.
| % Male: 80% | | | | | | T1: 10 minutes after the end of surgery --> 430 pg/ml.
| | | | | | | T2: 4 hours after the end of surgery --> 491 pg/ml. (Various measures of NT-proBNP over time)
Song 2004 | Condition 1 - mean age: 66.7+/- 9.3 years (on-pump CABG) | 40 | New York Heart Association | BNP levels | NR/NR | Simple and multiple regression: BNP = CAB + pleural effusion BNP + CAB + atrial fibrillation | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Peak BNP of > 450 pg/mL was found to be the most powerful predictor of post-operative pleural effusion and atrial fibrillation (no quantitative data are reported).
Japan | Condition 2 - mean age: 71.6 +/- 7.4 (off-pump CABG) | Followup: 1 month | | Correlations between BNP and sample characteristics in both surgery groups. | | | Threshold: 450 pg/ml
| % Male: 72.5%
Watanabe 2003 | Not Reported | 14 | Undergoing elective CABG with cardiopulmonary bypass (CPB) | 1) Clincal status: death, requiring intra-aortic balloon pump (IABP) support for left ventricular dysfunction, angina, graft failure, heart disease, cardiac scintingraphy, occlusion or critical stenosis of bypass grafts or progression of native coronary stenosis).; 2) Presence of angina, NYHA class, positive cardiac scintigraphy, occlusion or critical stenosis of bypass grafts. | NR/NR | Simple linear regression: BNP = clinical status | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Not reported
Japan | | Followup: 20 months | | | | | Threshold: None

Abbreviations: CAD=cardiovascular artery disease, MI=myocardial infarction, NR=not reported, ECG=electrocardiogram, AMI=acute myocardial infarction, OR=odds ratio, CI=confidence interval, CHF=congestive heart disease, NYHA=New York Heart Association, ACS=acute coronary syndrome, CABG=coronary artery bypass graft

Table 9 Evidence Table. Summary of studies in patients with HF and mortality outcomes:BNP

Study | Sample Characteristics | Sample Size/Followup | Diagnostic criteria | Outcomes | Quality: Consecutive Cohort / Outcome Blinding | Analysis /Model | BNP method/Unit threshold | Measure of Association
Maisel 2004 | - Cohort: REDHOT; - Age: Mean, 64; - Age: Range, 51–76; - % Male: 54% | 464 | - REDHOT cohort enrolled only If had BNP > 100pg/mL NYHA (I–IV): 3.0% level I, 29% level II, 46% level III, 22.6% level IV. 45 % Level III; - Clinical evaluation only.; - LVEF Not Reported | Mortality | NR/Yes | Multivariate logistic regression | [BNP] Biosite Diagnostics - Triage | Mortality 90 days:Multivariate: Baseline Exp(Beta) for logBNP = 4.531 (beta p = 0.001)
USA | | Followup: 30 and 90 days | | | | | Threshold:200 pg/mL (chosen retrospectively based on internal analysis)
van der Meer 2004 | - Cohort: NA; - Age: ange, 26 to 90; - % Male: 80% | 74 | - Stable mild to moderate CHF patients admitted to clinic (NYHA II - IV): 37% level II,32% level III, 31% level IV; - Based on standard criteria from European Society for Cardiology (including echocardiography) and standard criteria (NYHA); - Used in regression analyses as a continuous variable to predict all cause mortality | All cause mortality | Yes/No | Uni and multivariate Cox backward Wald regression | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | All cause mortality: Univariate: Baseline BNP (pmol/L) H.R. =1.006, CI = 1.003–1.009, P = 0.001
Netherlands | | Followup: Deceased: mean 621 days (range 16 to 1,728 days) | | | | | Threshold:No threshold specified. Mean BNP 109.9 +/- 13.5 pmol/L [Conversion 380 pg/mL +/- 46.71] | All cause mortality: Multivariate: Baseline BNP did not remain independently associated
| | Survivors: mean 1100 days (range 844 to 1,934 days) and a median of 987 days (37 months)
Latini 2004 | - Cohort: Val-HeFT; - Age: Mean, No info; - %Male: No info | 4300 | - ValHeFT cohort: stable but symptomatic HF (NYHA I–IV); - LVEF < 40% and LV internal diameter in diastole adjusted for body surface area (LVIDd/BSA) of =>2.9 cm/m2.; - LVEF < 40% | Mortality | NR/No | Uni and multivariate Cox proportional hazard regression | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Mortality: Univariate Baseline BNP >= 97 pg/mL HR = 2.47 [95% CI, 2.13–2.87] (significant)
Italy | | Followup: Not Specified (23 months outcomes are discussed in the results but not clear if this is total followup time) | | | | | Threshold:97 pg/mL (median sample) | Mortality: Mulitvariate Baseline BNP >= 97 pg/mL 2.48 [95% CI, 2.13–2.88] (significant)
| | | | | | | | Mortality: Multivarite Baseline BNP change = 10 pg/mL HR = 1.012 [95% CI, 1.010–1.014] p<0.0001 (adjusted for the other 3 neurohormones)
Kyuma 2004 | - Cohort: N.A.; - Age: Mean, 64+/-13,; - % Male: 69.6% | 158 | - NHYA (I–IV): 12% level I, 49% level 2, 25% level III, 14% level IV; - Presence of symptoms, 2D echocardiogram, I-MIGB scintography; - Pr34 % had </= 30% LVEF | Cardiac death due to pump failure | Yes/No | Uni and mulitvariate Cox proportional hazards regression | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Cardiac mortality: Univariate: Baseline BNP HR = 1.0010 [95% CI, 1.0000–1.0021], p = 0.00018
Japan | | Followup: 16 months +/-9 months | | | | | Threshold: >172 pg/mL (median of sample) | Cardiac mortality: Multivariate: Baseline BNP HR = 1.0010 [95% CI, 1.0001–1.0019], p = 0.02404 (only variable significant)
| | | | | | | | Cardiac mortality: Difference with Kaplan Meier curves: Baseline BNP >172 pg/mL HR = 7.2 [95% CI 1.6–32.1], p = 0.002
Bettencourt 2004 | - Cohort: N.A.; - Age: Mean, 69.4+/-9.3; - % Male: 71.4% | 84 | - Patients referred to a HF clinic and then followed on an outpatient basis. Note that those who did not survive to second scheduled measurement were excluded from the study. (NYHA I–III): 11.9% level I, 81% level II, 7% level III.; - Clinical examination including ECG, chest X-ray, spirometry, echocardiogram, serum biochemical analyses.; - Mean LVEF 31.2% +/- 12.0 | Mortality | NR/Yes | Uni and multivariate Cox regression | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Mortality: Univariate: Baseline BNP > 260.4 pg/mL HR = 2.96 [95% CI, 1.06–8.26]
Portugal | | Followup: Median 1190 days (interquartile range 863–1572). 40 months | | | | | Threshold: 260.4 pg/mL (median of sample); also compared subjects whose BNP levels increased versus those that decreased following treatment. | Mortality: Univariate: 1) BNP increase (vs decrease) HR = 2.64 [95% CI, 1.00–7.00], 2) delta BNP (per increase in 100 pg/mL) HR = 1.28 (95% CI, 1.15–1.43]
| | | | | | | | Mortality: Multivariable: delta BNP (per increase in 100 pg/mL) HR = 1.34 [95% CI, 1.10 to 63]
Ishii 2003 | - Cohort: N.A.; - Age: Mean, 68 + 11; - % Male: 56% | 100 | - Patients admitted to hospital for worsening CHF (NYHA III–IV): 54% level III and 46% level IV; - Cardiologists not directly involved in the study determined if pateients met exclusion criteria. 2D Echocardiogram and venous blood samples were used to detrmine severity.; - 12% of patients had mean LVEF 36% | Cardiac death (death from worsening CHF, fatal MI or sudden death) | NR/Yes | Uni and multivariate Cox regression | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Cardiac deaths: Univariate: Baseline Log BNP (10-fold increase), HR = 5.66 [95% CI 1.55–20.7], p = 0.006
Japan | | Followup: Mean 391 days (range 16–884) 13 months | | | | | Threshold:160 ng/L (based on ROC with best sensitivity). [Conversion 160 pg/mL] | Cardiac deaths: Multivariate model including cTnT and BNP concentrations: Baseline Log BNP (10-fold increase) HR = 3.11[95% CI, 1.61–6.01], p = 0.0005
Vrtovec 2003 | - Cohort: N.A.; - Age: Mean, 67+/-14,; - % Male: 59% | 241 | - Patients referred with heart failure to single centre (Patients with BNP >400 pg/mL who had been NYHA class III–IV for at least 2 months before evaluation) (NYHA III–IV): 74% level III, 26% level IV.; - Clinical evaluation and ECG.; - Mean LVEF = 26% +/- 9% | All cause mortality | NR/No | Uni and multivariate Cox proportional hazard regression | [BNP] Biosite Diagnostics - Triage | All cause death: Univariate: Baseline BNP 400–700 pg/mL, p = 0.0003, Baseline BNP 701–1000 pg/mL, p = 0.0003, Baseline BNP >1000 pg/mL, p = 0.0001
New Zealand | | Followup: 6 months | | | | | Threshold: Three categories (<700 pg/ml, 701–1000 pg/mL, > 1000 pg/mL) | All cause death: Multivariate Baseline BNP > 1000 pg/mL HR = 1.99 [95% CI, 1.18–3.36], p 0.0005
| | | | | | | | Cardiac death: Univariate: Baseline BNP 400–700 pg/mL, p = 0.0004, BNP 701–1000 pg/mL, p = 0.0004, BNP >1000 pg/mL, p = 0.0003
| | | | | | | | Cardiac death: Multivariate Baseline BNP HR = 1.76 [95% CI, 1.01–3.07], p 0.0007
| | | | | | | | Pump failure death: Univariate: Baseline BNP 400–700 pg/mL, p = 0.0003, Baseline BNP 701–1000 pg/mL, p = 0.0003, Baseline BNP >1000 pg/mL, p = 0.0001
| | | | | | | | Pump failure: Mutlivariate Baseline BNP HR = 3.78 [1.63–8.78], p = 0.0007
| | | | | | | | Sudden cardiac death: All were not significant
Ishii 2002 | - Cohort: N.A.; - Age: Mean, All subjects, 69+/- 9; - Age: Mean, Condition 1: 71+/-10; - Age: Mean, Condition 2: 68+/-10; - Age Range, All subjects, 22–88; - % Male: 52% | 98 | - Patients were admitted to a coronary care unit due to worsening CHF. (NYHA mean 3.5 +/- 0.6); - 2D echocardiography read by experts blinded to the study.; - Mean LVEF = 42% +/- 17 | 1) Cardiac death (death from worsening chronic heart failure, fatal myocardial infarction, or sudden death) | Yes/No (but endpoints judged by independent researchers) | Uni and multivariate Cox regression | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Cardiac death: Univariate: Baseline Log BNP, Chi Sq.= 6.66, p = 0.0098
Japan | | Followup: Mean 451 +- 98 days (range 13 to 667 days) 15 months | | | | | Threshold: BNP 440 pg/ml (based on ROC analysis) | Cardiac death: Multivariate: Baseline Log BNP Chi Sq. = 4.45, p = 0.034
Harrison 2002 | - Cohort: N.A.; - Age: Mean, 65; - Age: Range, 29–83; - % Male: 95% | 325 | A convenience sample presenting with dyspnea to the emergency department (41% CHF) Diagnosis: Echocardiogram results from previous records was used to establish CHF. LVEF not reported | Mortality (any cardiac, noncardiac, and CHF) | No/Yes | Unadjusted Relative Risks | [BNP] Biosite Diagnostics - Triage | CHF death: Unadjusted: Baseline BNP>230 pg/mL vs. <=230 pg/mL: RR = 24.1 [95% CI, 6.3.5-491.1]
USA | | Followup: Mean followup time=682.2 +- 55.0 days 23 months | | | | | Threshold: 480 pg/mL based on ROC; 230 pg/mL (provided few false negative values) | Cardiac death: Unadjusted: Baseline BNP>230 pg/mL vs. <=230 pg/mL: RR = 37.9 [95% CI, 5.7.5-755.8]
Stanek 2001 | Subjects with HF (LVEF < 25%) from a substudy of subjects from RCT evaluating those on atenolol versus placebo. (NYHA II–IV): 78% level II, 13% level III, 2% level IV. | SS = 91 | Radionuclide ventriculography and clinical evaluation | Cardiac mortality | NR/No | Uni and mulitvariate Cox proportional hazards regression | [NT-proBNP] Biomedica Grupe - No instrument, EIA (manual assay) | Death: Multivariate: Baseline LogBNP Chi Sq. = 13.9, p = 0.0002
Austria | | Followup: 4 years | | | | | Threshold: 300 fmol/ml N-BNP (last available plasma level) | Death: Multivariate: Last followup LogBNP Chi Sq. = 21.3, p = 0.0001
| | | | | | | | Death: Multivariate: Last followup LogNT-proBNP Chi Sq. = 8.9, p = 0.0027
Imamura 2001 | - Cohort: Ehime MIBG Heart Failure (EMIHEF Study); - Age: Mean, All subjects, 63 +/- 11; - Age: Mean, Condition 1: 64 +/- 11 (Event free); - Age: Mean, Condition 2: 65 +/- 12 (Cardiac death); - Age: Mean, Condition 3: 61 +/- 14 ( hospitalization); - % Male: 73% | 171 | - Ehime MIBG Heart Failure Study (EMIHEF) randomized trial. (NYHA II–IV): 54% level II, 18% level III, 3% level IV.; - Clinical evaluation, including NYHA, I-MIBG images, Chest x-ray, 2D echocardiography; - Mean LVEF 27%+/-10% | Cardiac mortality, defined as death from progressive CHF or sudden cardiac death | NR/No | Uni and multivariate Cox regression | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Cardiac death: Univariate: Baseline BNP RR = 1.005 [95% CI,1.002–1.008], p = 0.0002
Japan | | Followup: 27+/- 8 months | | | | | Threshold: <160 pg/ml (mean of sample) | Cardiac death: Multivariate: Baseline BNP not statistically significant at 5% level (no quantitative data were reported).
Cheng 2001 | - Cohort: N.A.; - Age: Mean, 68 +/- 1.6; - Age: Range, 28–110; - % Male: 100% | 72 | - Convenience sample of veterans (NYHA III–IV) : mean level 3.64 +/- 0.07.; - New-onset CHF: confirmed by at least one cardiologist using standard Framingham criteria or exacerbation of previously documented CHF, NYHA class.; - LVEF < 50% (mean LVEF 37% +/-2%) | 1) Death in hospital or death within 30 days after initial discharge | NR/No | Univariate logistic regression | [BNP] Biosite Diagnostics - Triage | Mortality outcomes not reported
USA | | Followup: 30 days | | | | | Threshold: Mean admission and discharge levels, and four categories of threshold (430 pg/mL, 840 pg/mL, 1090 pg/ml, 1220 pg/mL)
Akioka 2000 | - Cohort: N.A.; - Age: Mean, 71 +/- 15; - % Male: 57% | 33 | - Patients with chronic CHF admitted to the ER for episodes of acute decompensation. (NYHA III–IV): 23% level III, 73% level IV.; - Clinical evaluation, chest X-ray, and 2D echocardiography.; - Mean LVEF 41% +/- 13% | Cardiac mortality | NR/No | Univariate Cox proportional hazards regression | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Cardiac Mortality: Univariate: Baseline BNP Chi Sq. = 2.17, p = 0.141
Japan | | Followup: 3 months | | | | | Threshold: > 700 pg/ml (median level) | Cardiac Mortality: Univariate: Deceleration time (DcT) < 120 and Baseline BNP > 700 pg/mL Chi Sq. = 5.87, p = 0.015
Bettencourt 2000 | - Cohort: N. A.; - Age: Mean, 69.6 +/- 9.3; - % Male: 59% | 139 | - Patients with mild to moderate heart failure who were referred to an outpatient HF clinic. (NYHA I–III): 11.5% level I, 82.7% level II, 5.8% level III.; - Clinical examination, echocardiography, and doppler; - Mean LVEF = 33.5% +/-13.2%. | All cause mortality | Yes/No | Uni and multivariate Cox regression | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Mortality: Univariate:Baseline BNP Beta = 0.001, p < 0.0001
Portugal | | Followup: 541.4+346.5 days. 11.5 months | | | | | Threshold: 274 pg/mL (median of sample) | Mortality: Multivariate: Baseline BNP Beta = 0.0001, p = 0.002
Maeda 2000 | - Cohort: N.A.; - Age: Mean, 63.6 +/- 1.5; - % Male: 64% | 102 | - Patients hospitalized with chronic severe. (NYHA III–IV): 56% level III, 44% level IV.; - Echocardiography at admission and 3 months.; - Mean LVEF 23% +/- 0.9% | 1) Cardiac death (worsening CHF, lethal MI, sudden death) or survival | Yes/No (but judged independently by researchers) | Uni and multivariate Cox proportional hazards regression | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Mortality: Univariate: Baseline BNP Chi Sq. = 5.79, p = 0.0161; BNP 3 months post Tx Chi Sq. = 40.7, p < 0.0001
Japan | | Followup: Mean: 807 days (+/- 42.3) Range: 120–1568 days (27 months) | | | | | Threshold: 170 pg/ml (median from sample) or 240 pg/ml (from ROC curve) | Mortality: Multivariate: Baseline BNP Chi Sq.= 2.61, p = 0.11, BNP 3 months post Tx Chi Sq. = 29.1, p < 0.0001
Tsutamoto 1999 | - Cohort: N.A.; - Age: Mean, 59 + 0.7; - Age: Range,18–82; - % Male: 76.6% | 290 | - Consecutive early-stage HF patients who subsequently underwent cardiac catheterization. (NYHA I–II):32% level I, 68% level II.; - Clinical evaluation and LVEF demonstrated by ventriculography with contrast medium.; - LVEF < 45% | Cardiac mortality | Yes/No | Linear regression Uni and multivariate Cox proportional hazards regression | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Mortality: Multivariate: Baseline BNP HR = 1.004 [95% CI, 1.003–1.006], p < 0.001 (only high level of BNP was significant)
Japan | | Followup: Mean = 502 days (range 31–1,619 days) in patients with an outcome | | | | | Threshold: 56 pg/mL (median of total sample) | Mortality: Univariate: Baseline BNP Chi Sq. = 100.5, p < 0.0001
| | Mean = 1,071 days (range 31–2,541 days) for event-free patients. 36 months | | | | | | Mortality: Multivariate: Baseline BNP Chi Sq. = 59.21, p < 0.001
Tsutamoto 1997 | - Cohort: N.A.; - Age: Mean, 60; - Age: Range, 22–84; - % Male: 72% | 85 | - Chronic CHF pateints admitted to hospital. (NYHA II–IV): 54% level II, 21% level III, 25% level IV.; - LVEF of <45% determined with ventriculography with radionuclide or contrast medium, and laboratory tests.; - LVEF < 45% (Mean LVEF = 31.1% +/-1.1% | Cardiac mortality | NR/No | Uni and multivariate Cox proportional hazard regression | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Cardiac mortality: Univariate: Baseline BNP Chi Sq. = 60.83, p < 0.001
Japan | | Followup: > 1 year (mean 24 months) | | | | | Threshold: 73 pg/mL (median plasma concentration) | Cardiac mortality: Multivariate: Baseline BNP Chi Sq. = 19.68, p < 0.0001
| | | | | | | | Cardiac Mortality: Multivariate: Baseline BNP HR = 1.003 [95% CI, 1.001 to 1.004]
Wallén 1997 | - Cohort: 70 year old people in Gothenburg Sweden; - Age: Mean, 85; - % Male: No info. | 541 | - Sample from longitudinal study of those born in 1901 -02 in Swedish city; the current study followed 85 year olds for 5 years. Not all patients had CHF.; - Clinical evaluation and heart volume.; - Not Reported | All cause mortality | NR/No | Multivariate Cox regression | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Mortality: Multivariate: Baseline BNP HR = 1.259 [95% CI, 1.088–1.457], p = 0.0020 (total population)
Sweden | | Followup: 60 months | | | | | Threshold: Divided into quintiles: Q1= 1.0–11.3 fmol/mL [39.8 pg/mL], Q5 = 61.5–1103.0 fmol/mL [212.8 pg/mL - 3816.4 pg/mL] | Mortality: Multivariate: Baseline BNP HR = 1.240 [95% CI, 1.037–1.483], p = 0.0020 (cardiovascular disorder population)
| | | | | | | | Mortality: Multivariate: Baseline BNP HR = 1.382 [95% CI, 1.046–1.826], p = 0.0020 (without defined cardiovascular disorder population)
Watanabe 2005 | - Cohort: CHART; - Age: Mean, 64; - % Male: 69.4% | 417 | - Hospital based cohort from the CHART study who represented CHF in real clinical situations as they had both impaired or preserved systolic dysfuntion. (NYHA III–IV): 19.3% had level III/IV.; - Framingham criteria for HF, echocardiography and clinical evalution.; - LVEF < 50% (mean LVEF 38% +/- 12%) | Mortality (due to exacerbation of HF) | NR/No | Multivariate Cox regression | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Mortality HF: Multivariate: Not included in model as not significant
Japan | | Followup: mean 26 months | | Sudden death (without unexpected worsening of HF) | | | Threshold: Log BNP >=2.12 (median based on sample) | Sudden death: Multivariate: Baseline logBNP >=2.12 HR = = 3.46 [95% CI, 1.39–7.94], p = 0.005
| | | | Mortality (all cause) Combined HF events (HF mortality of hospitalization due to exacerbation of HF)
Berger 2005 | | 452 | - Ambulatory patients recruited from a HF centre.(NYHA I–IV): 12% level I, 34% l3vel II, 33% level III, 21% level IV.; - Clinical evaluation and LVEF (method not specified).; - LVEF < 35% (Mean 20% +/- 7%) | Sudden death and heart failure death | NR/No | Uni and multivariate Cox proportional hazard regression | [BNP] Biosite Diagnostics - Triage Threshold: logBNP = 2.11 (approximated 130 pg/mL and based on ROC curve analysis (to discriminate between patients who succumbed to sudden death and survivors). | Pump Failure: Multivariate: Baseline BNP Chi Sq. = 7.4, p 0.007
Austria | | Followup: mean 592 days +/- 387 days 20 month s | | | | | Thresholds for BNP, N-BNP, logN-bnp were not reported but used inmultivariate analyses. | Pump Failure: Univariate: Baseline Log BNP Chi Sq. = 33.4, p 0.0001
| | | | | | | | Pump Failure: Univariate: Baseline Log N-BNP Chi Sq. = 28.4, p 0.0001
| | | | | | | | Pump Failure: Multivariate: Baseline Log BNP Chi Sq. = 10.7, p 0.001
Van Beneden 2004 | - Cohort: N.A.; - Age: Mean, 58 +/- 6 (Controls); - Age: Mean, Condition 1: 62 +/- 7 (Mild to moderate CHF); - Age: Mean, Condition 2: 67 +/- 8 (Severe CHF),; - % Male: 84% | 117 | - Three groups: Patients with mild to moderate CHF, severe CHF, and 30 healthy age and sex matched controls. (NYHA I–IV); - Clinical evaluation only.; - Mean LVEF Mild /moderate group = 29.4% +/- 4%, mean LVEF severe CHF = 20.8% +/- 6%. | All cause mortality Cardiovascular mortality | NR/No | Multivariate Cox regression analysis | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Mortality in severe CHF group: Univariate: Baseline N-BNP Log Likelihood Chi Sq. = 5.68, p = 0.017
Belgium | | Followup: Severe CHF group survivors mean 81 +/- 15 months (range 60–91 months) | | Urgent heart transplant | | | Threshold: Median values of BNP, N-BNP, LogBNP, and LogN-BNP (values not reported) were used only if significant. Only logN-BNP was used as it had the highest statisitical significance. Mean values for mild to moderate CHF N-BNP = 491 fmol/mL [4152.3 pg/mL], and severe CHF N-BNP = 1,521 fmol/mL [8,457 pg/mL] | Mortality in severe CHF group: Univariate: Baseline BNP RIA Log Likelihood Chi Sq. = 2.14, p = 0.143
| | Mild to moderate CHF group survivors mean 92 +/- 3 months (range 87–96) | | | | | | Mortality in severe CHF group: Univariate: Baseline BNP IRMA Log Likelihood Chi Sq. = 0.71, p = 0.40
Alehagen 2004 | - Cohort: N.A.; - Age: Mean, 73 +/- 6; - Age: Range, 65–87; - % Male: 52% | 458 | - Patients referred to primary care with signs and symptoms attributed to HF. (NYHA I–III): 46% level I, 43% level II, 10% level III.; - Cardiologist performed clinical evaluation, echocardiography.; - Not reported but in multivariate analysis used LVEF < 40% as variable | All cause mortality and cardiovascular mortality | NR/No | Mutlivariate Cox proportional hazard regression | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | For step 1 (n = 458. excluded only those who who declined blood test or poor doppler)
Sweden | | Followup: 5.5 years median (range 242–2,222 days) all patients | | | | | Threshold: Two levels: 50–100 pmol/L and >100 pmol/L. [Conversion 173–346 pg/mL and > 346 pg/mL] | Cardiovascular mortality: Baseline BNP 50–100 pmol/L HR =1.58, p = 0.3
| | 3.8 years median non-survivors (range 242–2,156 days) | | | | | | Cardiovascular mortality: Baseline BNP >100 pmol/L HR = 3.38, p = 0.002
| | 5.7 years median survivors (range 1,883–2,222 days) 68 months | | | | | | All cause mortality: Baseline BNP 50–100 pmol/L HR=0.99, p = 0.99
| | | | | | | | All cause mortality: Baseline BNP >100 pmol/L HR=1.90, p = 0.18
| | | | | | | | For step 3 (n = 349, excluded those with no malignancy during followup and S-creatine < 200 mM)
| | | | | | | | Cardiovascular mortality: Baseline BNP 50–100 pmol/L HR = 1.76, p = 0.33
| | | | | | | | Cardiovascular mortality: Baseline BNP >100 pmol/L HR=6.92, p = 0.01
| | | | | | | | All casue mortality: Baseline BNP 50–100 pmol/L HR = 1.20, p = 0.76
| | | | | | | | All cause mortality: Baseline BNP >100 HR = 3.23, p = 0.053

Abbreviations: NYHA=New York Heart Association, LVEF=left ventricular ejection fraction, NR=not reported, HF=heart failure

Table 10 Evidence Table. Summary of studies in patients with HF and mixed outcomes: BNP

Study | Sample Characteristics | Sample Size /Followup | Diagnostic criteria | Outcomes | Quality: Consecutive Cohort / Outcome Blinding | Analysis /Model | BNP method /Unit threshold | Measure of Association
de Groote 2004 | - Cohort: N/A,; - Age: Mean, 57 +/- 11,; - % Male: No info. | 407 | - CHF patients referred to cardiology department (26% had NYHA III); - [Angiography, Echocardiography, Cardiopulmonary exercise test, 24 h halter monitoring]; - LVEF <= 45% | 1) Cardiac mortality (defined as cardiac related death or urgent cardiac transplantation; 2) Cardiac event-free (defined as cardiac-related death or cardiac transplantation) | NR/No | Multivariate Cox proportional hazard analyses | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Cardiac event free survival: Multivariate: Baseline BNP HR = 3.45 [95% CI 1.88 to 6.31], p = 0.0001
France | | Followup: median followup period of 787 days 26 months | | | | | Threshold: 109 pg/ml (median level of group)
Barcarse 2004 | - Cohort: N/A; - Age: Mean, 64.6 +/- 1.2; - % Male:100% | 98 | - Convenience sample presenting to urgent care centre or emergency department (58% CHF); - Cardiologist blinded to the hemodynamic parameters reviewed the patient's medical record; Echocardiogram for every patient; - Subgroup LVEF <= 45% to distinguish those with systolic dysfunction | 1) Sensitivity and specificity predicting death or re-admission when BNP and Cardiac index elevated; 2) Severity of CHF (include death, re-admission, and emergency visit within 90 days) | NR/No | Multivariate logistic regression | [BNP] Biosite Diagnostics - Triage | Multivariate analyses showed that thoracic fluid content, acceleration index, left cardiac work index were the best clinical predictors of more severe illness (cardiac deaths, readmissions, and emergency department visits within 90 days) in patients with baseline BNP levels > 100 pg/ml.
USA | | Followup: 90 day end point | | | | | Threshold: 100 pg/ml (Based on literature)
Maisel 2004 | - Cohort: REDHOT; - Age: Mean, 64; - Age: Range, 51 – 76; - % Male: 54% | 464 | - REDHOT cohort enrolled only If had BNP > 100pg/mL NYHA (I–IV): 3.0% level I, 29% level II, 46% level III, 22.6% level IV.; 45 % Level III; - Clinical evaluation only.; - LVEF Not Reported | Cardiac events (mortality, or cardiac related admission, or emergency room visit) | NR/Yes | Multivariate Logistic Regression | [BNP] Biosite Diagnostics - Triage | Cardiac events at 90 days: Multivariate: Baseline Exp(Beta) for logBNP = 2.030 (beta p = 0.005)
USA | | Followup: 30 and 90 days | | | | | Threshold: 200 pg/ml (chosen retrospectively based on internal analysis)
Gwechenberger 2003 | Cohort: NA Age: Condition 1 mean 52.47+/- 9.69 | SS = 100 Followup: mean 378 days (range 4 to 999 days) 13 months | Stable CHF (NYHA II–IV), 78% level II, 20% level III, 2% level IV Clinical Examination LVEF <=25% | Worsening Myocardial Failure (WHF) defined as any of the following: | NO (Clinical Trial)/ NO | Uni and Multivariate Cox proportional hazards regression | [NT-proBNP] Biomedica Grupe - No instrument, EIA (manual assay) | Worsening Heart Failure: Univariate: Log NT-proBNP Chi Sq. = 3.857, p = 0.0495
Austria | Condition 2 mean 50.52+/- 11.0 % Male: 89% | | | (1) Hospitalized for WHF;; (2) need for IV therapy;; (3) need for urgent CTx; or; (4) death from pump failure as a consequence of WHF | | | Threshold: 277 fmol/L (Median) | Worsening Heart Failure: Multivariate: LogNT-proBNP Chi Sq. not significant
| | | | | | | | Worsening Heart Failure: Univariate: Log BNP Chi Sq. = 19.331, p = 0.0001
| | | | | | | | Worsening Heart Failure: Multivariate: LogBNP Chi Sq. = 14.165, p = 0.0002
Sakatani 2004 | - Cohort: N.A.; - Age: Mean, All subjects, 72 +/- 12; - Age: Mean, Condition 1: 74 +/- 10; - Age: Mean, Condition 2: 71 +/- 12; - Age: Range, All subjects, 33–91; - % Male: 49% | 80 | - CHF patients admitted to hospital (NYHA I–IV):6% level 1, 43% level 2, 43% level III, 8% level IV; - Clinical evaluation only.; - Not reported | Cardiac event (i.e. death or rehospitalization) | Yes/No | Multivariate Cox proportional hazard regression | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Cardiac event: Multivariate Baseline BNP OR = 1.029 [95% CI, 0.984–1.075], p = 0.213
Japan | | Followup: 17 =/- 9 months | | | | | Threshold: No threshold specified. Mean BNP in cardiac event group 402 +/-168 pg/ml; mean BNP in non-cardiac event group 153 +/-51 pg/ml.
Latini 2004 | - Cohort: Val-HeFT; - Age: Mean, No info; - %Male: No info | 4300 | - ValHeFT cohort: stable but symptomatic HF (NYHA I–IV); - LVEF < 40% and LV internal diameter in diastole adjusted for body surface area (LVIDd/BSA) of =>2.9 cm/m2.; - LVEF < 40% | Combined mortality and morbidity (morbidity defined as cardiac arrest with resuscitation, hospitalization for HF or administration of intravenous inotropic or vasodilator drugs for 4 hours or more without hospitalization) | NR/No | Uni and multivariate Cox proportional hazard regression | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Mortality and Morbidity: Univariate Baseline BNP >= 97 pg/mL HR = 2.06 [95% CI 1.82–2.33] demographics, clinical/echo variables)
Italy | | Followup: Not Specified (23 months outcomes are discussed in the results but not clear if this is total followup time) | | | | | Threshold: 97 pg/mL (median of same) | Mortality and morbidity: Multivariate Baseline BNP change = 10 pg/mL, HR = 1.012 [95% CI 1.010–1.013] p<0.0001
Logeart 2004 | - Cohort: N.A.; - Age: Mean, Condition 1: 69.4+/- 14.4 (Derivation study); - Age: Mean, Condition 2: 70.9 +/- 13.3 (Validation study); - % Male: 60.5 % | 223 (114 finally included (derivation study) and 109 from another centre included in validation study) | - Patients presenting to two hospitals (NYHA class IV); - The diagnosis of decompensated CHF was confirmed by two senior cardiologists using the generally accepted Framingham criteria and corroborative information including the hospital course and results of further cardiac tests.; - Derivation group: LVEF 37.5% +/-14.9; Validation group 31.8% +/- 14.5 | Combined death or first re-admission for CHF | Yes/No | Uni and multivariate Cox proportional hazards regression | [BNP] Biosite Diagnostics - Triage | Death and readmission: Univariate: Baseline BNP per 100 ng/L increase HR = 1.06 [95% CI, 1.03–1.10], p = 0.0001
France | | Followup: 1 month and 6 months for 51/105 patients either dead or re-admitted; mean time from discharge to first event was 72 +/- 48 days | | | | | | Death and readmission: Univariate: Predischarge per quartile HR 4th quartile = 13.77 [95% CI, 4.71–40.23], p = 0.0001
| | | | | | | | Death and readmission: Multivariate Pre-discharge BNP HR = 1.14 [95% CI, 1.02 to 1.28], p < 0.027, 2) at one month
| | | | | | | | Death and readmission: Multivariate: Pre-discharge BNP HR = 1.17 [95% CI, 1.06 to 1.28], p = 0.002, 3) at six months
| | | | | | | | Death and readmission: Multivariate: Pre-discharge BNP level > 350 mg/L BNP HR = 12.6 [95% CI, 5.7–28.1], p =0.0001
| | | | | | | | Death and readmission: Multivariate: Pre-discharge BNP 350–700 ng/L HR = 5.1 [95% CI, 2.8–9.1]
| | | | | | | | Death and readmission: Multivariate: Predischarge BNP >700 ng/L HR = 15.2 [95% CI, 8.5–27.0], p=< 0.0001
| | | | | | | | Readmission: Multivariate: at 6 months Pre-discharge BNP HR = 1.25 [95% CI, 1.16 to 1.34], p = 0.001
Ishii 2003 | - Cohort: N.A.; - Age: Mean, 68 + 11; - % Male: 56% | 100 | - Patients admitted to hospital for worsening CHF (NYHA III–IV): 54% level III and 46% level IV; - Cardiologists not directly involved in the study determined if patients met exclusion criteria. 2D Echocardiogram and venous blood samples were used to determine severity.; - 12% of patients had mean LVEF 36% | Cardiac events (death from worsening CHF, fatal MI or sudden death) and re-admission for worsening CHF or MI | NR/Yes | Uni and multivariate Cox regression | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Cardiac events: Univariate: Baseline Log BNP (10-fold increase), HR = 4.26 [95% CI 2.20–8.23], p < 0.0001
Japan | | Followup: Mean 391 days (range 16–884) 13 months | | | | | Threshold: 160 ng/L (based on ROC with best sensitivity). [Conversion 160 pg/mL] | Cardiac events: Multivariate model including cTnT 0.01 (increase of 0.1 ug/L and Baseline BNP >160 mg/L as continuous variables: Baseline BNP > 160 ng/L, HR = 2.07 [95% CI, 1.43–3.01], p = 0.0001
| | | | | | | | Cardiac events: Multivariate model including cTnT 0.01 > 0.01 ug/L and Baseline BNP >160 mg/L as continuous variables: Baseline BNP > 160 ng/L, HR = 2.35 [95% CI, 1.14–4.84], p = 0.013
Horwich 2003 | - Cohort: N.A.; - Age: Mean, 52+/-13; - % Male: 71% | 238 | - Patients with advanced heart failure referred for cardiac transplantation to a single centre (NYHA class III–IV): 50% were level IV.; - Clinical evaluation only; - Mean LVEF 0.25 +/- 0.09 | All cause mortality or urgent cardiac transplantation. | Yes/No | Univariate and multivariate Cox regression | [BNP] Biosite Diagnostics - Triage | Combined outcome: Multivariate: Baseline BNP < 485 pg/mL and Tropinin I < 0.04 ng/mL RR = 1.0
USA | | Followup: 18 months | | | | | Threshold: <485 pg/ml (based on ROC curve; BNP not considered independent of Troponin I levels). | Combined outcome: Multivariate:Baseline BNP < 485 pg/mL and Tropinin I > 0.04 ng/mL RR= 2.1 [95% CI, 0.3–16.6]
| | | | | | | | Combined outcome: Multivariate:Baseline BNP > 485 pg/mL and Tropinin I < 0.04 ng/mL RR= 4.7 [95% CI, 0.8–26.9]
| | | | | | | | Combined outcome: Multivariate:Baseline BNP > 485 pg/mL and Tropinin I > 0.04 ng/mL RR 12.3 [95% CI, 2.4–64.0]
Anand 2003 | - Cohort: Valsartan Heart Failure Trial (Val-HeFT); - Age: Mean, No info.; - % Male: No info. | 4300 | - ValHeFT cohort: stable but symptomatic HF (NHYA I–IV); - Patients with stable, symptomatic HF who were undergoing prescribed HF therapy and had left ventricular ejection fraction (LVEF) =/< 40% and P7; - LVEF < 40% | All cause mortality and first morbid event (death, sudden death with resuscitation, hospitalization for HF, or intravenous inotropic or vasodilator therapy for at least 4 hours) | NR/No | Multivariate Cox proportional hazard model [% change, quartile changes after 4 months] | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | First morbid event: Univariate: Baseline BNP > 97 pg/mL HR = 2.2 [95% CI,1.98 to 2.52]
USA | | Followup: mean followup 2–3 years (at 4 months, year, and 2 years) 32 months | | | | | Threshold: 97 pg/mL median (no range specified). Also evaluated using quartiles < 41pg/mL, 41–97 pg/mL, 97– 238pg/mL, >238 pg/mL). | First morbid event within 4 months: Controlling for Norepinephrine: % change 3rd vs 1st quartile Baseline BNP HR = 1.66 [95% CI, 1.36– 2.04], p < 0.0001
| | | | | | | | First morbid event within 4 months: Controlling for Norepinephrine only: % change 4th vs 1st quartile Baseline BNP HR = 2.20 [95% CI, 1.80– 2.67], P = <0.0001
Bettencourt 2002 | - Cohort: N.A.; - Age: Mean, 71+/-44; - % Male: 44% | 50 | - Patients admitted with decompensated heart failure to hospital (NYHA II–IV): 12% level II, 54% level III, 35% level IV.; - Clinical evaluation only; - Not reported | Death or hospital re-admission for cardiovascular causes | NR/No | Univariate Cox regression | [BNP] Biosite Diagnostics - Triage | Mortality or readmission: Univariate: Baseline BNP > 541 pg/mL HR = 1.0 [95% CI, 0.4 to 2.5]
Portugal | | Followup: 6 months (time from discharge to first event ranged from 4 to 153 days (mean, 53 days)) | | | | | Threshold: No threshold specified. Admission median levels < 541 pg/mL, discharge median level < 321 pg/ml, and these that decreased by discharge. | Mortality or readmission: Univariate: Increased BNP during hospital stay HR = 3.3 [95% CI, 1.3 to 8.8]
| | | | | | | | Mortality or readmission: Univariate: DIscharge BNP level above the median (321 pg/mL) HR = 2.3 [95% CI, 0.9 to 5.8]
Hulsmann 2002 | - Cohort: N.A.; - Age: Mean, 57 +/- 8; - % Male: 82% | 96 | - Patients treated in clinic with documented HF based on LVEF function. Subjects were excluded from analysis if they underwent elective heart transplant. (NYHA I–III): 35% level I, 30% level II, 29% level III, 6% level IV.; - HF based on LVEF level; - Mean LVEF 26+/- 10%. | Death or worsening heart failure (decompensation, needing I.V. support and malignant arrhythmia) | Yes/No | Multivariate Cox proportional hazard regression | [BNP] Biosite Diagnostics - Triage | Death or worsening HF: Multivariate: Baseline BNP Chi Sq. = 8, p < 0.01
Austria | | Followup: 1 year | | | | | Threshold: No thresholds specified for BNP and proBNP. Mean BNP: 182 +/- 264 fmol/mL [629.7 pg/mL] in patients no events and 688 +/- 423 fmol/ml [2380 pg/mL] in patients who either died or developed worsening heart failure within 1 year. Mean proBNP 325 +/-198 fmol/ml [913.4 pg/mL] in patients with no events and 593 +/- 275 fmol/ml in patients who either died or developed worsening HF. | Death or worsening HF: Multivariate: Baseline proBNP Chi Sq. = 58, p < 0.0001
Tsutsui 2002 | - Cohort: N.A.; - Age: Mean, All subjects 63 +/- 1.5; - Age: Mean, Condition 1: 58.9 +/- 3.1; - Age: Range, All subjects, 17–85; - Age: Range, Condition 1: 17–79; - % Male: 75% (subjects), 78% (controls) | 84 + 18 Controls | - Patients with CHF with DCM or ischemic cardiomyopathy, LVEF < 45% (NYHA II–IV).; - Serum blood tests and Echocardiogram; - Mean LVEF = 30.7% +/- 1.0 | Cardiac death (worsening CHF, lethal MI or sudden death) or hospitalization for worsening CHF, MI or fatal arrhythmia | Yes/No | Multivariate Cox proportional hazards regression | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Combined endpoint: Univariate: Baseline BNP Chi-Square = 36.77, p < 0.0001
Japan | | Followup: Survivors > 589 days (mean 780 +/- 15.6 days (range 589 to 984 days)). 26 months | | | | | Threshold not specified. Mean all patients 334 +/- 42 pg/mL | Combined endpoint: Multivariate: Baseline BNP Chi-Square = 13.65, p 0.0002
Ishii 2002 | - Cohort: N.A.; - Age: Mean, All subjects, 69+/- 9; - Age: Mean, Condition 1: 71+/-10; - Age: Mean, Condition 2: 68+/-10; - Age Range, All subjects, 22–88; - % Male: 52% | 98 | - Patients were admitted to a coronary care unit due to worsening CHF. (NYHA mean 3.5 +/- 0.6); - 2D echocardiography read by experts blinded to the study.; - Mean LVEF = 42% +/- 17 | 1) Cardiac death (death from worsening chronic heart failure, fatal myocardial infarction, or sudden death);; 2) Readmission for worsening chronic heart failure or myocardial infarction. | Yes/No (but endpoints judged by independent researchers) | Uni and multivariate Cox regression | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Cardiac event: Univariate: Baseline Log BNP, Chi Sq = 8.79, p = 0.003
Japan | | Followup: Mean 451 +- 98 days (range 13 to 667 days) 15 months | | | | | Threshold: >440 pg/mL (based on ROC) | Cardiac event: Multivariate: Baseline Log BNP, Chi Sq = 6.73, p = 0.0095
Harrison 2002 | - Cohort: N.A.; - Age: Mean, 65; - Age: Range, 29–83; - % Male: 95% | 325 | A convenience sample presenting with dyspnea to the emergency department (41% CHF) Diagnosis: Echocardiogram results from previous records was used to establish CHF. LVEF not reported | Hospital admissions (any cardiac and CHF), 3) repeat ED visits for CHF. | No/Yes | Unadjusted Relative Risks | [BNP] Biosite Diagnostics - Triage | CHF event (hospitalization, ED visit, or death for CHF): Unadjusted: Baseline BNP>230 pg/mL vs. <=230 pg/mL: RR = 15.5 [95% CI,6.2–43.7]
USA | | Followup: Mean followup time=682.2 +- 55.0 days 23 month | | | | | Threshold: 480 pg/mL based on ROC; 230 pg/mL (provided few false negative values) | CHF event (hospitalization, ED visit, or death for CHF): Unadjusted: Baseline BNP>480 pg/mL vs. <=230 pg/mL: RR = 8.2 [95% CI, 4.7–14.3]
| | | | | | | | Cardiac Event (all CHF events plus the same for from ischemia or infarction): Unadjusted: Baseline BNP>230 pg/mL vs. <=230 pg/ml: RR = 5.5 [95% CI, 2.9–6.9]
Dias 2001 | - Cohort: N.A.; - Age: Mean, 70.4+/-1.2; - % Male: 45.7% | 46 | - A convenience sample presenting with dyspnea to the emergency department (41% CHF); - Echocardiogram results from previous records was used to establish CHF.; - Not Reported | Death or hospitalization from cardiac cause | NR/Yes | Unadjusted relative risks | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Combined outcome:Univariate: Baseline BNP pg/mL (all patients) OR = 1.02 [95% CI not reported], p = 0.01
USA | | Followup: 6 months | | | | | Threshold: >480 pg/mL based on ROC curve of sample; 230 pg/mL (provided few false negative values) | Combined outcome:Univariate: Baseline BNP pg/mL (patients in group II only) OR = 1.002 [95% CI not reported], p = 0.02
Koglin 2001 | - Cohort: N.A.; - Age: Mean, 51 +/- 9; - Age: Range, 24 – 65,; - % Male: 88% | 78 | - Patients with chronic CHF who were referred to a heart failure outpatient clinic; subjects were included after optimization of medical therapy. (NHYA I–IV): 12.8% level I, 42.3% level II, 33.3% level III, 11.5% level IV.; - Clinical history and examination, ECG, echocardiogram, laboratory results cardiopulmonary exercise test.; - Mean LVEF 36% +/-15 at admission | Changes in degree of cardiovascular disability: improvement, stabilization, deterioration (includes death) | NR/No | Logistic regression and Cox proportional hazard regression | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Changes in limitations of physical activity: Baseline BNP was significantly related to deterioration of physical limitations Chi Sq. = 24.9, p = < 0.0001
Germany | | Followup: Median 398 days (range 248–493). 13 months | | | | | Threshold: 107.5 pg/ml (based on 75th percentile) and BNP change (increase by 100 pg/ml). | Clinical event: Univariate: Baseline BNP per 100 pg/ML HR = 1.492 [95% CI, 1.221–1.819]
| | | | | | | | Clinical event: Multivariate: Baseline BNP did not add prognostic information independent of HFSS (p = 0.748)
Imamura 2001 | - Cohort: Ehime MIBG Heart Failure (EMIHEF Study); - Age: Mean, All subjects, 63 +/- 11; - Age: Mean, Condition 1: 64 +/- 11 (Event free); - Age: Mean, Condition 2: 65 +/- 12 (Cardiac death); - Age: Mean, Condition 3: 61 +/- 14 ( hospitalization); - % Male: 73% | 171 | - Ehime MIBG Heart Failure Study (EMIHEF) randomized trial. (NYHA II–IV): 54% level II, 18% level III, 3% level IV.; - Clinical evaluation, including NYHA, I-MIBG images, Chest x-ray, 2D echocardiography; - Mean LVEF 27%+/-10% | Progressive CHF, (combined cardiac death and CHF requiring hospitalization) | NR/No | Uni and multivariate Cox regression | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Hospitalization and death: Univariate: Baseline BNP RR = 1.006 [95% CI, 1.004–1.007], p <0.0001
Japan | | Followup: 27+/- 8 months | | | | | Threshold: > 160 pg/mL ((based on mean of sample) | Progressive CHF:Multivariate: Baseline RR = 1.005 (no CI reported), p <0.0001.
Tamura 2001 | - Cohort: N.A.; - Age: Mean, All subjects, 78 +/- 1; - Age: Mean, Condition 1: 81 +/- 2 (Cardiac event); - Age: Mean, Condition 2: 77 +/- 1 (No cardiac event); - Age: Range, All subjects, 67–92; - % Male: 48% | 48 | - Patients aged >=65 admitted to hospital with their first episode of CHF (NYHA I–IV): 23% level I, 33% level II, 8% level III, 38% level IV.; - Clinical evaluation, 2D echocardiography, radionuclide angiography and laboratory tests.; - mean LVEF varied from 38.1% +/- 5.0 ((sample with cardiac events) and 49.2% +/-2.4 (groups with non-cardiac events) | Cardiac event (readmission because of worsening CHF, angina pectoris or acute myocardial infarction or death from CHF or sudden cardiac death) | Yes/No | Uni and multivariate Cox regression | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Cardiac event: Multivariate: Predischarge logBNP = 2.656 [No CI reported], p < 0.05
Japan | | Followup: 10.8+-1.1 months (range: 1–25 months) | | | | | Threshold: 132 pg/ml (median based on sample)
Cheng 2001 | - Cohort: N.A.; - Age: Mean, 68 +/- 1.6; - Age: Range, 28 – 110; - % Male: 100% | 72 | - Convenience sample of veterans (NYHA III–IV) : mean level 3.64 +/- 0.07.; - New-onset CHF: confirmed by at least one cardiologist using standard Framingham criteria or exacerbation of previously documented CHF, NYHA class.; - LVEF < 50% (mean LVEF 37% +/-2%) | 1) readmission to the hospital facility for CHF within 30 days of initial discharge; 2) All events (combined into a single dichotomous outcome (occurrence of death or re-admission vs. no occurrence of either event)). | NR/No | Univariate logistic regression | [BNP] Biosite Diagnostics - Triage | All endpoints:Univariate: Admission BNP = p = 0.003; Admission Log BNP = p = 0.001
USA | | Followup: 30 days | | | | | Threshold: Mean admission and discharge levels, and four categories of threshold (430 pg/mL, 840 pg/mL, 1090 pg/mL, 1220 pg/mL) | All endpoints:Univariate: Discharge BNP = p < 0.0001;Discharge Log BNP = p < 0.0001
USA | | | | | | | | 30 day readmission:Univariate: Admission BNP = p = 0.03; Admission Log BNP = p = 0.01
| | | | | | | | 30 day readmission:Univariate: Discharge BNP = p = 0.05;Discharge Log BNP = p = 0.02
Maeda 2000 | - Cohort: N.A.; - Age: Mean, 63.6 +/- 1.5; - % Male: 64% | 102 | - Patients hospitalized with chronic severe. (NYHA III–IV): 56% level III, 44% level IV.; - Echocardiography at admission and 3 months.; - Mean LVEF 23% +/- 0.9% | Hospitalization for worsening CHF or MI | Yes/No (but judged independently by researchers) | Uni and multivariate Cox proportional hazards regression | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay)
Japan | | Followup: Mean: 807 days (+/- 42.3) Range: 120–1568 days (27 months) | | | | | Threshold: >170 pg/mL (median from sample) or 240 pg/ml (from ROC)
Tsutamoto 1999 | - Cohort: N.A.; - Age: Mean, 59 + 0.7; - Age: Range, 18–82; - % Male: 76.6% | 290 | - Consecutive early-stage HF patients who subsequently underwent cardiac catheterization. (NYHA I–II):32% level I, 68% level II.; - Clinical evaluation and LVEF demonstrated by ventriculography with contrast medium.; - LVEF < 45% | Morbidity (hospitalization) or mortality due to cardiovascular causes | Yes/No | Linear regression Uni and multivariate Cox proportional hazards regression | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Morbidity and Mortality: Univariate: Baseline BNP Chi Sq. = 90.5, p < 0.0001
Japan | | Followup: Mean = 502 days (range 31–1,619 days) in patients with an outcome | | | | | Threshold: 56 pg/mL (median of total sample) | Morbidity and Mortality: Multivariate: Baseline BNP Chi Sq. = 23.83, p < 0.0001
| | Mean = 1,071 days (range 31–2,541 days) for event-free patients. 36 months
Watanabe 2005 | - Cohort: CHART; - Age: Mean, 64; - % Male: 69.4% | 417 | - Hospital based cohort from the CHART study who represented CHF in real clinical situations as they had both impaired or preserved systolic dysfunction. (NYHA III–IV): 19.3% had level III/IV.; - Framingham criteria for HF, echocardiography and clinical evaluation.; - LVEF < 50% (mean LVEF 38% +/- 12%) | Combined HF events (HF mortality of hospitalization due to exacerbation of HF) | NR/No | Multivariate Cox regression | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Combined HF events: Multivariate: Baseline logBNP >= 2.12 and low ejection fraction (<=38%) HR = 2.10 [95% CI, 1.14–3.85], p = 0.0168
Japan | | Followup: mean 26 months | | | | | Threshold: Log BNP >=2.12 (median based on sample)
Hamada 2005 | - Cohort: N.A.; - Age: Mean, Condition 1: 67 +/- 9 (old MI); - Age: Mean, Condition 2: 60 +/- 17 years (dilated cardiomyopathy); - % Male: 63% | 52 | - Patients with chronic CHF admitted for acute emergency decompensation. (NYHA III–IV); - Clinical evaluation, chest X-ray, and echocardiography.; - LVEF <40 | Re-hospitalization for acute decompensation of CHF or cardiac death | NR/No | Multivariate Cox proportional hazards regression | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Cardiac events: Multivariate: Baseline BNP Chi Sq.= 1.016, p = 0.314
Japan | | Followup: 1 year (5.9 +/- 3.7 months) | | | | | Threshold: > 230 pg/ml (median pre-discharge BNP level) | Cardiac events: Multivariate: Baseline BNP & Decceleration time Chi Sq.= 0.282, p = 0.596
| | | | | | | | Cardiac events: Multivariate: Discharge BNP Chi Sq.= 6.899, p = 0.0086 (Exponential of coefficient = 15.758)
| | | | | | | | Cardiac events: Multivariate: Discharge BNP & Decceleration time Chi Sq.= 2.96, p = 0.853
Bertinchant 2005 | - Cohort: N.A.; - Age: Median, 54 +/- 7.2; - % Male: 87% | 63 | - Acute and chronic CHF patients referred to the cardiology department. Those that were acute (n=19) required urgent hospital admission because of cardiac decompensation. All patients had been symptomatic within the previous 12 months. (NYHA I–IV): 36.6 levels I/II, 49.2 level III, 14.3 level IV.; - Clinical evaluation only.; - LVEF < 45% (mean 24% +/- 9.7%) | Worsening CHF and cardiac death | NR/No | Uni and multivariate Logistic Cox regression analysis | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Mortality or HF: Univariate: Baseline BNP > 254 ng/L Chi Sq. = 7.33, p = 0.0068
France | | Followup: median 22 months (range 1–45), median event-free survival time for all CHF patients was 33.8 months | | | | | Threshold: > 254 ng/l (optimal threshold from ROC analysis). [Conversion 254 pg/mL] | Mortality or HF: Multivariate: Baseline BNP > 254 ng/L RR = 3.23 [95% CI, 1.32–7.94], p 0.01 (BNP was only significant independent predictor).
Van Beneden 2004 | - Cohort: N.A.; - Age: Mean, 58 +/- 6 (Controls); - Age: Mean, Condition 1: 62 +/- 7 (Mild to moderate CHF); - Age: Mean, Condition 2: 67 +/- 8 (Severe CHF),; - % Male: 84% | 117 | - Three groups: Patients with mild to moderate CHF, severe CHF, and 30 healthy age and sex matched controls. (NYHA I–IV); - Clinical evaluation only.; - Mean LVEF Mild /moderate group = 29.4% +/- 4%, mean LVEF severe CHF = 20.8% +/- 6%. | Urgent heart transplant | NR/No | Multivariate Cox regression analysis | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) | Not reported
Belgium | | Followup: Severe CHF group survivors mean 81 +/- 15 months (range 60–91 months) Mild to moderate CHF group survivors mean 92 +/- 3 months (range 87–96) | | | | | Threshold: Median values of BNP, N-BNP, LogBNP, and LogN-BNP (values not reported) were used only if significant. Only logN-BNP was used as it had the highest statisitical significance. Mean values for mild to moderate CHF N-BNP = 491 fmol/mL [4152.3 pg/mL], and sever CHF N-BNP = 1,521 fmol/mL [8,457 pg/mL]
Berger 2003 | - Cohort: N.A.; - Age: Mean, 54 +/- 10; - % Male: 87% | 452 | - Ambulatory patients recruited from a HF centre.(NYHA I -IV): 12% level I, 34% l3vel II, 33% level III, 21% level IV.; - Clinical evaluation and LVEF (method not specified; - Not specified | Death or urgent heart transplantation | NR/NR | Multivariate Cox proportional hazard regression | [BNP] Biosite Diagnostics - Triage/Evaluated BNP and N-BNP | For combined death and urgent cTx: Multivariate
Austria | | Followup: followed up at 1, 2, and 3 years. 36 months | | | | | Threshold: logBNP 2.11 (approximated 130 pg/mL) and was based on the highest sensitivity from ROC curve analysis (to discriminate between patients who succumbed to sudden death and survivors). | MILD CHF (Group A):Baseline Log BNP 2 yr Chi Sq. = 5, p < 0.05; 3 yr Chi Sq. = 8, p < 0.005
| | | | | | | Thresholds for BNP, N-BNP, logN-bnp were not reported but use dinmultivariate analyses. | MODERATE CHF (Group B): Baseline Log BNP 3 yr Chi Sq. = 8, p < 0.001 ALL Subjects: Log BNP (not significant for any year)
| | | | | | | | MILD CHF (Group A): Baseline Log N-BNP Not significant for any year
| | | | | | | | MODERATE CHF (Group B):Log N-BNP 2 yr Chi Sq. = 19, p < 0.0001; LogN-BNP 3 yr Chi Sq. = 22, p < 0.0001
| | | | | | | | ALL Subjects: Baseline Log N-BNP 1 yr Chi Sq. = 4, p < 0.05; Log N-BNP 2 yr Chi Sq. = 10, p < 005; Log N-BNP 3 yr Chi Sq. = 11, p < 0.005

Abbreviations: NA=not applicable, NR=not reported, HF=heart failure, CHF=congestive heart failure, LVEF=left ventricular ejection fraction, NYHA=New York Heart Association, MI=myocardial infarction, ECG=electrocardiograph

Table 11 Evidence Table. Summary of studies in patients with HF and mortality outcomes: NT-proBNP

Study | Sample characteristics | Sample size /Followup | Diagnostic criteria | BNP method /Unit threshold | Quality Consecutive cohort /Outcome blinding | Outcomes | Analysis / model | Measure of association
Rossig 2004 | Cohort: NA | 48 | Outpatient HF clinic (NYHA class II–): 42% level II, 44% level III, 14% level IV. Clinical evaluation and previous medical history. Mean LVEF 25% +/- 1% | [NT-proBNP] Roche Diagnostics - Elecsys 1010, Elecsys 2010, E170 or Modular | No/No | All-cause mortality | Uni and multivariable Cox Proportional Hazard Regression | Mortality: Univariate: Baseline LogNT-proBNP HR = 7.76 (95% CI, 2.63–22.86), p < 0.001
Germany | Age: mean 57 +/- 1 | Followup: Minimum followup of 30 months (median followup for survivors 1254 days). 42 months | | Threshold: continuous variable (pg/mL) | | | | Mortality: Multivariate with NYHA class: Step I: Baseline Log NT-proBNP per log (NT-proBNP), HR = 5.66 (95% CI, 1.69–18.95), p 0.005
| % Male: 77% | | | | | | | Mortality: Multivariate with serum creatinine: Baseline Log NT-proBNP per log (pro-BNP), HR =6.61 (95% CI, 2.05–21.29), p = 0.002
| | | | | | | | Mortality: Multivariate with blood pressure: Baseline Log NT-proBNP per log (pro-BNP), HR = 9.18 (95% CI, 2.52–33.41), p = 0.001 (When Log NT-proBNP and blood pressure were considered together, both parameters remained independent significant predictors of mortality)
| | | | | | | | Mortality: Multivariate with blood pressure and apoptosis: Baseline Log NT-proBNP per log (pro-BNP), HR = 9.35 (95% CI, 2.42–36.10), p = 0.001
Rothenburger 2004 | Cohort: NA | 550 | Recruited to interdisciplinary Heart Failure Program (NYHA II–IV): Dilative Cardiomyopathy mean NYHA 2 +/- 1, CAD mean NYHA 3 +/- 1. Clinical, Echocardiography, ECG. Dilative Cardiomyopathy mean LVEF 32% +/- 13% CAD LVEF 31% +/- 11%. | [NT-proBNP] Roche Diagnostics - Elecsys 1010, Elecsys 2010, E170 or Modular | Yes/Yes | Prediction ability for selection of cardiac transplant by cardiologists blinded to NT-proBNP levels | Multivariate Cox Logistic Regression | Cardiac Transplantation selection: Univariate: Baseline NT-proBNP > 1000ng/mL OR = 10.6 [95% CI, 3.7– 14.5], p = 0.01
Germany | Age: Condition 1 mean age 55 +/- 11 | Followup: 2 yrs | | Threshold: > 1000 ng/mL
| Age: Condition 2 mean age 57 +/- 8
| % Male: 75%
Hartmann 2004 | Cohort: COPERNICUS | 1048 | European patients with chronic severe HR enrolled in a Multicenter RCT (Copernicus) one treatment arm on carvedilol (NYHA not reported). Clinical evaluation, LVEF. Mean LVEF 20.4% +/- 3.6% | [NT-proBNP] Roche Diagnostics - Elecsys 1010, Elecsys 2010, E170 or Modular | No/No | (1) all cause mortality; (2) all cause mortality or heart failure hospitalisation; (3) all cause mortality or hospitalisation for cardiovascular reasons; (4) all cause mortality or hospitalisation for any reason | Univariate Cox proportional hazards regression | All cause mortality: UnivariateL NT-proBNP (10 pmol/L increase) RR = 1.005 [95% CI, 1.003–1.006], p = 0.0001
Germany | Age: Mean 62.5 +/- 11.0 | Followup: 29 months | | Threshold: specified as above and below median (value not reported) (pmol/L) | | | | All cause mortality: Univariate: NT-proBNP (above and below median) > 1762 pmol/L RR = 3.13 [95% CI, 1.94–5.07], p = 0.0001
| % Male: 81%
Kirk 2004 | Cohort: CHHF (Copenhagen Hospital Heart Failure Study) | 2230 | Patients admitted to general city hospital with HF (NYHA classification not reported) (Total sample contained subjects subsequently determined to not have HF). European Society of Cardiology criteria (clinical and echocardiography). mean LVEF HF group: 45.3% +/- 1.1% | [NT-proBNP] Roche Diagnostics - Elecsys 1010, Elecsys 2010, E170 or Modular | Yes/No (Physician blinded to NT-proBNP levels) | All cause mortality | Multivariate logistic regression | Mortality in total sample: Univariate: NT-proBNP levels predicted mortality in total population (data not shown)
Denmark | Age: Condition 1 mean 73.0 years (no HF) | Followup: 1 year | | Threshold: continuous variable (pmol/L) | | | | Mortality in HF patients: Multivariate: ln(NT-proBNP) OR = 1.66 [95% CI, 1.25–2.2], was significant (p value not reported)
| Age: Condition 2 mean 78.0 years (HF) % Male: 41%
| % Male: 41%
Gardner 2003 | Cohort: NA | 142 | Patients with advanced CHF referred for consideration of heart transplant surgery (NYHA II–IV): 14.8% level II, 66.2% l3v3l III, 19% level IV. Clinical evaluation and radionuclide ventriculography. Mean LVEF = 14.9% +/- 7.1%; LVEF < 35% | [NT-proBNP] Roche Diagnostics - Elecsys 1010, Elecsys 2010, E170 or Modular | Yes/No | 1) All cause mortality,; (2) death from worsening HF,; 3) Hospitalisation for CHF or Coronary syndromes | Uni and multivariate Cox proportional hazards analysis | All cause mortality:Univariate: NT-proBNP > 1490 pg/mL OR = 5.0 [95% CI, 1.6–15.9], p = 0.006
Scotland | Age: mean 50.4+/-10.5 | Followup: median time 374 days range (1–660 days)13 months | | Threshold: >1490 pg/mL (median of sample) | | | | All cause mortality or urgent transplantation: Univariate: NT-proBNP > 1490 pg/mL OR = 6.8 [95% CI, 2.2–21.1], p = 0.001
| % Male: 82.4% | | | | | | | All cause mortality: Multivariate: NT-proBNP > 1490 pg/mL Chi Sq. = 6.03, p = 0.01 ONLY independent predictor
| | | | | | | | All cause mortality and urgent transplant: Multivariate: NT-proBNP > 1490 pg/mL Chi Sq. = 6.03, p = 0.01
Stanek 2001 | Cohort: NA | 91 | Subjects with HF (LVEF < 25%) from a substudy of subjects from RCT evaluating those on atenolol versus placebo. (NYHA II–IV): 78% level II, 13% level III, 2% level IV. Radionuclide ventriculography and clinical evaluation. LVEF < 25% (mean 17% ) | [NT-proBNP] Biomedica Grupe - No instrument, EIA (manual assay) | No (clinical trial)/No | Cardiac mortality | Uni and mulitvariate Cox proportional hazards regression | Death: Multivariate: Baseline LogBNP Chi Sq. = 13.9, p = 0.0002
Austria | Age: Condition 1 mean 51+/-11 years (Atenolol) | Followup: 4 years | | Threshold: continuous variable (fol/mL) | | | | Death: Multivariate: Last followup LogBNP Chi Sq. = 21.3, p = 0.0001
| Age: Condition 2 mean 52+/-10 years (Placebo) | | | | | | | Death: Multivariate: Last followup LogNT-proBNP Chi Sq. = 8.9, p = 0.0027
| % Male: 97%
Richards 2001 | Cohort NA: | 297 | Substudy of patients with chronic stable randomized to receive Atenolol or placebo. (NYHA II–IV). 30% level I at randomization, but 43% had been previously in level IV. Radionuclide ventriculography and clinical evaluation. LVEF < 45% (mean LVEF 29%) | [NT-proBNP] New Zealand (Christchurch) - no instrument, manual assay | No(subset of clinical trial)/No | 1) All-cause mortality; 2) Death from worsening HF; 3) Episodes of worsening HF (defined as deterioration requiring an increase in nonstudy anti-HF treatments, an increase in NYHA functional class, hospital admission for worsening symptoms of HF or nonsudden death from progressive HF); 4) Hospital admission for worsening HF and hospital admission for acute coronary syndromes | Multivariate Cox proportional hazards analysis | All cause mortality, Admission for worsening HF and episodes of worsening HF NT-proBNP (significant, p level not reported) [NT-proBNP not significant for admission with acute coronary syndrome]
New Zealand | Age: Not reported | Followup: 18 months | | Threshold: continuous variable (pmol/L)
| % Male: Not reported
Taniguchi 2004 | Cohort : NA | 71 | Patients hospitalized for acute HF (decompensated) (NYHA I–IV): 14% level I, 31% level II, 31% level III, 24% level IV. Clinical evaluation and roentgenographically apparent pulmonary eodema. LVEF Not reported | [NT-proBNP] Roche Diagnostics - Elecsys 1010, Elecsys 2010, E170 or Modular | Yes/No | Sudden death, CHF death, rehospitalization for CHF, adverse cardiac events (sudden death without apparent ischemia, death from CHF, or rehospitalisation for cardiac decompensation with pulmonary oedema) | Kaplan Meier's and ROC curves only | Not estimated
Japan | Age: mean 68.4 +/- 1.4 | Followup: 17 months | | Threshold: cardiac compensation 1.050 pg/ml; cardiac events 2,000 pg/ml (based on ROC a nalysis)
| % Male: 52%
Hartmann 2004 | Cohort: COPERNICUS | 1011 | European patients with chronic severe HF enrolled in a Multicenter RCT (Copernicus) one treatment arm on carvedilol (NYHA not reported). Clinical evaluation, LVEF. Mean LVEF 20.4% +/- 3.6% | [NT-proBNP] Roche Diagnostics - Elecsys 1010, Elecsys 2010, E170 or Modular | No/No | 1) All cause mortality; 2) death or hospitalized for HF; 3) death or hospitalized for CV reasons specified in protocol.; 4) death or hospitalization for any reason | Uni and multivariate Cox proportional hazards regression | All cause mortality : Univariate: NT-proBNP > 1767 pg/mL RR = 2.7 [95% CI, 1.7 to 4.3], p < 0.0001
Germany | Age: mean 62.7 +/- 10.9 | Followup: 24 months | | Threshold: > 1767 pg/ml (median) | | | | All-cause mortality or hospitalization for heart failure: Univariate: NT-proBNP > 1767 pg/mL RR = 2.4 [95% CI 1.8 to 3.4], p< 0.0001
| % Male: 81% | | | | | | | All-cause mortality or protocol specified CV hospitalizations: Univariate: NT-proBNP > 1767 pg/mL RR = 2.09 [95% CI, 1.57–2.77], p = 0.0001
| | | | | | | | All cause mortality : Multivariate: NT-proBNP > 1767 pg/mL RR = 2.17 [95% CI, 1.33 to 3.54], p < 0.02
| | | | | | | | All-cause mortality or hospitalization for HF: Multivariate: NT-proBNP > 1767 pg/mL RR = 2.11 [95% CI, 1.54 to 2.90], p< 0.0001
Berger 2005 | Cohort: none | 452 | Ambulatory patients recruited from a HF centre. (NYHA I –IV): 12% level I, 34% l3vel II, 33% level III, 21% level IV. Clinical evaluation and LVEF (method not specified). LVEF < 35% (Mean 20% +/- 7%) | [BNP] Biosite Diagnostics - Triage [NT-proBNP] Biomedica Grupe - No instrument, EIA (manual assay) | No/No | Sudden death and heart failure death | Uni and multivariate Cox proportional hazard regression | Pump Failure: Multivariate: Baseline BNP Chi Sq. = 7.4, p 0.007
Austria | Age: mean 54 +/- 10 | Followup: mean 592 days +/- 387 days 20 months | | Threshold: continous variable (pg/mL) | | | | Pump Failure: Univariate: Baseline Log BNP Chi Sq. = 33.4, p 0.0001
| % Male: 87% | | | | | | | Pump Failure: Univariate: Baseline Log N-BNP Chi Sq. = 28.4, p 0.0001
| | | | | | | | Pump Failure: Multivariate: Baseline Log BNP Chi Sq. = 10.7, p 0.001
VAN BENEDEN 2004 | Cohort: none | 117 | Three groups: Patients with mild to moderate CHF, severe CHF, and 30 healthy age and sex matched controls. (NYHA I–IV). Clinical evaluation only. Mean LVEF Mild /moderate group = 29.4% +/- 4%, mean LVEF severe CHF = 20.8% +/- 6%. | [BNP] Shionogi & Co. Ltd - No instrument, Shionoria-IRMA (manual assay) [ NT-proBNP] Biomedica Grupe - No instrument, EIA (manual assay) | No/No | All cause mortality Cardiovascular mortality Urgent heart transplant | Multivariate Cox regression analysis | Mortality in severe CHF group: Univariate: Baseline NT-BNP Log Likelihood Chi Sq. = 5.68, p = 0.017
Belgium | Age: All mean 58 +/- 6 years (Controls) | Followup: Severe CHF group survivors mean 81 +/- 15 months (range 60–91 months) Mild to moderate CHF group survivors mean 92 +/- 3 months (range 87–96) | | Threshold: continous variable (pg/mL) | | | | Mortality in severe CHF group: Univariate: Baseline BNP RIA Log Likelihood Chi Sq. = 2.14, p = 0.143
| Age: Condition 1 mean 62 +/- 7 years (Mild to moderate CHF) | | | | | | | Mortality in severe CHF group: Univariate: Baseline BNP IRMA Log Likelihood Chi Sq. = 0.71, p = 0.40
| Age: Condition 2 mean 67 +/- 8 years (Severe CHF
| % Male: 84%

Abbreviations: HF=heart failure, LVEF=left ventricular ejection fraction, HR=hazards ratio, CI=confidence interval, NA=not applicable, NYHA=New York Heart Association, RIA=radioimmunoassay, CHF=congestive heart failure, ROC=receiver operator characteristic, CAD=coronary artery disease, ECG=electrocardiogram

Table 12 Evidence Table. Summary of studies in patients with HF and mixed outcomes: NT-proBNP

Study | Sample characteristics | Sample size /Followup | Diagnostic criteria | NT-proBNP method/Unit threshold | Quality Consecutive cohort /Outcome blinding | Outcomes | Analysis | Measure of Association
Gwechenberger 2004 | Cohort: NA | 100 | Stable CHF (NYHA II–IV), 78% level II, 20% level III, 2% level IV. Clinical examination. LVEF <=25% | [NT-proBNP] Biomedica Grupe - No instrument, EIA (manual assay) | No/No | Worsening Myocardial Failure (WHF) defined as any of the following: | Uni and Multivariate Cox proportional hazards regression | Worsening HF: Univariate: Baseline Log NT-proBNP Chi Sq. = 3.857, p = 0.049
Austria | Age: Condition 1 mean 52.47+/- 9.69/ | Followup: mean 378 days (range 4 to 999 days) 13 mon | | Threshold: not specified for NT-proBNP (fmol/L) | | (1) Hospitalised for WHF;; (2) need for IV therapy;; (3) need for urgent CTx; or; (4) death from pump failure as a consequence of WHF | | Worsening HF: Multivariate: Baseline LogNT-proBNP not significant predictor
| Condition 2 mean 50.52+/- 11.0 | | | | | | | Worsening HF Univariate: Baseline LogBNP Chi Sq. = 19.331 p = 0.001
| % Male: 89% | | | | | | | Worsening HF: Multivariate: BaselineLogBNP Chi Sq. = 14.163, p = 0.0002
Hartmann 2004 | Cohort: COPERNICUS | 1048 | European patients with chronic severe HR enrolled in a Multicentre RCT (Copernicus) one treatment arm on carvedilol (NYHA not reported). Clinical evaluation, LVEF. Mean LVEF 20.4% +/- 3.6% | [NT-proBNP] Roche Diagnostics - Elecsys 1010, Elecsys 2010, E170 or Modular | No/No | (1) all cause mortality; (2) all cause mortality or heart failure hospitalisation; (3) all cause mortality or hospitalisation for cardiovascular reasons; (4) all cause mortality or hospitalisation for any reason | Univariate Cox proportional hazards regression | Not reported
Germany | Age: Mean 62.5 +/- 11.0 | Followup: 29 months | | Threshold: specified as above and below median (value not reported) (pmol/L)
| % Male: 81%
Gardner 2003 | Cohort: NA | 142 | Patients with advanced CHF referred for consideration of heart transplant surgery (NYHA II–IV): 14.8% level II, 66.2% l3v3l III, 19% level IV. Clinical evaluation and radionuclide ventriculography. Mean LVEF = 14.9% +/- 7.1%; LVEF < 35% | [NT-proBNP] Roche Diagnostics - Elecsys 1010, Elecsys 2010, E170 or Modular | Yes/No | (1) All cause mortality,; (2) death from worsening HF,; (3) Hospitalisation for CHF or Coronary syndromes | Uni and multivariate Cox proportional hazards analysis | All cause mortality:Univariate: NT-proBNP > 1490 pg/mL OR = 5.0 [95% CI, 1.6–15.9], p = 0.006
Scotland | Age: mean 50.4+/-10.5 | Followup: median time 374 days range (1–660 days)13 months | | Threshold: >1490 pg/mL (median of sample) | | | | All cause mortality or urgent transplantation: Univariate: NT-proBNP > 1490 pg/mL OR = 6.8 [95% CI, 2.2–21.1], p = 0.001
| % Male: 82.4% | | | | | | | All cause mortality: Multivariate: NT-proBNP > 1490 pg/mL Chi Sq. = 6.03, p = 0.01 ONLY independent predictor
| | | | | | | | All cause mortality and urgent transplant: Multivariate: NT-proBNP > 1490 pg/mL Chi Sq. = 6.03, p = 0.01
O'Brien 2003 | Cohort: NA | 96 | Patients admitted to coronary care unit with dianosis of acute left ventricular failure. (Killp class II–IV): 39% level II, 55% level III, 6% level IV. Clinical evalation. LVEF not reported | [NT-proBNP] Manual method referencing * | Yes/No | Combined endpoint of death, HF readmission, and worsening HF in an outpatient setting. | Univariate and multivariate analyses (type not specified) | Combined endpoint: Multivariate: Whole sample Baseline NT-proBNP OR = 1.84 [95% CI, 0.75–4.51], p = 0.185
UK | Age: mean 74 | Followup: median 350 days (2–762) 11.6 months | | Threshold: continuous variable (fmol/mL) | | | | Combined endpoint: Multivariate: Subset sample Predischarge NT-proBNP OR = 15.30 [95% CI, 1.4–168.9], p = 0.026
| % Male: 56%
Fisher 2003 | Cohort: NA | 87 | Patients admitted on an emergency basis with CHF caused by left ventricular systolic dysfunction (NYHA II–IV): 24% level II, 32% level III, 44% level IV. Clinical evaluation. LVEF not reported | [NT-proBNP] Roche Diagnostics - Elecsys 1010, Elecsys 2010, E170 or Modular | No (clinical trial)/Yes | Death or readmission with HF | Uni and multivariate regression analysis (type not specified) | Death or re-hospitalization: Multivariate: Predischarge NT-proBNP OR = 4.15, p = 0.003
UK | Age: mean 75 | Followup: mean 12 months | | Threshold: > 2994 pg/mL (median in sample) | | | | Death: Multivariate: Predischarge NT-proBNP OR = 2.22, p = 0.03
| % Male: 58.6%
Hulsmann 2002 | Cohort: NA | 96 | Patients treated in clinic with documented HF based on LVEF function. Subjects were excluded from analysis if they underwent elective cTx. (NYHA I–III): 35% level I, 30% level II, 29% level III, 6% level IV. HF based on LVEF level. Mean LVEF 26+/- 10%. | [BNP] Biosite Diagnostics - Triage [N-BNP] Biomedica | Yes/No | Death or worsening heart failure (decompensation, needing I.V. support and malignant arrhythmia) | Multivariate Cox proportional hazard regression | Death or worsening HF: Multivariate: Baseline BNP Chi Sq. = 8, p < 0.01
Austria | Age: mean age 57 +/- 8 | Followup: 1 year | | Threshold: continuous variable (fmol/mL) | | | | Death or worsening HF: Multivariate: Baseline proBNP Chi Sq. = 58, p < 0.0001
| % Male: 82%
Zugck 2002 | Cohort: NA | 408 | Ambulatory chronic CHF patients being treated with ACE inhibitor or angiotensin type 1 receptor antagonist. Subjects divided into 2 groups: those treated with Beta-blockers and those not treated with b-blockers. (NYHA I–IV). 15% level I, 41% level II, 42% level III, 2% level IV, and mean NYHA level 2.3 +/- 0.7. Clinical evaluation, Radionuclide ventriculography. LVEF < 45%. Mean LVEF = 22% +/- 10% | [NT-proBNP] Manual method referencing * | Yes/No | Cardiac death or hospital admission for worsening HF or hospital admission with IV inotropic, diuretic, or mechanical support. | Uni and multivariate Cox regression analysis | Combined outcome: Univariate: All patients NT-proBNP Chi Sq. = 49.2, p = 0.0001 (also significant for groups treated with and without Beta-blockers)
Germany | Age: mean 55 +/11 | Followup: 1 year | | Threshold: continuous variable (pmol/L) | | | | Combined outcome: Multivariate: All patients NT-proBNP Chi Sq. = 8.1, p = 0.0045 (significant only for patients NOT on Beta-blockers)
| % Male: 84%
Bettencourt 2004 | Cohort: NA | 156 | Patients admitted due to decompensated heart failure (NYHA III–IV): 33% level III, 67% level IV. Clinical diagnosis using European Society of Cardiology criteria or Framingham criteria for HF. LVEF not reported on admission | [NT-proBNP] Roche Diagnostics - Elecsys 1010, Elecsys 2010, E170 or Modular | Yes/No | Death or hospital re-admission | Uni and multivariate Cox proportional hazard regression | Composite outcomes: ~ Univariate: Baseline NT-proBNP (per 1000 pg/mL increase) HR = 1.012, [95% CI, 1.005–1.020] p NR
Portugal | Age: mean 73 +/- 11 | Followup: 6 months | | Threshold: continuous variable but categorized into 1000 pg/mL and relative change of 30% | | | | ~Univariate: Discharge NT-proBNP (per 1000 pg/mL increase) HR = 1.018, [95% CI, 1.012–1.024] p NR
| % Male: 47% | | | | | | | ~Univariate: Change in NT-proBNP (vs decrease > 30%) changed in either direction HR = 2.19, [95% CI, 1.23– 3.91] p NR
| | | | | | | | 'Univariate: Change in NT-proBNP (vs decrease > 30%) increased > 30% HR = 6.64, [95% CI, 3.60– 12.23] p NR
| | | | | | | | ~ Multivariate: Change in NT-proBNP (vs decrease > 30%) changed ineither direction HR = 2.03 [95% CI, 1.14 – 3.64], p NR
| | | | | | | | ~ Multivariate: Change in NT-proBNP (vs decrease > 30%) increase > 30% HR = 5.96 [95% CI, 3.23–11.01], p NR
| | | | | | | | Death: Multivariate Change in NT-proBNP (vs decrease > 30%) changed in either direction HR = 2.59 [95% CI, 0.98–6.87], p NR
| | | | | | | | Death: Multivariate Change in NT-proBNP (vs decrease > 30%) increase > 30% HR = 3.67 [95% CI, 1.36–9.87], p NR
Hartmann 2004 | Cohort: COPERNICUS | 1011 | European patients with chronic severe HR enrolled in a Multicentre RCT (Copernicus) one treatment arm on carvedilol (NYHA not reported). Clinical evaluation, LVEF. Mean LVEF 20.4% +/- 3.6% | [NT-proBNP] Roche Diagnostics - Elecsys 1010, Elecsys 2010, E170 or Modular | No/No | 1) All cause mortality; 2) death or hospitalized for HF; 3) death or hospitalized for CV reasons specified in protocol; 4) death or hospitalization for any reason | Uni and multivariate Cox proportional hazards regression | All cause mortality : Univariate: NT-proBNP > 1767 pg/mL RR = 2.7 [95% CI, 1.7 to 4.3], p < 0.0001
Germany | Age: mean 62.7 +/- 10.9 | Followup: 24 months | | Threshold: > 1767 pg/ml (median) | | | | All-cause mortality or hospitalization for heart failure: Univariate: NT-proBNP > 1767 pg/mL RR = 2.4 [95% CI 1.8 to 3.4], p< 0.0001
| % Male: 81% | | | | | | | All-cause mortality or protocol specified CV hospitalizations: Univariate: NT-proBNP > 1767 pg/mL RR = 2.09 [95% CI, 1.57–2.77], p = 0.0001
| | | | | | | | All cause mortality : Multivariate: NT-proBNP > 1767 pg/mL RR = 2.17 [95% CI, 1.33 to 3.54], p < 0.02
| | | | | | | | All-cause mortality or hospitalization for HF: Multivariate: NT-proBNP > 1767 pg/mL RR = 2.11 [95% CI, 1.54 to 2.90], p< 0.0001
Berger 2003 | Cohort: none | 452 | Ambulatory patients recruited from a HF centre.(NYHA I –IV): 12% level I, 34% l3vel II, 33% level III, 21% level IV. Clinical evaluation and LVEF (method not specified). LVEF not specified | [BNP] Biosite Diagnostics - Triage [NT-proBNP] Biomedica Grupe - No instrument, EIA (manual assay) | No/No | death, urgent heart transplantation | Multivariate Cox proportional hazard regression | For combined death and urgent cTx: Multivariate MILD CHF (Group A):Baseline Log BNP 2 yr Chi Sq. = 5, p < 0.05; 3 yr Chi Sq. = 8, p < 0.005 MODERATE CHF (Group B): Baseline Log BNP 3 yr Chi Sq. = 8, p < 0.001
Austria | Age: mean 54 +/- 10 | Followup: 1, 2, and 3 years. 36 months | | Threshold: continous variable (pg/mL) | | | | ALL Subjects: Log BNP (not significant for any year) MILD CHF (Group A): Baseline Log N-BNP Not significant for any year MODERATE CHF (Group B):Log N-BNP 2 yr Chi Sq. = 19, p < 0.0001; LogNT-proBNP 3 yr Chi Sq. = 22, p < 0.0001
| % Male: 87% | | | | | | | ALL Subjects: Baseline Log NT-proBNP 1 yr Chi Sq. = 4, p < 0.05; Log NT-proBNP 2 yr Chi Sq. = 10, p < 005; Log NT-proBNP 3 yr Chi Sq. = 11, p < 0.005

* Carl J., Borgya A., Gallusser A. et al. Development of a novel, N-terminal-proBNP (NT-proBNP) assay with a low detection limit. Scand J Clin Lab Invest Suppl 1999; 230:177–81

Abbreviations: LVEF=left ventricular ejection fraction, NYHA=New York Heart Association, HF=heart failure, CHF=congestive heart failure, cTx=heart transplant, CV=cardiovascular, NR=not reported, NA=not applicable

Table 13 Evidence Table: Tests for heterogeneity due to STUDY SETTINGS for BNP using the lowest cut point provided in each study (Figures 3 a-e)

Study Setting | Heterogeneity Statistic (Q-test) | Probability | I-Squared
SENSITIVITY
Clinic (n=1) | NA | NA | NA
ED (n=8) | 8.55 | 0.286 | 18.2%
Primary Care (n=2) | 9.03 | 0.003 | 88.9%
Overall (n=11) | 47.77 | 0.000 | 79.1%
SPECIFICITY
Clinic | NA | NA | NA
ED | 335.03 | 0.000 | 97.9%
Primary Care | 66.25 | 0.000 | 98.5%
Overall | 508.63 | 0.000 | 98.0%
LR +
Clinic | NA | NA | NA
ED | 149.64 | 0.000 | 95.3%
Primary Care | 0.64 | 0.425 | 0.0%
Overall | 238.47 | 0.000 | 95.8%
LR -
Clinic | NA | NA | NA
ED | 22.36 | 0.002 | 68.7%
Primary Care | 0.83 | 0.362 | 0.0%
Overall | 108.45 | 0.000 | 90.8%
DOR
Clinic | NA | NA | NA
ED | 48.55 | 0.000 | 85.6%
Primary Care | 0.13 | 0.713 | 0.0%
Overall | 99.8 | 0.000 | 90.0%

Abbreviations: DOR = diagnostic odds ratio, ED = emergency department, LR- = negative likelihood ratio, LR+ = positive likelihood ratio, NA = not able calculate because not enough studies

Table 14 Evidence Table: Tests for heterogeneity due to STUDY SETTINGS for BNP using the lowest cut point provided in each study (Figures 4a-e)

Study Setting | Heterogeneity Statistic (Q-test) | Probability | I-Squared
SENSITIVITY
Clinic (n=1) | NA | NA | NA
ED (n=3) | 6.86 | 0.032 | 70.8%
Primary Care (n=3) | 6.17 | 0.046 | 67.6%
Overall (n=7) | 24.15 | 0.000 | 75.2%
SPECIFICITY
Clinic | NA | NA | NA
ED | 15.99 | 0.000 | 87.5%
Primary Care | 75.63 | 0.000 | 97.4%
Overall | 121.61 | 0.000 | 95.1%
LR +
Clinic | NA | NA | NA
ED | 10.64 | 0.005 | 81.2%
Primary Care | 25.22 | 0.000 | 92.1%
Overall | 49.51 | 0.000 | 87.9%
LR -
Clinic | NA | NA | NA
ED | 7.31 | 0.026 | 72.6%
Primary Care | 1.61 | 0.447 | 0.0%
Overall | 11.55 | 0.073 | 48.1%
DOR
Clinic | NA | NA | NA
ED | 9.51 | 0.009 | 79.0%
Primary Care | 0.2 | 0.904 | 0.0%
Overall | 11.81 | 0.066 | 49.2%

Abbreviations: DOR = diagnostic odds ratio, ED = emergency department, LR- = negative likelihood ratio, LR+ = positive likelihood ratio, NA = not able calculate because not enough studies

Table 15 Evidence Table: Tests for heterogeneity due to STUDY SETTINGS for BNP in the ED using a cut point of 100 pg/mL (Figures 5a-e)

Study Setting | Heterogeneity Statistic (Q-test) | Probability | I-Squared
SENSITIVITY
ED (n=6) | 14.24 | 0.014 | 64.9%
SPECIFICITY
ED | 203.58 | 0.000 | 97.5%
LR +
ED | 152.93 | 0.000 | 96.7%
LR -
ED | 9.16 | 0.103 | 45.4%
DOR
ED | 33.56 | 0.00 | 85.1%

Abbreviations: DOR = diagnostic odds ratio, ED = emergency department, LR- = negative likelihood ratio, LR+ = positive likelihood ratio

Table 16 Evidence Table: Tests for heterogeneity due to STUDY DESIGN for BNP using the lowest cut point provided in each study

Study Setting | Heterogeneity Statistic (Q-test) | Probability | I-Squared
SENSITIVITY
Cross sectional (n=8) | 35.68 | 0.000 | 80.4%
Diagnostic (n=2) | 11.93 | 0.001 | 91.6%
Prospective Cohort (n=1) | NA | NA | NA
Overall (n=11) | 47.77 | 0.000 | 79.1%
SPECIFICITY
Cross sectional | 424.00 | 0.000 | 98.3%
Diagnostic | 14.94 | 0.00 | 93.37%
Prospective Cohort | NA | NA | NA
Overall | 508.63 | 0.000 | 98.1%
LR +
Cross sectional | 219.52 | 0.000 | 96.8%
Diagnostic | 0.16 | 0.689 | 0.0%
Prospective Cohort | NA | NA | NA
Overall | 238.47 | 0.000 | 95.8%
LR -
Cross sectional | 78.89 | 0.00 | 91.2%
Diagnostic | 9.93 | 0.002 | 89.9%
Prospective Cohort | NA | NA | NA
Overall | 108.45 | 0.00 | 90.8%
DOR
Cross sectional | 76.71 | 0.000 | 90.9%
Diagnostic | 6.78 | 0.009 | 85.3%
Prospective Cohort | NA | NA | NA
Overall | 99.80 | 0.00 | 90.0%

Abbreviations: DOR = diagnostic odds ratio, LR- = negative likelihood ratio, LR+ = positive likelihood ratio, NA = not able calculate because not enough studies

Table 17 Evidence Table: Tests for heterogeneity due to STUDY DESIGN for NT-proBNP using the lowest cut point provided in each study

Study Setting | Heterogeneity Statistic (Q-test) | Probability | I-Squared
SENSITIVITY
Cross sectional (n=3) | 8.51 | 0.014 | 80.40%
Diagnostic (n=2) | 0.76 | 0.382 | 0.00%
Prospective Cohort (n=1) | NA | NA | NA
Randomized Trial (n=1) | NA | NA | NA
Overall (n=7) | 24.15 | 0.000 | 75.2%
SPECIFICITY
Cross-sectional | 72.43 | 0.000 | 97.2%
Diagnostic | 17.79 | 0.000 | 94.4%
Prospective Cohort | NA | NA | NA
Randomized trial | NA | NA | NA
Overall | 121.61 | 0.000 | 95.1%
LR +
Cross-sectional | 219.52 | 0.000 | 96.8%
Diagnostic | 0.16 | 0.689 | 0.0%
Prospective Cohort | NA | NA | NA
Randomized Trial | NA | NA | NA
Overall | 49.53 | 0.000 | 87.90%
LR -
Cross-sectional | 7.56 | 0.023 | 73.5%
Diagnostic | 0.19 | 0.667 | 0.0%
Prospective Cohort | NA | NA | NA
Randomized Trial | NA | NA | NA
Overall | 11.58 | 0.072 | 48.2%
DOR
Cross-sectional | 9.84 | 0.007 | 79.7%
Diagnostic | 0.00 | 0.955 | 0.0%
Prospective Cohort | NA | NA | NA
Randomized Trial | NA | NA | NA
Overall | 11.80 | 0.066 | 49.2%

Abbreviations: DOR = diagnostic odds ratio, LR- = negative likelihood ratio, LR+ = positive likelihood ratio, NA = not able calculate because not enough studies

Table 18 Evidence Table: Tests for heterogeneity due to STUDY DESIGN for BNP in the ED using a cut point of 100 pg/mL

Study Setting | Heterogeneity Statistic (Q-test) | Probability | I-Squared
SENSITIVITY
Cross sectional (n=5) | 9.89 | 0.042 | 59.5%
Diagnostic (n=1) | NA | NA | NA
SPECIFICITY
Cross sectional | 159.97 | 0.000 | 97.5%
Diagnostic | NA | NA | NA
LR +
Cross sectional | 139.89 | 0.000 | 97.1%
Diagnostic | NA | NA | NA
LR -
Cross sectional | 7.90 | 0.095 | 49.4%
Diagnostic | NA | NA | NA
DOR
Cross sectional | 33.51 | 0.000 | 88.1%
Diagnostic | NA | NA | NA

Abbreviations: DOR = diagnostic odds ratio, ED = emergency department, LR- = negative likelihood ratio, LR+ = positive likelihood ratio, NA = not able calculate because not enough studies:

Table 19 Evidence Table: Tests for heterogeneity due to CUT POINT near or exactly 100 pg/mL BNP

Study Setting | Heterogeneity Statistic (Q-test) | Probability | I-Squared
SENSITIVITY
Exactly 100pg/mL (n=1) | NA | NA | NA
Greater than 100 pg/mL (n=4) | 32.52 | 0 | 90.80%
Less than 100 pg/mL (n=6) | 1.52 | 0.911 | 0.00%
Overall (n=11) | 47.77 | 0 | 79.10%
SPECIFICITY
Exactly 100pg/mL | NA | NA | NA
Greater than 100 pg/mL | 41.19 | 0 | 92.70%
Less than 100 pg/mL | 400.57 | 0 | 98.80%
Overall | 508.63 | 0 | 98.00%
LR +
Exactly 100pg/mL | NA | NA | NA
Greater than 100 pg/mL | 19.28 | 0 | 84.40%
Less than 100 pg/mL | 212.84 | 0 | 97.70%
Overall | 238.47 | 0 | 95.80%
LR -
Exactly 100pg/mL | NA | NA | NA
Greater than 100 pg/mL | 19.5 | 0.006 | 69.50%
Less than 100 pg/mL | 16.41 | 0.006 | 69.50%
Overall | 108.45 | 0 | 90.80%
DOR
Exactly 100pg/mL | NA | NA | NA
Greater than 100 pg/mL | 31.23 | 0 | 88.80%
Less than 100 pg/mL | 41.56 | 0 | 88.00%
Overall | 99.8 | 0 | 90.00%

Abbreviations: DOR = diagnostic odds ratio, LR- = negative likelihood ratio, LR+ = positive likelihood ratio, NA = not able calculate because not enough studies:

Table 20 Evidence Table: Tests for heterogeneity due to CUT POINT exactly or greater than 100 pg/mL BNP studies in ED

Study Setting | Heterogeneity Statistic (Q-test) | Probability | I-Squared
SENSITIVITY
Exactly 100pg/mL (n=4) | 9.28 | 0.026 | 67.70%
Greater than 100 pg/mL (n=2) | 0.81 | 0.369 | 0.00%
Overall (n=6) | 14.24 | 0.14 | 64.90%
SPECIFICITY
Exactly 100pg/mL | 154.28 | 0 | 98.10%
Greater than 100 pg/mL | 48.26 | 0 | 97.90%
Overall | 203.58 | 0 | 97.50%
LR +
Exactly 100pg/mL | 117.42 | 0 | 97.40%
Greater than 100 pg/mL | 34.94 | 0 | 97.10%
Overall | 152.93 | 0 | 96.70%
LR -
Exactly 100pg/mL | 4.89 | 0.18 | 38.60%
Greater than 100 pg/mL | 0.08 | 0.777 | 0.00%
Overall | 9.16 | 0.103 | 45.40%
DOR
Exactly 100pg/mL | 25.55 | 0 | 88.30%
Greater than 100 pg/mL | 1.29 | 0.255 | 22.70%
Overall | 33.56 | 0 | 85.10%

Abbreviations: DOR = diagnostic odds ratio, ED = emergency department, LR- = negative likelihood ratio, LR+ = positive likelihood ratio

Table 21 Evidence Table: Heterogeneity for SAMPLE SIZE for the lowest cutpoint provided in each BNP study

Study Setting | Heterogeneity Statistic(Q-test) | Probability | I-Squared
SENSITIVITY
Large [n>=500](n=1) | NA | NA | NA
Small [n<500] (n=10) | 46.55 | 0.000 | 80.7%
Overall (n=11) | 47.77 | 0.000 | 79.1%
SPECIFICITY
Large [n>=500] | NA | NA | NA
Small [n<500] | 463.31 | 0.000 | 98.1%
Overall | 508.63 | 0.000 | 98.0%
LR+
Large [n>=500] | NA | NA | NA
Small [n<500] | 191.11 | 0.000 | 95.3%
Overall | 238.47 | 0.000 | 95.8%
LR-
Large [n>=500] | NA | NA | NA
Small [n<500] | 63.49 | 0.000 | 85.8%
Overall | 108.45 | 0.00 | 90.8%
DOR
Large [n>=500] | NA | NA | NA
Small [n<500] | 83.41 | 0.000 | 89.2%
Overall | 99.80 | 0.00 | 90.0%

Abbreviations:DOR = diagnostic odds ratio, LR-= negative likelihood ratio, LR+ = positive likelihood ratio, NA = not able calculate because note nough studies

Table 22 Evidence Table: Heterogeneity for SAMPLE SIZE for the lowest cut point provided in each NT-proBNP study

Study Setting | Heterogeneity Statistic(Q-test) | Probability | I-Squared
SENSITIVITY
Small [n<500] (n=7) | 24.11 | 0.0000 | 75.2%
SPECIFICITY
Small [n<500] | 121.61 | 0.000 | 95.1%
LR+
Small [n<500] | 49.53 | 0.000 | 87.9%
LR-
Small [n<500] | 11.58 | 0.072 | 48.2%
DOR
Small [n<500] | 11.80 | 0.066 | 49.2%

Abbreviations:DOR = diagnostic odds ratio, LR- = negative likelihood ratio, LR+ = positive likelihood ratio

Table 23 Evidence Table: Heterogeneity for SAMPLE SIZE for ED with a BNP cut point near 100 pg/mL

Study Setting | Heterogeneity Statistic (Q-test) | Probability | I-Squared
SENSITIVITY
Large [n≥500] (n=1) | NA | NA | NA
Small [n<500] (n=5) | 5.12 | 0.275 | 21.9%
SPECIFICITY
Large [n≥500] | NA | NA | NA
Small [n<500] | 102.66 | 0.000 | 96.7%
LR +
Large [n≥500] | NA | NA | NA
Small [n<500] | 152.93 | 0.000 | 96.7%
LR -
Large [n≥500] | NA | NA | NA
Small [n<500] | 7.91 | 0.095 | 49.4%
DOR
Large [n≥500] | NT | NT | NT
Small [n<500] | NT | NT | NT

Abbreviations: DOR = diagnostic odds ratio, ED = emergency department, LR- = negative likelihood ratio, LR+ = positive likelihood ratio, NA = not able calculate because not enough studies

Table 24 Evidence Table: Tests for heterogeneity due to REFERENCE used to diagnose HF for BNP using the lowest cut point provided in each study

Study Setting | Heterogeneity Statistic (Q-test) | Probability | I-Squared
SENSITIVITY
Compared to LVEF (n=5) | 15.21 | 0.004 | 73.7%
Compared to SS (n=4) | 0.50 | 0.919 | 0.0%
HF to Clinical Scales (n=2) | 26.02 | 0.00 | 96.2%
Overall (n=11) | 47.77 | 0.000 | 79.1%
SPECIFICITY
Compared to LVEF | 206.99 | 0.000 | 98.1%
Compared to SS | 216.40 | 0.00 | 98.6%
HF to Clinical Scales | 4.44 | 0.035 | 77.5%
Overall | 508.63 | 0.000 | 98.0%
LR +
Compared to LVEF | 53.03 | 0.000 | 92.5%
Compared to SS | 87.43 | 0.000 | 96.6%
HF to Clinical Scales | 11.16 | 0.001 | 91.0%
Overall | 238.47 | 0.000 | 95.8%
LR -
Compared to LVEF | 24.44 | 0.000 | 83.6%
Compared to SS | 4.10 | 0.251 | 26.9%
HF to Clinical Scales | 19.95 | 0.000 | 95.0%
Overall | 108.45 | 0.00 | 90.8%
DOR
Compared to LVEF | 53.03 | 0.000 | 92.5%
Compared to SS | 87.43 | 0.000 | 96.6%
HF to Clinical Scales | 11.16 | 0.001 | 91.0%
Overall | 99.80 | 0.00 | 90.0%

Abbreviations: DOR = diagnostic odds ratio, HF = heart failure, LR- = negative likelihood ratio, LR+ = positive likelihood ratio, LVEF = left ventricular ejection fraction, SS = suggestive symptoms

Table 25 Evidence Table: Tests for heterogeneity due to REFERENCE used to diagnose HF for NT-proBNP using the lowest cut point provided in each study

Study Setting | Heterogeneity Statistic(Q-test) | Probability | I-Squared
SENSITIVITY
Compared to LVEF(n=5) | 15.88 | 0.003 | 74.8%
HF to Clinical Scales(n=2) | 7.96 | 0.005 | 87.4%
Overall (n=7) | 24.15 | 0.000 | 75.2%
SPECIFICITY
Compared toLVEF | 85.52 | 0.000 | 95.3%
HF to Clinical Scales | 5.13 | 0.024 | 80.5%
Overall | 121.61 | 0.000 | 95.1%
LR+
Compared to LVEF | 33.13 | 0.000 | 88.1%
HF to Clinical Scales | 4.92 | 0.0227 | 79.7%
Overall | 49.53 | 0.000 | 87.9%
LR-
Compared toLVEF | 4.85 | 0.303 | 17.6%
HF to Clinical Scales | 6.69 | 0.010 | 85.1%
Overall | 11.58 | 0.072 | 48.2%
DOR
Compared to LVEF | 1.44 | 0.837 | 0.0%
HFto Clinical Scales | 9.84 | 0.002 | 89.8%
Overall | 11.80 | 0.066 | 49.2%

Abbreviations: DOR = diagnostic odds ratio, HF = heart failure, LR- = negative likelihood ratio, LR+ = positive likelihood ratio, LVEF = left ventricular ejection fraction

Table 26 Evidence Table: Tests for heterogeneity due to REFERENCE used to diagnose HF forBNP in the ED usinga cut point of 100pg/mL

Study Setting | Heterogeneity Statistic(Q-test) | Probability | I-Squared
SENSITIVITY
Compared to LVEF(n=2) | 4.36 | 0.037 | 77.1%
Compared to SS (n=3) | 8.68 | 0.013 | 77.0%
HF to Clinical Scales (n=1) | NA | NA | NA
Overall (n=6) | 14.24 | 0.014 | 64.9%
SPECIFICITY
Compared to LVEF | 2.04 | 0.1530 | 51.0%
Compared to SS | 124.18 | 0.000 | 98.4%
HF to Clinical Scales | NA | NA | NA
Overall | 203.58 | 0.000 | 97.5%
LR+
Compared to LVEF | 0.65 | 0.420 | 0.0%
Compared to SS | 111.88 | 0.000 | 98.2%
HF to Clinical Scales | NA | NA | NA
Overall | 152.93 | 0.000 | 96.7%
LR-
Compared to LVEF | 2.15 | 0.143 | 53.4%
Compared to SS | 3.79 | 0.151 | 47.2%
HF to Clinical Scales | NA | NA | NA
Overall | 9.16 | 0.103 | 45.4%
DOR
Compared to LVEF | 1.51 | 0.219 | 33.8%
Compared to SS | 19.69 | 0.000 | 89.8%
HF to Clinical Scales | NA | NA | NA
Overall | 33.56 | 0.000 | 85.1%

Abbreviations: DOR = diagnostic odds ratio, ED = emergency department, HF = heartfailure, LR- = negative likelihood ratio, LR+ = positive likelihood ratio, LVEF = lef tventricular ejection fraction, NA = notable calculate because not enough studies, SS = suggestive symptoms

Figure 1 QUADAS results for question 2ai papers

Figure 2 QUADAS results for question 2aii papers

Figure 3 QUADAS results for question 2aiii papers

Figure 4 QUADAS results for all question 2 papers

## References

Akioka K, Takeuchi K, Yanagi S, et al. Prognostic value of Doppler transmittal flow patterns and cardiac natriuretic peptides in patients with chronic congestive heart failure admitted for episodes of acute decompensation. Heart Vessels. 2000;15(2):53-60. [pmid: 11199504].
Alehagen U, Dahlstrom U, Lindahl TL, et al. Elevated D-dimer level is an independent risk factor for cardiovascular death in out-patients with symptoms compatible with heart failure. Thromb Haemost. Dec. 2004;92(6):1250-8. [pmid: 15583730].
Alehagen U, Eriksson H, Nylander E, et al. Heart failure in the elderly: Characteristics of a Swedish primary health care population. Heartdrug. 2002;2(5):211-20.
Anand IS, Fisher LD, Chiang YT, et al. Changes in brain natriuretic peptide and norepinephrine over time and mortality and morbidity in the Valsartan Heart Failure Trial (Val-HeFT).[see comment]. Circulation. Mar 11. 2003;107(9):1278-83. [pmid: 12628948].
Atisha D, Bhalla MA, Morrison LK, et al. A prospective study in search of an optimal B-natriuretic peptide level to screen patients for cardiac dysfunction. Am Heart J. Sep. 2004;148(3):518-23. [pmid: 15389242].
Barcarse E, Kazanegra R, Chen A, et al. Combination of B-type natriuretic peptide levels and non-invasive hemodynamic parameters in diagnosing congestive heart failure in the emergency department. Congest Heart Fail. Jul. 2004;10(4):171-6. [pmid: 15314474].
Bayes-Genis A, Santalo-Bel M, Zapico-Muniz E, et al. N-terminal probrain natriuretic peptide (NT-proBNP) in the emergency diagnosis and in-hospital monitoring of patients with dyspnoea and ventricular dysfunction. Eur J Heart Fail. Mar 15. 2004;6(3):301-8. [pmid: 14987580].
Bazzino O, Fuselli JJ, Botto F, et al. Relative value of N-terminal probrain natriuretic peptide, TIMI risk score, ACC/AHA prognostic classification and other risk markers in patients with non-ST-elevation acute coronary syndromes.[see comment]. Eur Heart J. May. 2004;25(10):859-66. [pmid: 15140534].
Berger R, Huelsmann M, Strecker K, et al. Neurohormonal risk stratification for sudden death and death owing to progressive heart failure in chronic heart failure. Eur J Clin Invest. Jan. 2005;35(1):24-31. [pmid: 15638816].
Berger R, Strecker K, Huelsmann M, et al. Prognostic power of neurohumoral parameters in chronic heart failure depends on clinical stage and observation period. J Heart Lung Transplant. Sep. 2003;22(9):1037-45. [pmid: 12957614].
Bertinchant JP, Combes N, Polge A, et al. Prognostic value of cardiac troponin T in patients with both acute and chronic stable congestive heart failure: comparison with atrial natriuretic peptide, brain natriuretic peptide and plasma norepinephrine. Clin Chim Acta. Feb. 2005;352(12):143-53. [pmid: 15653109].
Bettencourt P, Azevedo A, Pimenta J, et al. N-terminal-pro-brain natriuretic peptide predicts outcome after hospital discharge in heart failure patients. Circulation. Oct 12. 2004;110(15):2168-74. [pmid: 15451800].
Bettencourt P, Ferreira A, Dias P, et al. Evaluation of brain natriuretic peptide in the diagnosis of heart failure.[see comment]. Cardiology. 2000;93(12):19-25. [pmid: 10894902].
Bettencourt P, Ferreira A, Dias P, et al. Predictors of prognosis in patients with stable mild to moderate heart failure. J Card Fail. Dec. 2000;6(4):306-13. [pmid: 11145755].
Bettencourt P, Ferreira A, Pardal-Oliveira N, et al. Clinical significance of brain natriuretic peptide in patients with postmyocardial infarction. Clin Cardiol. Dec. 2000;23(12):921-7. [pmid: 11129679].
Bettencourt P, Ferreira A, Sousa T, et al. Brain natriuretic peptide as a marker of cardiac involvement in hypertension. Int J Cardiol. May 15. 1999;69(2):169-77. [pmid: 10549840].
Bettencourt P, Ferreira S, Azevedo A, et al. Preliminary data on the potential usefulness of B-type natriuretic peptide levels in predicting outcome after hospital discharge in patients with heart failure. Am J Med. Aug 15. 2002;113(3):215-9. [pmid: 12208380].
Bettencourt P, Frioes F, Azevedo A, et al. Prognostic information provided by serial measurements of brain natriuretic peptide in heart failure. Int J Cardiol. Jan. 2004;93(1):45-8. [pmid: 14729434].
Bhalla MA, Chiang A, Epshteyn VA, et al. Prognostic role of B-type natriuretic peptide levels in patients with type 2 diabetes mellitus. J Am Coll Cardiol. Sep 1. 2004;44(5):1047-52. [pmid: 15337217].
Bibbins-Domingo K, Ansari M, Schiller NB, et al. Is B-type natriuretic peptide a useful screening test for systolic or diastolic dysfunction in patients with coronary disease? Data from the Heart and Soul Study.[see comment]. Am J Med. Apr 15. 2004;116(8):509-16. [pmid: 15063811].
Cheng V, Kazanagra R, Garcia A, et al. A rapid bedside test for B-type peptide predicts treatment outcomes in patients admitted for decompensated heart failure: a pilot study. J Am Coll Cardiol. Feb. 2001;37(2):386-91. [pmid: 11216951].
Dao Q, Krishnaswamy P, Kazanegra R, et al. Utility of B-type natriuretic peptide in the diagnosis of congestive heart failure in an urgent-care setting. J Am Coll Cardiol. Feb. 2001;37(2):379-85. [pmid: 11216950].
de Groote P, Dagorn J, Soudan B, et al. B-type natriuretic peptide and peak exercise oxygen consumption provide independent information for risk stratification in patients with stable congestive heart failure.[see comment]. J Am Coll Cardiol. May 5. 2004;43(9):1584-9. [pmid: 15120815].
de Winter RJ, Stroobants A, Koch KT, et al. Plasma N-terminal pro-B-type natriuretic peptide for prediction of death or nonfatal myocardial infarction following percutaneous coronary intervention. Am J Cardiol. Dec 15. 2004;94(12):1481-5. [pmid: 15589000].
Dias P, Rodrigues RA, Queiros MC, et al. Prognosis in patients with heart failure and preserved left ventricular systolic function. Rev Port Cardiol. Dec. 2001;20(12):1223-32. [pmid: 11865682].
Dokainish H, Pillai M, Murphy SA, et al. Prognostic implications of elevated troponin in patients with suspected acute coronary syndrome but no critical epicardial coronary disease: a TACTICS-TIMI-18 substudy. J Am Coll Cardiol. Jan 4. 2005;45(1):19-24. [pmid: 15629367].
Fisher C, Berry C, Blue L, et al. N-terminal pro B type natriuretic peptide, but not the new putative cardiac hormone relaxin, predicts prognosis in patients with chronic heart failure. Heart. Aug. 2003;89(8):879-81. [pmid: 12860863]. [pmcid: 1767758].
Fung JW, Yu CM, Yip G, et al. Effect of beta blockade (carvedilol or metoprolol) on activation of the renin-angiotensin-aldosterone system and natriuretic peptides in chronic heart failure. Am J Cardiol. Aug 15. 2003;92(4):406-10. [pmid: 12914870].
Gaede P, Hildebrandt P, Hess G, et al. Plasma N-terminal pro-brain natriuretic peptide as a major risk marker for cardiovascular disease in patients with type 2 diabetes and microalbuminuria. Diabetologia. 2005;48(1):156-63. [pmid: 15619076].
Galvani M, Ottani F, Oltrona L, et al. N-terminal pro-brain natriuretic peptide on admission has prognostic value across the whole spectrum of acute coronary syndromes. Circulation. Jul 13. 2004;110(2):128-34. [pmid: 15197143].
Gardner RS, Ozalp F, Murday AJ, et al. N-terminal pro-brain natriuretic peptide. A new gold standard in predicting mortality in patients with advanced heart failure. Eur Heart J. Oct. 2003;24(19):1735-43. [pmid: 14522568].
Grabowski M, Filipiak KJ, Karpinski G, et al. Serum B-type natriuretic peptide levels on admission predict not only short-term death but also angiographic success of procedure in patients with acute ST-elevation myocardial infarction treated with primary angioplasty. Am Heart J. Oct. 2004;148(4):655-62. [pmid: 15459597].
Groenning BA, Raymond I, Hildebrandt PR, et al. Diagnostic and prognostic evaluation of left ventricular systolic heart failure by plasma N-terminal pro-brain natriuretic peptide concentrations in a large sample of the general population. Heart. Mar. 2004;90(3):297-303. [pmid: 14966052]. [pmcid: 1768111].
Gustafsson F, Badskjaer J, Hansen FS, et al. Value of N-terminal proBNP in the diagnosis of left ventricular systolic dysfunction in primary care patients referred for echocardiography. Heartdrug. 2003;3(3):141-6.
Gwechenberger M, Hulsmann M, Berger R, et al. Interleukin-6 and B-type natriuretic peptide are independent predictors for worsening of heart failure in patients with progressive congestive heart failure. J Heart Lung Transplant. Jul. 2004;23(7):839-44. [pmid: 15261178].
Hamada Y, Tanaka N, Murata K, et al. Significance of predischarge BNP on one-year outcome in decompensated heart failure-comparative study with echo-Doppler indexes. J Card Fail. Feb. 2005;11(1):43-9. [pmid: 15704063].
Hammerer-Lercher A, Neubauer E, Muller S, et al. Head-to-head comparison of N-terminal pro-brain natriuretic peptide, brain natriuretic peptide and N-terminal pro-atrial natriuretic peptide in diagnosing left ventricular dysfunction. Clin Chim Acta. Aug 20. 2001;310(2):193-7. [pmid: 11498085].
Harrison A, Morrison LK, Krishnaswamy P, et al. B-type natriuretic peptide predicts future cardiac events in patients presenting to the emergency department with dyspnea. Ann Emerg Med. Feb. 2002;39(2):131-8. [pmid: 11823766].
Hartmann F, Packer M, Coats AJ, et al. Prognostic impact of plasma N-terminal pro-brain natriuretic peptide in severe chronic congestive heart failure: a substudy of the Carvedilol Prospective Randomized Cumulative Survival (COPERNICUS) trial. Circulation. Sep 28. 2004;110(13):1780-6. [pmid: 15381643].
Hartmann F, Packer M, Coats AJ, et al. NT-proBNP in severe chronic heart failure: rationale, design and preliminary results of the COPERNICUS NT-proBNP substudy. Eur J Heart Fail. Mar 15. 2004;6(3):343-50. [pmid: 14987586].
Hedberg P, Lonnberg I, Jonason T, et al. Electrocardiogram and B-type natriuretic peptide as screening tools for left ventricular systolic dysfunction in a population-based sample of 75-year-old men and women. Am Heart J. Sep. 2004;148(3):524-9. [pmid: 15389243].
Heeschen C, Hamm CW, Mitrovic V, et al. N-terminal pro-B-type natriuretic peptide levels for dynamic risk stratification of patients with acute coronary syndromes. Circulation. Nov 16. 2004;110(20):3206-12. [pmid: 15533869].
Hobbs FD, Davis RC, Roalfe AK, et al. Reliability of N-terminal proBNP assay in diagnosis of left ventricular systolic dysfunction within representative and high risk populations. Heart. Aug. 2004;90(8):866-70. [pmid: 15253955]. [pmcid: 1768355].
Horwich TB, Patel J, MacLellan WR, et al. Cardiac troponin I is associated with impaired hemodynamics, progressive left ventricular dysfunction, and increased mortality rates in advanced heart failure. Circulation. Aug. 2003;108(7):833-8. [pmid: 12912820].
Hulsmann M, Berger R, Sturm B, et al. Prediction of outcome by neurohumoral activation, the six-minute walk test and the Minnesota Living with Heart Failure Questionnaire in an outpatient cohort with congestive heart failure. Eur Heart J. Jun. 2002;23(11):886-91. [pmid: 12042010].
Hutfless R, Kazanegra R, Madani M, et al. Utility of B-type natriuretic peptide in predicting postoperative complications and outcomes in patients undergoing heart surgery. J Am Coll Cardiol. May. 2004;43(10):1873-9. [pmid: 15145114].
Imamura Y, Fukuyama T, Mochizuki T, et al. Prognostic value of iodine-123-metaiodobenzylguanidine imaging and cardiac natriuretic peptide levels in patients with left ventricular dysfunction resulting from cardiomyopathy. Jpn Circ J. Mar. 2001;65(3):155-60. [pmid: 11266187].
Ishii J, Cui W, Kitagawa F, et al. Prognostic value of combination of cardiac troponin T and B-type natriuretic peptide after initiation of treatment in patients with chronic heart failure. Clin Chem. Dec. 2003;49(12):2020-6. [pmid: 14633873].
Ishii J, Nomura M, Nakamura Y, et al. Risk stratification using a combination of cardiac troponin T and brain natriuretic peptide in patients hospitalized for worsening chronic heart failure. Am J Cardiol. Mar 15. 2002;89(6):691-5. [pmid: 11897211].
James S, James S. Coagulation, inflammation and myocardial dysfunction in unstable coronary artery disease and the influence of glycoprotein IIb/IIIa inhibition and low molecular weight heparin. Ups J Med Sci. 2004;109(2):71-122. [pmid: 15259448].
James SK, Lindahl B, Siegbahn A, et al. N-terminal pro-brain natriuretic peptide and other risk markers for the separate prediction of mortality and subsequent myocardial infarction in patients with unstable coronary artery disease: a Global Utilization of Strategies To Open occluded arteries (GUSTO)-IV substudy.[see comment]. Circulation. Jul 22. 2003;108(3):275-81. [pmid: 12847065].
Jarai R, Iordanova N, Jarai R, et al. Risk assessment in patients with unstable angina/non-ST-elevation myocardial infarction and normal N-terminal pro-brain natriuretic peptide levels by N-terminal pro-atrial natriuretic peptide. Eur Heart J. Feb. 2005;26(3):250-6. [pmid: 15618049].
Jernberg T, Lindahl B, Siegbahn A, et al. N-terminal pro-brain natriuretic peptide in relation to inflammation, myocardial necrosis, and the effect of an invasive strategy in unstable coronary artery disease.[see comment]. J Am Coll Cardiol. Dec 3. 2003;42(11):1909-16. [pmid: 14662251].
Jernberg T, Stridsberg M, Venge P, et al. N-terminal pro brain natriuretic peptide on admission for early risk stratification of patients with chest pain and no ST-segment elevation. J Am Coll Cardiol. Aug 7. 2002;40(3):437-45. [pmid: 12142108].
Jiang CY, Li N, Wang JA, et al. Use of B-type natriuretic peptide in evaluation of early percutaneous coronary intervention in patients with acute coronary syndrome. Chin Med J. Aug. 2004;117(8):1130-4. [pmid: 15361283].
Jose JV, Gupta SN, Selvakumar D. Utility of N-terminal pro-brain natriuretic peptide for the diagnosis of heart failure. Indian Heart J. Jan. 2003;55(1):35-9. [pmid: 12760585].
Jose JV, Gupta SN, Selvakumar D. Utility of N-terminal pro-brain natriuretic peptide for the diagnosis of heart failure. Indian Heart J. Jan. 2003;55(1):35-9. [pmid: 12760585].
Jose JV, Gupta SN, Selvakumar D. Utility of N-terminal pro-brain natriuretic peptide for the diagnosis of heart failure. Indian Heart J. Jan. 2003;55(1):35-9. [pmid: 12760585].
Julier K, Da Silva R, Garcia C, et al. Preconditioning by sevoflurane decreases biochemical markers for myocardial and renal dysfunction in coronary artery bypass graft surgery: A double-blinded, placebo-controlled, multicenter study. Anesthesiology. 2003;98(6):1315-27. [pmid: 12766638].
Kawai K, Hata K, Takaoka H, et al. Plasma brain natriuretic peptide as a novel therapeutic indicator in idiopathic dilated cardiomyopathy during beta-blocker therapy: a potential of hormone-guided treatment. Am Heart J. Jun. 2001;141(6):925-32. [pmid: 11376305].
Kellett J, Kellett J. Prediction of in-hospital mortality by brain natriuretic peptide levels and other independent variables in acutely ill patients with suspected heart disease.[see comment]. Can J Cardiol. May 15. 2004;20(7):686-90. [pmid: 15197420].
Kerbaul F, Collart F, Giorgi R, et al. Increased plasma levels of pro-brain natriuretic peptide in patients with cardiovascular complications following off-pump coronary artery surgery. Intensive Care Med. Sep. 2004;30(9):1799-806. [pmid: 15138672].
Kirk V, Bay M, Parner J, et al. N-terminal proBNP and mortality in hospitalised patients with heart failure and preserved vs. reduced systolic function: data from the prospective Copenhagen Hospital Heart Failure Study (CHHF). Eur J Heart Fail. Mar 15. 2004;6(3):335-41. [pmid: 14987585].
Knudsen CW, Omland T, Clopton P, et al. Diagnostic value of B-Type natriuretic peptide and chest radiographic findings in patients with acute dyspnea.[see comment]. Am J Med. Mar 15. 2004;116(6):363-8. [pmid: 15006584].
Knudsen CW, Riis JS, Finsen AV, et al. Diagnostic value of a rapid test for B-type natriuretic peptide in patients presenting with acute dyspnoe: effect of age and gender. Eur J Heart Fail. Jan. 2004;6(1):55-62. [pmid: 15012919].
Koglin J, Pehlivanli S, Schwaiblmair M, et al. Role of brain natriuretic peptide in risk stratification of patients with congestive heart failure. J Am Coll Cardiol. Dec. 2001;38(7):1934-41. [pmid: 11738297].
Kyuma M, Nakata T, Hashimoto A, et al. Incremental prognostic implications of brain natriuretic peptide, cardiac sympathetic nerve innervation, and noncardiac disorders in patients with heart failure. J Nucl Med. Feb. 2004;45(2):155-63. [pmid: 14960630].
Lainchbury JG, Campbell E, Frampton CM, et al. Brain natriuretic peptide and n-terminal brain natriuretic peptide in the diagnosis of heart failure in patients with acute shortness of breath. J Am Coll Cardiol. Aug 20. 2003;42(4):728-35. [pmid: 12932611].
Landray MJ, Lehman R, Arnold I, et al. Measuring brain natriuretic peptide in suspected left ventricular systolic dysfunction in general practice: cross-sectional study.[see comment]. BMJ. Apr 8. 2000;320(7240):985-6. [pmid: 10753153]. [pmcid: 27340].
Latini R, Maggioni AP, Peri G, et al. Prognostic significance of the long pentraxin PTX3 in acute myocardial infarction. Circulation. Oct. 2004;110(16):2349-54. [pmid: 15477419].
Latini R, Masson S, Anand I, et al. The comparative prognostic value of plasma neurohormones at baseline in patients with heart failure enrolled in Val-HeFT.[see comment]. Eur Heart J. Feb. 2004;25(4):292-9. [pmid: 14984917].
Lee SC, Stevens TL, Sandberg SM, et al. The potential of brain natriuretic peptide as a biomarker for New York Heart Association class during the outpatient treatment of heart failure. J Card Fail. Jun. 2002;8(3):149-54. [pmid: 12140807].
Lindahl B, Lindback J, Jernberg T, et al. Serial analyses of N-terminal pro-B-type natriuretic peptide in patients with non-ST-segment elevation acute coronary syndromes A Fragmin and fast Revascularisation during InStability in coronary artery disease (FRISC)-II substudy. J Am Coll Cardiol. Feb 15. 2005;45(4):533-41. [pmid: 15708700].
Logeart D, Saudubray C, Beyne P, et al. Comparative value of Doppler echocardiography and B-type natriuretic peptide assay in the etiologic diagnosis of acute dyspnea.[see comment]. J Am Coll Cardiol. Nov 20. 2002;40(10):1794-800. [pmid: 12446063].
Logeart D, Thabut G, Jourdain P, et al. Predischarge B-type natriuretic peptide assay for identifying patients at high risk of re-admission after decompensated heart failure. J Am Coll Cardiol. Feb 18. 2004;43(4):635-41. [pmid: 14975475].
Maeda K, Tsutamoto T, Wada A, et al. Plasma brain natriuretic peptide as a biochemical marker of high left ventricular end-diastolic pressure in patients with symptomatic left ventricular dysfunction. Am Heart J. May. 1998;135(5 Pt 1):825-32. [pmid: 9588412].
Maeda K, Tsutamoto T, Wada A, et al. High levels of plasma brain natriuretic peptide and interleukin-6 after optimized treatment for heart failure are independent risk factors for morbidity and mortality in patients with congestive heart failure. J Am Coll Cardiol. Nov 1. 2000;36(5):1587-93. [pmid: 11079662].
Maisel A, Hollander JE, Guss D, et al. Primary results of the Rapid Emergency Department Heart Failure Outpatient Trial (REDHOT). A multicenter study of B-type natriuretic peptide levels, emergency department decision making, and outcomes in patients presenting with shortness of breath.[see comment]. J Am Coll Cardiol. Sep 15. 2004;44(6):1328-33. [pmid: 15364340].
Maisel AS, Clopton P, Krishnaswamy P, et al. Impact of age, race, and sex on the ability of B-type natriuretic peptide to aid in the emergency diagnosis of heart failure: results from the Breathing Not Properly (BNP) multinational study. Am Heart J. Jun. 2004;147(6):1078-84. [pmid: 15199359].
Maisel AS, Krishnaswamy P, Nowak RM, et al. Rapid measurement of B-type natriuretic peptide in the emergency diagnosis of heart failure.[see comment][summary for patients in J Fam Pract. 2002 Oct;51(10):816; PMID: 12401145]. N Engl J Med 2002 Jul 18;347(3):161–7.
McCullough PA, Nowak RM, McCord J, et al. B-type natriuretic peptide and clinical judgment in emergency diagnosis of heart failure: analysis from Breathing Not Properly (BNP) Multinational Study. Circulation. Jul 23. 2002;106(4):416-22. [pmid: 12135939].
Mega JL, Morrow DA, de Lemos JA, et al. B-type natriuretic peptide at presentation and prognosis in patients with ST-segment elevation myocardial infarction: an ENTIRE-TIMI-23 substudy. J Am Coll Cardiol. Jul 21. 2004;44(2):335-9. [pmid: 15261928].
Morrison LK, Harrison A, Krishnaswamy P, et al. Utility of a rapid B-natriuretic peptide assay in differentiating congestive heart failure from lung disease in patients presenting with dyspnea.[see comment]. J Am Coll Cardiol. Jan 16. 2002;39(2):202-9. [pmid: 11788208].
Morrow DA, de Lemos JA, Sabatine MS, et al. Evaluation of B-type natriuretic peptide for risk assessment in unstable angina/non-ST-elevation myocardial infarction: B-type natriuretic peptide and prognosis in TACTICS-TIMI 18.[see comment][erratum appears in J Am Coll Cardiol. 2003 May 21;41(10):1852]. J Am Coll Cardiol 2003 Apr 16;41(8):1264–72.
Murdoch DR, McDonagh TA, Byrne J, et al. Titration of vasodilator therapy in chronic heart failure according to plasma brain natriuretic peptide concentration: randomized comparison of the hemodynamic and neuroendocrine effects of tailored versus empirical therapy.[see comment]. Am Heart J. Dec. 1999;138(6 Pt 1):1126-32. [pmid: 10577444].
Nagao K, Hayashi N, Kanmatsuse K, et al. B-type natriuretic peptide as a marker of resuscitation in patients with cardiac arrest outside the hospital. Circ J. May. 2004;68(5):477-82. [pmid: 15118292].
Nielsen LS, Svanegaard J, Klitgaard NA, et al. N-terminal pro-brain natriuretic peptide for discriminating between cardiac and non-cardiac dyspnoea. Eur J Heart Fail. Jan. 2004;6(1):63-70. [pmid: 15012920].
O'Brien RJ, Squire IB, Demme B, et al. Pre-discharge, but not admission, levels of NT-proBNP predict adverse prognosis following acute LVF. Eur J Heart Fail. Aug. 2003;5(4):499-506. [pmid: 12921811].
Olsen MH, Wachtell K, Tuxen C, et al. N-terminal pro-brain natriuretic peptide predicts cardiovascular events in patients with hypertension and left ventricular hypertrophy: a LIFE study. J Hypertens. Aug. 2004;22(8):1597-604. [pmid: 15257184].
Omland T, Aakvaag A, Bonarjee VV, et al. Plasma brain natriuretic peptide as an indicator of left ventricular systolic function and long-term survival after acute myocardial infarction Comparison with plasma atrial natriuretic peptide and N-terminal proatrial natriuretic peptide.[see comment]. Circulation. Jun 1. 1996;93(11):1963-9. [pmid: 8640969].
Omland T, Persson A, Ng L, et al. N-terminal pro-B-type natriuretic peptide and long-term mortality in acute coronary syndromes.[see comment]. Circulation. Dec 3. 2002;106(23):2913-8. [pmid: 12460871].
Palmer BR, Pilbrow AP, Yandle TG, et al. Angiotensin-converting enzyme gene polymorphism interacts with left ventricular ejection fraction and brain natriuretic peptide levels to predict mortality after myocardial infarction.[see comment]. J Am Coll Cardiol. Mar 5. 2003;41(5):729-36. [pmid: 12628714].
Panteghini M, Cuccia C, Bonetti G, et al. Rapid determination of brain natriuretic peptide in patients with acute myocardial infarction. Clin Chem Lab Med. Feb. 2003;41(2):164-8. [pmid: 12667002].
Ray P, Arthaud M, Lefort Y, et al. Usefulness of B-type natriuretic peptide in elderly patients with acute dyspnea. Intensive Care Med. Dec. 2004;30(12):2230-6. [pmid: 15502931].
Redfield MM, Rodeheffer RJ, Jacobsen SJ, et al. Plasma brain natriuretic peptide to detect preclinical ventricular systolic or diastolic dysfunction: a community-based study. Circulation. Jun 29. 2004;109(25):3176-81. [pmid: 15184280].
Richards AM, Doughty R, Nicholls MG, et al. Plasma N-terminal pro-brain natriuretic peptide and adrenomedullin: prognostic utility and prediction of benefit from carvedilol in chronic ischemic left ventricular dysfunction. Australia-New Zealand Heart Failure Group. J Am Coll Cardiol. Jun 1. 2001;37(7):1781-7. [pmid: 11401111].
Richards AM, Nicholls MG, Espiner EA, et al. B-type natriuretic peptides and ejection fraction for prognosis after myocardial infarction.[see comment]. Circulation. Jun 10. 2003;107(22):2786-92. [pmid: 12771003].
Richards AM, Nicholls MG, Troughton RW, et al. Antecedent hypertension and heart failure after myocardial infarction. J Am Coll Cardiol. 2002;39(7):1182-8. [pmid: 11923044].
Richards AM, Nicholls MG, Yandle TG, et al. Plasma N-terminal pro-brain natriuretic peptide and adrenomedullin: new neurohormonal predictors of left ventricular function and prognosis after myocardial infarction. Circulation. May. 1998;97(19):1921-9. [pmid: 9609085].
Rossig L, Fichtlscherer S, Heeschen C, et al. The pro-apoptotic serum activity is an independent mortality predictor of patients with heart failure. Eur Heart J. Sep. 2004;25(18):1620-5. [pmid: 15351161].
Rothenburger M, Wichter T, Schmid C, et al. Aminoterminal pro type B natriuretic peptide as a predictive and prognostic marker in patients with chronic heart failure. J Heart Lung Transplant. Oct. 2004;23(10):1189-97. [pmid: 15477114].
Sabatine MS, Morrow DA, de Lemos JA, et al. Multimarker approach to risk stratification in non-ST elevation acute coronary syndromes: simultaneous assessment of troponin I, C-reactive protein, and B-type natriuretic peptide. Circulation. Apr 16. 2002;105(15):1760-3. [pmid: 11956114].
Sadanandan S, Cannon CP, Chekuri K, et al. Association of elevated B-type natriuretic peptide levels with angiographic findings among patients with unstable angina and non-ST-segment elevation myocardial infarction. J Am Coll Cardiol. Aug 4. 2004;44(3):564-8. [pmid: 15358021].
Sakatani T, Hadase M, Kawasaki T, et al. Usefulness of the percentage of plasma lymphocytes as a prognostic marker in patients with congestive heart failure. Jpn Heart J. Mar. 2004;45(2):275-84. [pmid: 15090704].
Schnabel R, Rupprecht HJ, Lackner KJ, et al. Analysis of N-terminal-pro-brain natriuretic peptide and C-reactive protein for risk stratification in stable and unstable coronary artery disease: results from the AtheroGene study. Eur Heart J. Feb. 2005;26(3):241-9. [pmid: 15618051].
Seino Y, Ogawa A, Yamashita T, et al. Application of NT-proBNP and BNP measurements in cardiac care: a more discerning marker for the detection and evaluation of heart failure. Eur J Heart Fail. Mar 15. 2004;6(3):295-300. [pmid: 14987579].
Shiga T, Hosaka F, Wakaumi M, et al. Amiodarone decreases plasma brain natriuretic peptide level in patients with heart failure and ventricular tachyarrhythmia. Cardiovasc Drugs Ther. Jul. 2003;17(4):325-33. [pmid: 14618094].
Shimpo M, Morrow DA, Weinberg EO, et al. Serum Levels of the Interleukin-1 Receptor Family Member ST2 Predict Mortality and Clinical Outcome in Acute Myocardial Infarction. Circulation. 2004;109(18):2186-90. [pmid: 15117853].
Song MH, Kobayashi Y, Michi H, et al. Clinical implication of atrial and brain natriuretic Peptide in coronary artery bypass grafting. Asian Cardiovasc Thorac Ann. Mar. 2004;12(1):41-6. [pmid: 14977741].
Stanek B, Frey B, Hulsmann M, et al. Prognostic evaluation of neurohumoral plasma levels before and during beta-blocker therapy in advanced left ventricular dysfunction. J Am Coll Cardiol. Aug. 2001;38(2):436-42. [pmid: 11499735].
Suzuki M, Hamada M, Yamamoto K, et al. Brain natriuretic peptide as a risk marker for incident hypertensive cardiovascular events. Hypertens Res. Sep. 2002;25(5):669-76. [pmid: 12452317].
Suzuki S, Yoshimura M, Nakayama M, et al. Plasma level of B-type natriuretic peptide as a prognostic marker after acute myocardial infarction: a long-term follow-up analysis. Circulation. Sep 14. 2004;110(11):1387-91. [pmid: 15353502].
Takase H, Toriyama T, Sugiura T, et al. Brain natriuretic peptide in the prediction of recurrence of angina pectoris. Eur J Clin Invest. Feb. 2004;34(2):79-84. [pmid: 14764069].
Tamura K, Takahashi N, Nakatani Y, et al. Prognostic impact of plasma brain natriuretic peptide for cardiac events in elderly patients with congestive heart failure. Gerontology. Jan. 2001;47(1):46-51. [pmid: 11244291].
Taniguchi R, Sato Y, Yamada T, et al. Combined measurements of cardiac troponin T and N-terminal pro-brain natriuretic peptide in patients with heart failure. Circ J. Dec. 2004;68(12):1160-4. [pmid: 15564700].
Tarnow L, Hildebrandt P, Hansen BV, et al. Plasma N-terminal pro-brain natriuretic peptide as an independent predictor of mortality in diabetic nephropathy. Diabetologia. Jan. 2005;48(1):149-55. [pmid: 15616804].
Troughton RW, Frampton CM, Yandle TG, et al. Treatment of heart failure guided by plasma aminoterminal brain natriuretic peptide (N-BNP) concentrations.[see comment]. Lancet. Apr 1. 2000;355(9210):1126-30. [pmid: 10791374].
Tsutamoto T, Wada A, Maeda K, et al. Plasma brain natriuretic peptide level as a biochemical marker of morbidity and mortality in patients with asymptomatic or minimally symptomatic left ventricular dysfunction. Comparison with plasma angiotensin II and endothelin-1. Eur Heart J. Dec. 1999;20(24):1799-807. [pmid: 10581138].
Tsutamoto T, Wada A, Maeda K, et al. Attenuation of compensation of endogenous cardiac natriuretic peptide system in chronic heart failure: prognostic role of plasma brain natriuretic peptide concentration in patients with chronic symptomatic left ventricular dysfunction.[see comment]. Circulation. Jul 15. 1997;96(2):509-16. [pmid: 9244219].
Tsutsui T, Tsutamoto T, Wada A, et al. Plasma oxidized low-density lipoprotein as a prognostic predictor in patients with chronic congestive heart failure. J Am Coll Cardiol. Mar 20. 2002;39(6):957-62. [pmid: 11897436].
Ueda R, Yokouchi M, Suzuki T, et al. Prognostic value of high plasma brain natriuretic peptide concentrations in very elderly persons.[see comment]. Am J Med. Mar. 2003;114(4):266-70. [pmid: 12681452].
Ueland T, Jemtland R, Godang K, et al. Prognostic value of osteoprotegerin in heart failure after acute myocardial infarction. J Am Coll Cardiol. 2004;44(10):1970-6. [pmid: 15542278].
Van Beneden R, Gurne O, Selvais PL, et al. Superiority of big endothelin-1 and endothelin-1 over natriuretic peptides in predicting survival in severe congestive heart failure: a 7-year follow-up study. J Card Fail. Dec. 2004;10(6):490-5. [pmid: 15599839].
van der MP, Voors AA, Lipsic E, et al. Prognostic value of plasma erythropoietin on mortality in patients with chronic heart failure. J Am Coll Cardiol. Jul 7. 2004;44(1):63-7. [pmid: 15234408].
Vasan RS, Benjamin EJ, Larson MG, et al. Plasma natriuretic peptides for community screening for left ventricular hypertrophy and systolic dysfunction: the Framingham heart study. JAMA. Sep 11. 2002;288(10):1252-9. [pmid: 12215132].
Villacorta H, Duarte A, Duarte NM, et al. The role of B-type natriuretic peptide in the diagnosis of congestive heart failure in patients presenting to an emergency department with dyspnea. Arq Bras Cardiol. 2002;79(6):569-72. [pmid: 12532240].
Vrtovec B, Delgado R, Zewail A, et al. Prolonged QTc interval and high B-type natriuretic peptide levels together predict mortality in patients with advanced heart failure.[see comment]. Circulation. Apr 8. 2003;107(13):1764-9. [pmid: 12665499].
Wallen T, Landahl S, Hedner T, et al. Brain natriuretic peptide predicts mortality in the elderly. Heart. Mar. 1997;77(3):264-7. [pmid: 9093047]. [pmcid: 484695].
Wang TJ, Larson MG, Levy D, et al. Plasma natriuretic peptide levels and the risk of cardiovascular events and death.[see comment]. N Engl J Med. Feb 12. 2004;350(7):655-63. [pmid: 14960742].
Watanabe J, Shiba N, Shinozaki T, et al. Prognostic value of plasma brain natriuretic peptide combined with left ventricular dimensions in predicting sudden death of patients with chronic heart failure. J Card Fail. Feb. 2005;11(1):50-5. [pmid: 15704064].
Watanabe M, Egi K, Hasegawa S, et al. Significance of serum atrial and brain natriuretic peptide release after coronary artery bypass grafting. SURG. 2003;33(9):671-3.
Weber M, Arnold R, Rau M, et al. Relation of N-terminal pro-B-type natriuretic peptide to severity of valvular aortic stenosis. Am J Cardiol. Sep 15. 2004;94(6):740-5. [pmid: 15374777].
Wendelboe Nielsen O, Kirk V, Bay M, et al. Value of N-terminal pro brain natriuretic peptide in the elderly: data from the prospective Copenhagen Hospital Heart Failure study (CHHF). Eur J Heart Fail. Mar 15. 2004;6(3):275-9. [pmid: 14987576].
Wiviott SD, Cannon CP, Morrow DA, et al. Differential expression of cardiac biomarkers by gender in patients with unstable angina/non-ST-elevation myocardial infarction: a TACTICS-TIMI 18 (Treat Angina with Aggrastat and determine Cost of Therapy with an Invasive or Conservative Strategy-Thrombolysis In Myocardial Infarction 18) substudy.[see comment]. Circulation. Feb 10. 2004;109(5):580-6. [pmid: 14769678].
Wright SP, Doughty RN, Pearl A, et al. Plasma amino-terminal pro-brain natriuretic peptide and accuracy of heart-failure diagnosis in primary care: a randomized, controlled trial. J Am Coll Cardiol. Nov. 2003;42(10):1793-800. [pmid: 14642690].
Wylie JV, Murphy SA, Morrow DA, et al. Validated risk score predicts the development of congestive heart failure after presentation with unstable angina or non-ST-elevation myocardial infarction: results from OPUS-TIMI 16 and TACTICS-TIMI 18. Am Heart J. Jul. 2004;148(1):173-80. [pmid: 15215808].
Yamada Y, Goto J, Yokota M, et al. Brain natriuretic peptide is a sensitive indicator of impaired left-ventricular function in elderly patients with cardiovascular disease. Cardiology. Sep. 1997;88(5):401-7. [pmid: 9286500].
Yoshizawa A, Yoshikawa T, Nakamura I, et al. Brain natriuretic peptide response is heterogeneous during beta-blocker therapy for congestive heart failure. J Card Fail. Aug. 2004;10(4):310-5. [pmid: 15309697].
Zeller M, Cottin Y, Laurent Y, et al. N-terminal pro-brain natriuretic peptide levels in patients with non-ST-elevation myocardial infarction. Cardiology. 2004;102(1):37-40. [pmid: 14988617].
Zugck C, Haunstetter A, Kruger C, et al. Impact of beta-blocker treatment on the prognostic value of currently used risk predictors in congestive heart failure. J Am Coll Cardiol. May 15. 2002;39(10):1615-22. [pmid: 12020488].