# Appendix A: Search Strings

Search terms for Peptides review

[underlined: Main Review]

MEDLINE® February 2005

natriuretic peptide, brain/

2. bnp.mp. [mp=title, original title, abstract, name of substance word, subject heading word]

3. nt-probnp.mp.

4. brain-type natriuretic peptide.mp.

5. bnp1-32.mp.

6. bnp-32.mp.

7. bnp77-108.mp.

8. probnp.mp.

9. nt-probnp1-76.mp.

10. natriuretic factor-32.mp.

11. natriuretic peptide type-b.mp.

12. type-b natriuretic peptide.mp.

13. ventricular natriuretic peptide.mp.

14. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13

15. 14

16. limit 15 to yr=1989 - 2005

EMBASE 2005 Week 08

1 Brain Natriuretic Peptide/ct, ec, an, dv [Clinical Trial, Endogenous Compound, Drug Analysis, Drug Development] (2172)
2 bnp.tw. (1838)
3 nt-probnp.tw. (150)
4 brain-type natriuretic peptide.tw. (9)
5 bnp 1-32.tw. (4)
6 bnp1-32.tw. (1)
7 bnp-32.tw. (44)
8 bnp77-108.tw. (0)
9 bnp 77-108.tw. (2)
10 probnp.tw. (195)
11 nt-probnp1-76.tw. (0)
12 nt-probnp 1-76.tw. (1)
13 natriuretic factor-32.tw. (0)
14 natriuretic peptide type-b.tw. (3)
15 type-b natriuretic peptide.tw. (16)
16 ventricular natriuretic peptide.tw. (24)
17 or/1-16 (2895)
18 limit 17 to yr=1989-2005 (2881)
19 from 18 keep 1–1000 (1000)

CINAHL February 2005 Week 3

1 exp Peptides/an, me, bl, ph, st, df, du, ur [Analysis, Metabolism, Blood, Physiology, Standards, Deficiency, Diagnostic Use, Urine] (657)
2 nt-probnp.tw. (3)
3 brain-type natriuretic peptide.tw. (1)
4 bnp 1-32.tw. (0)
5 bnp-32.tw. (0)
6 bnp77-108.tw. (0)
7 probnp.tw. (3)
8 nt-probnp1-76.tw. (0)
9 natriuretic factor-32.tw. (0)
10 natriuretic peptide type-b.tw. (0)
11 type-b natriuretic peptide.tw. (0)
12 ventricular natriuretic peptide.tw. (0)
13 or/1-12 (659)
14 limit 13 to yr=1989-2005 (654)
15 from 14 keep 1–654 (654)

AMED February 2005

1 exp peptides/ (142)
2 bnp.tw. (2)
3 nt-probnp.tw. (0)
4 brain-type natriuretic peptide.tw. (0)
5 bnp 1-32.tw. (0)
6 bnp-32.tw. (0)
7 bnp77-108.tw. (0)
8 probnp.tw. (0)
9 nt-probnp1-76.tw. (0)
10 natriuretic factor-32.tw. (0)
11 natriuretic peptide type-b.tw. (0)
12 type-b natriuretic peptide.tw. (0)
13 ventricular natriuretic peptide.tw. (0)
14 or/1–13 (143)
15 limit 14 to yr=1989-2005 (143)
16 from 15 keep 1–143 (143)

Cochrane 2005 CDSR, ACP Journal Club, DARE

1 [Natriuretic Peptide, Brain/me, bi, bl, se, du [Metabolism, Biosynthesis, Blood, Secretion, Diagnostic Use]] (0)

2 bnp.mp. [mp=ti, ab, tx, kw, ct] (10)

3 nt-probnp.mp. [mp=ti, ab, tx, kw, ct] (0)

4 brain-type natriuretic peptide.tw. (0)

5 bnp1-.tw. (0)

6 bnp-32.tw. (0)

7 bnp77-108.tw. (0)

8 probnp.tw. (0)

9 nt-probnp1-76.tw. (0)

10 natriuretic factor-32.tw. (0)

11 natriuretic peptide type-b.tw. (0)

12 type-b natriuretic peptide.tw. (0)

13 ventricular natriuretic peptide.tw. (0)

14 or/1–13 (10)

15 limit 14 to yr=1989-2005 [Limit not valid in: DARE; records were retained] (10)

17 from 15 keep 1–10 (10)

[underlined: Review of Reviews]

EMBASE 2005 Week 45

1 meta-analysis.sh,pt. or meta-analy:.tw. or metaanaly:.tw. (23869)
2 ((systematic: or quantitativ:) adj (review: or overview:)).tw. (7475)
3 (chochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library)).tw. (12680)
4 ((handsearch: or search:) and (cochrane or medline or cinahl or embase or scisearch or psychinfo or psychlit or psyclit or (national and library) or (hand: or manual: or electronic: or bibliograph: or database:))).tw. (18474)
5 ((review or guideline).pt. or consensus.ti. or guideline:.ti. or literature.ti. or overview.ti. or review.ti.) and (3 and 4) (6533)
6 ((synthesis or overview or review or survey) and (systematic or critical or methodologic or quantitative or qualitative or literature or evidence or evidence-based)).ti. (21933)
7 1 or 2 or 3 or 4 or 5 or 6 (62142)
8 heart failure.mp. [mp=title, abstract, subject headings, heading word, drug trade name, original title, device manufacturer, drug manufacturer name] (43809)
9 exp heart failure/ (54121)
10 8 or 9 (58713)
11 7 and 10 (1802)
12 diagnosis/ (1735)
13 diagnos:.ti. (75557)
14 12 or 13 (77064)
15 11 and 14 (27)
16 15 (27)
17 limit 16 to (english language and yr=“2000 - 2005”) (17)
18 from 17 keep 1–10 (10)

Ovid MEDLINE(R) October 2005 Week 4

1 meta-analysis.sh,pt. or meta-analy:.tw. or metaanaly:.tw. (17167)
2 ((systematic: or quantitativ:) adj (review: or overview:)).tw. (7963)
3 (chochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library)).tw. (15249)
4 ((handsearch: or search:) and (cochrane or medline or cinahl or embase or scisearch or psychinfo or psychlit or psyclit or (national and library) or (hand: or manual: or electronic: or bibliograph: or database:))).tw. (22660)
5 ((review or guideline).pt. or consensus.ti. or guideline:.ti. or literature.ti. or overview.ti. or review.ti.) and (3 and 4) (9900)
6 ((synthesis or overview or review or survey) and (systematic or critical or methodologic or quantitative or qualitative or literature or evidence or evidence-based)).ti. (22940)
7 1 or 2 or 3 or 4 or 5 or 6 (59490)
8 heart failure.mp. [mp=title, original title, abstract, name of substance word, subject heading word] (32938)
9 exp heart failure/ (23361)
10 8 or 9 (35572)
11 7 and 10 (683)
12 diagnos:.ti,ab. (402579)
13 diagnosis/ (1065)
14 12 or 13 (403061)
15 11 and 14 (121)
16 15 (121)
17 limit 16 to (english language and yr=“2000 - 2005”) (81)
18 [from 17 keep 1–159] (0)
19 from 17 keep 1–81 (81)