# Appendixes

Appendix A: Search Strings

Appendix B: Forms

Appendix C: Evidence Tables

Appendix D: Excluded Studies

Appendix E: Technical Expert Panel