# References

1 Cieslak TJ, Henretig FM. Ring-a-ring-a-roses bioterrorism and its peculiar relevance to pediatrics. Curr Opin Peds. 2003;15:107-111.
2 Guidelines for Surveillance and Control of Anthrax in Humans and Animals. World Health Organization. June. Available at: http://www.who.int/emc. Accessed August 12, 2003.
3 Bioterrorism alleging use of anthrax and interim guidelines for management--United States, 1998. MMWR Morb Mortal Wkly Rep. Feb 5 1999;48:69–74.
4 Update: Investigation of anthrax associated with intentional exposure and interim public health guidelines, October 2001. MMWR Morb Mortal Wkly Rep. Oct 19 2001;50:889–893.
5 From the Centers for Disease Control and Prevention. Interim guidelines for investigation of and response to Bacillus anthracis exposures. JAMA. Nov 28. 2001;286:2540-2541. [pmid: 11763848].
6 From the Centers for Disease Control and Prevention. Updated recommendations for antimicrobial prophylaxis among asymptomatic pregnant women after exposure to Bacillus anthracis. JAMA. Nov 21. 2001;286:2396-2397. [pmid: 11759668].
7 From the Centers for Disease Control and Prevention. Update: Investigation of bioterrorism-related anthrax and interim guidelines for exposure management and antimicrobial therapy, October 2001. JAMA. Nov 14. 2001;286:2226-2232. [pmid: 11757528].
8 Interim guidelines for investigation of and response to Bacillus anthracis exposures. MMWR Morb Mortal Wkly Rep. Nov 9 2001;50:987–990.
9 Clinical Pathway: Anthrax Inhalational Exposure. Center for Infectious Disease Research and Policy (CIDRAP) and Infectious Diseases Society of America (IDSA). Available at: http://www.cidrap.umn.edu/cidrap/files/17/anthrax-clinical-pathway.pdf. Accessed September 9, 2003.
10 Inglesby TV, O'Toole T, Henderson DA, et al. Anthrax as a biological weapon, 2002: Updated recommendations for management. JAMA. 2002;287:2236-2252. [pmid: 11980524].
11 Chemical-biological terrorism and its impact on children: A subject review. Pediatrics. 2000;105:662–670.
12 Markenson D, Redlener I. Pediatric Preparedness for Disasters and Terrorism: A National Consensus Conference. New York: National Center for Disaster Preparedness; 2003.
13 Hancoch AP, Feigin RD. Diagnosis and management of suspected cases of bioterrorism: A pediatric perspective. Pediatrics. 2002;109:685-692. [pmid: 11927716].
14 Abramova FA, Grinberg LM, Yampolskaya O, Walker DH. Pathology of inhalational anthrax in 42 case from Sverdlovsk outbreak of 1979. Proc Natl Acad Sci U S A. 1993;90:2291-2294. [pmid: 8460135]. [pmcid: 46072].
15 Meselson M, Guillemin J, Hugh-Jones M, et al. The Sverdlovsk Anthrax Outbreak of 1979. Science. 1994;266:1202-1208. [pmid: 7973702].
16 Wilkening DA. Sverdlovsk revisited: understanding human inhalation anthrax. Manuscript under review.
17 Bravata DM, McDonald KM, Owens DK, et al. Regionalization of Bioterrorism Preparedness and Response (Evidence Report/Technology Assessment). Rockville, MD: Agency for Healthcare Research and Quality; April 2004. AHRQ Publication No. 04-E016-2.
18 Grinberg LM, Abramora AA, Yampolska O, Walker DH, Smith JH. Quantitative pathology of inhalational anthrax 1: quantitative microscopic findings. Mod Pathol. 2001;14:482-495. [pmid: 11353060].
19 Gill JR, Melinek J. Inhalational anthrax: gross autopsy findings. Arch Pathol Lab Med. 2002;126:993-994. [pmid: 12197510].
20 Brachman PS, Kaufmann A. Anthrax (Chapter 4). In: Evans AS, Brachman PS, eds. Bacterial Infections of Humans. Epidemiology and Control. 3rd ed. New York: Plenum; 1998:95–107.
21 Koch R. [The etiology of anthrax, based on the life history of Bacillus anthracis]. Beitr Biol Pflanz. 1877;2:277-308.
22 McFadyean J. Extraneous sources of infection in outbreaks of anthrax. J Comp Path. 1903;16:346-357.
23 Eurich FW, Hewlett RT. Bacillus anthracis. In: Topley WWC, ed. A System of Bacteriology in Relation to Medicine. Vol 5. London: Majesty's Stationary Office; 1930:439–478.
24 Holty JE, Bravata DM, Liu H, Olshen RA, McDonald KM, Owens DK. A century of inhalational anthrax: A systematic review of cases from 1900 to 2005. Ann Intern Med. 2006;144:270-280. [pmid: 16490913].
25 Hupert N, Bearman GM, Mushlin AI, Callahan MA. Accuracy of screening for inhalational anthrax after a bioterrorist attack. Ann Intern Med. Sep 2. 2003;139:337-345. [pmid: 12965942].
26 Kronberger H. Ein fall von lungenmilzbrand mit gungstigem Ausgung. Beitr Klin Tuberk Spezif Tuberkuloseforsch. 1917;38:135-144.
27 Brachman PS, Plotkin SA. An epidemic of inhalation and cutaneous anthrax: Studies of Anthrax in a goat hair mill in New Hampshire; Final Report: Anthrax Investigations Unit, Epidemiology Branch, Communicable Disease Center, Public Health Service, U. S. Department of Health, Education and Welfare; Dec 1 1959.
28 Brachman PS, Plotkin SA, Bumford FH, Atchison MM. An epidemic of inhalation anthrax: the first in the twenieth century, II. Epidemiology. Am J Hyg. 1960;72:6-23. [pmid: 13803672].
29 Brachman PS, Gold H, Plotkin SA, Fekety FR, Werrin M, Ingraham NR. Field evaluation of a human anthrax vaccine. Amer J Public Health. 1962;52:632-645.
30 Plotkin SA, Brachman PS, Utell M, Bumford FH, Atchison MM. An epidemic of inhalation anthrax. Am J Med. 1960;29:992-1001. [pmid: 13736379].
31 Plotkin SA, Brachman PS, Utell M, Bumford FH, Atchison MM. An epidemic of inhalation anthrax, the first in the twentieth century: I. Clinical features. Am J Med. 2002;112:4-12. [pmid: 11812400].
32 Bales ME, Dannenberg AL, Brachman PS, Kaufmann A, Klatsky PC, Ashford DA. Epidemiologic response to anthrax outbreaks: field investigations, 1950-2001. Emerg Infect Dis. 2002;8:1163-1174. [pmid: 12396934].
33 Winter H, Pfisterer RM. [Inhalation anthrax in a textile worker: non-fatal course]. Schweiz Med Wochenschr. 1991;121:832-835. [pmid: 1905838].
34 Pfisterer RM. [An anthrax epidemic in Switzerland. Clinical, diagnostic and epidemiological aspects of a mostly forgotten disease]. Schweiz Med Wochenschr. 1991;121:813-825. [pmid: 1905837].
35 McKitterick JC, Pearson GJ. Pneumonic Anthrax in a Child. Am J Dis Child. 1929;38:1252-1255.
36 Vessal K, Yeganehdoust J, Dutz W, Kohout E. Radiological changes in inhalation anthrax. A report of radiological and pathological correlation in two cases. Clin Radiol. Oct. 1975;26:471-474. [pmid: 811421].
37 Krzyszkowski J. [Several words about the pathological anatomy of anthrax]. Przegl Lek. 1901;40:543-545.
38 Krzyszkowski J. [Several words about the pathological anatomy of anthrax]. Przegl Lek. 1901;40:556-557.
39 Schereffetin O. Zur milzbrandbehandlung. Wien Klin Wochenschr. 1931;44:1083-1084.
40 Skolubovich GV, Ruban GE. [An outbreak of anthrax in Amur Province in 1954 (from experience in the diagnosis and control of anthrax)]. Zh Mikbriol Epidemiol Immunobiol. 1995:102–105.
41 Skolubovich GV, Ruban GE. [Errors in the diagnosis of anthrax]. Klin Med (Mosk). 1995;73:54-55. [pmid: 8577111].
42 Beatty ME, Ashford DA, Griffin PM, Tauxe RV, Sobel J. Gastrointestinal anthrax: review of the literature. AMA Arch Intern Med. 2003;163:2527-2531. [pmid: 14609791].
43 Kanafani ZA, Ghossain A, Sharara AI, Hatem J, Kanj SS. Endemic gastrointesinal anthrax in 1960's Lebanon: clinical maifestations and surgical findings. Emerg Infect Dis. 2003;9:520-525. [pmid: 12737733].
44 Sirisanthana T, Navacharoen N. Outbreak of oral-pharyngeal anthrax: unusual manifestations of human infection with Bacillus anthracis. Am J Trop Med Hyg. 1984;33:144-150. [pmid: 6696173].
45 Ndyabahinduka DG, Chu IH, Abdou AH, Gaifuba JK. An outbreak of human gastrointestinal anthrax. Ann Ist Super Sanita (Roma). 1984;20:205-208.
46 Doganay M, Ahmet A, Hanagasi R. Primary throat anthrax. A report of six cases. Scand J Infect Dis. 1986;18:415-419. [pmid: 3775269].
47 Pandey R. Anthrax of the palate. Indian J Otolaryngol. 1977;29:140.
48 Mansour-Ghabaei F, Zareh S, Salimi A. GI Anthrax: report of one case confirmed with autopsy. Med Sci Monit. 2002;8:CS73-76. [pmid: 12218950].
49 Alizad A, Ayoub EM. Intestinal anthrax in a two-year old child. Ped Infect Dis J. 1995;14:394-395.
50 Chandra Sekhar P, Jaya Singh RS, Sridhar MS, Jaya Bhaskar C, Sreehari Rao Y. Outbreak of human anthrax in Ramabhadrapuram village of Chittoor district in Andhra Pradesh. Indian J Med Res. 1990;91:448-452. [pmid: 2091991].
51 Nalin DR, Sultana B, Sahunja R, Islam AK, Rahim MA, Islam M. Survival of a patient with intestinal anthrax. Am J Med. 1977;62:130-132. [pmid: 835581].
52 Tantachumroon T, Panas-Ampol K. Intestinal anthrax: a report of two cases. J Med Assoc Thai. 1968;51:477-481.
53 Anonymous. Proceedings of the Symposium on Anthrax in Man. Philadelphia: Hospital of the University of Pennsylvania; October 8 1954.
54 Tabatabaie P, Syadati A. Bacillus anthracis as a cause of bacterial meningitis. Ped Infect Dis J. 1993;12:1035-1037.
55 Kwong KL. Fatal meningioencephalitis due to Bacillus anthracis. J Paediatr Child Health. 1997;33:539-551. [pmid: 9484689].
56 Berthier M, Fauchere JL, Perrin J, Grignon B, Oriot D. Fulminant meningitis due to Baciluus anthracis in an 11-year-old girl during Ramadan. Lancet. 1996;347:828. [pmid: 8622353].
57 Raper AB. Anthrax meningo-encephalitis. East African Med J. 1953;30:339-401.
58 Yeung STK. Human anthrax in Hong Kong in the past 2 decades. Public Health and Epidemiology. 2002;11:9-11.
59 Department of Health Hong Kong C. A fatal case of anthrax infection in 2003. Public Health and Epidemiology Bulletin. 2003;12:47.
60 Sarada D, Valentina GO, Lalitha MK. Cutaneous anthrax involving the eye lids. Indian J Med Microbiol. 1999;17:92-95.
61 Mallon E, McKee PH. Extraordinary case report: cutaneous anthrax. Amer J Dermatopathology. 1997;19:79-82.
62 Matz MH, Brugsch HG. Anthrax in Massachusetts: 1943 through 1962. JAMA. 1964;188:635-638. [pmid: 14121284].
63 Caksen H, Arabaci F, Abuhandan M, Tuncer O, Cesur Y. Cutaneous anthrax in eastern Turkey. Cutis. 2001;67:488-492. [pmid: 11419020].
64 Stretton JL. A case of anthrax successfully treated with Sclavo's serum. Lancet. May 27 1905:1420–1421.
65 Herley R. Eight cases of external anthrax. Lancet. Dec 4 1909:1662–1665.
66 McGlannan A. The treatment of anthrax infections. Ann Surg. 1923;77:263-266. [pmid: 17864788].
67 Santee HE. Anthrax and its treatment. Ann Surg. Sept. 1923;78:326-331. [pmid: 17864896].
68 Riebeling M. Roentgen treatment of external infections due to Bacillus anthracis. Radiology. 1948;51:333-340. [pmid: 18882264].
69 Felek S, Akbulut A, Kalkan A. A case of anthrax sepsis: non-fatal course. J Infection. 1999;38:201-202.
70 McRitchie M. Anthrax in a Masai child. Nurs Mirror Midwives J. 1972;134:23-25. [pmid: 4482132].
71 Ciftci E, Ince E, Dogru U. Traditions, anthrax and children. Pediatr Dermatol. 2002;19:36-38. [pmid: 11860568].
72 Bonnar W. Sulfapyridine in human anthrax. BMJ. 1940;1:389.
73 Page CHW. British Industrial Anthrax Part II. J Hyg. 1909;9:357-398. [pmid: 20474403].
74 Yorston D, Foster A. Cutaneous anthrax leading to corneal scarring from cicatrical extropion. Br J Ophthalmol. 1989;73:809-811. [pmid: 2818989]. [pmcid: 1041890].
75 Abdenour D, Larouze B, Dalichaouche M, Aouati M. Familial occurence of anthrax in eastern algeria. J Infect Dis. 1987;155:1083-1084. [pmid: 3559284].
76 Green DM, Jamieson WM. Anthrax and bone-meal fertiliser. Lancet. July 10. 1958;2:153-154. [pmid: 13564787].
77 Gilbert FW. Human anthrax in Barotseland treated with Novarsenobenzene. Lancet. 1935;2:1283-1285.
78 Kutluk MT, Secmeer G, Kaura G. Cutaneous anthrax. Cutis. 1987;40:117-118. [pmid: 3621994].
79 Husain N. Anthrax pustule of the neck. Indian Medical Gazette. 1932;67:517.
80 Legge TM. Industrial anthrax: Lecture II. Lancet. 1905:765–776.
81 Celebi S, Aykan U, Alagoz G, Esmerligil S. Palpebral anthrax. Eur J Ophthalmol. 2001;11:171-174. [pmid: 11456020].
82 Celebi S, Celebi H, Celikier UO, Kandemir B, Alagoz G, Esmerligil S. Anthrax as the cause of preseptal cellulitis. Acta Ophtalmol Scand. 1997;75:462-463.
83 Ruiz Sanchez F, Ruiz Sanchez A. Kanamycin in anthrax, typhoid, paratyphoid and brucellosis. Ann N Y Acad Sci. 1958;76:235-241. [pmid: 13595514].
84 Perl AF. Anthra: its incidence and therapy (with report of a case). Canad Med Assoc J. 1945;52:592-600. [pmid: 20323461].
85 House SJ. Hemorrhagic meningoencephalitis in anthrax: a report of three cases. J Infect Dis. 1920;27:513-526.
86 Clarke PS. Chloramphenicol in the treatment of cutaneous anthrax. BMJ. Jan 12. 1952;1:86-87. [pmid: 14896037].
87 Vijaikumar M, Thappa DM, Jeevankumar B. Cutaneous anthrax: still a reality in India. Pediatr Dermatol. 2001;18:456-457. [pmid: 11737702].
88 Roberts CJ. An outbreak of anthrax in the Mondoro tribal trust lands. Cent Afr J Med. 1975;21:73-76. [pmid: 1170020].
89 Buntine RM. Anthrax in East Africa. Med J Aust. 1933;1:647.
90 Bell JH. Two cases of malignant pustule; recovery. Lancet. 1900;1:1005-1006.
91 Bechtold A. What kind of infection? Probably Anthrax. JAMA. 1911;56:1214.
92 Sobernheim G. XVI. Milzbrand. In: Kolle W, Kraus R, Uhlenhuth P, eds. Handbuch der Pathogenen Mikroorganismen. Vol 3 (2). Berlin: Urban & Schwarzenberg; 1931:1041–1174.
93 Druett HA, Henderson DW, Packman L, Peacock S. Studies on respiratory infection. I. The influence of particle size on respiratory infection with anthrax spores. J Hyg (London). 1953;51:359-371. [pmid: 13096744].
94 Barnes JM. The development of anthrax following the administration of spores by inhalation. Br J Exp Pathol. 1947;28:385-394.
95 Al-Dulaimy SB, Al-Allaf GA. Anthrax meningitis. Trans R Soc Trop Med Hyg. 1978;72:315. [pmid: 675792].
96 Croix IC, Pluot M. Un cas de charbon humain a localisation unique cerebromenigee observe dans la region de Reims. Med Mal Infect. 1975;5:583-585.
97 Pluot M, Vital C, Aubertin J, Croix JC, Pire JC, Poisot D. Anthrax meningitis: report of two cases with autopsies. Acta Neuropathol (Berl). 1976;36:339-345. [pmid: 1015242].
98 Mitchell GF. Meningeal anthrax. BMJ. 1921;2:508.
99 Holty JEC, Kim RY, Bravata DM. Anthrax: A systematic review of atypical presentations. Ann Emerg Med. 2006;In press.
100 Rangel RA, Gonzalez DA. Bacillus anthracis meningitis. Neurology. 1975;25:525-530. [pmid: 1168871].
101 Ker WG. Clinical notes. East Afr Med J. 1944;21:93-96.
102 Inda FF, Natin I, Da Rin C. El carbunclo por inhalacion. Sem Med. 1943;50:754-761.
103 Inda FF, Natin I, Guiliano A. El diagnostico del carbunclo por inhalacion. Sem Med. 1947;54:38-42. [pmid: 20239585].
104 Marandian MH, Kamali A. [Anthrax meningitis: an ostensibly primary case]. Nouv Presse Med. 1981;10:1747-1748. [pmid: 7232164].
105 Bezzi C. Un raro caso di meningite da carbonchio ematico. G Batteriol Immunol. 1952;6:353-360. [pmid: 12998979].
106 Gross H, Plate H. Milzbrandbacillen-Meningitis. Klin Wochenschr. 1940;19:1036-1037.
107 Slatineanu A, Balteanu I, Franche M. Doua cazuri de meningo-encefalita carbunoasa. Miscarea Med Romana. 1939:12–18.
108 Aguiah A. Un cas de meningite charbonneuse primitive chez un garcon de onze ans. Arch Med Enfants. 1928;31:676-680.
109 Regan JC. The advantage of serum therapy as shown by a comparison of various methods of treatment of anthrax. Am J Med Sci. Sept. 1921;162:406-423.
110 Sclavo A. Sullo stato presente della sieroterapia anticarbonchiosa. Rivista di Igiene e Sanita pubblica. 1903;14:519-587.
111 Henderson DW, Peacock S, Belton FC. Observations on the prophylaxis of experimental pulmonary anthrax in the monkey. J Hyg (London). 1956;54:28-36. [pmid: 13319688].
112 Lucchesi PF. Serum treatment of 19 cases of anthrax including one of external, internal and bacteremic type. Am J Med Sci. 1932;183:795-802.
113 D'Agostino S, Maddaluno R. Considerazioni su 593 casi di carbonclio umano. Agg Pediatr. 1962;13:663-676.
114 Mitchell W. Anthrax and fatalism. Br Med J. 1911;1:751-752. [pmid: 20765547].
115 Stein CD. Anthrax. In: Hull TG, Thomas CC, eds. Diseases transmitted from animals to man. Springfield, IL; 1963:82–125.
116 Karginov V, Robinson T, Riemenschneider J, et al. Treatment of anthrax infection with combination of ciprofloxacin and antibodies to protective antigen of Bacillus anthracis. FEMS Immunol Med Microbiol. 2004;40:71-74. [pmid: 14734189].
117 Knudson GB. Treatment of anthrax in man: history and current concepts. Military Medicine. 1986;151:71-77. [pmid: 3083296].
118 Casadevall A. Passive antibody administration (Immediate Immunity) as a specific defense against biological weopons. Emerg Infect Dis. 2002;8:833-841. [pmid: 12141970].
119 Greenfield RA, Bronze MS. Prevention and treatment of bacterial diseases caused by bacterial bioterrorism threat agents. Drugs Discovery Today. 2003;8:881-888.
120 Rainey GJA, Young JAT. Antitoxins: novel strategies to target agents of bioterrorism. Nature Reviews Microbiology. 2004;2:721-726.
121 Welkos SL, Little SF, Friedlander AM, Fritz DL, Fellows P. The role of antibodies to Bacillus anthracis and anthrax toxin components in inhibiting the early stages of infection by anthrax spores. Microbiology - SGM. 2001;147:1677-1685.
122 Cote CK, Rossi CA, Kang AS, Morrow PR, Lee JS, Welkos SL. The detection of protective antigen (PA) associated with spores of Bacillus anthracis and the effects of anti-PA antibodies on spore germination and macrophage interactions. Microbial Pathogenesis. 2005;38:209-225. [pmid: 15925272].
123 Sawada-Hirai R, Jiang I, Wang F, et al. Human anti-anthrax protective antigen neutralizing monoclonal antibodies derived from donors vaccinated with anthrax vaccine absorbed. J Immune Based Therapies and Vaccines. 2004;2:1-15.
124 Zhao P, Liang X, Kalbfleisch J, Koo HM, Cao B. Neutralizing monoclonal antibody against anthrax lethal factor inhibits intoxication in a mouse animal. Human Antibodies. 2003;12:129-135. [pmid: 15156101].
125 Turnbull PCB, Broster MG, Carman JA, Manchee RJ, Melling J. Development of antibodies to protective antigen and lethal factor components of anthrax toxin in humans and guinea pigs and their relevenace to protective immunity. Infect Immun. 1986;52:356-363. [pmid: 3084381]. [pmcid: 261006].
126 Heilman FR, Herrell WE. Penicillin in the treatment if experimental infections with Bacillus anthracis. Proc Staff Meetings Mayo Clin. 1944;19:492-496.
127 Turnbull PCB. Guidelines for the surveillance and control of anthrax in humans and animals. 3rd Edition: World Health Organization; Emerging and other communicable diseases, surveillance and control; 1998. WHO/EMC/ZDI/98.6.
128 Dong SL. Progress in the control and research of anthrax in china. Salisbury Med Bull. 1990;68:104-105.
129 Cangene awarded contract to supply anthrax immune globulin to the U.S. Government for preliminary efficacy testing. September 30, 2005. Cangene Corporation. Available athttp://micro.newswire.ca/release.cgi?rkey=1309306242&review=6128-0&Start=0. Accessed January 19, 2006.
130 Anthrax immune globulin. September 15, 2005. Cangene Corporation. Available at:http://www.cangene.com/products-hyperimmunes.htm#Anthrax. Accessed January 19, 2006. September 15, 2005. Accessed January 19, 2006.
131 Acquisition of therapeutic products for trteatment of inhalational anthrax disease for the strategic national stockpile (RFP: 2004-N-01385). August 18, 2004. U.S. Department of Health and Human Services. Available at:http://fs1.eps.gov/EPSData/HHS/Synopses/37271/Reference-Number-2004-N-01385/AnthraxTherapeuticRFPFFinal.pdf. Accessed Januray 19, 2006.
132 65 - Anthrax therapeutics (Reference-Number-RFI-ORDC-05-04). April 5, 2005. U.S. Department of Health and Human Services. Available at:http://www2.eps.gov/servlet/Documents/R/1115363. Accessed January 19, 2006.
133 Project BioShield related procurement activities. November 3, 2005. U.S. Department of Health and Human Services. Available at:http://www.hhs.gov/ophep/bioshield/PBPrcrtPrjct.htm. Accessed January 19, 2006.
134 Mair M. Brief Report: Recent progress in biodefense countermeasure development. Highlights & Happenings; Biosecurity and Bioterrorism: Biodefense Strategy, Practice and Science. 2005;3:280-285.
135 Pittman PR, Leitman SF, Barrera Oro JG, et al. Protective antigen and toxin neutralization antibody patterns in anthrax vaccinees undergoing serial plasmapheresis. Clinical and Diagnostic Laboratory Immunology. 2005;12:713-721. [pmid: 15939745]. [pmcid: 1151968].
136 Human genome sciences awarded two-phase contract to supply ABthraxTM for the treatment of inhalational anthrax diseases to the U.S. Government. October 3, 2005. Human Genome Sciences, Inc.; Available at:http://www.hgsi.com/news/press/05-10-03_ABthrax_contract.htm. Accessed January 19, 2006.
137 Subramanian GM, Cronin PW, Poley G, et al. A phase 1 study of PAmAB, a fully human monoclonal antibody against Bacillus anthracis protective antigen, in healthy volunteers. Clin Infect Dis. 2005;41:12-20. [pmid: 15937757].
138 Rapoport J, Teres D, Zhao Y, Lemeshow S. Length of stay data as a guide to hospital economic performance for ICU patients. Med Care. Mar. 2003;41:386-397. [pmid: 12618642].
139 Weber RJ, Kane SL, Oriolo VA, Saul M, Skledar SJ, Dasta JF. Impact of intensive care unit (ICU) drug use on hospital costs: a descriptive analysis, with recommendations for optimizing ICU pharmacotherapy. Crit Care Med. Jan. 2003;31:S17-24. [pmid: 12544972].
140 Medicare and Medicaid 2003 Reimbursement Schedules. Center for Medicare and Medicaid Services. Available at: http://cms.hhs.gov/. Accessed Sepetember 5, 2003.
141 Bell DM, Kozarsky PE, Stephens DS. Conference Summary: Clinical issues in prophylaxis, diagnosis and treatment of anthrax. Emerg Infect Dis. 2002;8:222-225. [pmid: 11897081].
142 Fowler RA, Sanders GD, Bravata DM, et al. Cost-effectiveness of defending against bioterrorism: A comparison of vaccination and antibiotic prophylaxis against anthrax. Ann Intern Med. 2005;142:601-610. [pmid: 15838066].
143 Bravata DM, McDonald K, Smith W, et al. Systematic Review: Surveillance Systems for Early Detection of Bioterrorism-Related Diseases. Ann Intern Med. 2004;140:910-922. [pmid: 15172906].
144 Bourgeois FT, Olson KL, Brownstein JS, McAdam AJ, Mandl KD. Validation of Syndromic Survillance for Respiratory Infections. Ann Emerg Med. 2006;47:265-271. [pmid: 16492494].
145 The Impact of Malaria, a Leading Cause of Death Worldwide. Centers for Disease Control and Prevention. September 13. Available at: http://www.cdc.gov/malaria/impact/. Accessed October 12, 2005.
146 Veenema TG. Safeguarding out nation's children: The diagnosis, management and containment of smallpox in infants and children. Biological Research for Nursing. 2003;4:295-304. [pmid: 12698922].
147 Basch PF. Textbook of International Health. New York: Oxford University Press; 1990.
148 Fleischauer AT, Silk BJ, Schumacher M, et al. The validity of chief complaint and discharge diagnosis in emergency department-based syndromic surveillance. Acad Emerg Med. Dec. 2004;11:1262-1267. [pmid: 15576514].