# Executive Summary

## Overview

In response to the 2001 U.S. anthrax attack, there has been a proliferation of guidelines for the diagnosis and treatment of patients with anthrax. However, most of these have not specified screening and management protocols for specific populations, such as children. Efforts to prepare for and respond to future attacks of anthrax bioterrorism will be aided by detailed information about the clinical presentation and treatment responses of both adult and pediatric populations exposed to anthrax.

We performed a systematic review of case reports of pediatric anthrax to describe the clinical course, treatment responses, and predictors of disease progression and mortality for children with anthrax infection. In addition to cases of inhalational, gastrointestinal, and cutaneous anthrax, we included in our analysis case reports of primary anthrax meningoencephalitis (without an identifiable inhalational, gastrointestinal, or cutaneous source).

## Key Questions

We sought to synthesize the data from English-language case reports of children with anthrax to answer three key research questions:

1 What is the evidence for an age-dependent clinical course associated with anthrax?
2 How effective are antibiotic prophylaxis and treatment for anthrax in children compared to adults? Similarly, how effective are other medical treatments in children compared to adults (e.g. ventilator/respiratory support)?
3 Based on the review of evidence for Questions 1 and 2, what are the implications for children versus adults in terms of preparedness and response planning for anthrax exposure (i.e., healthcare provider education on diagnosis and management, considerations for hospitals, vaccination strategies)?

## Methodology

We sought English-language case reports of patients aged 18 years or younger with confirmed inhalational, gastrointestinal, or atypical anthrax (e.g., primary anthrax meningoencephalitis without an identifiable inhalational or cutaneous source). Because there have been hundreds of case reports of pediatric cutaneous anthrax, we selected a random sample of 50 English-language case reports of pediatric cutaneous anthrax for abstraction. We then augmented the data abstracted from the English-language pediatric case reports with the data available from our prior Evidence Report on adult cases of inhalational anthrax. Given key physiological differences among infants, toddlers, and adolescents, we analyzed case reports in three age groups: 0 to 2 years, >2 to 13 years, and >13 to 18 years.

We identified case reports of pediatric anthrax referenced in MEDLINE® between January 1966 and June 2005 using the MeSH terms anthrax and case report. We then performed additional comprehensive searches of retrieved bibliographies and the indexes of selected journals from 1900 to 1966 (e.g., New England Journal of Medicine, JAMA, Lancet, Medical Journal of Australia, La Presse Médicale, Deutsche Medizinische Wochenschrift, La Semana Medicale). We also performed extensive manual searches of retrieved bibliographies.

Two investigators screened potentially relevant articles to determine whether they met inclusion criteria. One investigator independently abstracted patient data from each included case report and reviewed bibliographies for additional potentially relevant studies. Because the purpose of this project was to characterize the spectrum of pediatric anthrax disease as well as to identify the differences in disease progression and treatment responses of adults and children with anthrax, we abstracted three primary types of data from each included article: (1) patient information (e.g., age, gender); (2) symptom and clinical course information (e.g., whether the patient developed meningitis); and (3) treatment information.

We performed univariate analyses to summarize the key patient and treatment characteristics. We applied a Bonferroni correction to account for multiple comparisons.

## Findings

We identified 246 titles of potentially relevant articles from our MEDLINE® search and 2253 additional references from our manual search of the bibliographies of retrieved articles and the indexes of the 14 selected journals. We identified 62 case reports of pediatric anthrax including two inhalational cases, 20 gastrointestinal cases, 37 cutaneous cases, and three atypical cases. Most of the included cases were of adolescents: we found seven cases of children aged 0 to 2 years old, 22 cases of children more than 2 years to 13 years old, and 34 cases of adolescents aged more than 13 years to 18 years old. We did not find any reports of anthrax in pregnant women or reports of prenatal cases of anthrax.

Among the 59 case reports which stated the patient's gender, only 14 (24%) were girls. This is similar to the gender discrepancy observed among adults. Several plausible explanations for this gender disparity include that anthrax has largely been an occupational disease among professions traditionally dominated by men and boys (e.g., woolsorters and butchers) and that there may be biases that result in the under-diagnosis and under-reporting of girls with anthrax.

Overall, the mortality rate was 31%. Among patients who received antibiotics, 71% survived compared to 82% of patients who received antiserum. Only one patient was treated with a fluroquinolone—a key component of the current treatment guidelines for anthrax. None of the included patients received anthrax vaccine.

### Pediatric Inhalational Anthrax

Inhalational anthrax occurs when anthrax spores are inhaled into the lung. There is insufficient evidence available from the two English- and three foreign-language case reports of pediatric anthrax to classify the typical presentation of inhalational anthrax or treatment responses or to compare them to adults with inhalational disease. In particular, we have very little information about inhalational anthrax in infants or toddlers. However, the evidence that is available on pediatric inhalation anthrax does provide us with four key observations.

- Among adults, inhalational anthrax presents with a prodromal phase (often described as flu-like) for whom the most common symptoms or findings at admission are abnormal temperature, abnormal lung findings, fever or chills, tachycardia, fatigue or malaise, cough, dyspnea, and nausea or vomiting. Notably, these symptoms are typically accompanied by nonheadache neurological symptoms such as dizziness, visual changes, and syncope, which are not typical of routine influenza infection. The three children for whom we have signs and symptom data were found to have dyspnea and abnormal lung exams; however, none had either nonheadache neurological symptoms or nausea or vomiting. This suggests that screening algorithms based on adult findings may have less diagnostic accuracy for children presenting with inhalational anthrax.
- Adult patients typically have abnormal chest roentgenograms characterized by pleural effusions or widened mediastinum. Both of the pediatric patients with inhalational anthrax who had chest roentgenograms were found to have similar abnormalities.
- Prior to the introduction of antibiotics, anthrax infection was primarily treated with anti-serum, which reportedly decreased mortality by 75% compared to untreated patients. Later, effective antibiotics such as penicillin and chloramphenicol were added to anthrax treatment strategies. Current treatment guidelines for inhalational in children vary among different professional organizations; however, most recommend triple intravenous antibiotics with ciprofloxacin or doxycycline with two other antibiotics such as clindamycin, rifampin, penicillin, among others. Among adult patients, nearly all of those not given antibiotics or anthrax anti-serum during the prodromal phase progress to the fulminant phase which is a characterized by a rapidly progressive critical illness with respiratory failure, shock. Regardless of antibiotic/anti-serum therapy or other medical intervention such as mechanical ventilation, the overall mortality rate in fulminant phase is 97%. Similarly, the child who received antibiotic treatment during the fulminant phase died. The two children who survived inhalational anthrax were treated with antiserum—a treatment not typically included in current treatment guidelines or bioterrorism preparedness inventories.
- In adults, pleural fluid drainage has been significantly associated with survival after the development of fulminant inhalational anthrax. Only one child with inhalational anthrax received pleural fluid drainage and she survived.

### Pediatric Gastrointestinal Anthrax

Gastrointestinal anthrax results from the ingestion of B. anthracis spores leading to the infection (and often ulceration) of the gastrointestinal epithelium. We found 20 English-language case reports of pediatric gastrointestinal anthrax—most of them were associated with known outbreaks, typically resulting from the consumption of contaminated meat. The average age of these patients was 10.5 years (four children were ≤ 2 years old, eight children were >2 to 13 years old; and eight children were >13 to 18 years old). Five were girls and none of the cases were from the U.S. The literature on pediatric gastrointestinal anthrax provides four key results.

- Compared to inhalational and cutaneous disease, gastrointestingal anthrax is considered quite rare among adults, especially in the U.S. However, among children, there have been more case reports of gastrointestinal disease than inhalational disease. Clearly, children are susceptible to gastrointestinal anthrax from agricultural sources—whether they would be more or less likely to present with primary gastrointestinal disease after a bioterrorism event is not known.
- Historically, gastrointestinal anthrax has been recognized as presenting in two forms: oropharyngeal disease among patients in whom the site of infection is the upper gastrointestinal tract and intestinal disease among patients in whom the site of infection is the lower gastrointestinal tract. Like adults, children seem to have two presentations of gastrointestinal anthrax: upper tract disease characterized by dysphagia and oropharyngeal findings and lower tract disease characterized by fever, abdominal pain, and nausea and vomiting.
- Of the four patients with gastrointestinal anthrax who had roentgenograms, two were found to have pulmonary abnormalities, one patient had “ascites but no other abnormalities,” and one had a normal examination. From the limited evidence, we cannot determine whether roentgenograms contributed significantly to the early diagnosis of pediatric gastrointestinal anthrax.
- The mortality rate for treated gastrointestinal anthrax among adults is generally reported as approximately 40%. However, the children with gastrointestinal anthrax (both treated and untreated) had a somewhat higher case-fatality rate (63%). Among the children with gastrointestinal disease who died, many had developed meningoencephalitis, presumably as a result of hematologic dissemination.

### Pediatric Cutaneous Anthrax

Cutaneous anthrax has long been recognized as an occupational hazard for adults handling contaminated animal products who introduce B. anthracis spores into the skin through cuts, abrasions, or insect bites. It is reported to account for more than 95% of clinical anthrax disease. We randomly selected 50 English-language case reports of children with cutaneous anthrax. Of these, only 37 provided sufficient information about individual patients to be included in our analysis. In general, even the included reports of pediatric cutaneous anthrax were of very poor quality, often providing only a few sentences about the patient and their clinical course (and rarely even describing the skin lesions in detail). The reports of these 37 children with cutaneous anthrax provide three key findings.

- Historically, cutaneous anthrax usually begins with a small, painless, pruritic papule on an exposed area. This lesion enlarges and becomes an oval eschar surrounded by vesicles with marked, painless brawny edema and tissue necrosis. The skin lesions described for children are similar to the classical skin lesions described for adults.
- Only seven of the included pediatric cutaneous cases were girls (the gender was unreported for three cases). This male predominance is similar to what has been observed among adults and may represent the relatively higher risk of occupational exposures among boys and men or under-diagnosis or under-treatment of girls with anthrax.
- Among adults, untreated cutaneous anthrax has been associated with a 5 to 20% case fatality rate (presumably from hematologic dissemination of disease) but is rarely fatal when treated. Only five children died (13.5% case fatality rate) which falls within the range of adult case fatality rates. All of these were boys, three of whom had not received antibiotics. One child developed meningoencephalitis before he died.

### Atypical Anthrax

Historically, anthrax has been classified according to the three principal exposures: inhalational, gastrointestinal, and cutaneous. Although rare, atypical anthrax presentations do occur among adults including laryngopharyneal and nasopharyngeal disease and primary anthrax meningoencephalitis. Some authors have speculated that the port of entry for primary anthrax meningoencephalitis is either an unrecognized lower respiratory tract port of entry or transethmoid migration of occult nasopharyngeal infection.

We found 2 cases of pediatric laryngopharyngeal anthrax, one report of a girl with nasopharyngeal disease, and one English-language and five foreign language case reports of children with primary meningoencephalitis (97% of whom died). From these cases, we conclude, that, although uncommon, children can have atypical presentations of anthrax. Although we cannot determine with certainty the means by which these patients contracted anthrax, we suspect an inhalational exposure for many, if not most, of them. To prevent delays in diagnosis and therapy during future bioterrorist attacks, clinicians should recognize that anthrax infection in both adults and children might present with primary nasal, laryngeal, pharyngeal, and/or meningeal symptoms.

## Discussion and Summary Answers to the Key Questions

Anthrax is a relatively common and historically well-recognized disease and yet rarely reported among children—particularly among the very young children. The paucity of pediatric anthrax case reports, particularly among the youngest children, suggests that these children may have less exposure to anthrax or that anthrax infection in this population may be under-diagnosed and/or under-reported. We note that the presenting symptoms for pediatric inhalational anthrax are very common for many childhood diseases and that naturally occurring anthrax disease is most prevalent in poor countries where children may never come to medical attention or have diagnostic cultures confirmed. Additionally, there may be a significant publication bias in this literature (e.g., cases that are unusual or fatal may be more likely to be published)..

Question #1 What Is the Evidence for an Age-dependent Disease Progression Associated with Anthrax?

Although children with anthrax may present with somewhat different symptoms than adults, we found no specific evidence for age-dependent differences in disease progression. Like adults, children with gastrointestinal anthrax, seem to have two distinct clinical presentations: One resulting from upper tract disease and another resulting from lower tract disease. Additionally, children with inhalational disease may have non-pulmonary presentations including primary meningoencephalitis.

Question #2 How Effective Are Antibiotic Prophylaxis and Treatment for Anthrax in Children Compared to Adults? Similarly, how effective are other medical treatments in children compared to adults (e.g. ventilator/respiratory support)?

Most of the children included in our analysis who received an antibiotic were given penicillin-based antibiotics which produced a 63% survival rate. Other successful treatments included antiserum, which produced an 82% survival rate. These survival rates were similar to those observed for adults.

In adults, pleural fluid drainage was significantly associated with survival after the development of fulminant inhalational anthrax. One child with inhalational anthrax received pleural fluid drainage and she survived. However, we found insufficient cases of children who received pleural fluid drainage (or other treatment modalities such at mechanical ventilation) to determine the extent which they may be more or less effective in children than they are in adults.

Question #3 Based on the review of evidence for Questions 1 and 2, what are the implications for children versus adults in terms of preparedness and response planning for anthrax exposure (i.e., healthcare provider education on diagnosis and management, considerations for hospitals, vaccination strategies)?

The results of our systematic review have implications for preparedness planning efforts that relate to the diagnosis and management of children with anthrax. The presenting signs and symptoms of children with anthrax are very similar to the signs and symptoms of children presenting with much more common infectious diseases. This creates a difficult diagnostic challenge both for clinicians needing to make a timely diagnosis and public health officials implementing syndromic surveillance systems. More research is needed to identify the specific signs and symptoms that distinguish common pediatric infections such as influenza from early anthrax infection.

Only one of the 62 pediatric anthrax cases was treated with a fluoroquinolone; however, penicillin-based and antiserum regimens were much more commonly used among the included cases and were associated with favorable survival rates. Antiserum is not included in current treatment guidelines or bioterrorism preparedness inventories and has been associated with serum sickness and inconsistency in effectiveness across batches. Similarly, current treatment guidelines do not include penicillin as a single agent due to concerns of penicillin-resistant organisms. Thus, we have little evidence about the use of the medical regimens currently considered first line against anthrax and more evidence about those therapies not currently being recommended

## Future Research

To facilitate accurate diagnosis and effective treatment of children with anthrax, future pediatric anthrax case reports should provide much more detailed information about exposure, clinical presentation, and treatment responses for infants, toddlers, and adolescents with anthrax.

The finding that anthrax antiserum was associated with survival among historical cases of children with anthrax warrants additional research on the safety, efficacy, and potential availability of this therapy. Similarly, we found no reports of children having received anthrax vaccine (which is currently only available for adults)—additional research is required regarding the safety and effectiveness of anthrax vaccination for both prophylaxis and treatment of children exposed to anthrax.

The finding that children may not present with the same signs and symptoms as adults has implications for syndromic surveillance systems (e.g., the finding that non-headache neurological symptoms was a key distinguishing feature of adult inhalational anthrax was not found among children). Specifically, the development of pediatric syndromic surveillance requires additional research to identify the key presenting signs and symptoms of pediatric anthrax that distinguish patients with this disease from other common infections.