# Acknowledgments

We thank Emilee Wilhelm for her help with article retrieval and Corinna Haberland for her assistance with translations.