# Discussion

This is the first published synthesis of the literature describing the spectrum of clinical anthrax in children. The 62 English-language pediatric cases included in this review provide four key findings.

First, children with anthrax present with a wide range of clinical signs and symptoms—which differ somewhat from the presenting features of adults with anthrax. Like adults, children with gastrointestinal anthrax have two distinct clinical presentations: One resulting from upper tract disease characterized by dysphagia and oropharyngeal findings and another resulting from lower tract disease characterized by fever, abdominal pain, and nausea and vomiting. Additionally, children with inhalational disease may have atypical presentations including primary meningoencephalitis. Clinicians and public health officials need to recognize the broad spectrum of potential presentations of anthrax in children for timely diagnosis and for the design of syndromic surveillance systems.^144^

Second, whereas children with inhalational anthrax did have abnormal chest roentgenograms, children with other forms of anthrax often had normal roentgenograms. Thus, the usefulness of roentgenograms in the early diagnosis of non-inhalational anthrax disease may be limited.

Third, most of the children included in our analysis who received an antibiotic were given penicillin-based antibiotics which produced a 63% survival rate. Other successful treatments included antiserum, which produced a 82% survival rate. Antiserum is not typically included in current treatment guidelines or bioterrorism preparedness inventories. Similarly, current treatment guidelines do not include penicillin as a single agent due to concerns of penicillin-resistant organisms.^9,^ ^138–141^ Only one child received a fluoroquinolone—which is a key component of current treatment guidelines for children with anthrax. In the event of shortfalls in stockpiles of the currently recommended antibiotics, penicillin or antiserum may provide some therapeutic benefit.

Finally, anthrax is a relatively common and historically well-recognized disease and yet rarely reported among children. We did not find evidence to support or refute the claim that children may be less susceptible to anthrax infection. In general, the relatively small number of pediatric cases of anthrax may reflect that this has traditionally been an occupational disease so that, particularly young children, may not have the same degree of exposure to anthrax spores. Additionally, the paucity of pediatric anthrax case reports suggests that anthrax may be under-diagnosed in children. Under-diagnosis and under-reporting of anthrax is likely to occur for several reasons: The presenting symptoms for pediatric inhalational anthrax are very common for many childhood diseases and since acute respiratory infections are the second leading cause of death worldwide for children under five years old, it is highly likely that naturally occurring pediatric anthrax has been attributed to one of the common childhood respiratory infections.^145,^ ^146^ Additionally, naturally occurring anthrax disease is most prevalent in poor countries with few healthcare resources and high infant mortality rates, where children may never come to medical attention or have diagnostic cultures confirmed.^147^ Also, clinicians may be unlikely to report a case without culture confirmation which can be difficult since B. anthracis is quickly cleared after the initiation of antibiotics.

## Limitations

This review has several limitations. First, because we did not have access to the original hospital and medical records, our analyses are dependent upon the data presented in the case reports. Second, because most of the patients in our review are presumed to have contracted anthrax from an occupational exposures or direct contact with contaminated animal products, our results may have limited generalizability to anthrax infection that occurs from bioterrorism. However, we cannot assess the extent to which differences in virulence and inoculating doses between anthrax infection from bioterrorism and from occupational exposure may result in differences in clinical presentations and treatment responses. Third, among the included cases, most were of older children. Thus, our results may not be generalizable to infants and toddlers with anthrax. Finally, the general paucity of pediatric cases suggests that there may be a significant publication bias in this literature.

## Future Research

In order to facilitate accurate diagnosis and effective treatment of children with anthrax, future pediatric anthrax case reports should provide much more detailed information about exposure, clinical presentation, and treatment responses (such as those data described in Appendix A).

The finding that children may not present with the same signs and symptoms as adults has implications for syndromic surveillance systems. An evaluation of a drop-in syndromic surveillance system compared the syndromic categorization by emergency department staff in 11 Phoenix hospitals with chief complaints and discharge diagnoses.^148^ Overall, agreement between the syndromic categorization and the discharge diagnoses was moderate (κ =0.63; [CI, 0.59–0.67]) with the greatest agreement for the gastroenteritis/diarrheal syndrome and lowest for the febrile respiratory tract infection syndrome.^148^ However, pediatric chief complaints showed lower agreement for the febrile respiratory tract infection syndrome when compared with adults (κ = 0.34 [95% CI = 0.20 to 0.47] versus κ = 0.44 [95% CI = 0.28 to 0.59], respectively). ^148^ This suggests that additional research is needed on the presenting signs and symptoms of pediatric anthrax to inform the development of pediatric syndromic surveillance categories.

Additionally, to determine the extent to which children and adults differ with respect to the prevention and treatment of anthrax-associated morbidity and mortality, comprehensive evaluations are required of the safety and efficacy of prophylactic vaccines, the role of various antibiotics (including those not currently recommended in prophylaxis and treatment guidelines), and the role of non-antibiotic therapies such as antiserum and pleural fluid drainage.

## Conclusions

The limited data available on children with anthrax suggest that their clinical presentation and treatment responses differ somewhat from adults with anthrax. Clinicians and public health officials should be aware of these differences for the timely diagnosis of children with anthrax and for the development of syndromic surveillance tools for populations that include pediatric patients.