# Results

## Summary of Included Studies

We identified 246 titles of potentially relevant articles from our MEDLINE® search and 2253 additional references from our manual search of the bibliographies of retrieved articles and the indexes of the 14 selected journals. After removing duplicate reports, we included 62 English case reports of pediatric anthrax from which we abstracted detailed patient, treatment, and disease progression information. We did not find any reports of anthrax in pregnant women or reports of prenatal cases of anthrax.

Table 6 describes the distribution of these cases by source of anthrax infection and compares them to the non-English language case reports and adult case reports for which we have limited data (previously collected).

Table 6 Distribution of anthrax case reports by source, language, and age

Source of Anthrax Infection | Number of Pediatric Cases | | | Number of Adult Cases
| English | Non-English | Total | English | Non-English | Total
Inhalational | 2 | 3 | 5 | 45 | 32 | 77
Gastrointestinal | 20 | 2 | 22 | 42 | 50 | 92
Cutaneous | 222^b^ | 229 | 451 | 895 | 1724 | 2619
Atypical: Laryngopharyngeal | 2 | 0 | 2 | 0 | 2 | 2
Atypical: Nasopharyngeal | 0 | 1 | 1 | 2 | 3 | 5
Atypical: Primary Meningoencephalitis | 1 | 5 | 6 | 22 | 10 | 32

a Pediatric Cases were defined as those in persons ≤ 18 years old.

b Of the 222 cutaneous cases, we selected a random sample of 50 for abstraction, of which only 37 provided sufficient data for inclusion in this analysis

Given key physiological differences among infants, toddlers, and adolescents, we analyzed the English-language case reports according to three age groups: 0 to 2 years old (7 cases), more than 2 years to 13 years old (22 cases), and more than 13 years to 18 years old (34 cases) (Table 7). We found relatively few English-language case reports of infants and young children with anthrax. This paucity of case reports among the youngest children result from several factors. First, anthrax has been historically recognized as an occupational disease so it is reasonable that only older children would have these occupational exposures. Additionally, particularly because the presenting signs and symptoms of anthrax-related disease are similar to other infectious diseases, there may be biases resulting in under-diagnosis and under-reporting of anthrax among the youngest children.

Table 7 Distribution of English-language cases by age

Age Group | Source of Anthrax Infection | Number of Cases | Number of Females | Number Surviving
0 to 2 years | Inhalational | 0 | 0 | N/A
| Gastrointestinal | 4 | 2 (50%) | 1 (25%)
| Cutaneous | 3 | 2 (66.7%) | 1 (33%)
| Atypical | 0 | 0 | N/A
>2 to 13 years | Inhalational | 1^a^ | 1 (100%) | 1 (50%)
| Gastrointestinal | 8 | 1 (12.5%) | 3 (42.8%)^b^
| Cutaneous | 12 | 1 (8%) | 12 (100%)
| Atypical: Laryngopharyngeal | 1 | 0 (0%) | 1 (100%)
>13 to 18 years | Inhalational | 1 | 1 (100%) | 0
| Gastrointestinal | 8 | 2 (25%) | 3 (37.5%)
| Cutaneous | 22 | 4 (21%)^c^ | 18 (82%)
| Atypical: Laryngopharyngeal | 1 | 0 (0%) | 1 (100%)
| Atypical: Primary Meningoencephalitis | 1 | 0 (0%) | 0 (0%)

a This cases was 2.5 years old.

b One case report of gastrointestinal anthrax did not state if the patient survived.

c Three reports of patients with cutaneous anthrax did not state the patients' gender.

N/A = not applicable

In the sections that follow, we first present the results for each types of pediatric anthrax (e.g., inhalational, gastrointestinal) then present summary information about all reviewed cases including summary information about treatment responses.

### Inhalational Anthrax

Background. Because it is assumed that during a bioterrorism event, anthrax spores would be inhaled from an aerosolized source, a comprehensive assessment of the clinical presentation of inhalational anthrax is essential for early diagnosis. We direct interested readers elsewhere for reviews of the adult literature of inhalational anthrax.^24,25^ Briefly, among adults inhalational anthrax typically presents with a prodromal phase (often described as flu-like) during which fever, chills, and cough are the most common presenting symptoms. ^24,25^ Among adults, the most common symptoms and/or findings at admission are abnormal temperature, abnormal lung findings, complaint of fever or chills, tachycardia, fatigue or malaise, cough or dyspnea.^24^ Non-headache neurological symptoms such as dizziness, visual changes, and syncope are also prominent and are key symptoms that distinguish patients with inhalational anthrax in the prodromal phase from patients with influenza. ^24,25^ Among adult patients, with the exception of one patient (who was a veterinarian and thought to have partial immunity to anthrax from prior exposure), patients not treated during the prodromal phase progress to the fulminant phase.^26^ The fulminant phase of disease is characterized by a rapidly progressive critical illness with respiratory failure, shock, and, usually, death. Regardless of antibiotic/anti-serum therapy or other medical intervention such as mechanical ventilation, the overall mortality rate in fulminant phase is 97% (only two patients are known to have survived the fulminant phase of inhalational anthrax).^27^–^34^All adult patients with inhalational anthrax who had chest roentenograms had abnormal findings including pleural effusions (69%) or widened mediastinum (54%).^24^

Pediatric inhalational anthrax reports. There have been two English-language case reports of pediatric inhalational anthrax (Table 8).

Table 8 Pediatric inhalational anthrax case reports

Yr. (Ref.) | Age, Gender | Country | Anthrax Exposure Risk | Symptoms at Presentation | Initial Physical Exam | Initial Labs | Treatment* | Complications^‡^ | Died | Autopsy Findings
English-Language Pediatric Cases
1928^35^ | 2.5, F | U.S. | Unknown | Cough, restlessness | Febrile, abnormal lung exam, cyanosis, pharyngeal erythema & edema, abdominal distension, mottled skin, erythematous bulging tympanic membranes | WBC 18K; purulent urine | H | PE, PFD, C | No | n/a
1975^36^ | 16, F | Iran | Unknown | Dyspnea, axilla swelling | Abnormal lung exam, afebrile, abnormal chest roentenogram | | P, Ch | - | Yes | Pulmonary edema, mediastinal widening, hemorrhagic mediastinal and axillary nodes
Foreign-Language Pediatric Cases
1901^37,38^ | 16, F | Poland | Unknown | “In agony” | - | - | None | M, PE | Yes | n/a
1929^39^ | 17, M | Germany | Wool | Fever, chills, pleurisy, cough, dyspnea, hemoptysis | Febrile, tachycardia, abnormal lung exam | - | As | - | No | n/a
1954^40,41^ | 13,M | Russia | Dust from infected sheep and calf | - | - | - | None | M | Yes | n/a

* Treatment abbreviations: As-Anthrax anti-serum, Ch-Chloramphenicol, H-Horse anti-serum, P-Penicillin.

‡ Complications: M-Meningitis, C-Cyanosis, PE-Pleural effusion(s), PFD-Pleural fluid drainage.

The symbol '-' represents either not seen prior to death or no additional signs or symptoms noted in case report at presentation.

The first was a 1928 report of a 2½ year old girl who lived on a farm in Iowa on which several horses had died. She presented with a fever to 103°F; restlessness; coughing; bulging, erythematous tympanic membranes; and “a marked translucent edema about the eyes” that extended to the waist.^35^ Her initial lung exam was notable for “numerous fine crepitant râles were superimposed over tubular breathing.”^35^ Her laboratory tests were significant for a leukocyte count of 18,000 and urinalysis that was frankly purulent. Chest roentenogram revealed a “diffuse pneumonic process of the right lung.^35^ Because copious gram-positive organisms grew from her pleural fluid, she was given anthrax anti-serum. On hospital day ten she defervesced and was much improved; however, it was noted that she could not see. On fundoscopic examination, she was noted to have pale retinae and almost white optic cups, no visible veins, and arteries “that showed only as minute threads.” ^35^ Her clinicians concluded that she had suffered septic emboli of her optic arteries.^35^ She was discharged and on follow up examination was noted to be a healthy child who “walked and talked, and gave evidence of light perception, but no vision.”^35^

The second case was a 1975 report of a 16 year old Iranian farmer girl admitted with dyspnea and painless swelling in her left axilla for two days.^36^ On admission, she was afebrile but was noted to have edema of her chest wall and scattered râles of the lung bases.^36^ Over the first hospital day, her axillary swelling increased in size and the skin overlying it developed petechial hemorrhages.^36^ Her leukocyte count was 33,000 with 90% neutrophils and her chest roentenogram showed “marked widening of the mediastinum with smooth borders and a soft tissue swelling over the right chest wall. The lung fields were clear.”^36^ She became stuporous and developed severe respiratory stridor and was treated with penicillin and chloramphenicol. On hospital day three, despite this treatment, she became hypotensive and died.^36^ Autopsy showed massive pulmonary edema, mediastinal widening with hemorrhage of the mediastinal lymph nodes—one of which had eroded into the carina. B. anthracis was cultured from the mediastinum and lungs.^36^

We also found three foreign language case reports of children aged 13 to 17 for which we were able to obtain only scant clinical, laboratory, or disease progression data from our prior Evidence Report. The child who received antiserum survived, but the two children who did not receive therapy died (Table 8).

A screening algorithm based principally on adult anthrax cases designed to distinguish patients with inhalational anthrax from those with common viral respiratory tract infections found that rhinorrhea and sore throat were the two symptoms most associated with viral illnesses (positive likelihood ratios of 0.2 [CI, 0.1–0.4] and 0.2 [CI, 0.1–0.5] respectively).^25^ None of the included pediatric patients were reported to have either of these symptoms. In this screening algorithm, the symptoms most suggestive of inhalational anthrax were nonheadache neurological symptoms (no positive likelihood ratio calculated), dyspnea (positive likelihood ratio, 5.1 [CI, 3.0–8.5]), nausea or vomiting (positive likelihood ratio, 5.3 [CI, 3.7–7.4]), and any abnormality on lung auscultation (positive likelihood ratio, 8.1 [CI, 5.3–12.5]). ^25^ All of the children for whom we have signs and symptom data were found to have dyspnea and abnormal lung exams; however, none had either nonheadache neurological symptoms or nausea or vomiting. This suggests that this screening algorithm may have less diagnostic accuracy for children than for adults presenting with inhalational anthrax.

In adults, pleural fluid drainage was significantly associated with survival after the development of fulminant inhalational anthrax.^24^ One child with inhalational anthrax received pleural fluid drainage (and she survived). However, we have insufficient cases to determine the extent which pleural fluid drainage (or other treatment modalities) were particularly associated with survival.

Summary. In the event of an aerosolized anthrax bioterrorism attack, most of the resultant morbidity and mortality will be from inhalational disease. The five published case reports of pediatric anthrax provide insufficient evidence to classify the typical presentation or treatment responses of children with inhalational anthrax or to compare them to adults with inhalational disease. However, the little evidence that is available on pediatric inhalation anthrax does provide us with three interesting observations. First, we note that the adolescent who received treatment during the fulminant phase died. This is in keeping with the high fatality rate for patients with fulminant inhalational anthrax observed for adult cases. Second, the two children who survived were treated with antiserum—a treatment not typically included in current treatment guidelines or bioterrorism preparedness inventories (we describe the use of anti-serum in greater detail in the section on treatment response in the summary of all cases at the end of this chapter). Finally, there is a paucity of pediatric cases in the literature for what is a relatively common and historically well-recognized disease. This suggests that pediatric cases may be under-diagnosed (we note that the presenting symptoms for pediatric inhalational anthrax are very common for many childhood diseases), or that children may have decreased exposure (as this has traditionally been an occupational illness), or that a significant publication bias may exist in this literature (e.g., cases that are unusual or fatal may be more likely to be published). For example, we question whether the case of the two year old Iowa farm girl was published because of the unusual complication of septic emboli, and may not represent the typical spectrum of presentations of inhalational anthrax.

### Gastrointestinal Anthrax

Background. Gastrointestinal anthrax results from the ingestion of B. anthracis spores leading to the infection (and often ulceration) of the gastrointestinal epithelium. Whereas the vegetative forms of B. anthracis can be killed by pasteurization, anthrax spores are robust and can cause disease even after exposure to heat, cold, desiccation, and exposure to acid.^42^ Thus, a bioterrorism attack in which spores were used to contaminate food or beverages could result in gastrointestinal disease. Additionally, after a mail-based attack (such as during 2001), gastrointestinal disease could occur through manual deposition of spores into the mouth or contamination of nearby consumables.

Compared to inhalational and cutaneous disease, gastrointestingal anthrax is considered quite rare among adults, especially in the U.S. Often there have been outbreaks of several patients presenting with gastrointestinal anthrax after consuming contaminated meat.^43^ The mortality rate for treated gastrointestinal anthrax is generally reported as approximately 40%.^42^ Historically, gastrointestinal anthrax has been recognized as presenting in two forms: oropharyngeal disease among patients in whom the site of infection is the upper gastrointestinal tract and intestinal disease among patients in whom the site of infection is the lower gastrointestinal tract.^42^ Oropharyngeal anthrax presents with high fevers, ulcerations of the posterior oropharynx, severe sore throat, and cervical lymphadenopathy (often with marked swelling of the neck).^42^ In a report of an outbreak of adults with oropharyngeal disease contracted from consuming contaminated meat, three of the 24 patients died.^44^

In contrast, intestinal anthrax presents with high fevers, diarrhea, severe abdominal pain, and serosanginous or frankly hemorrhagic ascites.^42^ In a report of 155 people in Uganda who ate a contaminated zebu, 91% developed anthrax with gastrointestinal complaints (including nine children who died within 48 hours of onset of symptoms^2^ ).^45^ Whereas bowel ulcerations are a common finding among adults with gastrointestinal anthrax; nonulcerative, hemorrhagic lesions of the bowel are often associated with anthrax sepsis from inhalational, cutaneous, and oropharyngeal disease.^42^ Abdominal roentgenograms generally reveal nonspecific findings such as increased bowel gas patterns with air-fluid levels or evidence of ascites.^42^

2 These nine children are not included in our analysis because individual case report data have not been published for them.

Pediatric gastrointestinal anthrax reports. We found 20 English-language case reports of pediatric gastrointestinal anthrax—most of which were associated with a known outbreak, typically resulting from the consumption of contaminated meat. Seven patients survived. The average age of these patients was 10.5 years (four children were ≤ 2 years old, eight children were >2 to 13 years old; and eight children were >13 to 18 years old). Five were girls and none of the cases were from the U.S.

The pediatric cases presented with symptoms similar to those reported for adults:^46,47^ The most common presenting symptoms were fever (60%), abdominal pain (45%), and nausea and vomiting (45%) without any reports of hematemesis. Four patients (20%) had diarrhea and only one reported a bloody stool. Three cases presented with symptoms of oropharyngeal or upper gastrointestinal disease (Table 9). Of the three patients who went on to have abdominal surgery, all had mesenteric lymphadenopathy. Nine patients (45%) developed meningoencephalitis. Of the 19 patients for whom we were able to determine short-term survival after anthrax, 12 died (63% case fatality rate).

Table 9 English-language pediatric gastrointestinal anthrax case reports

Yr. (Ref.) | Age, Gender | Country | Type of GI disease^§^ | Initial Symptoms | Initial Physical Exam | Treatment* | Complications^‡^ | Died | Autopsy Findings
2002^48^ | 15, M | Iran | LG | Fever, abd pain, diarrhea | Febrile but vital signs otherwise normal. Abdomen tender, no splenomegaly. | P | Sh, DIC | Yes | Subendocardial petechiae non hemorrhagic effusion.
| | | | | | | | | Stomach, small bowel, mesentery and spleen had edema, hemorrhage, adenopathy but no ulcerations. Esophagus hemorrhagic spots
1991 | 2, F | Iran | LG | Fever, abd pain, emesis | Febrile, tachycardic, tachypneic, hypotensive Cyanosis, abd tender, distended, no bowel sounds, no skin lesions | A, G, Ch | | Yes | None reported
2002^48,49^ | 8, M | Iran | LG | None reported | None reported | None reported | | Yes | None reported
1989^50^ | 11, M | India | LG | | No info | Antibiotics, type not specified | | Not stated | None reported
1976^51^ | 17, M | Bangladesh | LG | Fever, anorexia, abd pain | Febrile, no lung findings, abd tender, no distention, no hepato/splenomegaly, slight R flank tenderness, bowels sounds slightly decreased | P, A, Ch, S, T, E | T, Sh | No | Not applicable
1965^43^ | 7, M | Lebanon | LG | Periumbilical pain, fever, vomiting | Distended abd, palpable mass in R iliac fossa ascites, hypotension | P | S | No | Not applicable
1962^43^ | 17, M | Lebanon | LG | Fever, abd pain | Tender distended abdomen, ascites | P, S | S | No | Not applicable
1974^43^ | 15, M | Lebanon | LG | None reported | Ascites, oculofacial congestion | P | S, Sh | No | Not applicable
1965^52^ | 14, M | Thailand | LG | Fever, abd pain, emesis, diarrhea | On admission vital signs were stable, respiratory distress, delerium, abd tender, distended, ascites | “antimicro-bials not given” | Sh, RF | Yes | No cerebral findings, lung hemorrhage; small bowel, mesentery and spleen edema and hemorrhage; small bowel ulcerations; mesenteric adenopathy
1932^53^ | 7, M | Philippines | LG | Fever, abd pain | None reported | None reported | | No | Not applicable
1989^54^ | 6, M | Iran | LG | Fever, emesis | Febrile, tachypneic, nuchal rigidity, kernigs sign | P, S | PE, PFD, Sh, M | No | Not applicable
1989^54^ | 2, F | Iran | LG | | Febrile, tachypneic, coma, seizure, nuchal rigidity, + kernigs, ptosis, dilatation rt pupil | P, S | M | Yes | None reported
1997^55^ | 13, M | Asia | LG | Emesis | Febrile, dehydrated, RLQ tenderness, no rebound or guarding, decreased bowel sounds, no meningeal or skin signs | Cf,A, Cm | MV, Sh, RF, DIC, M | Yes | Grossly swollen brain with focal subarachnoid hemorrhage, lots of gram + bacteria; cecum hemorrhagic and necrotic with polys, macrophages, bacteria
1996^56^ | 11, F | Europe | LG | Fever, abd pain, emesis | Febrile, ALOC, no nuchal rigidity,no skin signs | None reported | MV, RF, M | Yes | None reported
1953^57^ | 15, M | Africa | LG | Emesis | Febrile, coma, no focal neuro, no nuchal rigidity | P | M | Yes | Petechial, subarachnoid hemorrhage, no hemorrhagic lesions of mouth, no lung findings, small bowel hemorrhage and small ulcer, no splenic findings, mild jaundice of all tissues
1994^58^ | 13, M | Asia | LG | Fever, abd pain, emesis | None reported | A, Cx, Cm,M, Fl, Ac | M | Yes | Meningial involvement of anthrax bacilli
2003^59^ | 2, M | Asia | LG | Fever, abd pain, emesis | ALOC, coma | None reported | M | Yes | None reported
1977^47^ | 3 mos, M | India | UG | Emesis | No fever on admission (abx prior), blebs, ulceration and sloughing of gums and hard palate, ulcerations covered with “dirty looking slough” | P | | No | Not applicable
1981^46^ | 18, F | Turkey | UG | Fever, dyspnea, dysphagia | None reported | P,G | RF | Yes | Brain, lung hemorrhage, tonsillar findings, ENT adenopathy, no abdominal findings noted
1983^46^ | 16, F | Turkey | UG | Fever, dysphagia | Febrile, lethargic, orolaryngeal edema, large tonsil with pseudomembrane and right-sided neck mass | None reported | Sh | Yes | Brain, lung hemorrhage, tonsillar findings, ENT adenopathy, small bowel hemorrage, hyperemia kidneys and liver

§ Type of GI disease refers to whether the primary source of infection was the upper (UG) or lower (LG) gastrointestinal tract.

* Antibiotics or anthrax anti-serum. Abbreviations: A-Ampicillin, Ac-Acylovir, Ag-Amoxicillin/Clavulanate, Am-Ambramycin, As-Anthrax anti-serum, Ax-Amoxicillin, Au-Aureomycin, Az-Azithromycin, C-Ciprofloxacin, Ce-Cefamandol, Cf-Cefuroxime, Ch-Chloramphenicol, Cl-Clindamycin, Cm-Cefotaxime, Cn-Ceftriaxone, Cx-Cloxacillin, Cz-Ceftazidime, D-Doxycycline, E-Erythromycin, F-Flucloxacillin, Fl-Fluconazole, G-Gentamicin, H-Horse anti-serum, L-Levofloxacin, M-Metronidazole, N-Naficillin, P-Penicillin, R-Rifampin, Re-Reverin, S-Streptomycin, Sd-Sulfadiazine, Sf-Sulfanilamide, St-Sulfathiazole, T-Tetracycline, Ts-Trimethoprim/Sulfamethoxazole, U-Ampicillin/Sulbactam, V-Vancomycin.

‡ Complications: M-Meningitis, C-Cyanosis, DIC-disseminated intravascular coagulation, PE-Pleural effusion(s), PFD-Pleural fluid drainage, S-surgery, Sh-shock, MV-mechanical ventilation, RF-Respiratory failureT-transfusion(s)

Thirteen of the 14 patients who received antibiotics were given a regimen that included a penicillin-based antibiotic, ten patients received more than one antibiotic, and no patients received anti-serum. The use of penicillin-based antibiotics likely reflects the year of the case report, the country of origin of the patient, among other factors. We found no patient or treatment factors that were significantly associated with survival from gastrointestinal anthrax; however, this analysis had limited power to detect predictors of survival given the small sample size. However, it is notable that whereas all five girls with gastrointestinal anthrax died, only seven of the 14 boys with gastrointestinal anthrax died. Additionally, cases prior to 1977 were less likely to die (six of the eight pre-1977 cases lived) compared to more recent cases (ten of the 11 cases after 1977 died).

Summary. The literature on pediatric gastrointestinal anthrax (of which only eight cases were less than 10 years old) provides four key results. First, whereas gastrointestinal anthrax is much rarer than other forms of anthrax for adults, there have been many more case reports of gastrointestinal disease than inhalational disease among children. Clearly, children are susceptible to gastrointestinal anthrax from agricultural sources—whether they would be more or less likely to present with primary gastrointestinal disease after a bioterrorism event likely depends on the type of bioterrorism attack (e.g., intentional contamination of food sources or surfaces could result in gastrointestinal disease). Second, like adults, children have two presentations of gastrointestinal anthrax: upper tract disease characterized by dysphagia and oropharyngeal findings and lower tract disease characterized by fever, abdominal pain, and nausea and vomiting. Third, among the reported cases of gastrointestinal anthrax among children, there is a high case-fatality rate (63%). Among those who died, many had developed meningoencephalitis. Finally, that case reports from before 1977 were more likely to describe patients who lived is not readily explainable, and might represent publication bias among the more recent case reports.

### Cutaneous Anthrax

Background. Cutaneous anthrax has long been recognized as an occupational hazard for adults handling contaminated animal products who introduce B. anthracis spores into the skin through cuts, abrasions, or insect bites.^60^ It is reported to account for more than 95% of clinical anthrax disease.^61^ Historically, after an incubation period of less than three days, cutaneous anthrax usually begins with a small, painless, pruritic papule on an exposed area.^61^ Classically, this lesion enlarges and becomes “oval eschar surrounded by vesicles with painless and marked edema.”^62^ Subcutaneously inoculated anthrax produce toxins resulting in the marked “brawny edema” and tissue necrosis characteristic of this disease.^63^ Anthrax bacilli can usually be easily demonstrated on gram stain smears of fluid from these lesions.^61^ Among adults, untreated cutaneous anthrax has been associated with a 5 to 20% case fatality rate (usually from haematologic dissemination of disease) but is rarely fatal when treated.^61^ During an aerosolized bioterrorism event with anthrax, children touching a contaminated surface may present with cutaneous disease.

Pediatric cutaneous anthrax reports. We randomly selected 50 English-language case reports of children with cutaneous anthrax. Of these, 13 provided insufficient information about individual patients to be included in this analysis, 37 reports (74% of the randomly selected sample of cases) provided sufficient detail that data could be abstracted (Table 10). In general, even the included reports of pediatric cutaneous anthrax were of very poor quality, often providing only a few sentences about the patient and their clinical course (and rarely even describing the skin lesions in detail).

Table 10 English-language pediatric cutaneous anthrax case reports

Yr. (Ref.) | Age, Gender | Country | Symptoms at Presentation | Initial Physical Exam | Treatment^*^ | Died
1905^64^ | 17, F | G.B. | Throat swelling, skin lesion | Skin pustule, vesicle with edema | As | No
1906^65^ | 18, M | G.B. | Painless skin lesion | Fever, mildly tachycardic, pustule and edema | As, FFP | Yes
1922^66^ | 16,F | U.S. | Skin lesion | Circumscribed papulopustule | Surgical debridement | No
1923^67^ | 17, ? | U.S. | Cheek lesion | Cheek lesion | H | No
1923^67^ | 14, ? | U.S. | Skin lesion | Skin lesion | H | No
1946^68^ | 12, M | Mexico | Skin lesion | Skin eschar and edema | Cutaneous radiation rx | Not stated
1999^69^ | 16, M | Turkey | Fever, throat swelling, skin lesion with pruritis | Febrile, tachycardic, tachypneic, skin lesion | P; Flouroquinolone not specified. Steroids, surgical debridement | No
1971^70^ | 2, F | Africa | Fever, swelling on left side of face | Febrile, left face and mouth lesion | Ch; E | No
2002^71^ | 6, M | Turkey | Fever, skin lesion | Febrile, Forehead lesion | P | No
2002^71^ | 5, M | Turkey | Fever, skin lesion | Febrile, Forehead lesion | P | No
1998^63^ | 3, F | Turkey | Skin lesion forehead; Throat swelling | Forehead lesion | P | No
1998^63^ | 17, M | Turkey | Skin lesion on fingers | Finger lesion | P | No
1998^63^ | 17, F | Turkey | Skin lesions on fingers | Finger lesion | P | No
1939^72^ | 17, M | G.B. | Fever, skin lesion | Fever, pustule | Sulfa; As | No
1906^73^ | 17, M | G.B. | Neck lesion | Neck lesion | General antiserum, surgical debridement | Yes
1906^73^ | 17, M | G.B. | Right cheek lesion | Right cheek lesion | General antiserum; surgical debridement | Not stated
1906^73^ | 16, M | G.B. | 2 pustules on arm and foot | 2 pustules on arm and foot | General antiserum; surgical debridement | Not stated
1986^74^ | 3, M | Africa | Ectropion, no corneal scar | Ectropion, no corneal scarring | Left upper ectropian surgery | Not stated
1983^75^ | 2, M | Africa | No sx reported | Edema and eschar | P | Yes
1958^76^ | 15, M | G.B. | Skin lesion | Nothing documented | P and aminoglycoside | No
1934^77^ | 15, M | Africa | Fever, skin lesion | Fever, tachycardic, tachypneic, pustule and edema | Other abx unspecified | No
1987^78^ | 9, M | Turkey | Fever and skin lesion | Pustule and edema | P, steroids | No
1932^79^ | 17, M | India | Fever, malaise, painful pruritic skin lesion | Fever on admission, tender pustule initially, on admission evolved into vesicle | Neosalvarsan intravenously | No
1961^62^ | 7, M | U.S. | No complaints | Fever, rd on admission, circular black lesion on neck with vesicles | P, aminoglycoside | Not stated
1901^80^ | 16, M | Italy | Pustule on chin with swelling | Pustule and edema | As | Not stated
2000^81^ | 7, M | Turkey | Pruritic skin lesion | Erythematous pustule of eyelid, with edema | P | No
1996^82^ | 4, M | Turkey | Periorbital swelling, eyelid lesion, visual acuity ok | Edema and eschar, eye and vision not affected | P | No
1958^83^ | 17, M | Mexico | Right hand and forearm lesion | Skin lesion on hand | Aminoglycoside | No
1944^84^ | 5, M | Canada | Fever, right chin blister with edema and induration | Fever, tachycardia, nontender R submental blister surrounded by induration and pitting edema | P, sulfathiazole | No
1999^60^ | 18, F | India | None reported | Edema and eschar | P | No
1920^85^ | 15, M | US | Fever on admission, initial headache, odynophasia and throat swelling (no skin findings reported) | Febrile, tachycardic, tachypneic, coma and pharynx read and edematous | | Yes**
1950^86^ | 10, M | India | No reports | Barely febrile, mild tachycardia and tachypnea. Vessicle, edema on back of knee, inguinal lymphadenopathy | Ch | Not stated
2001^87^ | 5, M | India | Febrile, no respiratory distress, abdominal pain, swelling of rt cheek, painless lip ulcer | Febrile, nontoxic, extensive gelatinous edema of right cheek, nontender eschar, superficial lip lesion, no mouth involvement and cervical adenopathy | P | No
1974^88^ | 2, F | Africa | No sx reported | Vessical and edema on admission | P, Ch | No
1933^89^ | <5, ? | Australia | Fever, skin lesions | Afebrile with eschar, surrounding edema and blebs. No lymphadenopathy. | Carbolic ointment | No
1900^90^ | 16, M | China | On admission “patient looked and felt very ill” with indurated mass on upper lip and black scab | Febrile, ill-appearing with indurated mass and edema on upper lip with central eschar on admission. | Perchloride topically, carbolic acid orally, surgical debridement | No
1911^91^ | 17, M | U.S. | Fever, lip and cheek lesion | Febrile and tachycardic. Mouth, lip pustules with surrounding edema | Antistreptococcal serum | Yes

* Treatment with antibiotics or anthrax anti-serum. Abbreviations: A-Ampicillin, Ac-Acylovir, Ag-Amoxicillin/Clavulanate, Am-Ambramycin, As-Anthrax anti-serum, Ax-Amoxicillin, Au-Aureomycin, Az-Azithromycin, C-Ciprofloxacin, Ce-Cefamandol, Cf-Cefuroxime, Ch-Chloramphenicol, Cl-Clindamycin, Cm-Cefotaxime, Cn-Ceftriaxone, Cx-Cloxacillin, Cz-Ceftazidime, D-Doxycycline, E-Erythromycin, F-Flucloxacillin, Fl-Fluconazole, G-Gentamicin, H-Horse anti-serum, L-Levofloxacin, M-Metronidazole, N-Naficillin, P-Penicillin, R-Rifampin, Re-Reverin, S-Streptomycin, Sd-Sulfadiazine, Sf-Sulfanilamide, St-Sulfathiazole, T-Tetracycline, Ts-Trimethoprim/Sulfamethoxazole, U-Ampicillin/Sulbactam, V-Vancomycin.

** This patient developed meningitis.

The average age of these patients was 11.8 years (range: 1.5 to 18 years)—15 were less than 10 years old (Table 7). Only seven were girls (the gender was unreported for three cases). This male predominance is similar to what has been observed among adults. Generally the lesions described were similar to the classical description of adult skin lesions with eschars surrounded by edema. Sixteen children received penicillin and eight had surgical debridement of their lesions. Only five children died (13.5% case fatality rate) which is similar to the ranges of adult cases. All of these were boys, three of whom had not received antibiotics. One child developed meningoencephalitis before he died.

Summary. The data from our sample of 37 cases of pediatric cutaneous anthrax are limited by very poor reporting of disease progression, patient characteristics, and treatment information. Among these included cases, the skin lesions described for children are similar to the classical skin lesions historically described for cutaneous anthrax. Similarly, the male predominance of disease and case fatality rates for children were similar to what has been described for adults with cutaneous anthrax.

### Atypical Anthrax

Background. Historically, anthrax has been classified according to the three principal exposures: inhalational, gastrointestinal, and cutaneous. Historical reports^92^ and more recent animal data^93,94^ suggest that two distinct inhalational anthrax syndromes may occur—one characterized by the typical and well-documented lower respiratory tract port of entry and another that develops after upper respiratory tract port of entry. Furthermore, some authors have speculated that the port of entry for primary anthrax meningoencephalitis is either an unrecognized lower respiratory tract port of entry ^95^ or transethmoid.^96^–^98^ If the variety of inhalational anthrax presentations is not well recognized, misdiagnosis or delayed diagnosis and treatment may result, thereby increasing anthrax-associated morbidity and mortality.

In our prior Evidence Report, we found that although rare, atypical anthrax presentations do occur among adults.^99^ Specifically, we found two case reports of adults presenting with laryngopharyngeal anthrax, five cases of adults with nasopharyngeal anthrax, and 26 cases of adults presenting with anthrax meningoencephalitis without inhalational, gastrointestinal, or cutaneous lesions.^99^ (If patients presented with these atypical symptoms but were known to have exposure to contaminated meat, we classified them as having gastrointestinal disease.)

Not surprisingly, patients with atypical anthrax were less likely to have a cough, chest pain, or abnormal lung exam than patients with typical inhalational disease.^99^ Adults with primary nasopharyngeal involvement experienced more rhinorrhea, nasal congestion or epistaxis than patients with typical inhalational disease.^99^ Patients with primary meningoencephalitis were more likely to experience non-headache neurologic complaints than patients with typical inhalational anthrax.^99^ The mortality rate for patients with primary anthrax meningoencephalitis was 97%.^99^

Pediatric laryngopharyngeal case results. We found 2 cases of pediatric laryngopharyngeal anthrax (Table 11). Both were from the same 1944 case series of East African presentations of atypical anthrax. Both were boys, aged 6 and 11 years, who survived. The 6 year old required a tracheostomy, but neither experienced disseminated intravascular coagulation, meningitis, respiratory failure, or septic shock. Other than noting signs of respiratory distress and laryngeal obstruction on admission, no other signs, symptoms, treatments or other clinical data are available for these boys.

Table 11 Pediatric laryngopharyngeal anthrax case reports

Yr. (Ref.) | Age, Gender | Country | Symptoms at Presentation | Initial Physical Exam | Treament | Complications | Died | Autopsy Findings
1944 ^101^ | 6, M | East Africa | Dyspnea | Afebrile, laryngeal obstruction | Tracheostomy | None reported | No | N/A
1944 ^101^ | 11, M | East Africa | Dyspnea | Febrile, laryngeal obstruction | N/S | None reported | No | N/A

Table 12 Pediatric nasopharyngeal anthrax case report (non-English)

Yr. (Ref.) | Age, Gender | Country | Symptoms at Presentation | Initial Physical Exam | Died | Autopsy Findings | Suspected route of entry^‡‡^
1942 ^102,103^ | 17, F | Argentina | Epistaxis, odynophagia, nasal obstruction, coryza, neck swelling | Tachycardia, febrile, pharyngitis; Face, palate & neck edema; Nasal serosanguinous discharge; Cervical adenopathy; No skin or tonsil lesions | No | N/A | Inhaled

The two reports of adults with laryngopharyngeal anthrax are reviewed in detail elsewhere. ^99^ Briefly, one patient was a 20 year old African man (1970) while the other was a 41 year old German man (1904). Both of these adults with laryngeal disease presented with neck swelling and ultimately died of their disease. The German patient had autopsy evidence of leptomengingitis, laryngeal and pharyngeal edema with epithelial necrosis but no skin, tracheal, bronchial, lung, or small bowel abnormalities. Given the paucity of available clinical and treatment details in the case reports of these four patients, we are unable to conclude whether adults and children with laryngopharyngeal anthrax are likely to either present or progress differently.

Pediatric nasopharyngeal case results. We found one pediatric case report from 1942 of a 17 year old Argentinean girl suspected of inhaling horsehair in a bristle mill. She went on to develop nasopharyngeal disease (Table 13). This patient initially presented with epistaxis, nasal obstruction, and neck swelling, and she survived. Detailed treatment information is not available from this case report. Among the five adults presenting between 1902 and 1942 with nasal/nasopharyngeal anthrax, three worked directly with animal hair or skins, most were thought to have either inhaled or deposited spores directly into their noses, and most presented with nasal obstruction and facial swelling. Three of the six adults died. We have no treatment data available for any of these adult cases. Again, based on the single case report of a girl with nasopharyngeal disease, we cannot evaluate the salient differences between pediatric and adult presentations of this type of anthrax.

Table 13 Pediatric primary meningoencephalitis anthrax case report

Yr. (Ref.) | Age, Gender | Country | Anthrax Exposure Risk | Symptoms at Presentation | Initial Physical Exam | Died | Autopsy Findings
English language case
1975 ^100^ | 14, M | Mexico | Slaughter-house | Headache, emesis, delirium, malaise, fever, seizures | Febrile, comatose, neurologic deficits, meningeal signs; No skin or abdominal abnormalities; Normal chest roentenogram | Yes | Congested lungs^§§^, patchy bronchopneumonia, splenic congestion, cerebral, hemorrhagic meningoencephalitis, few bowel ulcerations; No skin lesions
Foreign language cases
1981 ^104^ | 16, M | Iran | Unknown, food product salesman^§^ | Headache, emesis, fever, convulsions | Febrile, comatose, neurologic deficits, meningeal signs; No skin, lung or abdominal abnormalities | Yes | N/P
1951 ^105^ | 1, F | Italy | N/S | Fever, diarrhea, restlessness | Febrile; Tonsillar & oral cavity erythema/edema without ulceration/plaques; No skin, lung or abdominal abnormalities | Yes | N/P
1940 ^106^ | 17, M | Germany | N/S | Fever, headache, back pain, stomach complaints | Febrile; No skin, lung or abdominal abnormalities; No neurologic deficits | Yes | N/P
1936 ^107^ | 18, M | Romania | N/S | Fever, headache, abdominal pain, delirium | Comatose, cyanosis, abnormal lung exam, abdominal distension, neurologic deficits; No skin lesions | Yes | Hemorrhagic meningoencephalitis; Ascites and mesenteric adenopathy without bowel ulcerations; No lung or skin lesions
1927 ^108^ | 11, M | France | Horses, cattle | Anorexia, headache, chills, malaise, fatigue, emesis, delirium | Febrile, tachycardia, neurologic deficits, menigeal signs; No skin, throat, lung or abdominal abnormalities | Yes | N/P

* We classified cases according to one of three anatomical sites: nasal/nasopharyngeal, larygeal/laryngopharyngeal, or primary meningoencephalitis (without known cutaneous, gastrointestinal, or respiratory port of entry). Cases were classified primary according to the primary author(s) suspicion for the port of entry as well the anatomical site(s) of mucosol and lymph node abnormalities on exam or at autopsy.

Table Abbreviations: Ref=Reference(s); Yr=Year; F=Female; M=Male; U.S.=United States; G.B.=Great Britain; N/A=Not applicable; N/S=Not specified; N/P=Not performed; GI=Gastrointestinal; CT=Computed tomography

‡‡ What the primary author(s) of the case report suspected as the route of entry for Bacillus anthracis spores.

§§ The primary author suspected a primary nasopharyngeal infection with a secondary stomach/intestinal infection from swallowing nasal secretions.

¶¶ Throat swabs cultured Bacillus anthracis with no other pathogenic organisms.

Pediatric primary mengingoencephalitis case results. Of the 6 pediatric case reports of primary meningoencephalitis only 1 was an English-language report for which complete data are available.^100^ This patient was a 14 year old Mexican boy who was thought to have been exposed in a slaughterhouse. He presented with high fever but otherwise normal vital signs, headache, delirium, seizures, and emesis. Initial physical exam was notable for the absence of pulmonary symptoms. Neurological findings included meningeal signs, eye deviation with horizontal nystagmus and nonreactive pupils, and coma. His initial significant laboratory results included an elevated white blood cell count with predominance of neutrophils and a lumbar puncture with a markedly elevated opening pressure and elevated cerebrospinal fluid protein. He had a normal chest roentenogram. The patient received penicillin and chloramphenicol but succumbed nevertheless. At autopsy, he was found to have hemorrhagic meningoencephalitis, lung and splenic edema, and small bowel ulcerations.

Among the five children described in the foreign language reports of patients with primary meningoencephalitis we have little patient or treatment information; however, fever, headache, and abdominal complaints including emesis and diarrhea were common presenting complaints. All five died.

Summary: Although rare, children (particularly adolescents) do present with atypical presentations of anthrax. Although we cannot determine with certainty the means by which these patients contracted anthrax, we suspect an inhalational exposure for many, if not most, of them. However, some of the atypical cases may be due to unrecognized cutaneous or gastrointestinal exposures. We attempted to limit this situation by excluding patients with skin lesions, histories of consuming contaminated meat, or symptoms or autopsy findings highly suggestive of gastrointestinal anthrax. Additionally, the consumption of contaminated meat is unlikely to cause nasal or nasopharyngeal involvement. To prevent delays in diagnosis and therapy during future bioterrorist attacks, clinicians should recognize that anthrax infection in both adults and children might present with atypical presentations.

## Summary Analyses Including All Cases

The included cases were highly heterogeneous in terms of their clinical presentations and treatments received.

### Clinical Presentations

Among the 59 case reports which stated the patient's gender, only 14 (24%) were girls. This is similar to the gender discrepancy observed among adults and has historically been attributed to the fact that anthrax has largely been an occupational disease among professions (e.g., woolsorters and butchers) traditionally dominated by men. However, other biases may be contributing to the under-diagnosis and under-reporting of anthrax in girls relative to boys.

Eleven patients were reported to have had chest roentgenograms. Both of the patients with inhalational anthrax were found to have abnormalities on chest roentenogram. Of the four patients with gastrointestinal anthrax who had roentgenograms, two were found to have pulmonary abnormalities, one patient had “ascites but no other abnormalities,” and one had a normal examination. All four of the patients with cutaneous anthrax had normal chest roentgenograms. We conclude that the role of roentgenograms for diagnostic decision making in pediatric anthrax is not well established.

Among the included cases, nine developed meningoencephalitis (seven of these had gastrointestinal anthrax, one had cutaneous anthrax, and one had primary anthrax meningoencephalitis). All but one of these patients died.

### Treatment Responses

Prior to the introduction of antibiotics, anthrax infection was primarily treated with anti-serum.^109^ Anthrax anti-serum reportedly decreased mortality by 75% compared to untreated patients.^110^–^115^ and its efficacy is supported by recent animal data.^116^ However, anaphylactic reactions and serum sickness were major side-effects. ^117^ Because anthrax virulence is caused by the production of two bacterial toxins, lethal factor and edema factor,^10^ it has been theorized that therapeutics (such as antiserum) directed against these toxins could be superior to antimicrobial agents.^117^–^122^ Additionally, the efficacy of anthrax immune therapy is supported by recent animal data using neutralizing monoclonial antibodies.^116,123^–^125^ In the 1940's effective antibiotics such as penicillin and chloramphenicol were added to anthrax treatment strategies.^86,126^ Anthrax anti-serum is no longer commercially available in most western countries including the U.S., but is still available in the Russian Federation and in China.^117,^,^127,128^ Recently, the U.S. Department of Health and Human Services awarded a contract to the Cangene Corporation (Winnipeg, Canada), to produce anthrax immune globulin between 10,000 and 100,000 doses for the Strategic National Stockpile.^129^–^134^ Anthrax immune globulin is a highly purified human antibody that is specific to anthrax and is collected from the plasma of soldiers who were inoculated with the anthrax vaccine.^123,135^ Additionally, Human Genome Sciences, Inc. (Rockville, Maryland) was awarded a similar contract to develop a monoclonal antibody inhibitor specific for anthrax protective antigen to also be included within the Strategic National Stockpile.^12,131^–^134,^,^136,137^

The included cases differed with respect to their treatments and treatment responses (Table 14). Overall, the mortality rate was 31% (19 of 61; note, survival information was not available for one patient). There was no significant association between gender or age and survival. Among those patients who received antibiotics, 71% survived compared to 82% survival among those patients who received antiserum. Only one patient was treated with a fluroquinolone. Current treatment guidelines for inhalational or gastrointestinal anthrax in children vary among different professional organizations; however, most recommend triple intravenous antibiotics with ciprofloxacin or doxycycline with two other antibiotics such as clindamycin, rifampin, penicillin, among others.^9,^,^12,138^–^141^ Recommended treatment for cutaneous anthrax is with one oral antibiotic: penicillin, amoxicillin, ciprofloxacin, or doxycycline.^9,^,^12,138^–^141^

Table 14 Summary of treatments received

Treatment Received | Number of Patients | Number who Lived (%) | P value*
Any antibiotic vs. no antibiotic or antiserum | 38 | 27 (71%) | 0.78
Penicillin or penicillin-based antibiotic (e.g., ampicillin) vs. all other treatments | 30 | 19 (63%) | 0.89
Antiserum vs. all other treatments | 11 | 9 (82%) | 0.29
Aminoglycosides (most often streptomycin) vs. all other treatments | 10 | 7 (70%) | 0.85
Chloramphenicol vs. all other treatments | 8 | 5 (63%) | 0.91
Fluoroquinolones vs. all other treatments | 1 | 1 (100%) | 0.44

* P value for the comparison of whether patients who received this treatment were more likely to survive than those who did not receive this treatment.

None of the included patients received anthrax vaccine. The currently licensed, Anthrax Vaccine Adsorbed (AVA, Bioport Corporation, Lansing, MI) may have a role in post-exposure prophylaxis;^142^ however, it is currently only approved for 18 to 65 year olds.^1,12^

We had initially hoped to be able to evaluate the effect of time to onset of treatment on disease progression; however, insufficient evidence was available from the case reports to perform this analysis.

## Summary Answers to the Key Questions

Question #1 What Is the Evidence for an Age-dependent Disease Progression Associated With Anthrax?

Although children with anthrax may present with somewhat different symptoms than adults, we found no specific evidence for age-dependent differences in disease progression. Like adults, children with gastrointestinal anthrax, seem to have two distinct clinical presentations: One resulting from upper tract disease and another resulting from lower tract disease. Additionally, children with inhalational disease may have non-pulmonary presentations including primary meningoencephalitis.

Question #2 How Effective Are Antibiotic Prophylaxis and Treatment for Anthrax in Children Compared to Adults? Similarly, How Effective Are Other Medical Treatments in Children Compared to Adults (e.g. Ventilator/Respiratory Support)?

Most of the children included in our analysis who received an antibiotic were given penicillin-based antibiotics which produced a 63% survival rate. Other successful treatments included antiserum, which produced an 82% survival rate. These survival rates were similar to those observed for adults.

In adults, pleural fluid drainage was significantly associated with survival after the development of fulminant inhalational anthrax.^24,143^ One child with inhalational anthrax received pleural fluid drainage and she survived. However, we found insufficient cases of children who received pleural fluid drainage (or other treatment modalities such at mechanical ventilation) to determine the extent which they may be more or less effective in children than they are in adults.

Question #3 Based on the Review of Evidence for Questions 1 and 2, What Are the Implications for Children Versus Adults in Terms of Preparedness and Response Planning for Anthrax exposure (i.e., Healthcare Provider Education on Diagnosis and Management, Considerations for Hospitals, Vaccination Strategies)?

The results of our systematic review have implications for preparedness planning efforts that relate to the diagnosis and management of children with anthrax. The presenting signs and symptoms of children with anthrax are very similar to the signs and symptoms of children presenting with much more common infectious diseases. This creates a difficult diagnostic challenge both for clinicians needing to make a timely diagnosis and public health officials implementing syndromic surveillance systems. More research is needed to identify the specific signs and symptoms (e.g., rhinorrhea) that distinguish common pediatric infections such as influenza from early anthrax infection.^144^

Only one of the 62 pediatric anthrax cases was treated with a fluoroquinolone; however, penicillin-based and antiserum regimens were much more commonly used among the included cases and were associated with favorable survival rates. Antiserum is not included in current treatment guidelines or bioterrorism preparedness inventories and has been associated with serum sickness and inconsistency in effectiveness across batches. Similarly, current treatment guidelines do not include penicillin as a single agent due to concerns of penicillin-resistant organisms.^9,138^–^141^ Thus, we have little evidence about the use of the medical regimens currently considered first line against anthrax and more evidence about those therapies not currently being recommended.