# Methods

We sought all English-language case reports of patients aged 18 years or younger with inhalational, gastrointestinal, or atypical anthrax (e.g., primary anthrax meningoencephalitis without an identifiable inhalational or cutaneous source). Because there have been hundreds of case reports of pediatric cutaneous anthrax, given limited resources, we selected a random sample of 50 English-language case reports of pediatric anthrax for abstraction. We then augmented the data abstracted from the English-language pediatric case reports with the data available from our prior Evidence Report on adult cases of inhalational anthrax.^17^

## Inclusion and Exclusion Criteria

We considered articles eligible for inclusion if the authors of the case report established a definitive diagnosis of anthrax. To confirm the diagnosis of anthrax, we used the case criteria that we developed previously which require that patients have positive cultures, gram stain, or immunologic evidence of recent Bacillus anthracis infection and/or associated clinical or autopsy findings consistent with anthrax infection.^17^ We present our overall inclusion strategy in Figure 1 and our separate inclusion criteria for inhalational anthrax in Table 1, gastrointestinal anthrax in Table 2, cutaneous anthrax in Table 3, primary anthrax meningoencephalitis in Table 4, and atypical anthrax inTable 5. If the authors of a case report described a patient as having a particular type of anthrax (such as gastrointestinal disease) and they did not meet our inclusion criteria for that type of anthrax, we noted this. We excluded reports in which the authors presented summary information about a group of patients with anthrax but did not include individual patient data.

Table 1 Inclusion criteria for cases with presumed inhalational anthrax

Any one of the following:
| 1 Cultures^a^ AND symptoms^b^ or autopsy findings^c^ consistent with inhalational anthrax.; 2 Symptoms and gram-stain evidence^d^ AND improvement with appropriate therapy or autopsy findings.; 3 During an ongoing anthrax outbreak with confirmed cases (meeting criteria 1 or 2): Symptoms AND autopsy findings or improvement with appropriate therapy.^e^; 4 For patients with high-risk inhalational anthrax exposure (e.g., wool mill worker) who did not receive antibiotic treatment: Symptoms AND improvement with anthrax antiserum.

a Culture (any source) or immunological evidence of recent Bacillus anthracis infection.

b Clinical symptoms of inhalational anthrax included flu like symptoms, fever, cough, dyspnea, chest pain, abnormal lung exam, or mediastinal widening or pleural effusions on chest roentenogram.

c Autopsy findings of inhalational anthrax included excessive pleural fluid (particularly if hemorrhagic), enlarged or hemorrhagic mediastinum, mediastinal lymphadenopathy, or subpleural congestion.^14,^,^18,19^

d Gram-stain evidence (any source) of B. anthracis: gram-positive, spore-forming, nonmotile, hemolytic, spore-forming bacilli measuring1–1.3 × 3–10 μm^20^

e Received appropriate antibiotics (% B. anthracis strains susceptible ≥70%) or anti-serum.

Table 2 Inclusion criteria for cases with presumed gastrointestinal anthrax

Any one of the following (exclude if patient meets cutaneous or inhalational case definition):
| 1 Symptoms^f^ AND cultures or gram-stain AND history of contaminated meat consumption or during outbreak of gastrointestinal anthrax.; 2 History of contaminated meat consumption or cases occurred during an ongoing gastrointestinal anthrax outbreak with confirmed cases (meeting criteria 1) AND Autopsy findings^g^ or symptoms with improvement with appropriate therapy.

f Clinical symptoms of gastrointestinal anthrax included diarrhea (especially bloody/tarry), abdominal pain, abdominal distension and/or evidence of ascites.

g Autopsy findings of gastrointestinal anthrax included excessive peritoneal fluid (particularly if hemorrhagic), enlarged or hemorrhagic mesenteric lymphadenopathy, and/or small bowel/stomach ulceration(s).

Table 3 Inclusion criteria for cases with presumed cutaneous anthrax

Any one of the following (exclude if patient meets inhalational case definition):
| 1 Cultures AND any skin lesion; 2 Skin lesion and gram-stain^d^ AND improvement with appropriate therapy; 3 During an ongoing anthrax outbreak with confirmed cases (meeting criteria 1 or 2): skin lesions AND improvement with appropriate therapy; 4 For patients with high-risk inhalational anthrax exposure (e.g. wool mill worker) who did not receive antibiotic treatment: skin lesions AND improvement with anthrax antiserum.

d Gram-stain evidence (any source) of B. anthracis: gram-positive, spore-forming, nonmotile, hemolytic, spore-forming bacilli measuring1–1.3 × 3–10 μm^20^

Table 4 Inclusion criteria for cases with presumed primary anthrax meningoencephalitis

The following (exclude if patient meets inhalational, gastrointestinal, or cutaneous case definitions):
| Culture or gram-stain AND either cerebrospinal fluid^h^ or autopsy^i^ findings consistent with anthrax meningoencephalitis.

h Cerebral spinal fluid consistent with meningoencephalitis (e.g., bloody fluid, leukocytosis, etc.)

i Autopsy findings consistent with meningoencephalitis (e.g., hemorrhagic meninges).

Table 5 Inclusion criteria for cases with presumed atypical anthrax

The following (exclude if patient meets inhalational, gastrointestinal, cutaneous, or primary anthrax meningitis case definitions):
| Culture or gram-stain or autopsy^i^ findings consistent with anthrax.

i Autopsy findings consistent with meningoencephalitis (e.g., hemorrhagic meninges).

Figure 1. Inclusion strategy

## Search Strategy

We identified case reports of pediatric anthrax referenced in MEDLINE® between January 1966 and June 2005 using the MeSH terms anthrax and case report. We then performed additional comprehensive searches of retrieved bibliographies and the indexes of the following selected journals from 1900 to 1966: New England Journal of Medicine, JAMA, AMA-Archives of Internal Medicine, Lancet, BMJ, Medical Journal of Australia, La Presse Médicale, Bulletins et Mémoires de la Société Médicale des Hôpitaux de Paris, Deutsche Medizinische Wochenschrift, Wiener Medizinische Wochesnschrift, Wiener Klinische Wochenschrift, Muenchener Medizinische Wochenschrift, Berliner Klinische Wochenschrift, La Semana Medicale. From our previous synthesis of adult inhalational anthrax cases, we found that much of the literature on clinical anthrax was published before 1966 (the earliest publication referenced in MEDLINE®). Thus, we performed extensive manual searches of retrieved bibliographies.

Because case reports of pediatric inhalational anthrax are relatively rare, in an effort to maximize the number of included cases, we included case reports of pediatric anthrax (0 to 18 years of age) presenting from 1900 to 2005. Although medical treatment for anthrax has changed considerably since 1900 (particularly since the advent of effective antimicrobials), we were interested in presenting signs and symptoms, which would not be affected by medical interventions. We excluded articles that described cases presenting prior to 1900 because B. anthracis was not identified as the causative agent of clinical inhalational anthrax until 1877^21^ and because the use of reliable microscopic^22^ and cultural examination techniques^23^ to confirm the diagnosis were not developed until the late 19^th^ century.

## Data Abstraction and Evaluation

Two investigators screened potentially relevant articles to determine whether they met inclusion criteria. One investigator independently abstracted patient data from each included English language article and reviewed bibliographies for additional potentially relevant studies. We resolved abstraction discrepancies by repeated review and discussion. If two or more studies presented the same data from a single patient, we included the data only once in our analyses.

Because the purpose of this project is to characterize the spectrum of pediatric anthrax disease as well as to identify the differences in disease progression and treatment responses of adults and children with anthrax, we abstracted three primary types of data from each included article: (1) patient information (e.g., age, gender, nationality); (2) symptom and disease progression information (e.g., whether the patient developed meningitis); and (3) treatment information (e.g., treatments received, year of treatment). Data abstractions were performed directly into a detailed Excel abstraction form. The abstracted variables and their brief definitions are provided in Appendix A (including the definitions of some of the medical terms used in the case descriptions of individual patients).

To obtain a random sample of 50 case reports of pediatric cutaneous anthrax, we used a random number generator to select 50 reference identification numbers from the more than 200 pediatric cutaneous case reports that we retrieved from our literature search.

To evaluate the quality of the included case reports, we determined the extent to which the diagnosis of anthrax was confirmed (e.g., autopsy versus cultures versus response to therapy during a known outbreak) and whether the source of infection (e.g., inhalational disease) was established.

## Statistical Analysis

Given key physiological differences among infants, toddlers, and adolescents, we analyzed case reports according to three age groups: 0–2 years, 3–13 years, and 14–18 years. Univariate analyses enabled us to summarize the key patient and treatment characteristics. We computed correlation coefficients between mortality and patient and treatment factors. For single comparisons, we considered a p-value less than 0.05 statistically significant. When comparing U.S 2001 to pre-2001 cases (or patients who lived to those who died), we applied a Bonferroni correction to account for multiple comparisons (we considered a p-value less than 0.025 statistically significant (0.05/2 = 0.025)).

## Peer Review Process

A draft of this Evidence Report was sent to a panel of seven experts in pediatrics, infectious diseases, public health, and bioterrorism preparedness (Appendix C). Their comments were incorporated into the final Report.