# Introduction

Ring-a-ring-a-roses

A pocket full of posies

A-tishoo! A-tishoo!

We all fall down. ^1^

1 This nursery rhyme has been attributed to the pandemic of bubonic plague of the 1340s. Specifically, the ring-a-roses refers to the rose-colored rash of plague and the posies refer to the flowers and spices put into the pockets of victims to ward off the stench of death. The last two lines refer to the sneezing that was common among the victims just before their seemingly inevitable deaths.

In response to the intentional release of Bacillus anthracis by mail in 2001, there has been a proliferation of guidelines for the diagnosis and treatment of patients with anthrax.^2^–^10^ However, most of these have not specified screening and management protocols for special populations, such as children. Children will likely be among the victims of future bioterrorism attacks on the general public as they were during the 1995 sarin attack in Tokyo (which affected 16 children and five pregnant women) and the 1984 intentional Salmonella contamination of salad bars in Oregon (which affected numerous high school students).^1^ Additionally, children may be the specific targets of some terrorists as they were during the unsuccessful 1995 plot to release a chlorine gas bomb in California's Disneyland.^11^ There is not a clear consensus as to whether children have particular physiological vulnerabilities to biological threat agents; however, young children may not be capable of seeking medical care or following the instructions of clinicians or public health officials—this can be particularly problematic if their parents or caregivers have, themselves, been incapacitated.^1,11^–^13^ Efforts to prepare for and respond to future attacks of anthrax bioterrorism will be aided by detailed information about the clinical presentation and treatment responses of both adult and pediatric populations exposed to anthrax.

Principally because of the paucity of pediatric cases in large case series of anthrax, observers have speculated that children are less susceptible to anthrax infection and may have different clinical courses after infection than adults. For example, during the 1979 Sverdlovsk outbreak, 70 patients were exposed and developed clinical anthrax after an airborne release of spores.^14,15^ However, there were no victims under the age of 24 reported—despite the fact that children were in the path of the plume.^16^ Additionally, researchers have noted that there was no age-dependent susceptibility noted among the Sverdlovsk victims above 24 years of age.^16^ However, because there are no published reports synthesizing data from all reported pediatric cases of anthrax, it is unknown to what extent patient characteristics, early detection, and early treatment affect disease progression and mortality in pediatric populations.

The development of protocols for the screening of pediatric patients with suspected anthrax and their subsequent management should be based on evaluation of the available literature regarding the clinical presentation and disease progression of children exposed to anthrax. Thus, we performed a systematic review of case reports of pediatric anthrax to describe the clinical course, treatment responses, and predictors of disease progression and mortality for children with anthrax infection. In addition to cases of inhalational, gastrointestinal, and cutaneous anthrax, we included in our analysis case reports of primary anthrax meningoencephalitis (i.e., without an identifiable inhalational, gastrointestinal, or cutaneous source).

## Key Research Questions

For a previous evidence report, “Regionalization of Bioterrorism Preparedness and Response”^17^ we synthesized all cases of adult inhalational anthrax published between 1900 and 2005. For the current project, we sought to synthesize the data from English-language case reports of children with inhalational, gastrointestinal, cutaneous, and atypical anthrax to answer three key research questions:

1) What is the evidence for an age-dependent clinical course associated with anthrax?
2) How effective are antibiotic prophylaxis and treatment for anthrax in children compared to adults? Similarly, how effective are other medical treatments in children compared to adults (e.g. ventilator/respiratory support)?
3) Based on the review of evidence for Questions 1 and 2, what are the implications for children versus adults in terms of preparedness and response planning for anthrax exposure (i.e., healthcare provider education on diagnosis and management, considerations for hospitals, vaccination strategies)?