# Appendix C: Peer Reviewers

Peer Reviewer | Organizational Affiliation
Ann M. Arvin, MD | Lucile Salter Packard Professor of Pediatrics
| Associate Dean of Research
| Professor of Microbiology & Immunology
| Stanford University
| Chief, Pediatric Infectious Diseases
Krista M. Scardina, Pharm.D. | Public Health Analyst; Health Resources and Services Administration; Healthcare Systems Bureau; Division of Healthcare Preparedness; National Bioterrorism Hospital Preparedness Program
Nathaniel Hupert, M.D., M.P.H. | Assistant Professor of Medicine and Public Health
| Weill Medical College, Department of Public Health
Gregory Moran, M.D. | Clinical Professor of Medicine, UCLA School of Medicine
| Department of Emergency Medicine and Division of Infectious Diseases, Olive View-UCLA Medical Center
Mike Osterholm, Ph.D. | Director of the Center for Infectious Disease Research and Policy (CIDRAP), Associate Director of the Department of Homeland Security's National Center for Food Protection and Defense (NCFPD), and Professor of Public Health, University of Minnesota
Irwin Redlener, M.D. | Professor of Clinical Public Health and Pediatrics
| Associate Dean & Director, The National Center for Disaster Preparedness Columbia University Mailman School of Public Health
Dean Wilkening, Ph.D. | Science Director, Center for International Security and Cooperation, Stanford University