# Appendix B: Adult Anthrax Case Reports Not Included in This Analysis

## Adult Inhalational Cases

1 Inglesby TV, O'Toole T, Henderson DA, et al. Anthrax as a biological weapon, 2002: updated recommendations for management. JAMA. 2002;287(17):2236-52. [pmid: 11980524].
2 Brachman PS. Inhalation anthrax. Ann N Y Acad Sci. 1980;353:83-93. [pmid: 7013615].
3 Jernigan JA, Stephens DS, Ashford DA, et al. Bioterrorism-related inhalational anthrax: The first 10 cases reported in the United States. Emerg Infect Dis. 2001;7(6):933-944. [pmid: 11747719].
4 Regan JC. The advantage of serum therapy as shown by a comparison of various methods of treatment of anthrax. Am J Med Sci. 1921;62:406-423.
5 Sclavo A. Sullo stato presente della sieroterapia anticarbonchiosa. Rivista di Igiene e Sanita pubblica. 1903;14:519-587.
6 Henderson DW, Peacock S, Belton FC. Observations on the prophylaxis of experimental pulmonary anthrax in the monkey. J Hyg (London). 1956;54:28-36. [pmid: 13319688].
7 Lucchesi PF. Serum treatment of 19 cases of anthrax including one of external, internal and bacteremic type. Am J Med Sci. 1932;183(6):795-802.
8 D'Agostino S, Maddaluno R. Considerazioni su 593 casi di carbonclio umano. Agg Pediatr. . 1962;13:663-676.
9 Karginov V, Robinson T, Riemenschneider J, et al. Treatment of anthrax infection with combination of ciprofloxacin and antibodies to protective antigen of Bacillus anthracis. FEMS Immunol Med Microbiol. 2004;40(1):71-4. [pmid: 14734189].
10 Heilman FR, Herrell WE. Penicillin in the treatment if experimental infections with Bacillus anthracis. Proc Staff Meetings Mayo Clin. 1944;19:492-496.
11 Clarke PS. Chloramphenicol in the treatment of cutaneous anthrax. BMJ. 1952;1(4759):86-87. [pmid: 14896037].
12 CDC. Update: Investigation of bioterrorism-related anthrax and interim guidelines for exposure and interim guidelines for exposure management and antimicrobial therapy. MMWR Morbidity & Mortality Weekly Report. 2001;50(42):909-919. [pmid: 11699843].
13 Schwartz M. Recognition and management of anthrax - an update. New England J Med. 2001;345:1621-26. [pmid: 11704686].
14 Inglesby TV, O'Toole T, Henderson DA, et al. Anthrax as a biological weapon, 2002: Updated recommendations for management. JAMA. 2002;287(17):2236-52. [pmid: 11980524].
15 Brachman PS, Kaufmann A. Anthrax (Chapter 4). In: Evans AS, Brachman PS, eds. Bacterial Infections of Humans Epidemiology and Control. 3d ed. New York: Plenum; 1998:95–107.
16 Brachman PS. Anthrax. Ann N Y Acad Sci. 1970;174(1):577-582. [pmid: 4993532].
17 Friedlander AM. Anthrax (Chapter 22). In: Zajtchuk R, Bellamy RF, eds. Textbook of Military Medicine: Medical Aspects of Chemical and Biological Warfare. Vol. 5. Washington, D. C.: Office of the Surgeon General; Department of the Army, U. S.A.; 1997:467–478.
18 Brachman PS, Plotkin SA. An epidemic of inhalation and cutaneous anthrax: Studies of Anthrax in a goat hair mill in New Hampshire; Final Report. Anthrax Investigations Unit, Epidemiology Branch, Communicable Disease Center, Public Health Service, U. S. Department of Health, Education and Welfare; Dec 1, 1959.
19 Koch R. [The etiology of anthrax, based on the life history of Bacillus anthracis]. Beitr Biol Pflanz. 1877;2:277-308.
20 McFadyean J. Extraneous sources of infection in outbreaks of anthrax. J Comp Path. 1903;16:346–357.
21 Eurich FW, Hewlett RT. Bacillus anthracis. In: Topley WWC, ed. A System of Bacteriology in Relation to Medicine. Vol. 5. London: Majesty's Stationary Office; 1930:439–478.
22 Barakat LA, Quentzel HL, Jernigan DB, et al. Fatal inhalational anthrax in a 94 year old Connecticut woman. JAMA. 2002;287(7):863-868. [pmid: 11851578].
23 Mina B, Dym JP, Kuepper F, et al. Fatal inhalational anthrax with unknown source of exposure in a 61 year old woman in New York City. JAMA. 2002;287(7):858-862. [pmid: 11851577].
24 Pile JC, Malone JD, Eitzen E, Friedlander AM. Anthrax as a potential biological warfare agent. Arch Intern Med. 1998;158(5):429-34. [pmid: 9508220].
25 Cavallo JD, Ramisse F, Girardet M, Vaissaire J, Mock M, Hernandez E. Antibiotic susceptibilities of 96 isolates of Bacillus anthracis isolated in France between 1994 and 2000. Antimicrob Agents Chemother. 2002;46(12):3843-5. [pmid: 12435686]. [pmcid: 132748].
26 Coker PR, Smith KL, Hugh-Jones ME. Antimicrobial susceptibilities of diverse Bacillus anthracis isolates. Antimicrob Agents Chemother. 2002;46(12):3843-5. [pmid: 12435686]. [pmcid: 132748].
27 Mohammed MJ, Marston CK, Popovic T, Weyant RS, Tenover FC. Antimicrobial susceptibility testing of Bacillus anthracis : comparison of results obtained by using the National Committee for Clinical Laboratory standards broth microdilution reference and Etest agar gradient diffusion methods. J Clin Microbiol. 2002;40(6):1902-7. [pmid: 12037041]. [pmcid: 130796].
28 Garrod LP. The sensitivity of Bacillus anthracis to antibiotics. Antibiot Chemother. 1952;11(12):689-692.
29 Turnbull BW. The empirical distribution function from arbitrarily grouped, censored and truncated data. Journal of Royal Statistical Society, Series B. 1976;38:290-295.
30 Bravata DM, Owens DK, McDonald KM, et al. Regionalization of Bioterrorism Preparedness and Response - Evidence Report/Technology Assessment, Prepared by the Stanford University - University of California San Francisco Evidence-based Practice Center under contract number 290-02-0017. Rockville, MD: Agency for Healthcare Research & Quality; 2004.
31 Johnson K. A nation challenges: the victim; By demanding a diagnosis, he lives to tell of anthrax. New York Times. 2001 December 3;1.
32 Teacher JH. Primary intestinal anthrax in man; septicaemia; haemorrhagic leptomeningitis. Lancet. 1906;1:1306-1311.
33 Teacher JH. Case of human anthrax septicaemia: infection through the intestine: Diffuse meningeal haemorrhage. Glasgow Med J. 1905;64:127-131.
34 Teacher JH. A case of primary intestinal anthrax in man. Lancet. 1906;2:830.
35 Haight TH. Anthrax meningitis: a review of the literature and report of two cases with autopsies. Am J Med Sci. 1952;224(1):57-59. [pmid: 14933414].
36 Brachman PS, Plotkin SA, Bumford FH, Atchison MM. An epidemic of inhalation anthrax: the first in the twenieth century, II. Epidemiology. Am J Hyg. 1960;72:6-23. [pmid: 13803672].
37 Brachman PS, Gold H, Plotkin SA, Fekety FR, Werrin M, Ingraham NR. Field evaluation of a human anthrax vaccine. Amer J Public Health. 1962;52(4):632-45.
38 Plotkin SA, Brachman PS, Utell M, Bumford FH, Atchison MM. An epidemic of inhalation anthrax. Am J Med. 1960;29:992-1001. [pmid: 13736379].
39 Plotkin SA, Brachman PS, Utell M, Bumford FH, Atchison MM. An epidemic of inhalation anthrax, the first in the twentieth century: I. Clinical features. Am J Med. . 2002;112:4-12. [pmid: 11812400].
40 Bales ME, Dannenberg AL, Brachman PS, Kaufmann A, Klatsky PC, Ashford DA. Epidemiologic response to anthrax outbreaks: field investigations 1950-2001. Emerg Infect Dis. 2002;8(10):1163-74. [pmid: 12396934].
41 Gill JR, Melinek J. Inhalational anthrax: gross autopsy findings. Arch Pathol Lab Med. 2002;126(8):993-4. [pmid: 12197510].
42 Jernigan JA, Raghunathan PL, Bell BP, et al. Investigation of bioterrorism-related anthrax, United States, 2001: Epidemiologic findings. Emerg Infect Dis. 2002;8(10):1019-28. [pmid: 12396909].
43 Guarner J, Jernigan JA, Shieh WJ, et al. Pathology and pathogenesis of bioterrorism-realted inhalational anthrax. Am J Pathol. 2003;163(2):701-9. [pmid: 12875989]. [pmcid: 1868222].
44 Bush LM, Abrams BH, Beall A, Johnson CC. Index case of inhalational anthrax due to bioterrorism in the United States. N Engl J Med. 2001;345(22):1607-10. [pmid: 11704685].
45 Traeger MS, Wiersema ST, Rosenstein NE, et al. First case of bioterrorism-related inhaltional anthrax in the United States, Palm Beach County, Florida, 2001. Emerg Infect Dis. 2002;8(10):1029-34. [pmid: 12396910].
46 Maillard JM, Fischer M, McKee KT Jr, Turner LF, Cline JS. First case of bioterrorism-related inhalational anthrax, Florida, 2001: North Carolina investigation. Emerging Infectious Diseases. 2001;8(10):1035-8. [pmid: 12396911].
47 Mayer TA, Bersoff-Matcha S, Murphy C, et al. Clinical presentation of inhalational anthrax following bioterrorism exposure: report of 2 surviving patients. JAMA. 2001;286(20):2549-53. [pmid: 11722268].
48 Dewan PK, Fry AM, Laserson K, et al. Inhalational anthrax outbreak among postal workers, Washington, D. C., 2001. Emerg Infect Dis. 2002;8(10):1066-72. [pmid: 12396917].
49 Earls JP, Cerva D, Berman EL, et al. Inhalational anthrax after bioterrorism exposure: spectrum of imaging findings in two surviving patients. Radiology. 2001;222(2):305-12. [pmid: 11818592].
50 Borio L, Frank D, Mani V, et al. Death due to bioterrorism-related inhalational anthrax: report of 2 patients. JAMA. 2001;286(20):2554-59. [pmid: 11722269].
51 Quintilliani R Jr, Mahajan AK, Quintilliani R. Fatal Case of Inhalational anthrax mimicking intra-abdominal sepsis. J Ibaraki Health Science Center. 2001;47:3-8.
52 Quintilliani R Jr. Quintilliani R Fatal case of inhalational anthrax mimicking intra-abdominal sepsis. Conn Med. 2002;66(5):261-67. [pmid: 12071107].
53 Wood BJ, DeFranco B, Ripple M, et al. Inhalational anthrax: Radiologic and pathologic findings in two cases. AJR Am J Roentgenol. 2003;181(4):1071-78. [pmid: 14500233]. [pmcid: 2386880].
54 Greene CM, Reefhuis J, Tan C, et al. Epidemiologic investigations of bioterrorism-related anthrax, New Jersey, 2001. Emerg Infect Dis. 2002;8(10):1048-55. [pmid: 12396914].
55 Krol CM, Uszynski M, Dillon EH, Farhad M, Machnicki SC, Rothman LM. Case report: Dynamic CT features of inhaltional anthrax infection. AJR Am J Roentgenol. 2002;178(5):1063-66. [pmid: 11959702].
56 Holtz TH, Ackelsberg J, Kool JL, et al. Isolated case of bioterrorism-related inhalational anthrax, New York City, 2001. Emerg Infect Dis. 2003;9(6):689-96. [pmid: 12781008].
57 Anonymous. Update: Investigation of bioterrorism-related inhalational anthrax - Connecticut, 2001. MMWR Morb Mortal Wkly Rep. 2001;50(47):1049–51.
58 Griffith KS, Mead P, Armstrong GL, et al. Bioterrorism-related inhalational anthrax in an elderly woman, Connecticut, 2001. Emerg Infect Dis. 2003;9(6):681-88. [pmid: 12781007].
59 Yorgancigil B, Sevuk E, Aydemir M, Demirci M, Doganay M. Anthrax meningitis. Turkish Journal of Medical Sciences. 1998;28:457-59.
60 Yorgancigil B, Demirci M, Unlu M, Sevuk E, Doganay M. Anthrax meningitis: case report. Int J Infect Dis. 2001;5(4):220-21. [pmid: 11953221].
61 Koshi G, Lalitha MK, Daniel J, Chacko A, Pulimood BM. Anthrax meningitis, a rare clinical entity. J Assoc Physicians India. 1981;29(1):59-62. [pmid: 6790511].
62 Suffin SC, Carnes WH, Kaufmann AF. Inhalation anthrax in a home craftsman. Hum Pathol. 1978;9(5):594-7. [pmid: 101438].
63 Anonymous. CPSC warns about possible anthrax contamination in imported yarn; Release #76-011. Washington, DC: US Consumer Product Safety Commission; Office of Information and Public Affairs; February 9, 1976, 1976.
64 Severn M. A fatal case of pulmonary anthrax. Br Med J. 1976;1(6012):748. [pmid: 1260311].
65 Vessal K, Yeganehdoust J, Dutz W, Kohout E. Radiological changes in inhalation anthrax A report of radiological and pathological correlation in two cases. Clin Radiol. 1975;26(4):471-74. [pmid: 811421].
66 LaForce FM, Bumford FH. Epidemiological study of a fatal case of inhalation anthrax. Arch Environ Health. 1969;18:798-805. [pmid: 4976545].
67 Enticknap JB. Anthrax due to working with imported dried bones. Med Sci Law. 1967;7(3):136-37. [pmid: 6052204].
68 Enticknap JB, Galbraith NS, Tomlinson AJ, Wlias-Jones TF. Pulmonary anthrax caused by contaminated sacks. Brit J Ind Med. 1968;25(1):72-74. [pmid: 4966788]. [pmcid: 1008665].
69 Suic M, Knezevic J, Tomic M. A case of pulmonary anthrax. Lijec Vjesn. 1966;88(12):1449-55. [pmid: 6011279].
70 Kohout E, Sehat A, Ashraf M. Anthrax: A continuous problem in southwest Iran. Am J Med Sci. 1964;247:565-75. [pmid: 14158491].
71 Anonymous. Inhalation anthrax - Delaware County, Pennsylvania. MMWR Morb Mortal Wkly Rep. 1961;10(28):2.
72 Albrink WS. Pathogenesis of inhalation anthrax. Bacteriol Rev. 1961;25:268-73. [pmid: 13860173]. [pmcid: 441103].
73 Gold H. Treatment of anthrax. Fed Proc. 1967;26(5):1563-68. [pmid: 6051335].
74 Albrink WS, Brooks SM, Biron RE, Kopel M. Human inhalation anthrax: a report of three cases. Am J Path. 1960;36:457-68. [pmid: 13792449].
75 Brachman PS, Pagano JS, Albrink WS. Two cases of fatal inhalation anthrax, one associated with sarcoidosis. N Engl J Med. 1961;265(5):203-8.
76 Anonymous. Anthrax. MMWR Morb Mortal Wkly Rep. 1957;6(20):2.
77 Wright FJ, Ochjeng EC. A case of anthrax septicaemia resembling bubonic plague. East Afr Med J. 1954;31:516. [pmid: 13231799].
78 Anonymous. Proceedings of the Symposium on Anthrax in Man. Philadelphia: Hospital of the University of Pennsylvania; October 8, 1954.
79 Cowdery JS. Primary pulmonary anthrax with septicemia. Arch Pathol. 1947;43:396-99.
80 Gold H. Anthrax: a report of one hundred seventeen cases. AMA Arch Intern Med. 1955;96:387-96. [pmid: 13248274].
81 McKitterick JC, Pearson JC. Pneumonic anthrax in a child. Am J Dis Child. 1929;38:1252-55.
82 Bell HH. Pulmonary anthrax, with report of case. J Mo State Med Assoc. 1924;21:407-9.

## Adult Primary Meningoencephalitis Cases

83 Aguiah A. Un cas de meningite charbonneuse primitive chez un garcon de onze ans. Arch Med Enfants. 1928;31(11):676-680.
84 Albayrak F, Memikoglu O, Kurt O, Cokca F, Birengel S, Tekeli E. A case of anthrax meningitis. Scand J Infect Dis. 2002;34(8):627-628. [pmid: 12238584].
85 Al-Dulaimy SB, Al-Allaf GA. Anthrax meningitis. Trans R Soc Trop Med Hyg. 1978;72(3):315. [pmid: 675792].
86 Bezzi C. Un raro caso di meningite da carbonchio ematico. G Batteriol Immunol. 1952;6:353-360. [pmid: 12998979].
87 Bharathmoorthy Chakravarthy I, Swaminathan RP, Das AK, Malini G. Haemorrhagic meningitis due to bacillus anthrax (letter). J Assoc Physicians India. 1992;40(2):134-135. [pmid: 1629129].
88 Bhat P, Mohan N. Human anthrax as seen in Southern India. Salisbury Med Bull. 1990;68(Suppl):12.
89 Bhat P, Pereira P, Mohan N. Primary anthrax meningitis - a case report. Neurol India. 1983;31(2):71-73.
90 Chandramukhi A, Shankar P, Rao TV, Sundararajan S, Sathyanarayana Swamy HS. Acute leptomeningitis due to Bacillus antracis. A case report. Trop Geogr Med. 1983;35(1):79-82. [pmid: 6612776].
91 Czyhlarz E. Beitrag zur lehre von der milzbrandmeningitis. Wien Klin Wochenschr. 1916;29(25):768-769.
92 Drake DJ, Blair AW. Meningitic Anthrax. Cent Afr J Med. 1971;17(5):97-98. [pmid: 5112600].
93 George S, Mathai D, Balraj V, Lalitha MK, Jacob John T. An outbreak of anthrax meningoencephalitis. Trans R Soc Trop Med Hyg. 1994;88(2):206-207. [pmid: 8036676].
94 Gross H, Plate H. Milzbrandbacillen-Meningitis. Klin Wochenschr. 1940;19(40):1036-1037.
95 Jones HW. Landry's paralysis with report of a case. Med Rec. 1913;84:335-337.
96 Kanungo R, Kumar A, Bhattacharya S, Dutta TK, Das AK, Badrinath S. Problem of timely diagnosis in anthrax meningitis. J Assoc Phys India. 2002;50:913-915.
97 Kanungo R, Sujatha S, Das AK, Rao RS. Anthrax meningitis - a clinical enigma. Indian J Med Microbiol. 1990;6:149-151.
98 Lalitha MK, Anandi V, Walter NM, et al. Unusual forms of anthrax - a clinical problem. Salisbury Med Bull. 1990;68(Suppl):38-40.
99 Marandian MH, Kamali A. [Anthrax meningitis: an ostensibly primary case]. Nouv Presse Med. 1981;10(21):1747-1748. [pmid: 7232164].
100 Mitchell GF. Meningeal anthrax. BMJ. 1921;2:508.
101 Rangel RA, Gonzalez DA. Bacillus anthracis meningitis. Neurology. 1975;25(6):525-530. [pmid: 1168871].
102 Reece RJ. Anthrax: simulating cerebro-spinal fever. Lancet. 1917;1:406-410.
103 Rozenier LA. [Internal forms of the malignant anthrax]. Klin Med (Mosk). 1944;20(1011):56-63.
104 Sakon H, Accart R. Un cas de meningite charbonneuse suraigue. Maroc Med. 1938;18:342-344.
105 Sirol J, Delpy J, Guard O. Une epidemie de charbon humain. A propos de 25 cas observes a l'Hopital de Fort Lamy, Tchad. Presse Med. 1971;79(37):1635-1638. [pmid: 5095402].
106 Slatineanu A, Balteanu I, Franche M. Doua cazuri de meningo-encefalita carbunoasa. Miscarea Med Romana. 1939:12-18.
107 Urechia CI, Retezeanu A, Muller M. Les complications nerveuses du charbon (encephalo-meningo-myelite). Monatsschr Psychiatr Neurol. 1940;102:336-352.
108 Vita A, Secu A, Cuciureanu G, Leibovici M, Bejenariu C, Cutu G. [Considerations on 3 cases of meningo-encephalitis due to anthrax bacilli]. Viata Med. 1960;(8):661-664.
109 Vita A, Secu A, Cuciureanu G, Leibovici M, Bejenariu C, Cutu G. Considerations on 3 cases of meningo-encephalitis due to anthrax bacilli. Rum Med Rev. 1961;5:36-39. [pmid: 13926268].

## Adult Atypical Cases

110 Inda FF, Natin I, Da Rin C. El carbunclo por inhalacion. Sem Med. 1943;50(1):754-761.
111 Inda FF, Natin I, Guiliano A. El diagnostico del carbunclo por inhalacion. Sem Med. 1947;54:38-42. [pmid: 20239585].
112 Pasha ZN. Anthrax in the nasal cavity. Br Med J. 1921;2:446.
113 Mathias Blobmke. Beitrage zur pathologie und klinik des menschlichen milzbrandes. Dtsch Med Wochenschr. 1914;40(42):1860-1862.
114 Parsons JG. Abscess of the nasal septum, probably due to anthrax infection. JAMA. 1908;51:1697.
115 Risel W. Ein beitrag zur pathologie des milzbrandes beim menschen. Z Hyg Infektionskr (Leipzig). 1903;42(32):381-418.
116 Sirol J, Delpy J, Guard O. Une epidemie de charbon humain. A propos de 25 cas observes a l'Hopital de Fort Lamy, Tchad. Presse Med. 1971;79(37):1635-1638. [pmid: 5095402].
117 Ker WG. Clinical notes. East Afr Med J. 1944;21:93-96.
118 Vaccarezza RF. Charbon primitif du pharynx. Presse Med. Dec. 1939;(94):1642-1644.
119 Glas E. Milzbrand des kehlkopfes. Munch Med Wochenschr. 1906;53(11):496-498.
120 Glas E. Milzbrand (Anthrax). In: Denker A, Kahler O, eds. Handbuch der Hals-Nasen-Ohrenheilkunde. Vol IV. Berlin: Springer-Verlag; 1928:398–406.