# Appendixes

Appendix A. Data Abstracted

Appendix B: Adult Anthrax Case Reports Not Included in This Analysis

Appendix C: Peer Reviewers