# References and Included Studies

1 U.S. Department of Health and Human Services, P.H.S., Office of the Surgeon General. The Health Consequences of Smoking: A Report of the Surgeon General. U.S. Department of Health and Human Services, Public Health Service, Office of the Surgeon General, 2004.
2 U.S. Department of Health and Human Services. Reducing Tobacco Use: A Report of the Surgeon General. Atlanta, GA: US Department of Health and Human Services, Centers for Disease Control and Prevention, Office on Smoking and Health; 2000.
3 Centers for Disease Control and Prevention. State-specific prevalence of current cigarette smoking among adults—United States, 2002. Morb Mortal Wkly Rep. 2004;52(53):1277-80.
4 American Lung Association. Smoking 101 Fact Sheet. http://www.lungusa.org/site/pp.asp?c=dvLUK9O0E&b=39853:2006.
5 Fiore MC, Bailey WC, Cohen SJ. Treating Tobacco Use and Dependence, Clinical Practice Guideline. Rockville, MD: US Department of Health and Human Services, Public Health Service;2000.
6 U.S. Department of Health, Education, and Welfare. Smoking and health: report of the Advisory Committee to the Surgeon General of the Public Health Service. U.S Department of Health, Education and Welfare, Public Health Service, Office of the Surgeon General, Public Health Service Publication No. 1103; 1964.
7 Task Force on Community Preventive Services. The Guide to Community Preventive Services: What Works to Promote Health? New York: Oxford University Press; 2005.
8 Centers for Disease Control and Prevention (CDC). Cigarette smoking among adults—United States, 2004. Morb Mortal Wkly Rep. 2005;54(44):1121-4.
9 Prochaska JJ, Delucchi K, Hall SM. A Meta-Analysis of Smoking Cessation Interventions With Individuals in Substance Abuse Treatment or Recovery. J Consult Clin Psychol. 2004;72(6):1144-56. [pmid: 15612860].
10 Ernster VL. Advertising and promotion of smokeless tobacco products. NCI Monogr 1989; (8):87–94.
11 Anonymous. Oral snuff: a preventable carcinogenic hazard. Lancet 1986;2(8500):198–200.
12 U.S. Department of Health and Human Services, P.H.S., Office of the Surgeon General. Women and Smoking: A Report of the Surgeon General. Rockville, MD: US Department of Health and Human Services, Public Health Service, Office of the Surgeon General, 2001.
13 Centers for Disease Control and Prevention. Incidence of initiation of cigarette smoking - United States, 1965-1996. Morb Mortal Wkly Rep. 1998;47(39):837-40.
14 Gilpin E, Choi W, Berry C, et al. How many adolescents start smoking each day in the United States?. J Adolesc Health. 1999;25:248-55. [pmid: 10505842].
15 U.S. Department of Health and Human Services. Preventing tobacco use among young people: A report of the Surgeon General. Atlanta, GA: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, Office on Smoking and Health, 1994.
16 Johnston L, O'Malley P, Bachman J, Schulenberg J. Monitoring the Future national results on adolescent drug use: Overview of key findings, 2005. (NIH Publication No. 06-5882). Bethesda, MD: National Institute on Drug Abuse: 2006.
17 U.S. Department of Health and Human Services, P.H.S., Office of the Surgeon General. The Health Consequences of Using Smokeless Tobacco: A Report to the Advisory Committee of the Surgeon General. Bureau of Maternal and Child Health and Resources Development. Office of Maternal and Child Health, 1986.
18 Federal Trade Commission. Smokeless Tobacco Report for the Years 2000 and 2001. Washington, DC: Federal Trade Commission: Available at: http://www.ftc.gov/os/2003/08/2k2k1smokeless.pdf. Accessed: July 2004; 2003.
19 US Department of Commerce, Census Bureau. National Cancer Institute and Centers for Disease Control and Prevention Co-sponsored Tobacco Use Supplement to the Current Population Survey (2001-2002): http://riskfactor.cancer.gov/studies/tus-cps/. Data files (AND/OR) technical documentation (technical documentation website: http://www.census.gov/apsd/techdoc/cps/cpsJun01Nov01Feb02.pdf): 2004.
20 Substance Abuse and Mental Health Services Administration. Results from the 2004 National Survey on Drug Use and Health. Detailed Tables. Rockville, MD: Substance Abuse and Mental Health Services Administration, Office of Applied Studies. Available at: http://oas.samhsa.gov/nhsda/2k3tabs/Sect2peTabs1to56.htm#tab2.39b: 2005.
21 Centers for Disease Control and Prevention. Health objectives for the nation: Cigarette smoking among adults - United States, 1993. Morb Mortal Wkly Rep. 1994;43(50):925-30.
22 Centers for Disease Control and Prevention (CDC). Cigarette smoking among adults—United States, 2000. MMWR Morb Mortal Wkly Rep. 2002;51(29):642-5. [pmid: 12186222].
23 Rosen-Chase C, Dyson V. Treatment of nicotine dependence in the chronic mentally ill. J Subst Abuse Treat. 1999;16(4):315-20. [pmid: 10349604].
24 Kalman D, Hayes K, Colby SM, Eaton CA, Rohsenow DJ, Monti PM. Concurrent versus delayed smoking cessation treatment for persons in early alcohol recovery. A pilot study. J Subst Abuse Treat. 2001;20(3):233-8. [pmid: 11516593].
25 Melvin CL, Maibach M, Marx J. Marketing research to drive interventions, program and policies to help pregnant smokers quit: A case study. 2002.National Conference on Tobacco or Health
26 Woller SC, Smith SS, Piasecki TM, et al. Are clinicians intervening with their patients who smoke? A “real-world” assessment of 45 clinics in the upper Midwest. Wis Med J. 1995;94(5):266-72. [pmid: 7618339].
27 Thorndike AN, Rigotti NA, Stafford RS, et al. National patterns in the treatment of smokers by physicians. JAMA. 1998;279(8):604-8. [pmid: 9486755].
28 Goldstein MG, Niaura N, Willey-Lessne C, et al. Physicians counseling smokers. A population-based survey of patients' perceptions of health care provider-delivered smoking cessation interventions. Arch Intern Med. 1997;157(12):1313-19. [pmid: 9201005].
29 Cokkinides VE, Ward E, Jemal A, et al. Under-use of smoking-cessation treatments: results from the National Health Interview Survey, 2000. Am J Prev Med. 2005;28(1):119-22. [pmid: 15626567].
30 el-Guebaly N, Cathcart J, Currie S, et al. Smoking cessation approaches for persons with mental illness or addictive disorders. Psychiatr Serv. 2002;53(9):1166-70. [pmid: 12221317].
31 Hopkins D, Briss P, Ricard C, et al. Reviews of evidence regarding interventions to reduce tobacco use and exposure to environmental tobacco smoke. Am J Prev Med. 2001;20(2 Suppl):16-66. [pmid: 11173215].
32 Lynch BS, Bonnie RJ. Institute of Medicine Committee on Preventing Nicotine Addiction in Children and Youths. Growing up Tobacco Free: Preventing Nicotine Addiction in Children and Youths. 1994.
33 Sowden AJ, Arblaster L. Mass media interventions for preventing smoking in young people. The Cochrane Database System Rev 1998;1(4):CD001006.
34 Thomas R. School-based programmes for preventing smoking. Cochrane Database Syst Rev 2002; (4):CD001293.
35 Centers for Disease Control and Prevention. Best practices for comprehensive tobacco control programs - August 1999. Atlanta, GA: U.S. Department of Health and Human Services, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health; 1999.
36 Secker-Walker RH, Gnich W, Platt S, Lancaster T. Community interventions for reducing smoking among adults. The Cochrane Database of Systematic Reviews 2002; (2).
37 Melvin CL, Gaffney C. Treating nicotine use and dependence of pregnant and parenting smokers: An update. Nicotine & Tobacco Research. 2004;6(S2):S107-S124. [pmid: 15203815].
38 Floyd R, Belodoff B, Sidhu J, et al. A survey of obstetrician-gynecologists on their patients'use of tobacco and other drugs during pregnancy. Prenat Neonat Med. 2001;6(4):201-7.
39 Winn DM. Smokeless tobacco and aerodigestive tract cancers: recent research directions. Adv Exp Med Biol. 1992;320:39-46. [pmid: 1442283].
40 Hatsukami DK, Edmonds A, Schulte S, et al. Preliminary study on reducing oral moist snuff use. Drug Alcohol Depend. 2003;70(2):215-20. [pmid: 12732415].
41 Hatsukami DK, Lemmonds C, Tomar SL. Smokeless tobacco use: harm reduction or induction approach?. Prev Med. 2004;38(3):309-17. [pmid: 14766113].
42 Kozlowski LT. First, tell the truth: a dialogue on human rights, deception, and the use of smokeless tobacco as a substitute for cigarettes. Tob Control. 2003;12(1):34-6. [pmid: 12612359]. [pmcid: 1759104].
43 Kozlowski LT. Harm reduction, public health, and human rights: smokers have a right to be informed of significant harm reduction options. Nicotine Tob Res. 2002;4(Suppl 2):S55-60. [pmid: 12580155].
44 Kozlowski LT, O'Connor RJ, Edwards BQ, et al. Most smokeless tobacco use is not a causal gateway to cigarettes: using order of product use to evaluate causation in a national US sample. Addiction. 2003;98(8):1077-85. [pmid: 12873242].
45 Stratton K, Shetty P, Wallace R, Bondurant S, eds. Clearing the smoke: assessing the science base for tobacco harm reduction. Washington, DC: National Academy Press; 2001.
46 ABC News. Smokeless Tobacco: a Good Alternative to Smoking? http://abcnews.go.com/WNT/QuitToLive/story?id=1322995: 2005.
47 Hall SM, Munoz RF, Reus VI, et al. Mood management and nicotine gum in smoking treatment: A therapeutic contact and placebo-controlled study. J Consult Clin Psychol. 1996;64(5):1003-9. [pmid: 8916629].
48 Brandon TH. Negative affect as motivation to smoke. Curr Psychol Res Rev. 1994;3(33):33-7.
49 Breslau N, Kilbey M, Andreski P. DSM-III-R nicotine dependence in young adults: Prevalence, correlates, and associated psychiatric disorders. Addiction. 1994;89(6):743-54. [pmid: 8069175].
50 Breslau N. Psychiatric co-morbidity of smoking and nicotine dependence. Behav Genet. 1995;25:95-101. [pmid: 7733862].
51 Budney AJ, Higgins S, Hughes JR, et al. Nicotine and caffeine use in cocaine-dependent individuals. J Subst Abuse. 1993;5(2):117-30. [pmid: 8400835].
52 Clemmey P, Brooner R, Chutuape MA, et al. Smoking habits and attitudes in a methadone maintenence treatment population. Drug Alcohol Depend. 1997;44(23):123-32. [pmid: 9088784].
53 DiFranza JR, G Guerrera M. Alcoholism and smoking. J Stud Alcohol. 1990;51(2):130-35. [pmid: 2308350].
54 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
55 National Health Service Centre for Reviews and Dissemination. Undertaking systematic reviews of research on effectiveness: CRD's guidance for those carrying out or commissioning reviews. 2nd edition. York, UK: CRD Report Number 4, NHS Centre for Reviews and Dissemination; 2001.
56 Briss PA, Zaza S, Pappaioanou M, et al. Developing an evidence-based Guide to Community Preventive Services—methods. The Task Force on Community Preventive Services. Am J Prev Med. 2000;18(1 Suppl):35-43. [pmid: 10806978].
57 Ebbert JO, Rowland LC, Montori V et al. Interventions for smokeless tobacco use cessation. Cochrane Database Syst Rev 2004; (3):CD004306.
58 Lancaster T, Stead L. Physician advice for smoking cessation. Cochrane Database Syst Rev 2004;(4):CD000165.
59 Lancaster T, Stead L. Self-help interventions for smoking cessation. Cochrane Database Syst Rev 2005;(3):CD001118.
60 Lancaster T, Stead LF. Individual behavioural counselling for smoking cessation. Cochrane Database Syst Rev 2005;(2):CD001292.
61 Lumley J, Oliver SS, Chamberlain C, Oakley L. Interventions for promoting smoking cessation during pregnancy. Cochrane Database Syst Rev 2004; (4):CD001055.
62 Moher M, Hey K, Lancaster T. Workplace interventions for smoking cessation. Cochrane Database Syst Rev 2005; (2):CD003440.
63 Rigotti NA, Munafo MR, Murphy MFG, Stead LF. Interventions for smoking cessation in hospitalised patients. The Cochrane Database Syst Rev 2002; (4. Art. No.: CD001837. DOI: 10.1002/14651858.CD001837).
64 Sowden A, Arblaster L, Stead L. Community interventions for preventing smoking in young people. The Cochrane Database of Systematic Reviews 2003; (1).
65 Stead LF, Lancaster T. Group behaviour therapy programmes for smoking cessation. Cochrane Database Syst Rev 2005; (2):CD001007.
66 Stead LF, Lancaster T, Perera R. Telephone counselling for smoking cessation. Cochrane Database Syst Rev 2003; (1):CD002850.
67 King C 3rd, Siegel M. The Master Settlement Agreement with the tobacco industry and cigarette advertising in magazines. N Engl J Med. 2001;345(7):504-11. [pmid: 11519505].
68 Ausems M, Mesters I, van Breukelen G, De Vries H. Effects of in-school and tailored out-of-school smoking prevention among Dutch vocational school students. Health Educ Res. 2004;19(1):51-63. [pmid: 15020545].
69 Aveyard P, Sherratt E, Almond J, et al. The change-in-stage and updated smoking status results from a cluster-randomized trial of smoking prevention and cessation using the transtheoretical model among British adolescents. Prev Med. 2001;33(4):313-24. [pmid: 11570836].
70 Brown KS, Cameron R, Madill C, et al. Outcome evaluation of a high school smoking reduction intervention based on extracurricular activities. Prev Med. 2002;35(5):506-10. [pmid: 12431899].
71 Crone MR, Reijneveld SA, Willemsen MC, van Leerdam FJ, Spruijt RD, Sing RA. Prevention of smoking in adolescents with lower education: a school based intervention study. J Epidemiol Community Health. 2003;57(9):675-80. [pmid: 12933772]. [pmcid: 1732562].
72 Ellickson PL, McCaffrey DF, Ghosh-Dastidar B, Longshore DL. New inroads in preventing adolescent drug use: results from a large-scale trial of project ALERT in middle schools. Am J Public Health. 2003;93(11):1830-6. [pmid: 14600049]. [pmcid: 1448059].
73 Ennett ST, Bauman KE, Pemberton M, et al. Mediation in a family-directed program for prevention of adolescent tobacco and alcohol use. Prev Med. 2001;33(4):333-46. [pmid: 11570838].
74 Josendal O, Aaro LE, Torsheim T, Rasbash J. Evaluation of the school-based smoking-prevention program “BE smokeFREE”. Scand J Psychol. 2005;46(2):189-99. [pmid: 15762946].
75 Perry CL, Komro KA, Veblen-Mortenson S, et al. A randomized controlled trial of the middle and junior high school D.A.R.E. and D.A.R.E. Plus programs. Arch Pediatr Adolesc Med. 2003;157(2):178-84. [pmid: 12580689].
76 Schofield MJ, Lynagh M, Mishra G. Evaluation of a Health Promoting Schools program to reduce smoking in Australian secondary schools. Health Educ Res. 2003;18(6):678-92. [pmid: 14654501].
77 Share M, Quinn M, Ryan C. Evaluation of a 5-year school-based county-wide smoking education programme. Ir Med J 2004; 97(9): 264, 266–7.
78 Simons-Morton B, Chen R, Abroms L, Haynie DL. Latent growth curve analyses of peer and parent influences on smoking progression among early adolescents. Health Psychol. 2004;23(6):612-21. [pmid: 15546229].
79 Thomson CC, Gokhale M, Biener L, Siegel MB, Rigotti NA. Statewide evaluation of youth access ordinances in practice: effects of the implementation of community-level regulations in Massachusetts. J Public Health Manag Pract. 2004;10(6):481-9. [pmid: 15643369].
80 Tyc VL, Rai SN, Lensing S, Klosky JL, Stewart DB, Gattuso J. Intervention to reduce intentions to use tobacco among pediatric cancer survivors. J Clin Oncol. 2003;21(7):1366-72. [pmid: 12663728].
81 Unger JB, Chou CP, Palmer PH, et al. Project FLAVOR: 1-Year Outcomes of a Multicultural, School-Based Smoking Prevention Curriculum for Adolescents. Am J Public Health. 2004;94(2):263-5. [pmid: 14759940]. [pmcid: 1448241].
82 Winkleby MA, Feighery E, Dunn M, Kole S, Ahn D, Killen JD. Effects of an advocacy intervention to reduce smoking among teenagers. Arch Pediatr Adolesc Med. 2004;158(3):269-75. [pmid: 14993087].
83 Sowden A, Stead L. Community interventions for preventing smoking in young people. Cochrane Database Syst Rev 2003 ;(1):CD001291.
84 Lipkus IM, McBride CM, Pollak KI, Schwartz-Bloom RD, Tilson E, Bloom PN. A randomized trial comparing the effects of self-help materials and proactive telephone counseling on teen smoking cessation. Health Psychol. 2004;23(4):397-406. [pmid: 15264976].
85 Rabius V, McAlister AL, Geiger A, Huang P, Todd R. Telephone counseling increases cessation rates among young adult smokers. Health Psychol. 2004;23(5):539-41. [pmid: 15367074].
86 Smith PM, Cameron R, McDonald PW, et al. Telephone counseling for population-based smoking cessation. Am J Health Behav. 2004;28(3):231-41. [pmid: 15152882].
87 McBride CM, Bepler G, Lipkus IM, et al. Incorporating genetic susceptibility feedback into a smoking cessation program for African-American smokers with low income. Cancer Epidemiol Biomarkers Prev. 2002;11(6):521-8. [pmid: 12050092].
88 Etter JF, Perneger TV. Post-intervention effect of a computer tailored smoking cessation programme. J Epidemiol Community Health. 2004;58(10):849-51. [pmid: 15365111]. [pmcid: 1763345].
89 Murray RP, Connett JE, Rand CS, Pan W, Anthonisen NR. Persistence of the effect of the Lung Health Study (LHS) smoking intervention over eleven years. Prev Med. 2002;35(4):314-9. [pmid: 12453707].
90 Bauman KE, Ennett ST, Foshee VA, Pemberton M, King TS, Koch GG. Influence of a family-directed program on adolescent cigarette and alcohol cessation. Prev Sci. 2000;1(4):227-37. [pmid: 11523750].
91 Bohadana A, Nilsson F, Rasmussen T, et al. Nicotine inhaler and nicotine patch as a combination therapy for smoking cessation: a randomized, double-blind, placebo-controlled trial. Arch Intern Med. 2000;160(20):3128-34. [pmid: 11074742].
92 Bier ID, Wilson J, Studt P, Shakleton M. Auricular acupuncture, education, and smoking cessation: a randomized, sham-controlled trial. Am J Public Health. 2002;92(10):1642-7. [pmid: 12356614]. [pmcid: 1447300].
93 Covey LS, Glassman AH, Stetner F, Rivelli S, Stage K. A randomized trial of sertraline as a cessation aid for smokers with a history of major depression. Am J Psychiatry. 2002;159(10):1731-7. [pmid: 12359680].
94 Helgason AR, Tomson T, Lund KE, Galanti R, Ahnve S, Gilljam H. Factors related to abstinence in a telephone helpline for smoking cessation. Eur J Public Health. 2004;14(3):306-10. [pmid: 15369039].
95 Mermelstein R, Hedeker D, Wong SC. Extended telephone counseling for smoking cessation: does content matter?. J Consult Clin Psychol. 2003;71(3):565-74. [pmid: 12795579].
96 Saules KK, Schuh LM, Arfken CL, Reed K, Kilbey MM, Schuster CR. Double-blind placebo-controlled trial of fluoxetine in smoking cessation treatment including nicotine patch and cognitive-behavioral group therapy. Am J Addict. 2004;13(5):438-46. [pmid: 15764422].
97 Hall SM, Humfleet GL, Reus VI, Munoz RF, Cullen J. Extended nortriptyline and psychological treatment for cigarette smoking. Am J Psychiatry. 2004;161(11):2100-7. [pmid: 15514412].
98 Carpenter MJ, Hughes JR, Solomon LJ, Callas PW. Both smoking reduction with nicotine replacement therapy and motivational advice increase future cessation among smokers unmotivated to quit. J Consult Clin Psychol. 2004;72(3):371-81. [pmid: 15279521].
99 Killen JD, Fortmann SP, Schatzberg AF, et al. Nicotine patch and paroxetine for smoking cessation. J Consult Clin Psychol. 2000;68(5):883-9. [pmid: 11068974].
100 Lerman C, Kaufmann V, Rukstalis M, et al. Individualizing nicotine replacement therapy for the treatment of tobacco dependence: a randomized trial. Ann Intern Med. 2004;140(6):426-33. [pmid: 15023708].
101 Simon JA, Duncan C, Carmody TP, Hudes ES. Bupropion for smoking cessation: a randomized trial. Arch Intern Med. 2004;164(16):1797-803. [pmid: 15364675].
102 Swan GE, Jack LM, Curry S, et al. Bupropion SR and counseling for smoking cessation in actual practice: predictors of outcome. Nicotine Tob Res. 2003;5(6):911-21. [pmid: 14668075].
103 Swan GE, McAfee T, Curry SJ, et al. Effectiveness of bupropion sustained release for smoking cessation in a health care setting: a randomized trial. Arch Intern Med. 2003;163(19):2337-44. [pmid: 14581254].
104 Macleod ZR, Charles MA, Arnaldi VC, Adams IM. Telephone counselling as an adjunct to nicotine patches in smoking cessation: a randomised controlled trial. Med J Aust. 2003;179(7):349-52. [pmid: 14503897].
105 Aveyard P, Griffin C, Lawrence T, Cheng KK. A controlled trial of an expert system and self-help manual intervention based on the stages of change versus standard self-help materials in smoking cessation. Addiction. 2003;98(3):345-54. [pmid: 12603234].
106 Dalsgareth OJ, Hansen NC, Soes-Petersen U, et al. A multicenter, randomized, double-blind, placebo-controlled, 6-month trial of bupropion hydrochloride sustained-release tablets as an aid to smoking cessation in hospital employees. Nicotine Tob Res. 2004;6(1):55-61. [pmid: 14982688].
107 Garvey AJ, Kinnunen T, Nordstrom BL, et al. Effects of nicotine gum dose by level of nicotine dependence. Nicotine Tob Res. 2000;2(1):53-63. [pmid: 11072441].
108 Chalmers K, Bramadat IJ, Cantin B, et al. A smoking reduction and cessation program with registered nurses: findings and implications for community health nursing. J Community Health Nurs. 2001;18(2):115-34. [pmid: 11407180].
109 Clark MM, Cox LS, Jett JR, et al. Effectiveness of smoking cessation self-help materials in a lung cancer screening population. Lung Cancer. 2004;44(1):13-21. [pmid: 15013579].
110 Croghan GA, Sloan JA, Croghan IT, et al. Comparison of nicotine patch alone versus nicotine nasal spray alone versus a combination for treating smokers: A minimal intervention, randomized multicenter trial in a nonspecialized setting. Nicotine Tob Res. 2003;5(2):181-7. [pmid: 12745490].
111 Hahn EJ, Rayens MK, Chirila C, Riker CA, Paul TP, Warnick TA. Effectiveness of a quit and win contest with a low-income population. Prev Med. 2004;39(3):543-50. [pmid: 15313094].
112 Hennrikus DJ, Lando HA, McCarty MC, et al. The TEAM project: the effectiveness of smoking cessation intervention with hospital patients. Prev Med. 2005;40(3):249-58. [pmid: 15533536].
113 Hitsman B, Pingitore R, Spring B, et al. Antidepressant pharmacotherapy helps some cigarette smokers more than others. J Consult Clin Psychol. 1999;67(4):547-54. [pmid: 10450625].
114 Holt S, Timu-Parata C, Ryder-Lewis S, et al. Efficacy of bupropion in the indigenous Maori population in New Zealand. Thorax. 2005;60(2):120-3. [pmid: 15681499]. [pmcid: 1747282].
115 Jones C, Griffiths RD, Skirrow P, et al. Smoking cessation through comprehensive critical care. Intensive Care Med. 2001;27(9):1547-9. [pmid: 11685350].
116 Jorenby DE, Leischow SJ, Nides MA, et al. A controlled trial of sustained-release bupropion, a nicotine patch, or both for smoking cessation. N Engl J Med. 1999;340(9):685-91. [pmid: 10053177].
117 Murray RP, Connett JE, Buist AS, et al. Experience of Black participants in the Lung Health Study smoking cessation intervention program. Nicotine Tob Res. 2001;3(4):375-82. [pmid: 11694205].
118 Rowe K, Clark JM. Evaluating the effectiveness of a smoking cessation intervention designed for nurses. Int J Nurs Stud. 1999;36(4):301-11. [pmid: 10404298].
119 Canga N, De Irala J, Vara E, et al. Intervention study for smoking cessation in diabetic patients: a randomized controlled trial in both clinical and primary care settings. Diabetes Care. 2000;23(10):1455-60. [pmid: 11023136].
120 Peterson W. A nurse managed smoking cessation and relapse prevention programme did not reduce smoking rates at 12 months beyond rates achieved by usual care in women with cardiovascular disease. Evidence Based Nursing. 2004;7(3):83. [pmid: 15252911].
121 Lancaster T, Dobbie W, Vos K, et al. Randomized trial of nurse-assisted strategies for smoking cessation in primary care. Br J Gen Pract. 1999;49(440):191-4. [pmid: 10343421]. [pmcid: 1313370].
122 McBride CM, Baucom DH, Peterson BL, et al. Prenatal and postpartum smoking abstinence a partner-assisted approach. Am J Prev Med. 2004;27(3):232-8. [pmid: 15450636].
123 Quist-Paulsen P, Gallefoss F. Randomised controlled trial of smoking cessation intervention after admission for coronary heart disease. BMJ. 2003;327(7426):1254-7. [pmid: 14644967]. [pmcid: 286243].
124 Ratner PA, Johnson JL, Richardson CG, et al. Efficacy of a smoking-cessation intervention for elective-surgical patients. Res Nurs Health. 2004;27(3):148-61. [pmid: 15141368].
125 Reid R, Pipe A, Higginson L, et al. Stepped care approach to smoking cessation in patients hospitalized for coronary artery disease. J Cardiopulm Rehabil. 2003;23(3):176-82. [pmid: 12782900].
126 Hand S, Edwards S, Campbell IA, Cannings R. Controlled trial of three weeks nicotine replacement treatment in hospital patients also given advice and support. Thorax. 2002;57(8):715-8. [pmid: 12149533]. [pmcid: 1746389].
127 Davies SL, Kohler CL, Fish L, Taylor BE, Foster GE, Annang L. Evaluation of an intervention for hospitalized African American smokers. Am J Health Behav. 2005;29(3):228-39. [pmid: 15899686].
128 Wakefield M, Olver I, Whitford H, Rosenfeld E. Motivational interviewing as a smoking cessation intervention for patients with cancer: randomized controlled trial. Nurs Res. 2004;53(6):396-405. [pmid: 15586136].
129 Lawrence T, Aveyard P, Cheng KK, Griffin C, Johnson C, Croghan E. Does stage-based smoking cessation advice in pregnancy result in long-term quitters? 18-month postpartum follow-up of a randomized controlled trial. Addiction. 2005;100(1):107-16. [pmid: 15598198].
130 Ockene JK, Lindsay E, Berger L, Hymowitz N. Health Care Providers as Key Change Agents in the Community Intervention Trial for Smoking Cessation (COMMIT). International Quarterly of Community Health Education 1990-1991; 11(3):223–37.
131 Borland R, Balmford J, Segan C, Livingston P, Owen N. The effectiveness of personalized smoking cessation strategies for callers to a Quitline service. Addiction. 2003;98(6):837-46. [pmid: 12780372].
132 Maguire TA, McElnay JC, Drummond A. A randomized controlled trial of a smoking cessation intervention based in community pharmacies. Addiction. 2001;96(2):325-31. [pmid: 11182878].
133 Ronda G, Van Assema P, Candel M, et al. The Dutch Heart Health Community Intervention 'Hartslag Limburg': effects on smoking behaviour. Eur J Public Health. 2004;14(2):191-3. [pmid: 15230508].
134 Cornuz J, Humair JP, Seematter L, et al. Efficacy of resident training in smoking cessation: a randomized, controlled trial of a program based on application of behavioral theory and practice with standardized patients. Ann Intern Med. 2002;136(6):429-37. [pmid: 11900495].
135 Russos S, Keating K, Hovell MF, et al. Counseling youth in tobacco-use prevention: determinants of clinician compliance. Prev Med. 1999;29(1):13-21. [pmid: 10419794].
136 Slama K, Karsenty S, Hirsch A. French general practitioners' attitudes and reported practices in relation to their participation and effectiveness in a minimal smoking cessation programme for patients. Addiction. 1999;94(1):125-32. [pmid: 10665104].
137 Smith PM, Reilly KR, Houston Miller N, DeBusk RF, Taylor CB. Application of a nurse-managed inpatient smoking cessation program. Nicotine Tob Res. 2002;4(2):211-22. [pmid: 12096707].
138 Young JM, D'Este C, Ward JE. Improving family physicians' use of evidence-based smoking cessation strategies: a cluster randomization trial. Prev Med. 2002;35(6):572-83. [pmid: 12460525].
139 Pbert L, Ockene JK, Zapka J, et al. A Community Health Center Smoking-Cessation Intervention for Pregnant and Postpartum Women. Am J Prev Med. 2004;26(5):377-85. [pmid: 15165653].
140 Pieterse ME, Seydel ER, DeVries H, Mudde AN, Kok GJ. Effectiveness of a minimal contact smoking cessation program for Dutch general practitioners: a randomized controlled trial. Prev Med. 2001;32(2):182-90. [pmid: 11162345].
141 Goldstein MG, Niaura R, Willey C, et al. An academic detailing intervention to disseminate physician-delivered smoking cessation counseling: smoking cessation outcomes of the Physicians Counseling Smokers Project. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2003;36(2):185-96.
142 Katz DA, Brown RB, Muehlenbruch DR, Fiore MC, Baker TB. Implementing guidelines for smoking cessation: comparing the efforts of nurses and medical assistants. Am J Prev Med. 2004;27(5):411-6. [pmid: 15556742].
143 Joseph AM, Arikian NJ, An LC, Nugent SM, Sloan RJ, Pieper CF. Results of a randomized controlled trial of intervention to implement smoking guidelines in Veterans Affairs medical centers: increased use of medications without cessation benefit. Med Care. 2004;42(11):1100-10. [pmid: 15586837].
144 Katz DA, Muehlenbruch DR, Brown RL, Fiore MC, Baker TB. Effectiveness of implementing the agency for healthcare research and quality smoking cessation clinical practice guideline: a randomized, controlled trial. J Natl Cancer Inst. 2004;96(8):594-603. [pmid: 15100337].
145 Piper ME, Fiore MC, Smith SS, et al. Use of the vital sign stamp as a systematic screening tool to promote smoking cessation. Mayo Clin Proc. 2003;78(6):716-22. [pmid: 12934781].
146 Choi WS, Farkas AJ, Rosbrook B. Does advertising promote smokeless tobacco use among adolescent boys? Evidence from California. Tob Control. 1995;4(Supplement 1):S57-S63.
147 Tomar SL. Is use of smokeless tobacco a risk factor for cigarette smoking? The U.S. experience. Nicotine Tob Res. 2003;5(4):561-9. [pmid: 12959794].
148 Lyon ER. A review of the effects of nicotine on schizophrenia and antipsychotic medications. Psychiatr Serv. 1999;50(10):1346-50. [pmid: 10506305].
149 Joseph AM, Willenbring ML, Nugent SM, Nelson DB. A randomized trial of concurrent versus delayed smoking intervention for patients in alcohol dependence treatment. J Stud Alcohol. 2004;65(6):681-91. [pmid: 15700504].
150 Brown RA, Kahler CW, Niaura R, et al. Cognitive-behavioral treatment for depression in smoking cessation. J Consult Clin Psychol. 2001;69(3):471-80. [pmid: 11495176]. [pmcid: 1832078].
151 Brown RA, Ramsey SE, Strong DR et al. Effects of motivational interviewing on smoking cessation in adolescents with psychiatric disorders. Tob Control 2003; 12 Suppl 4:IV3–10.
152 Joseph A. Nicotine treatment at the Drug Dependency Program of the Minneapolis VA Medical Center. A researcher's perspective. J Subst Abuse Treat. 1993;10(2):147-52. [pmid: 8389895].
153 Murray RP, Istvan JA, Voelker HT, et al. Level of involvement with alcohol and success at smoking cessation in the lung health study. J Stud Alcohol. 1995;56(1):74-82. [pmid: 7752637].
154 Cooney JL, Cooney NL, Pilkey DT, Kranzler HR, Oncken CA. Effects of nicotine deprivation on urges to drink and smoke in alcoholic smokers. Addiction. 2003;98(7):913-21. [pmid: 12814497].
155 Soulier-Parmeggiani L, Griscom S, Bongard O, Avvanzino R, Bounameaux H. One-year results of a smoking-cessation programme. Schweiz Med Wochenschr. 1999;129(10):395-8. [pmid: 10212973].
156 Stevens VJ, Glasgow RE, Hollis JF, Mount K. Implementation and effectiveness of a brief smoking-cessation intervention for hospital patients. Med Care. 2000;38(5):451-9. [pmid: 10800972].