# Discussion

This chapter reviews the quality of the literature and strength of the evidence base for selected outcomes relating to tobacco prevention, smoking cessation intervention, and smokeless tobacco marketing. The confidence that readers can have in our findings, conclusions, and recommendations is contingent on the quality of the research reviewed and the overall robustness of the evidence. Key question (KQ) 6, addressed in this chapter, concerned limitations in the literature and gaps in the knowledge base that point to needed future research. Our information and suggestions pursuant to this question will be especially pertinent to participants at the National Institutes of Health (NIH) State-of-the-Science Conference on Tobacco Use on June 12–14, 2006.

## Quality of Literature and Strength of Evidence

As described in Chapter 2 and documented in the evidence tables (Appendix C ^§§^), we selected articles for this review using rigorous criteria and assessed them using a component quality rating scale of “good,” “fair,” and “poor.” The prior systematic reviews that we used for several key questions or parts of questions were all of good or fair quality.

§§ Appendixes cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/tobusetp.htm.

We also evaluated the strength of the body of evidence based on the suitability and quality of execution of the study design, the amount of evidence available, and the coherence or consistency of available evidence. The strength-of-evidence categories were strong, sufficient, and insufficient. The suitability of the study design for assessing effectiveness is based on how well the study design protects against potential threats to validity.^56^ Concurrent comparison groups, prospective measurement of exposure, multiple outcome measurements conducted over time, and assessment of exposure that precedes assessment of outcome are ways to avoid potential threats to validity. Suitability of the study design was contingent on whether the study had concurrent comparison groups, no comparison group but multiple prepost measurements, or single prepost measurements and was assessed as greatest, moderate, or least, respectively. For assessing the quality of study execution (see Chapter 2), we considered the following areas that posed possible threats to validity: (1) study population, (2) intervention descriptions, (3) sampling, (4) exposure and outcome measurement, (5) data analysis, (6) interpretation of results, (7) followup, (8) bias, and (9) confounding. We evaluated studies based on limitations in one or more of these areas. The number of studies needed to assess the strength of the body of evidence is variable and depends on the suitability and execution of the studies.

### KQ 1. Effective Population- and Community-based Interventions to Prevent Tobacco Use in Adolescents and Young Adults

Population-based tobacco prevention interventions. Two studies implemented population-based tobacco prevention interventions.^73,^ ^79^ Thomson et al. examined the effects of statewide youth tobacco access ordinances in Massachusetts and had one result in the expected direction.^79^ Residents of towns with fewer free-standing tobacco product displays were less likely to perceive tobacco as easy to purchase. The study found an association between increased attempts to purchase tobacco and being older and male, but the study did not determine whether adolescents in towns with more tobacco access ordinances and regulations had less tobacco initiation. The second population-based study conducted within families was time intensive and required many resources to implement,^73^ but it was successful at reducing tobacco initiation for a subset of the population (i.e., non-Hispanic whites). These two studies alone provided little evidence to draw conclusions about population-based tobacco prevention interventions.

Prior systematic reviews reported strong evidence of effectiveness for two approaches to tobacco use prevention among adolescents and young adults: (1) increasing the unit price of tobacco products, and (2) mass media campaigns run concurrently with other interventions such as increased excise taxes or school- and community-based tobacco prevention programs.^7^ We found no other research to add to existing evidence on increasing unit price for tobacco products or on mass media campaigns alone or in conjunction with other tobacco prevention efforts.

Sufficient evidence of effectiveness was determined for tobacco prevention strategies that mobilize community support in conjunction with restricting tobacco product distribution, regulating the mechanisms of sale, enforcing access-to-minors laws, and educating and training merchants.^7^ The findings from the Massachusetts study on statewide youth tobacco access ordinances augments the already sufficient evidence of effectiveness for tobacco prevention strategies that coordinate community-wide interventions to regulate and enforce access-to-minors laws.^79^

Community-based tobacco prevention interventions. Ten studies implemented school-based tobacco prevention programs.^68^–^72,^ ^74^–^76,^ ^81,^ ^82^ The studies had adequate sample sizes and used appropriate cluster analysis for school-level data. Limitations of school-based tobacco prevention studies include high attrition rates, lack of long-term follow-up assessments, and inconsistent definitions of smoking status and abstinence.

Programs done over a single school year provided mixed results. At the end of the interventions or shortly afterwards, two studies, one using classroom instruction and the other using personalized letters, reduced tobacco initiation.^68,^ ^71^ Two other studies, however, both using classroom instruction (with one incorporating extracurricular activities and parent involvement), were effective only for boys.^75,^ ^81^

Interventions done over multiple school years, which provide longer or repeated exposure to prevention treatment, also produced mixed results. Two studies significantly reduced tobacco initiation rates,^72,^ ^74^ one study reduced tobacco uptake for boys but not girls,^70^ and two other studies had no effect.^76,^ ^82^ No school-based study reported long-term effects.

Past systematic reviews report limited support for community- and school-based tobacco prevention programs for reducing tobacco initiation.^34,^ ^64^ Long-term effects (i.e., greater than 2 years) have not been found with school-based interventions. Although educational strategies conducted together with population and community tobacco prevention efforts have postponed tobacco initiation,^2^ this result was not evident in our studies. Existing evidence is sufficient to demonstrate that tobacco prevention measures conducted in school settings have positive short-term effects on preventing adolescents from initiating tobacco use.^68,^ ^70^–^72,^ ^74,^ ^75,^ ^81^ Without definitive findings, evidence is insufficient to draw conclusions on the effectiveness of school-based programs to produce long-term effects. These results are consistent with past reviews that suggest school-based prevention strategies show limited effectiveness over the long run.^34^

Provider-based tobacco prevention interventions. The only provider-based study we reviewed found no intervention effects.^80^ Therefore, existing evidence is insufficient to determine whether tobacco prevention conducted in provider settings is effective for preventing tobacco use among adolescents. Past systematic reviews have not evaluated provider-based tobacco prevention strategies in health care settings.

### Gaps in Tobacco Prevention Literature

Population-based tobacco prevention interventions. With the exception of tobacco industry and product restriction, earlier systematic reviews had extensively evaluated tobacco prevention strategies and provided intervention recommendations that included increasing tobacco product prices, enforcing tobacco laws and regulations, and conducting mass media education campaigns. Our review identified two population-based studies (only one related to past reviews and recommendations). Population-based tobacco prevention research lacks tobacco industry and product restriction interventions. More research is needed on the effects of price increases in combinations with other strategies. Too few studies of good and fair quality report on the effects of enforcing tobacco youth access laws and regulations aimed at retailers, and many studies do not use reduced initiation as the outcome variable. More rigorous research on the enforcement of youth access laws and regulations and their impact on smoking initiation among adolescents and young adults is needed to help build the evidence base.

Limited information is available on the effectiveness of implementing several population-based interventions simultaneously. Implementing tobacco prevention strategies that we know are effective concomitantly may greatly influence the uptake of tobacco use among adolescents and young adults.

Community-based tobacco prevention interventions. The body of evidence for school-based tobacco prevention is large; our review found several recent school-based tobacco prevention studies. Improving this body of evidence entails producing more rigorous research through adequate use of randomization, using control groups without contamination or confounding issues, achieving low attrition rates, and consistently using operationally defined outcome variables. The lack of long-term effects of school-based programs is problematic, so sustainability of effects remains unknown.

Additionally, we found no research about comprehensive interventions that include combining school-based prevention programs with other effective interventions such as media campaigns or enforcement of tobacco youth access laws and regulations. More research on community-based tobacco prevention interventions is needed, because our review found no other community-based interventions beyond what has been reported in prior systematic reviews.

Provider-based tobacco prevention interventions. Virtually no evidence is available to report on provider-based tobacco prevention for adolescents. Provider-based tobacco prevention may be practical only for dental or orthodontic practices, where many adolescents have repeated visits. Research in this area has focused on measuring implementation, content of counseling, and frequency of counseling, but studies did not report on our outcome variable for KQ 1 (i.e., reduced initiation of tobacco use).^135^ Additional evidence is needed to assess whether provider settings are a viable place to implement tobacco prevention for this age group.

### KQ 2. Effective Strategies for Increasing Consumer Demand for and Use of Proven Individually Oriented Cessation Treatment

Multicomponent strategies to increase the number of users who attempt to quit. Telephone counseling. Findings from recent reviews show that proactive telephone counseling is effective in increasing tobacco use cessation for adults, especially when combined with other counseling formats. We identified three studies of fair quality that focused on telephone counseling with related print materials.^84^–^86^ These studies, on their own, yielded insufficient and inconsistent evidence to draw conclusions about the efficacy of telephone counseling. Two trials reported significant increases in cessation in the short term among those using telephone counseling;^85,^ ^86^ one trial reported no difference in either abstinence at each followup or in continuous abstinence.^84^ When considered within the context of recent systematic reviews and meta-analyses, results from two studies in our review were consistent with that body of evidence; each demonstrated a positive effect of telephone counseling along with relevant printed materials on quitting smoking.^85,^ ^86^

We found only two studies targeting youth and young adults with telephone counseling. Both showed that telephone counseling for youth and young adults resulted in quit rates comparable to those for adults. The small number of studies led us to conclude that, although promising, the evidence is currently insufficient to draw conclusions with regard to the effect of telephone counseling on adolescents and young adults.

We found no study evaluating other multiple formats for increasing the number of users who attempt to quit. One study that evaluated counseling enhanced by providing information on genetic susceptibility to lung cancer showed a short but unsustained effect on cessation rates. Results of studies evaluating persistence of effect in the long term were inconsistent.

Numerous design and measurement issues complicate the interpretation of study findings for this portion of the review. Smokers were defined in various ways in these studies; no two studies applied the same definition. The trials evaluated very different interventions; they also used different measures of smoking status and abstinence and different follow-up intervals. The five studies using continuous abstinence as an outcome, however, did consistently define it as abstinence at all reporting periods.

Strategies to improve the success of quit attempts. Our review included studies evaluating the efficacy of cessation strategies such as self-help, counseling, single pharmaceuticals, combined pharmacotherapies, and pharmacotherapies combined with psychological counseling. Three studies were determined to be of good quality; all others were fair. Our findings for self-help strategies were consistent with those of earlier reviews. We found insufficient evidence of the efficacy of self-help strategies given the small number of new studies and discrepancies across their reported effects. In the one study that showed an effect, we could not estimate the independent effect of practical tips for smoking cessation compared with other components of the intervention such as tips on exercise.^115^ These findings were consistent with those of other recent reviews showing the marginal efficacy of self-help when offered without any person-to-person intervention.

Our review of counseling showed mixed results. Two studies reported increased abstinence with counseling treatment; three showed no effect. This evidence is insufficient on its own to make a recommendation differing from those of prior reviews indicating that even brief individual cessation counseling is efficacious.

In our review of pharmaceutical approaches to increasing the success of quit attempts, we reviewed five studies, all of fair quality. Three studies evaluated the effect of bupropion, one studied the effect of nicotine gum and of different doses of nicotine gum, and one examined the comparative efficacy of transdermal nicotine and nicotine nasal spray.

Findings are consistent with those of prior reviews showing that nicotine gum is a significant aid to smoking cessation, more than doubling the odds of successful quitting. No differences in dose response (2 mg vs. 4 mg) for nicotine gum were found in one study.

Results were mixed for bupropion. Two studies showed a significant benefit of bupropion compared with placebo at 6-month assessment. Patients ready to quit participated in one study;^106^ participants at all stages of readiness in an indigenous population group were enrolled in another.^114^ In the final study, bupropion use in outpatients regardless of stage of readiness to quit showed a nonsignificant trend in favor of abstinence in the short term (3 months) but not at longer periods (e.g., 6 and 12 months).^101^ These mixed findings for bupropion are insufficient on their own to warrant a change in findings from previous reviews concluding that bupropion is a first-line pharmacotherapy for smoking cessation.

In a trial evaluating the comparative efficacy of transdermal nicotine and nicotine nasal spray, abstinence rates for the two groups were not significantly different at 6-month followup (15.0 percent vs. 12.2 percent, respectively; P > 0.2).^100^ These results are consistent with estimates of significant effect for transdermal nicotine and nicotine nasal spray found in prior reviews. Smokers with low to moderate dependence levels, who were not obese, and who were white achieved higher abstinence levels with transdermal nicotine. By contrast, smokers who were highly dependent, obese, or members of minority groups achieved higher abstinence rates with nasal spray.^100^ These findings provide useful information for those offering these pharmaceuticals to their patients.

Three studies assessed the efficacy of combined pharmaceutical therapy. Two of these studies showed a significant increase in long-term cessation (i.e., 12 months) compared with one pharmacotherapy alone. One of these studies was consistent with prior reviews showing that a combination of nicotine patch with a self-administered form of nicotine replacement therapy was more effective than a single form of replacement therapy. The other study showed the significant benefit of bupropion alone and in combination with the nicotine patch over the long term (12 months) compared with placebo. The third study showed no overall benefit of the patch and paroxetine combined, but did demonstrate significant differences between paroxetine groups and placebo in the short term (4 weeks).

We identified six studies combining pharmacotherapy and psychological interventions; interventions varied by type of pharmacotherapy and by content, format, and intensity of counseling. Five of these studies demonstrated a significant improvement in abstinence in treatment groups receiving combination pharmacotherapy and psychological interventions. These studies provide sufficient evidence of the efficacy of combined pharmacotherapy and psychological interventions and add to findings from previous reviews that pharmacotherapy either alone or in combination with counseling is effective.^5,^ ^30^ The single study on fluoxetine is not sufficient to add it to the list of efficacious pharmacotherapies.

Strategies to improve the success of quit attempts for special populations. Nine studies evaluated strategies to increase the success of quit attempts among special populations. Three studies focused on hospitalized patients in different diagnostic categories;^119,^ ^120,^ ^123^ four examined the impact of varying the intensity of interventions for hospitalized patients;^112,^ ^115,^ ^124,^ ^125^ one dealt with pregnant women^122^ and one with the indigenous Maori population in New Zealand.^114^

Hospitalized patients. When considering interventions for hospitalized patients by diagnosis, two studies of fair quality and one of good quality found results similar to those in prior studies; that biochemically validated abstinence rates at 12 months postdischarge, although reported as higher for the intervention group, were not statistically significant.^119,^ ^120,^ ^123^ In one study, significant differences at 12 months in compliant patients did not hold with intent-to-treat analysis.^123^ Overall, studies in our review were in agreement with findings of the Rigotti, et al. review showing that there was no strong evidence that clinical diagnosis affected the likelihood of quitting.^63^

Four studies considered whether cessation varied with counseling intensity for hospitalized patients.^112,^ ^115,^ ^124,^ ^125^ All three studies compared an intensive intervention (defined as inpatient contact plus followup for at least 1 month) with usual care and/or a less intensive intervention. One study showed significant differences in self-reported, but not biochemically validated, abstinence at 12-month followup. Two studies showed significant increases in abstinence at 3- or 6-month assessments but not at 12-month assessments. One study found a significant increase in abstinence but was unable to attribute it directly to the intervention.

Pregnant women. One study using enhanced counseling to prevent postpartum relapse, telephone counseling during and after pregnancy, and partner assistance in quitting demonstrated no significant improvement in abstinence.^122^

Ethnic groups. In a study of whether bupropion combined with smoking cessation counseling was effective in treatment of tobacco use in indigenous Maori in New Zealand, the investigators found quit rates similar to those observed in other trials of bupropion.^114^ They also reported no data to suggest that the Maori encountered any special problems related to bupropion use.

### Gaps in the Literature for Increasing Demand for and Use of Cessation Treatments

Very few studies examined the relative population impact of proven cessation interventions. For example, information on how proactive telephone counseling support compares with a face-to-face intervention would be useful; similarly, whether nicotine replacement therapy is offered in either of these (or other) situations would be useful for those designing combination interventions. Little is known about differential rates of success of and enrollment in various programs and how each may either offset or enhance the other. These research questions are especially important given the move toward provider referral to quit-line services.

We found no studies comparing the specific aspects of telephone counseling with each other. Issues about the number and timing of calls and the role of feedback to the caller's primary provider have not been studied sufficiently.

We did not identify sufficient studies of the role of mass media in increasing use of cessation services among specific subsets of the population. Research on specific messages and their effectiveness in reaching and motivating target audiences such as adolescents, young adults, and persons with low income and educational status could improve the impact of such interventions.

We found very few studies examining the effectiveness of multiple intervention formats, of combination pharmacotherapy, or of adjuncts other than pharmacotherapy to individual counseling in increasing the success of smoking cessation interventions. Similarly, very few studies examined differences in either withdrawal symptoms or side effects associated with continuation or success of pharmacotherapy. Persistence of effect on smoking status over time was reported by only two studies; larger, prospective trials are likely needed to increase the evidence base for this issue. Finally, very few studies focused on ways to reach or treat special populations such as adolescents and young adults.

### KQ 3. Effective Strategies for Increasing the Implementation of Proven Population-Level Tobacco Use Cessation Strategies, Particularly by Health Care Systems and Communities

Population-based implementation strategies. We found insufficient evidence to suggest that community-based interventions increase implementation of proven cessation strategies. Three studies, one of good quality and two of fair quality, focused on very different strategies and populations and produced inconsistent results.^131^–^133^ Positive results were shown only in a trial using community-based pharmacists to discuss smoking cessation with smokers coming to their pharmacies for a variety of services.^132^ The positive results observed with pharmacist-led interventions suggest that further research into how pharmacists might be engaged in and support community-based strategies would be useful.

Provider- and health care system-based tobacco use cessation strategies. One prior systematic review reported “strong” evidence of effectiveness for provider reminder systems with provider education, with or without client education, and for multicomponent interventions that include client telephone support; “sufficient” evidence of effectiveness for provider reminders alone and reductions in patient out-of-pocket costs; and “insufficient” evidence of effectiveness to recommend provider education alone and provider feedback and assessment.^7^

A meta-analysis identified six systems strategies to facilitate adoption of effective tobacco treatment in health care settings: (1) implementing a tobacco user identification system in every clinic; (2) providing education, resources, and feedback to promote provider intervention; (3) dedicating staff to provide tobacco dependence treatment and assessing the delivery of this treatment in staff performance evaluations; (4) promoting hospital policies that support and provide tobacco dependence services; (5) including tobacco dependence treatments (both counseling and pharmacotherapy) identified as effective as paid or covered services for all subscribers or members of health insurance packages; and (6) reimbursing clinicians and specialists for delivery of effective tobacco dependence treatments and including those interventions among the defined duties of the clinicians.

Four studies showed that provider training improved provision and uptake of smoking cessation strategies.^134,^ ^142,^ ^144^ When examining the effect of these changes on smoking abstinence, two studies reported significant increases in abstinence compared with control, and one reported no differences at 6-month followup after biochemical verification of self-reported abstinence.^144^ Our review supports the efficacy of provider-based strategies to increase the implementation of proven cessation strategies, but falls just short of providing sufficient evidence that these improvements in implementation will increase cessation.

In our review of interventions carried out in health care systems, we found sufficient evidence that academic detailing approaches improved provider delivery of effective smoking cessation treatments. Family physicians and other providers in office-based private practices, public clinics, hospitals, and orthodontist offices improved their knowledge and use of effective strategies as a result of personal educational visits in their own practice setting that included education, audit, and feedback.

The evidence was insufficient, however, to suggest that these improved treatment practices lead to significant, long-term increases in cessation among those being treated. Too few studies reported quit rates for the population served. Those studies reporting quit rates showed no consistent effects on cessation in the long term. One study found significant improvement in cessation in the short term; this occurred among pregnant women.^139^ This finding is especially important given the immediate positive health outcomes associated with quitting in the short term for a pregnant woman and her fetus.

No evidence was found to conclude that provider attitudes and smoking behavior have an effect on uptake and use of effective interventions. The only study to test this relationship found no effect.^136^

Evidence was also insufficient to suggest that interventions proven effective in earlier trials could be sustained as a part of routine care. Only one study examined this important aspect of improving the odds of maintaining an effective program.^86^ The investigators found that successfully implementing a proven strategy after completion of the original trial is possible; they also determined that the sustained program produced quit rates comparable to those observed in the trial and that success was more likely among cancer, cardiovascular, and pulmonary patients.

### Gaps in the Literature for Increasing Implementation of Cessation Strategies

We found inconsistencies in the literature evaluating academic detailing as an approach to improving implementation of cessation strategies. Additional studies are needed that use a standard definition of academic detailing, that observe changes not only in practice patterns but also in related smoking cessation outcomes, and that systematically assess the impact of academic detailing across and within practice types. At a minimum, all subsequent studies should incorporate all proven components of an academic model, such as provider reminder systems.

We found only one study describing how provider attitudes and smoking behavior affected provider use of effective interventions. Similarly, we found only one study examining the factors affecting incorporation of effective interventions into usual care. Many studies reported on implementation strategies to improve smoking cessation services in practice settings, but few studies collected data on whether these system-based improvements translate into increased quit rates.

### KQ 4. Effect of Smokeless Tobacco Product Marketing and Use on Population Harm From Tobacco Use

Smokeless tobacco product marketing and use. Two studies with quality ratings of fair focused on smokeless tobacco use.^146,^ ^147^ They investigated (1) how smokeless tobacco use affects smoking behaviors and (2) how exposure to smokeless tobacco advertising affects use. Tomar reported that smokers were more likely to quit smoking than become users of smokeless tobacco.^147^ More importantly, users of smokeless tobacco were significantly more likely than nonusers of tobacco to become smokers.^147^ One study does not provide sufficient evidence to draw conclusions on whether smokeless product marketing results in substituting smokeless tobacco for smoking.

Our review found one study that indicates smokeless tobacco marketing may lead to greater use at least for adolescents.^146^ Choi et al. found that exposure to advertising increased adolescents' susceptibility to smokeless tobacco. One predictor of current use of smokeless tobacco is exposure to smokeless tobacco advertising, resulting in a sevenfold increase in current use.^146^ Again, one study does not provide sufficient evidence to determine whether tobacco marketing increases smokeless tobacco use.

Prior systematic reviews did not address issues relevant to KQ 4. Past reviews focused on risks associated with the use of smokeless tobacco and on the potential offered by smokeless tobacco cessation treatments.^1,^ ^2,^ ^5^

### Gaps in Smokeless Tobacco Product Marketing and Use

Smokeless tobacco product marketing and use. The gaps in research on smokeless tobacco product marketing and use are substantial. No studies addressed two of three concerns presented in this review: (1) whether substituting smokeless tobacco for smoking results in less smoking-related harm on a population basis, and (2) whether data on harms and harm reduction associated with smokeless tobacco are used to model the potential health effects of substituting smokeless tobacco for smoking. Additional evidence is necessary to determine how smokeless tobacco use affects smoking behaviors and how exposure to smokeless tobacco advertising affects use.

### KQ 5. Effectiveness of Prevention and of Cessation Interventions in Populations with Co-Occurring Morbidities and Risk Behaviors

Tobacco cessation for persons with co-occurring morbidities. Three studies evaluated smoking cessation for persons with psychiatric conditions.^113,^ ^150,^ ^151^ Hitsman et al. hypothesized that smokers with greater depressive symptoms would be more likely to achieve abstinence when receiving fluoxetine combined with cognitive behavioral therapy (CBT) than when receiving a placebo and CBT.^113^ Brown et al. compared standard CBT with CBT tailored for depression for adults with a history of major depressive disorder (MDD).^150,^ ^151^ A second study by Brown and colleagues treated adolescent smokers hospitalized for psychiatric and substance use problems with either motivational interviewing or brief advice tobacco cessation interventions.^151^ Two of the three studies^113,^ ^151^ used some form of pharmacotherapy. Hitsman et al. achieved significant results in an adult population, but Brown et al. did not in an adolescent population.^113,^ ^151^ Counseling paired with CBT produced smoking cessation rates for people with a history of MDD but depression-based CBT did not significantly increase smoking cessation rates over standard CBT for this population.

Consistent with prior reviews, pharmacotherapy was effective.^5,^ ^30^ Participants treated with fluoxetine had a higher likelihood of abstinence than did participants treated with placebo, and fluoxetine benefited smokers with higher initial levels of depression.^113^ The effects of counseling and CBT are also congruous with the prior reviews, but depression-based CBT does not statistically increase abstinence rates above standard CBT abstinence rates.^150^ Neither motivational interviewing nor brief advice tobacco cessation interventions were effective for adolescents hospitalized for psychiatric and substance use problems.^151^ Prior reviews did not report effective smoking cessation interventions for adolescents in this population.

Our review of the effect of smoking cessation interventions for persons with co-occurring morbidities supports prior reviews. Nonetheless, because we found only a limited number of studies and inconsistent results, it does not provide sufficient evidence to make further recommendations about the effectiveness of smoking cessation interventions in populations with psychiatric conditions.

Tobacco cessation for persons with substance abuse addictions. Two studies investigated smoking cessation among alcohol and substance abusers.^149,^ ^152^ Joseph evaluated the feasibility of a smoke-free policy and a nicotine treatment program implemented in a drug and alcohol treatment hospital.^152^ In another study, Joseph et al. investigated the effects of concurrent versus delayed smoking cessation intervention in substance use and abuse treatment centers.^149^ These studies used some form of counseling or classroom smoking cessation instruction with pharmacotherapy; compared with control groups, these approaches produced significant results. Joseph et al. found no difference in smoking cessation rate between concurrent and delayed interventions, a point that suggests that the intervention is effective for smoking cessation regardless of when it is implemented. However, alcohol abstinence was negatively affected (i.e., lower) in the concurrent treatment group compared with the delayed treatment group.^149^

Consistent with prior systematic reviews,^9^ pharmacotherapy and psychological counseling significantly influence abstinence rates compared with control interventions in this population. The evidence is not consistent regarding the impact of smoking cessation treatment on non-nicotine substance use.^149,^ ^152^ Although the two studies reported significant short-term effects for smoking cessation, only one study reported long-term (i.e., 12-month) abstinence rates. More than 50 percent of the participants were lost to followup in this study.^152^ The studies support findings from past reviews on the positive short-term effects of such interventions;^30^ however, the body of evidence in our review is insufficient to point to further recommendations.

### Gaps in the Literature for Effectiveness of Prevention and of Cessation Interventions in Populations with Co-Occurring Morbidities and Risk Behaviors

The gaps in this evidence base remain significant for these populations. We found no research publications on tobacco prevention for populations with co-occurring morbidities and risk behaviors. Although the term co-occurring suggests that these populations are already smoking, tobacco prevention efforts, typically directed at adolescents, need to consider testing prevention strategies tailored for psychiatric and substance-addicted populations.

Additional studies need to determine whether smoking cessation treatment should be done at the same time as, at the beginning, or at the end of treatment for psychiatric and substance-addicted populations. Research to rule out any possibility of adverse effect from concurrent treatment regimes of psychiatric or substance use conditions and nicotine addiction is necessary to move forward with smoking cessation treatment for this population. More research explaining interaction effects among depression and smoking cessation interventions is needed.

Several studies allude to negative perceptions and attitudes of treatment center staff as barriers to treating nicotine addiction simultaneously with psychiatric conditions, especially, with substance abuse problems. Research exploring the legitimacy of these statements should be pursued. We believe the current opportunity to contribute to this area of tobacco research is extensive.

## Limitations of Evidence Base

### Inadequate Randomization and Concealment Allocation

Randomization procedures were rated inadequate in more than 25 percent of the randomized controlled trials (RCTs) we reviewed. Few studies used methods that ensured a chance assignment of participants in the treatment and control groups. Preset plans, alternation method, and hospital numbers were used in randomization schemes. Many studies failed to report how investigators achieved randomization. Only 25 percent of the RCTs reported adequate concealment allocation.

### Deficient Study Designs

In the absence of RCTs, particularly for studies on the effects of smokeless tobacco marketing on use and population harm, we accepted cross-sectional and cohort study designs. RCTs are the ideal, but, in some instances, more suitable study designs were appropriate for answering the KQs. Other study design deficiencies concerned control groups, recruiting, and power analyses. In about one-quarter of the studies, the control group was not adequately described. Studies lacked descriptions of comparison or control groups. A small number of studies employed convenience and volunteer samples, and studies rarely reported a power analysis.

### Refusal and Attrition Rates

Both refusal rates and attrition rates for tobacco cessation studies are quite high. Participants not ready to stop tobacco use will not participate, and those who do participate often drop out of studies because of noncompliance. Other issues contributing to refusal and attrition rates were parental refusal (i.e., tobacco prevention studies), relocation, discharge from hospital, and side effects of drugs. Investigators used intent-to-treat analysis in about two-thirds of the studies.

### Construct Validity Problems

Some intervention studies assessed tobacco use behaviors with a single item (e.g., “Have you smoked in the past 7 days?”). A single question measuring tobacco use may not provide adequate information about the key construct, tobacco use. Multiple items measuring tobacco use help to determine whether the behavior measured is actually the intended behavior.

Studies often used a single version of the prevention or cessation intervention in comparison with a control group. This creates a “mono-operation bias,” in which the results of the study reflect only the particular version of the intervention and not the actual construct. Implementing a single version of a program, in a single place at a single point in time, may not capture the full breadth of the concept of the program. Arguably, the results of the study reflect only the peculiar version of the intervention implemented, not the actual construct proposed.

### Reliability of Results

Biochemical verification was rarely used for tobacco prevention studies with adolescents. Randomized controlled trials, particularily pharmacotherapy studies, used biochemical verification such as expired carbon monoxide or salivary cotinine to verify self-reported tobacco use. Low response rates for expired carbon monoxide or salivary cotinine were reported. Although the reliability of self-reported data is assumed to be adequate for population-based studies on other topics, such data will typically underrepresent smoking status. Studies that used biochemical verification of smoking status did not routinely report statistics on discrepancies between self-report and biochemical verification. Often, investigators who used surveys and questionnaires to assess tobacco use, self-efficacy regarding quitting, perceived quitting intentions, and other variables did not document whether they (or others) had tested the instrument for reliability or other psychometric properties.

### Inconsistent Terminology

Studies lacked consistent and clear definitions of tobacco use. The definition of nonsmokers in KQ 1 ranged from “never smoked even one cigarette or a puff of one” to “no smoking in past 30 days” or “past 12 months” to “no intention of smoking in high school.” The definition of cigarette smoking in the other KQs ranged from “10 cigarettes per day on average over last year” to “having smoked greater than 100 cigarettes during a subject's lifetime” and “having smoked at least 1 cigarette in the last week.” This degree of variation in the dependent variable in smoking cessation studies makes comparing effect sizes across studies challenging if not impossible.

### Characteristics of Poor-Quality Studies

Table 16 documents the principal reasons for rating studies that we included and reviewed as poor quality. Only KQ 4 had all good or fair studies; KQ 2 had the highest number of poor studies. Problems with studies varied considerably, but we note in particular problems with study design (including selection of participants), lack of reporting of basic data (baseline; group comparisons), and attrition.

Table 16 Characteristics of studies rated poor quality

Intervention | Reasons for Rating
Design*
Sample Size
Key Question 1
Group counseling, social support^77^ | All methods (e.g., randomization, sampling) not well delineated
RCT | No baseline data reported
450 | analytical methods not well described
Video, classroom instruction^78^ | No baseline data reported
RCT | No treatment versus comparison data reported
3,038 | Post randomization exclusions
Key Question 2
Self-help materials^129^ | High attrition rate
RCT | No intention-to-treat analysis
918 | No power analysis
| Baseline differences
Self-help, computer-based program, telephone counseling, group counseling, social support, media campaign, individual counseling by health professional^111^ | Intervention group volunteer sample
Quasi-experiment | Control group care not reported
538 | Exposure to intervention low
| Findings not generalizable†
| High attrition
Self-help, individual counseling by health professional, social support^118^ | Self-selected sampling technique
Cohort study | Baseline differences regarding motivation to quit
110 | Incomplete reporting of data
Self-help, group counseling^108^ | Self-selection of intervention
Before/after study | Small group sample sizes
119 | High attrition rate
| No report of comparison of groups
| Findings not generalizableH
Individual counseling, | High attrition rate
Acupuncture^92^ | Completers analysis
RCT
141
Pharmaceuticals^110^ | High rate of noncompliance
RCT | High overall rate of attrition
1,384
Pharmacotherapy^93^ | Removed study participants perceived not to be motivated (similar to a “run-in period”)
RCT | Attrition moderately high
134 | Limited reporting on adverse events
| Randomization not described
Pharmacotherapy^126^ | Attrition rate not reported
RCT | Allocation to groups predictable
245 | No adverse events reported
| Poor randomization
Pharmaceuticals, group counseling^117^ | Large differences in baseline comparisons between white and black participants negate any conclusions from findings
RCT
5,887
Pharmacotherapy, cognitive behavioral counseling^96^ | Randomization not reported
RCT | No power analysis
150 | High attrition rate
| No adverse events reported
Pharmacotherapy, cognitive behavioral counseling^127^ | High attrition rate
RCT | Randomization not reported
248 | No adverse events reported
| No power analysis
Pharmacotherapy, self-help, counseling^128^ | High attrition rate
RCT | Lacked power
137 | Significant baseline differences not reported
Telephone quit line^94^ | High attrition rate
Cohort study | Confounded by “additional support”
1594 | Baseline data not reported for Proactive Treatment group
| No reliability or validity measures for instruments
| Inclusion/exclusion criteria not reported
Telephone counseling, group meetings^95^ | No true control group
RCT | Randomization not reported
756 | Population not described
| Inclusion/exclusion criteria not reported
| Intention-to-treat analysis not reported
Key Question 3
Video, telephone counseling, individual counseling by health professional, group counseling, social support, pharmaceuticals^155^ | Sampling not explained
Before/after study | No control group
299 | Limited generalizability^†^
Self-help, individual counseling by health professional, telephone counseling, video^156^ | Inadequate allocation of concealment and blinding
RCT | Contamination of usual care group
1,173 | Attrition not reported
Key Question 5
Group counseling, pharmaceuticals^153^ | Sampling technique not reported
RCT | Study criteria changed after one-third of participants recruited; post-randomization
3,976 | Attrition not reported
| Adverse events not reported
| No systematic measure of nicotine replacement therapy use among participants

* RCT, randomized controlled trial.

† Generalizability is noted but did not figure directly in the quality rating.

## Future Research Recommendations

Our review highlighted several gaps in the literature that could be addressed by future research and by improvement in methods. Future research should address the issues highlighted below.

### KQ 1. Effective Population- and Community-based Interventions to Prevent Tobacco Use in Adolescents and Young Adults

Population-based tobacco prevention programs. Future research in population-based tobacco prevention for adolescents and young adults needs to examine tobacco industry and product restrictions. In particular, how laws that regulate the content, labeling, promotion, and advertising of tobacco products affect adolescent and young adult tobacco use warrants greater attention. However, before tobacco prevention research in this area can move forward, changes in legislation are required. Continued research on whether enforcing tobacco youth access laws and regulations, when they are implemented community wide, can significantly reduce tobacco use support is important to build this body of evidence.

Other research using various combinations of population-based interventions may show that their effectiveness is greater than using interventions independently. Most important, future population-based studies on price increases, tobacco youth access laws and regulations, mass media campaigns, or tobacco industry and product restriction need to use control or comparison groups in their study designs to measure the impact that the intervention strategies have on the uptake of tobacco use among adolescents and young adults.

Community-based tobacco prevention programs. More community-based research that integrates an array of strategies such as community empowerment, dissemination of health education materials, media advocacy, youth antitobacco activities (e.g., contests, peer leadership programs), and letters to schools, parents, and tobacco retailers is urgently needed. Although sufficient evidence exists on the positive short-term effects of school-based tobacco prevention programs, more (and better-designed) studies demonstrating positive long-term effects will improve understanding of how best to prevent adolescents from initiating tobacco use. The approaches to tobacco prevention need to be comprehensive (e.g., combining school-based interventions with community mobilization, media campaigns, and enforcement of tobacco youth access laws and regulations). In general, the body of evidence for community-based tobacco prevention requires more rigorous research through adequate use of randomization, use of control groups without contamination or confounding issues, low attrition rates, and consistent and universal utilization of operationally defined outcome variables.

Provider-based tobacco prevention programs. Future research using providers as a conduit for tobacco prevention education should assess whether such settings are a viable place to implement tobacco prevention for adolescents and young adults. Because dental clinicians may be better suited for tobacco prevention, particularly in the case of smokeless tobacco use and for younger subjects, additional research in these settings is warranted.

### KQ 2. Effective Strategies for Increasing Consumer Demand for and Use of Proven Individually Oriented Cessation Treatment

Increasing the number of users who attempt to quit. Additional research will further our understanding of how to increase consumer demand for and use of individually oriented cessation treatment. The role of mass media in driving individuals to quit-line and other cessation services should be examined. Audience research on the effectiveness of specific messages in reaching and motivating target audiences such as adolescents, young adults, and persons with low income and educational status can inform and increase the impact of mass media. For expanding the use of quit-line or other telephone support services, future research should compare specific components of telephone counseling and their relative impact on enrollment and continuation in these services as well as their impact on individual motivation to quit and smoking status. Future research could investigate issues related to suitability and appropriateness of the services such as the number and timing of calls, the role of feedback to the caller's primary provider, and the participants' satisfaction with cessation services.

The relative population impact of various proven cessation interventions should also be examined. One example is to determine how proactive telephone counseling support compares with in-person intervention, regardless of whether nicotine replacement therapy is offered. Documenting whether differential rates of success and enrollment offset or enhance each other on a population basis will also be an important addition to the knowledge base. These research questions are especially important given the move toward provider referral to quit-line services.

Strategies to improve the success rate for quit attempts. To improve the success rate of cessation services, well-designed studies should examine the effectiveness of multiple intervention formats, of combination pharmacotherapy, and of adjuncts other than pharmacotherapy in comparison with individual counseling for all smokers and for special populations of smokers. Adjuncts to counseling could include patient incentives, biomarker feedback, and other approaches designed to increase the likelihood of quitting. Future studies should also examine ways to reduce withdrawal symptoms and cravings among those attempting to quit using tobacco products. Research on ways to minimize the side effects associated with use of various individual pharmacotherapies and combined pharmaceutical regimes is also needed. Identifying ways to increase the persistence of effect on smoking cessation over time also warrants further study.

### KQ 3. Effective Strategies for Increasing the Implementation of Proven Population-Level Tobacco Use Cessation Strategies, Particularly by Health Care Systems and Communities

Population-based implementation strategies. Some evidence, albeit inconsistent, suggests that interventions at the community level increase the implementation of tobacco use cessation strategies at the population level. Well-designed investigations should examine ways to reach out to smokers in the general population and to special populations such as adolescents and young adults with messages that motivate smokers and nonsmokers to become aware of, promote, and use existing cessation services.

Provider- and health care system-based tobacco use cessation strategies. Future research to improve strategies that providers and health care systems might employ should focus on well-designed studies of effective ways to change not only provider practice patterns but also related smoking cessation outcomes. To provide more awareness about what does and does not work with academic detailing, studies should assess the impact of academic detailing across and within practice types. At a minimum, future studies should incorporate all proven components of an academic model such as provider reminder systems.

Either within or separate from the academic detailing research, studies should explore how provider attitudes and smoking behavior affect provider use of effective interventions. Research is also needed to understand how other institutional barriers might hamper the adoption of effective strategies in health care settings and among providers. Better appreciation of the factors that affect incorporation of effective interventions into usual care is critical. More studies are also needed to understand how implementation of effective interventions by providers and/or health systems translates into increased abstinence from smoking.

### KQ 4. Effect of Smokeless Tobacco Product Marketing and Use on Population Harm From Tobacco Use

Smokeless tobacco marketing and use. The field of smokeless tobacco marketing and use is wide open for new research. Future research should investigate whether new tobacco industry marketing strategies are increasing use of smokeless tobacco, and, if so, whether the observed increase applies differentially to specific user populations. Of special importance is examining possible links between point-of-purchase tobacco promotion and advertising and increased use of smokeless tobacco among adolescents and young adults. We see many opportunities to build evidence in the area of smokeless tobacco product marketing; we advise researchers to advance this research with rigorous study designs.

Robust research has established links between use of smokeless tobacco and certain cancers.^1^ For that reason alone, future research should move away from investigating whether smokeless tobacco is a viable substitute for smoking and toward developing strategies to reduce its use. Research should continue to pursue possible treatments (i.e., counseling, pharmacotherapy) to assist or complement efforts aimed at smokeless tobacco cessation.

### KQ 5. Effectiveness of Prevention and of Cessation Interventions in Populations with Co-Occurring Morbidities and Risk Behaviors

Populations with psychiatric comorbidities and risk behaviors. Specifying the best approaches for smoking cessation treatment in populations with co-occurring morbidity and risk behaviors remains controversial. Because populations with these additional ailments and risk behaviors smoke at higher rates than others,^9,^ ^30^ successfully accomplishing therapy may require pharmacotherapy and tailored treatments.^9,^ ^113^

Investigators need to examine the effects of pharmacotherapy, particularily antidepressants alone or in combination with counseling, not only for people with a history of depression but also for people currently diagnosed with clinical depression. Additional pharmacotherapy studies using antidepressants such as fluoxetine alone or in combination with other nicotine replacement therapy will help determine whether rates of smoking cessation in psychatric and substance abuse populations can be improved (relative to those in the general population).^9^

Comprehensive research on concurrent versus delayed treatment for smoking cessation and chemical dependency is warranted in light of recent inconsistent results regarding adverse effects on sobriety or other drug use.^9,^ ^149,^ ^152^ Investigators need to determine the benefits gained from higher participation rates with concurrent treatment against the cost of the adverse effects and the lost opportunity to engage this elusive population with delayed smoking interventions.

Finally, barriers to smoking cessation treatment in patients with other health problems, such as contraindications of pharmacotherapy, and the validity of concerns on the part of clinicians about hindering sobriety should also be investigated.

### Methods Recommendations

Apart from the topics recommended above, we emphasize the need for investigators to use markedly better and more rigorous methods for all new research into tobacco prevention, control, and cessation. Essential scientific and technical improvements cut across many aspects of study design and conduct. Among the more critical are the following:

- Improved study designs using rigorous research methods such as control or at least adequate comparison groups, adequate randomization procedures, and tobacco use as the dependent variable for specific tobacco prevention strategies;
- Consistent definitions and measurement of baseline smoking status, abstinence, and continuous abstinence;
- Clear descriptions of interventions and comparison and control groups;
- Use and reporting of psychometrics of reliable and valid assessment instruments;
- Consistent definition of academic detailing;
- Use of biochemical validation of self-reported smoking status as appropriate;
- Use of intent-to-treat analysis; and
- Better methods of addressing drop-out and attrition, reporting power calculations, and taking loss to followup more into account in statistical analyses.

Finally, we note the absence of important documentation of study design, conduct, and other details in much of the literature reviewed. We hope that both investigators and those publishing their studies can find a way to provide more detail on methods, study populations, interventions, and the like, if not in published form then through web-based media.

## Conclusions

This review updates the literature found in previous systematic reviews. In most instances, the evidence in our review was consistent with that in those publications. On its own or in combination with findings from earlier reviews, the information from newer work is insufficient to draw new conclusions or conclusions different from those that prior reviews offered.

The new studies examining tobacco prevention for adolescents and young adults in our review found short-term effects for school-based interventions but no evidence to draw conclusions for long-term effects. Insufficient new evidence exists on population-, community-, and provider-based interventions for reducing tobacco initiation among adolescents and young adults.

Findings from studies in our review, although insufficient in number and quality to draw conclusions on their own about the effectiveness of multicomponent strategies such as telephone counseling, are consistent with previous reviews indicating the efficacy of these approaches.

Studies in our review of strategies to improve the success of quit attempts were consistent with previous reviews. Fundamentally, self-help strategies alone are not efficacious; counseling, pharmacotherapies either alone or in combination, or pharmacotherapies combined with psychological counseling all increase the likelihood of successful quitting.

When considering interventions for special populations, we found results both consistent and inconsistent with prior reviews. When evaluating interventions with hospitalized patients by diagnosis, studies in our review agreed with findings of a prior review showing that there was no strong evidence that clinical diagnosis affects the likelihood of quitting.^63^ Results of our review were inconsistent with two prior reviews indicating that hospitalized patients were more likely to quit smoking as intensity of the intervention increased.^5,^ ^63^ Although some studies in our review found significant gains in abstinence in the short term, all studies showed an absence of effect at 12-month assessment. The findings of our review remain consistent with those of prior reviews showing that counseling does increase the likelihood of abstinence among pregnant smokers. Investigators found quit rates for indigenous Maori in New Zealand to be similar to those observed in other trials of bupropion.^114^

Consistent with earlier findings, we also found insufficient evidence of effectiveness for population-based interventions to increase implementation of proven cessation strategies. Sufficient evidence in our review indicated that implementing provider-based interventions, such as training, and health systems-based interventions, such as academic detailing, improved provider delivery of cessation treatment, but the information was insufficient to conclude that implementing these approaches leads to higher quit rates.

We found no evidence on how smokeless tobacco product marketing affects population harm and only insufficient evidence on whether smokeless tobacco product marketing increases use and leads users to substitute smokeless tobacco for smoking.

Our review found no evidence for tobacco prevention in populations with co-occurring morbidities and risk behaviors. Consistent with other reviews, we found some support for pharmacotherapy and/or counseling, but the evidence was insufficient in number and quality to draw conclusions about the effectiveness of smoking cessation interventions in comorbid populations. Taken as a whole, this clearly illuminates the need for better studies to close these gaps.

We documented numerous gaps in the existing knowledge base and deficiencies in the design and conduct of currently available studies and recommend a variety of research initiatives to overcome these limitations.