# Results

This chapter presents results of our literature search and our findings for five key questions (KQs) regarding tobacco prevention, cessation, and control. These form the background for a State-of-the-Science (SOS) conference scheduled for June 12–14, 2006, under the auspices of the Office of Medical Applications Research (OMAR) of the National Institutes of Health (NIH). We report here on the following issues:

- KQ 1, initiation of tobacco use among young people;
- KQ 2, demand for and use of cessation treatments;
- KQ 3, increasing use and implementation of health care and community cessation programs;
- KQ 4, impact of smokeless tobacco product marketing on use, and
- KQ 5, cessation treatments for individuals with comorbidities and risk behaviors.

KQ 6 is covered in Chapter 4 and deals with the limitations of these bodies of literature and our recommendations for future research.

We discussed specific approaches for the first three KQs with our Technical Expert Panel (TEP) because, as noted in Chapter 2, we had a considerable pool of existing publications on which to draw. In each section below, we report first on previous reviews that covered the KQ, then on specific details about the yields of the literature searches and characteristics of the studies, and finally on literature pertaining to each question. Where appropriate, we provide summary tables presenting selected information on each included study that had a quality rating of good or fair.

Appendix C * contains all the full evidence tables for each question. Evidence tables are organized by major analytic topic; studies are then listed alphabetically by author. A glossary at the beginning of the appendix defines all acronyms and abbreviations appearing in the tables. If several articles report on a single study, they are grouped in a single entry (row); if a study or article has information concerning more than one KQ, it appears in every relevant evidence table.

* Appendixes cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/tobusetp.htm.

## Results of Literature Searches

Our literature searches yielded 1288 possible articles (see Figure 3). (Appendix A presents the search terms and yield for each database searched in June 2005.) Beginning with the 1,288 titles and abstracts, we excluded 642 entries at the abstract level because it was apparent that they did not meet our inclusion criteria.

Figure 3. Tobacco use: prevention, cessation, and control article disposition

To focus our review on the most rigorous research and avoid duplicating previous reviews, we did a cross-walk (i.e., checked for duplicate articles) between the 644 citations and the citations from related systematic reviews and meta-analyses (Table 5). Articles that overlapped with systematic reviews and meta-analyses are listed in Appendix D. This process further narrowed the pool to 488 articles, which we then pulled and fully reviewed. Of the reviewed articles, 102 studies were included in this report. Table 5 lists the systematic reviews, meta-analyses, and dates of included literature used as a basis for topics equivalent to KQs 1, 2, 3, and 5.

Specifically, the following publications have extensively covered tobacco prevention and cessation intervention strategies in diverse populations:

- The Guide to Community Preventive Services (2005),
- Treating Tobacco Use and Dependence (2000),
- Reducing Tobacco Use, A Report of the Surgeon General, (2000),
- The Cochrane Collaboration reviews (1998-2005),
- Treating nicotine use and dependence of pregnant and parenting smokers, (2003),
- A meta-analysis of smoking cessation interventions with individuals in substance abuse treatment or recovery (2004),
- Smoking cessation approaches for persons with mental illness or addictive disorders (2002), and
- Growing up tobacco free: preventing nicotine addiction in children and youths (1994).

The cross-walk identified 156 common citations. Because these reviews served as the starting point for the evidence-based report, we did not abstract the 156 shared citations.

We included original research studies that (1) were published beyond the date range included in the systematic reviews, (2) concerned topics related to the questions not covered by the reviews, and (3) provided sufficient detail regarding their methods and outcomes. The approaches for each specific question are as follows. For KQ 1, we included studies published between January 1, 2000, and June 10, 2005, that addressed topics 1 through 4 in Chapter 2. We also relied on the synthesis of previous reviews and meta-analyses for research and recommendations published before 2000. We included all primary data collection studies that addressed product restrictions in the tobacco industry (i.e., laws that regulate the content, labeling, promotion, and advertising of tobacco products), which represents subjects that the other systematic reviews did not cover. For KQ 2 and KQ 3, we included studies published between January 1, 1999, and June 10, 2005. We relied on the synthesis of past reviews and meta-analyses for research and recommendations published before 1999. For KQs 4 and 5, we included research found between January 1, 1980, and June 10, 2005, pertaining to the specific question.

## KQ 1. Effective Population- and Community-Based Interventions to Prevent Tobacco Use

The primary goals of population- and community-based interventions are to prevent or delay experimentation with tobacco and to prevent the transition from experimentation to regular use. Additionally, these interventions motivate and encourage people to quit. For the purpose of this report, population-based interventions employed traditional population sampling techniques such as random-digit dialing, and nationwide surveys to recruit participants and collect data. These interventions are easily generalizable to large groups of people. Community-based interventions are directed at a distinct segment of society that shares similarities or fellowship, and generalizability is limited by the uniqueness of the community studied.

As shown in our analytic frameworks for KQ 1 (in Chapter 2), we examined the effectiveness of population- and community-based strategies to prevent tobacco use by reducing tobacco initiation among adolescents and young adults. Prevention of tobacco use is measured by differences or changes in (1) self-reported tobacco use among adolescents and young adults, (2) self-reported purchases of tobacco products, (3) tobacco obtained from commercial sources (e.g., vending machines), and (4) retailer sales of tobacco products to minors.^7^

### Population-Based Interventions to Limit Access and Reduce Initiation

Nicotine addiction begins at an early age; 89 percent of adult daily smokers have tried cigarettes before age 18.^32^ In 2004, current use of tobacco was reported by 28 percent of high school students and 11.7 percent of middle school students.^8^ Cigarettes are the most commonly used tobacco product for both middle and high school students.

Population-based intervention efforts to reduce tobacco use initiation among adolescents and young adults include at least four mechanisms: (1) increases in the unit price of tobacco products; (2) laws that regulate and enforce bans on sales, purchases, and consumption of tobacco products by underage youth; (3) laws that regulate the content, labeling, promotion, and advertising of tobacco products; and (4) mass media education campaigns.

Synthesis of prior systematic reviews. Past reviews have evaluated interventions to limit access to tobacco products and reduce tobacco use initiation among adolescent and young adults. They include (1) increasing the unit price of tobacco products, (2) enforcing tobacco laws and regulations, (3) implementing tobacco industry and product restrictions, and (4) disseminating mass media campaigns.^2,^ ^7,^ ^32,^ ^33^

Increasing the unit price of tobacco products. An increase in the excise tax on tobacco, which requires passage of legislation or a statewide referendum, results in an overall increase in the cost of tobacco products. For adolescents and young adults with limited incomes, higher prices make cigarettes less attractive.^7^ Several earlier reports agree on the positive effects of economic approaches to reducing tobacco initiation.^2,^ ^7,^ ^32^ Recommendations from the Institute of Medicine state that a tax increase of $2.00 for each pack would make tobacco less accessible and raise money for tobacco control, health care, and other uses. Unit price has a direct influence on the demand for cigarettes.^2^ Eight studies that evaluated intervention strategies that increased the price of tobacco products provided price elasticity of demand estimates by combining information on local tobacco product prices and price changes or differences in survey responses over time on tobacco use and consumption.^7^ A 10 percent price increase in tobacco prices results in an approximately 4 percent decrease in consumption of tobacco products by adolescents (13 to 18 years of age). A similar strong effect is found for young adults (18 to 24 years of age).^7^

Enforcing tobacco laws and regulations. Minors obtain tobacco from retailers (merchants), commercial sources (vending machines), and social sources (other adults); all contribute to initiation and regular use of tobacco.^7^ Restricting distribution, regulating the mechanisms of sale, enforcing minimum age laws, and providing merchant education and training have some success in reducing minors' access to tobacco.^2^ Multicomponent interventions designed to reduce minors' access to tobacco include numerous strategies: stronger restrictions on retailer sales of tobacco products; restrictions directed at youth purchases, possession, and use; active reinforcement of tobacco sales laws; and retailer education interventions with or without reinforcement.^7,^ ^32^ Thirteen multicomponent studies, with 10 different combinations of interventions, investigated how restricting minors' access to tobacco affects tobacco initiation. Only five of these studies used differences or changes in tobacco use among youth as the outcome variable. Four of the studies coordinated community mobilization efforts with retailer education with enforcement, stronger local ordinance for retailers, enforcement of retailer sales laws, school-based education, or local ordinances directed at youth tobacco purchase, possession, or use.^7^ Interventions to reduce youth access to tobacco products that combined two or more interventions in a coordinated effort decreased students' self-reported tobacco use by 5.8 percentage points over a period of 2 to 4 years.^7^

Tobacco industry and product restrictions. In 1998, the Master Settlement Agreement prohibited tobacco advertising that targets people under 18 years of age. Despite this agreement, tobacco companies consistently allocate a higher proportion of their expenditures for advertising of youth brands to youth-oriented magazines.^67^ Reviews on tobacco industry and product restriction are still in progress.^31^ Strategies for regulating tobacco packaging, labeling, and contents are long-term steps, recommended by the Institute of Medicine Committee on Preventing Nicotine Addiction in Children and Youths,^32^ to sustain progress toward reducing health consequences of tobacco use. Warnings on cigarette packages in the United States are weaker and less conspicuous then those in other countries. In addition, purchasers of tobacco do not receive information about toxic constituents in tobacco smoke. To protect adolescents and young adults from inducement that might influence their decision to start smoking, implementing stricter regulations on packaging, advertising, and promotion is imperative and will likely reduce both prevalence and uptake of tobacco use.^2^

Mass media education campaigns. Mass media education campaigns disseminate brief recurring messages with the intent of providing information that will motivate children and adolescents to remain tobacco free.^7^ Campaign methods include broadcast messages on television and radio, billboards, print, and movies. Media campaigns increase awareness of the strategies that the tobacco industry uses to promote tobacco and they attempt to facilitate changes in both tobacco use behaviors and public tobacco policies. They also use educational messages relating to demand reduction to provide information and support to adolescents to help them decide to remain tobacco free.^7^ Reviews of mass media campaigns and community interventions that include a media component report some evidence that these are effective, particularly when combined with other intervention activities such as school- and community-based education programs and increases in excise taxes on tobacco.^33,^ ^64^

A review of 12 studies evaluated the effectiveness of mass media campaigns in reducing tobacco use among adolescents.^7^ The studies conducted the media campaign in conjunction with other intervention strategies such as school- and community-based educational programs, contests, and increased excise taxes. Mass media campaigns conducted concurrently with other interventions generally showed reductions of tobacco use among youth in the intervention communities. Five of these studies reported absolute differences in self-reported tobacco use. The media campaigns decreased the number of adolescents using tobacco by approximately 2.4 percentage points.^7^ Campaigns that last 2 years increase the effectiveness of the campaign.

Synthesis of current literature. Fifteen original studies examined interventions designed to reduce tobacco initiation among adolescents and young adults (KQ 1).^68^–^82^ In reviewing these studies, we used a three-level component rating scale to assess the quality of each study. We rated them good, fair, or poor based on the rigor of the study design and how well the study was conducted. Quality review ratings for KQ 1 consisted of 1 good rating, 12 fair ratings, and 2 poor ratings (poor ratings had one or more fatal flaws in design or conduct of the study). Therefore, we discuss 13 studies for KQ 1. Information on the two studies we rated as poor are in the evidence tables (Appendix C).^†^ We organized the KQ 1 studies by population-based (Evidence Table 1), school-based (Evidence Table 2), and provider-based interventions (Evidence Table 3).

† Appendixes cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/tobusetp.htm.

Population-based interventions to reduce tobacco initiation. Two of the 13 studies were population-based.^73,^ ^79^ As shown in Table 6, the studies were conducted in the United States and received quality ratings of fair. Sample sizes ranged from 1,316 to 3,831 adolescents ages 12 to 17. One study addressed youth access, specifically youth access ordinances and regulations,^79^ and the other was an intervention designed to prevent adolescent tobacco and alcohol use by targeting family risk factors.^73^

Table 6 Effective population-based interventions

Author Year | Design | Intervention | N | Results | Quality Rating
Setting | Exposure
| Followup
Ennett et al., 2001^73^ | RCT | G1: Booklets mailed to parents followed by telephone discussion with health educator and parents | 1,316 adolescent- parent pairs (adolescents ages 12–14 years) | Effects present for non- Hispanic whites only (n=791) | Fair
United States | 4 mailings over 14 months | C1: Did not receive “Family Matters” program | | Adolescents in the control group were more than 1.5 times as likely to smoke at the 3-month followup than adolescents in the intervention (OR, 1.59; P = 0.008, lower bound CI, 1.19 for a one-way test of significance)
48 contiguous states | 3 and 12 months | | | Program parents were more likely to discuss peer and media influences and set rules about smoking
Thomson et al., 2004^79^ | Cross-sectional | G1: parent involvement in community-level tobacco ordinances | 3,831 youth (12–17 years) | Youth living in towns that ban free-standing displays were less likely to perceive tobacco as easy to purchase (AOR, 0.6; 95% CI, 0.5–0.9; P = 0.007) | Fair
United States | NA | | | Increased perceived access was associated with being older (P < 0.0001) and male (P ≤ 0.002)
Boston, MA | NA

AOR, adjusted odds ratio; C1, control group; CI, confidence interval; G1, intervention group 1; NA, not applicable; NR, not reported; OR, odds ratio; RCT, randomized controlled trial.

We did not find studies implementing other prevention strategies related to unit price of tobacco products, tobacco industry and product restrictions, or media campaigns alone or in combination with other tobacco prevention interventions. With the exception of tobacco industry and product restrictions, these interventions have been covered extensively in past systematic reviews. New studies investigating these topics either did not meet our inclusion criteria, in particular did not report on the outcome variable for KQ 1 (i.e., reduced initiation of tobacco use among adolescents and young adults), or are not in publication.

Restricting adolescents' access to tobacco products is a population-based intervention aimed at reducing tobacco initiation. A study using Massachusetts statewide youth tobacco access ordinances and regulations examined the effects of these provisions on youth perceived access to tobacco products, youth purchase attempts, and youth tobacco use.^79^ In this cross-sectional study, the investigators surveyed youth from across Massachusetts using a random sample of households. Interviewers collected demographic data from the adult resident, screened for eligibility, and requested permission to interview all youth in the household between the ages of 12 and 17. After excluding inconsistent reports of resident's town, zip code, or telephone exchange and towns having no identified youth respondents, interviewers collected data from 3,831 participants in 314 towns. The Massachusetts Tobacco Control Program produces a biannual report on six provisions of youth access ordinances from each town:

1 Licensing (requires retailers to have a license to sell tobacco products),
2 Fines for merchants who sell tobacco products to minors;
3 Vending machine restrictions (a complete ban or restricted to adult-only establishment)
4 Ban on free-standing displays of tobacco products
5 Ban on sale of single cigarettes and
6 Ban on distribution of free samples.

The six provisions were used as predictor variables in the analysis. Additionally, a measure of antismoking sentiment provided a baseline measure in each town before expansion of the local youth access ordinance. The antismoking measure was highly correlated with the town-level socioeconomic measure. The outcome variables were dichotomous; smoking status was defined as “ever smoker” (has smoked or puffed a cigarette in one's lifetime) or “current smoker” (has smoked at least one cigarette in the past 30 days).^79^

In the fully adjusted model, only two provisions were statistically significant and only one in the expected direction. Youth living in towns that ban free-standing displays were less likely to perceive tobacco as easy to purchase (adjusted odds ratio [AOR], 0.6; 95% confidence interval [CI], 0.5–0.9; P = 0.007). Counterintuitively, youth reported easy access in towns that required tobacco vendors to have a license (odds ratio [OR], 1.3; 95% CI, 1.1–1.5; P = 0.009). Overall, 37 percent believed that it was easy to buy cigarettes in their town. No associations were found between youth access ordinances and attempts to purchase or between ordinances and tobacco use. Individual factors associated with increased attempts to purchase were associated with being older (P≤ 0.01) and male (P = 0.004). Individual factors associated with tobacco use were being older, living with a smoker, and having a close friend who smokes (P < 0.0001).^79^

The second population-based study enrolled 1,316 adolescent-parent pairs throughout the contiguous United States through random-digit dialing into a family-directed program called Family Matters.^73^ Pairs completed baseline interviews by telephone, were matched with another pair by date and time of completion, and were randomly assigned to either receive the Family Matters program or serve as controls. This program used both global attributes of families, such as supervision and attachment, and substance-specific family characteristics, such as parental drug use, to reduce tobacco initiation. The program assumes that changing global family characteristics (supervision, supportiveness, involvement, and communication) and substance-specific characteristics (parent expectations and attitudes toward child's drug use; parental monitoring, rules, and encouragement about drug use; availability of and outside influences regarding drugs; parental drug use) will change a third domain—adolescent cognitions regarding drug use and, in turn, will ultimately influence adolescent use.^73^

The investigators completed successive mailings of four booklets to parents and their 12- to 14-year-old children between July 1996 and September 1997 (1 year and 2 months). Following each mailing, telephone discussions occurred between parents (or guardians) and health educators. Families who completed the program spent an average of 4.5 hours doing the program; parents spent an additional hour talking with the health educator by telephone. The program measured exposure to the Family Matters program, adolescent tobacco and alcohol use, three sets of mediator variables, and sociodemographic characteristics at 3- and 12-month followups. Self-reported smoking status, without biochemical verification, categorized never-smoked adolescents as nonusers and adolescents who smoked even a puff of a cigarette as users.^73^

Baseline data showed fewer non-Hispanic whites students in the Family Matters intervention than in controls. The effects of the intervention were present only among non-Hispanic white adolescents—a subset of the population (n = 791). Adolescents in the control group were more than 1.5 times as likely to smoke at the 3-month followup assessment than adolescents in the Family Matters intervention (OR, 1.59; P = 0.008, lower bound CI = 1.19 for a one-way test of significance). No significant effects were evident at the 12-month followup. The conceptual model underlying the Family Matters program was validated for non-Hispanic whites only.^73^

### Community-Based Interventions to Prevent Tobacco Initiation

Community-based interventions are coordinated, widespread programs in a particular geographic area, such as a school district, or in a grouping of people who share common interests or needs.^64^ The Surgeon General's report on Reducing Tobacco Use ^2^ and two Cochrane reports on school-based programs and community interventions review smoking prevention strategies for young people.^34,^ ^64^

Synthesis of prior systematic reviews. Previous reviews have found limited support for school- and community-based interventions to reduce tobacco use initiation among adolescents and young adults.^34,^ ^64^ No prior systematic reviews were identified for provider-based interventions. School-based interventions reviewed include various educational strategies. Examples include classroom programs or curricula that provided information, used social influence approaches, and taught social competence. These programs often moved beyond the school population to involve parents and the community.^34^ Community-based interventions for preventing smoking among young people integrate an array of strategies such as community empowerment, dissemination of health education materials, media advocacy, youth antitobacco activities, contests, letters to schools and parents, school programs, and use of peer leaders to raise awareness and discourage tobacco use.^64^

School-based smoking prevention programs. Schools in the United States have existing tobacco use prevention policies and programs, but current interventions are not optimal. Effective educational strategies conducted in conjunction with other interventions such as mass media and community activities, can postpone or prevent smoking onset in 20 percent to 40 percent of adolescents.^2^ Such multifaceted programs reach adolescents on multiple levels by enlisting the positive influences of parents, community organizations, the mass media, and school programs.

An extensive review of all randomized controlled trials (RCTs) of behavioral interventions in schools to prevent tobacco use (ages 5 to 12 and 13 to 18) identified 16 studies of acceptable quality.^34^ The various strategies included information-giving methods, social influence approaches, generic skills training, and community interventions. Short-term positive effects were found in eight studies; however, no long-term effects were significant. Long-term is defined as 2 years after the end of the program; anything less than 2 years was considered a short-term effect.^34^

Community-based smoking prevention interventions. Some support exists for the premise that community interventions are effective at reducing the uptake of tobacco in young people. Of 13 studies comparing community interventions to no interventions, only 2 showed lower smoking prevalence. A comparison of a multicomponent community intervention with a community receiving a mass media campaign alone also showed a lower rate of smoking prevalence. Three studies compared community interventions to school-based interventions, but only one found differences in reported smoking prevalence.^83^

Synthesis of current literature. Of the 13 studies addressing KQ 1, 10 involved school-based efforts^68^–^72,^ ^74^–^76,^ ^81,^ ^82^ and 1 tested a provider-based intervention.80 Sample sizes ranged from 26 to 99 schools and 103 to 8,352 participants. These studies were conducted in the United States (5), the Netherlands (2), Australia (1), Canada (1), Norway (1), and the United Kingdom (1). We rated one study as good and the rest as fair.

Community interventions have been covered comprehensively in past systematic reviews.^2,^ ^64^ We did not identify any community-based tobacco prevention studies; those that we learned about either did not meet our inclusion criteria or are not yet in publication.

School-based interventions to reduce tobacco initiation. An effective method for reaching adolescents and young adults is to use school systems. Implementing tobacco prevention interventions in schools is convenient and allows for both optimum exposure of the intervention strategies and regular assessment of effectiveness. The school-based tobacco prevention studies in this report are heterogeneous in terms of prevention strategies, definitions of tobacco use, and length of follow-up assessments. Biochemical verification of self-reported smoking status, unless otherwise stated, was not used in these studies. Virtually all the studies defined smoking status differently.

Table 7 lists the various definitions of abstinence and tobacco use in the 10 school-based tobacco prevention studies reviewed. Interventions that sustain significant outcomes 2 years after the end of the intervention are considered to have long-term effects. School-based tobacco prevention programs were divided by length of exposure. Programs were implemented either within a single school year or over multiple school years. Single-year interventions are discussed first, followed by multiple-year interventions.

Table 7 School-based tobacco prevention program smoking status definitions

Author/Year | Smoking Status | Definition of Smoking Status
Single-School-Year Smoking Prevention Programs
Ausems et al., 2004^68^ | Never smoker | Never smoked a cigarette or even took a puff of a cigarette
| Noncurrent smoker | Smoked in the past but not in the past month
| Current smoker | Smoked during the past month
Aveyard et al., 2001^69^ | Nonweekly smoker | Smoked less than one cigarette per week
| Regular weekly smoker | Smoked at least one cigarette per week
Crone et al., 2003^71^ | Nonsmoker | Never smokers, experimenters that no longer smoke, and quitters
| Smoker | Smokes at least once a week or less than once a week and experimenters that continue to smoke
Perry et al., 2003^75^ | Nonsmoker | Not specified
| Current smoker | Measured by amount of current tobacco use (response categories not specified)
Unger et al., 2004^81^ | Nonsmoker | Never smokers
| Smoker | Tried smoking between 6th and 7th grade
Multiple-School-Year Smoking Prevention Programs
Brown et al., 2002^70^ | Never smoker | No history of smoking
| Tried once | Tried once
| Experimental smoker | Smoked less than once a week
| Quit | Smoked and quit
| Regular | Smoked weekly
Ellickson et al., 2003^72^ | Ever smoker | Lifetime use
| Past-month smoker | Frequency of use within past month
| Weekly Smoker | Frequency of use within past year
Josendal et al., 2005^74^ | Nonsmoker | Nonsmokers and smoked less than weekly
| Smoker | Smoked daily or weekly
Schofield et al., 2003^76^ | Nonsmoker | Did not smoke within the past 7 days
| Smoker | Smoked within the past 7 days
Winkelby et al., 2004^82^ | Nonsmoker | Never smoked or former tobacco smokers

Five school-based interventions were conducted within a single school year.^68,^ ^69,^ ^71,^ ^75,^ ^81^ As shown in Table 8, these interventions used classroom instruction, computer-based programs, competition, parent involvement, community advocacy, and personalized letters. Students were in grades six through eight in middle, lower secondary, and vocational schools.

Table 8 Effective school-based interventions

Author Year | Design | Intervention | N | Results | Quality Rating
Setting | Exposure
| Followup
Single School Year Interventions
Ausems et al., 2004^68^ | RCT | G1: In school: 3 lessons | 36 schools | At 12 months, the in-school intervention prevented more students from continuing to compared with controls | Fair
The Netherlands | 5 months | G2: Out of school: 3 tailored letters | Number of students not reported | (OR = 0.49, 95% CI, 0.29 – 0.84)
Middle and high (school level); vocational schools | 6, 12, and 18 months | G3: Both | | At 18 months, the tailored letters intervention prevented more smoking initiation compared with the controls
| | C1: Control, not described | | (OR = 0.42, 95% CI, 0.18 – 0.96)
Aveyard et al., 2001^69^ | RCT | G1: 3 computer-based program lessons with videos and 3 classroom lessons related to Transtheoretic Model | 52 schools | At 1- or 2-year followup, no evidence of change in stage or regular smoking | Fair
United Kingdom | Up to 6 sessions over an academic year | C1: Standard lessons | 8,352 students
Adolescents (ages 13 to 24) living in West Midlands | 1 and 2 years
Crone et al., 2003^71^ | RCT | G1: 3 classroom lessons on knowledge, attitudes, and social influence | 26 schools | At 20 months, nonsmokers who became smokers increased less in intervention groups than control group, the program successfully decreased smoking for regular smokers and maintained nonsmoking for nonsmokers versus control | Fair
The Netherlands | 8 months | C1: Usual drug prevention program | 2,562 students | Those with perceived social pressure were more likely to be smokers
Lower secondary schools | 8 and 20 months
Perry et al., 2003^75^ | RCT | G1: D.A.R.E. curriculum taught by police officers (10 sessions) | 24 schools | D.A.R.E. Plus significantly less likely than D.A.R.E. to show an increase in current smoking or intentions to use tobacco for boys | Fair
United States | 8 months | G2: G1 plus D.A.R.E. Plus—peer led, parental involvement in extracurricular activities | 6,237 students | No significant differences for girls
Middle and junior high schools in Minneapolis/St. Paul, Minnesota | 8 and 20 months | Control: Delayed program—D.A.R.E. offered in next school year
Unger et al., 2004^81^ | RCT | G1: 8 weekly classroom sessions by health educators relating smoking issues to several cultures | 16 schools | Overall, intervention effect was not significant | Fair
United States | 8 weeks over an academic year | C1: Without the cultural references | 1,970 students | Hispanic boys in the intervention group were less likely to report ever smoking at 1 year followup than the control group
6th and 7th graders in Southern California | 12 months
Multiple School Year Interventions
Brown et al., 2002^70^ | RCT | G1: Extracurricular activities, teacher-facilitated | 30 schools, | Male never smokers at baseline in the intervention group were significantly less likely to become “regular” smokers in 10th grade than controls | Fair
Canada | Students receiving tobacco prevention in elementary schools recruited for intervention in 9th and 10th grade | C1: Usual care | 2,776 students | No significant effect for females
High schools (9th and 10th grades) | At the end of each academic year
Ellickson et al., 2003^72^ | RCT | G1: 11 interactive teaching lessons in 7th grade, and 3 lessons in 8th grade, booster lessons in 9th and 10th | 55 schools 4,276 students | Treatment results for G1, G2 combined through 8^th^ grade; other results NR | Fair
United States | NR (11 lessons in 7th grade and 3 lessons in 8th grade) | G2: Same as G1 but no booster sessions | | At 18 months, cigarette initiation rates in G1+G2: were significantly lower than in the controls
Urban, rural, and middle schools in South Dakota | 18 months | C1: Regular prevention curriculums | | Project ALERT significantly reduced proportion of new smokers
Josendal et al., 2005^74^ | RCT | G1: Classroom (5 times per year), teacher in-service, parental involvement | 99 schools | Full program (G1) had significantly fewer smokers than controls across all 3 years | Good
Norway | Minimum class and lessons 5 times per year: 8 hours in 7th grade; 5 hours in 8th grade; 6 hours in 9th grade | G2: Same as GI, but no teacher in-service course | 4,223 students | Intervention without the parental involvement or the teacher in-service (G2 or G3) had significantly fewer smokers than the controls
7th to 9th grade schools | End of each academic year—7th, 8th, 9th grade | G3: Same as GI, but no parental involvement | | Odds of becoming a smoker (daily, weekly, any) during the intervention period were significantly lower in the full program group (G1) than in the controls
| | C1: Education on smoking and health, but about half of the number of hours as in G1 or G2
Schofield et al., 2003^76^ | RCT | G1: Self-help, group counseling, social support | 22 schools | Proportion of students who smoked in past 7 days did not differ significantly by treatment condition, intervention not effective | Fair
Australia | 2 school years | C1: Offered and received none of the experimental activities | 1,852 students | Significantly greater improvement in smoking knowledge for the intervention group compared with the control
7th to 10th grades in New South Wales school district | 24 months | | | Positive attitudes toward smoking significantly decreased among smokers
Winkelby et al., 2004^82^ | RCT | G1: Three-phase advocacy and empowerment | 10 continuation high schools | Regular smokers had greatest statistically significant net decrease in tobacco use | Fair
United States | Weekly lessons and activities over an academic semester | C1: Existing substance abuse curriculum, not specific to tobacco | 813 students | No differences in nonsmokers at baseline between intervention and control groups in uptake of smoking at followup
High Schools (11th or 12th grades) in San Francisco and San Jose, California | At the end of each semester and 6 months after the end of the semester

C1, Control Group; D.A.R.E., Drug Abuse Resistance Education; G1, intervention group; RCT, randomized controlled trial

One study implemented the intervention in a primarily Hispanic population,^81^ another in primarily non-Hispanic, white populations,^75^ and the other studies did not specify ethnicity of the population studied.^68,^ ^69,^ ^71^ The sample size for the five studies implementing within-school-year interventions ranged from 16 to 52 schools and 1,970 to 8,352 students.

The length of exposure students received was as short as 8 weeks^81^ and as long as 8 months.^75^ Followup assessments ranged from 6 months to 24 months. All prevention strategies included classroom lessons that included educational instruction typically combined with one or several other activities such as group discussion, role-play, videos, skills training, or computer-based lessons.^68,^ ^69,^ ^71,^ ^75,^ ^81^ Drug Abuse Resistance Education (D.A.R.E.), a well-known, school-based tobacco prevention program in the United States, also included parent involvement and a community youth action team in the multicomponent intervention.^75^

Three single-year smoking prevention programs compared their effects with those in control groups that received either standard smoking information, the original drug prevention program already in place, or the same classroom lessons without cultural sensitivity.^69,^ ^71,^ ^81^ An 8-month prevention program used educational strategies and competition to reduce tobacco initiation in 26 lower secondary education (mean age 13) schools in The Netherlands.^71^ Three lessons on knowledge, attitudes, and social influences were followed by a class agreement either not to start smoking or to stop smoking for the next 5 months. To increase students' motivation, the National Institute Against Smoking rewarded classes in which less than 10 percent of the students were smokers at the end of the 5 months; it also conducted a photography contest to find the best photograph that expressed a nonsmoking class.^71^

Smoking status measured by self-report was assessed at baseline, at the end of the intervention, and at 1-year followup. At the end of the intervention, the proportion of nonsmokers who became smokers had increased less in the intervention group (9.6 percent) than in the control group (14 percent) (OR, 0.61; 95% CI, 0.41–0.90). The proportion of smokers had also increased significantly less in the intervention group (2.6 percent) than in the control group (7.9 percent) (OR, 0.62; 95% CI, 0.43–0.90). The groups did not differ significantly at 1-year followup.

Aveyard et al. implemented a computer-based tobacco prevention intervention in 52 schools in West Midlands, United Kingdom.^69^ During school year 9, students ranging in age from 13 to 14 years received three class lessons and three interactive computer sessions (including video clips of young people discussing their smoking). The intervention continued throughout the ninth-grade year; the investigators administered a self-report questionnaire at baseline and at years 1 and 2.^69^ At followup in years 1 and 2, the intervention and control groups did not differ significantly in effect (year 1: AOR, 1.14; 95% CI, 0.93–1.39; year 2: AOR 1.06; 95% CI, 0.86–1.31).^69^

Project FLAVOR (Fun Learning about Vitality, Origins, and Respect), a school-based program that incorporates a curriculum sensitive to multiple cultures, focused on psychosocial risk factors to prevent tobacco initiation in eight of 16 middle schools in Southern California.^81^ The students were predominantly Hispanic (57 percent) and Asian American (27 percent) sixth and seventh graders. The culturally sensitive intervention programs provided eight weekly classroom sessions conducted by health educators that addressed smoking-related psychosocial concepts through activities such as role-playing, trivia games, and art projects.^81^

Students were surveyed at baseline and at 1-year followup. Overall, 8 percent of the intervention group and 11 percent of the control group initiated smoking (OR, 0.75; 95% CI, 0.48–1.18), but this difference was not significant. For one subgroup—Hispanic male never smokers—the intervention prevented smoking initiation between the two grades (OR, 0.49; 95% CI, 0.27–0.88).^81^

Two single-school-year smoking prevention programs compared classroom instruction to an alternative, more innovative tobacco prevention program.^68,^ ^75^ Vocational students (mean age 13) in 36 schools in The Netherlands participated in an in-school and out-of-school intervention to reduce tobacco initiation.^68^ The in-school and out-of-school interventions and a combined in- and out-of-school intervention were compared with a control group (not described). The in-school intervention had three classroom lessons consisting of educational instruction by the teacher reading from the workbook, a classroom discussion, a workbook task, and an additional task that summarized the main points of the lesson. The out-of-school intervention comprised three tailored letters with smoking prevention messages; the letters were illustrated with a picture puzzle and several cartoons. It also included a competition in which students could win CD vouchers. The letters were mailed to students' homes at 3-week intervals.^68^

Students' self-reported their smoking status at pretest and 6, 12, and 18 months following the intervention. Immediate treatment effects were not apparent at 6 months; at 12 months the in-school intervention was more effective at discontinuing smoking than the control condition (OR, 0.49; 95% CI, 0.29–0.84). At 18 months, the tailored out-of-school intervention was effective in preventing smoking initiation compared with the control condition (OR, 0.42; 95% CI, 0.18–0.96). The combined approach was not as successful as the in-school and the out-of-school efforts.^68^

D.A.R.E., based on the decisionmaking model, has been widely implemented in elementary schools and extensively evaluated. D.A.R.E. Plus, a new multicomponent curriculum used in middle and high schools, has received less attention than the original program.^75^ An independent evaluation of D.A.R.E. and D.A.R.E. Plus in 24 Minnesota middle and junior high schools was conducted with seventh- and eighth-grade students (51.6 percent male, 67.3 percent white, 7.5 percent African American, 12.7 percent Asian American, 3.6 percent Hispanic, 4.0 percent American Indian, and 4.9 percent of mixed or other ethnicity). The research team matched students on socioeconomic status, drug use, and size of school and randomly assigned schools to one of three conditions: D.A.R.E. only, D.A.R.E. Plus, or control group. The D.A.R.E. program, taught by trained D.A.R.E. police officers, consisted of 10 sessions providing skills in resisting influences to use drugs, building character, and building citizenship skills. The D.A.R.E. Plus program has three components: (1) “On the VERGE,” a classroom-based, peer-led, parental involvement program; (2) Youth Action Teams to implement in-school extracurricular activities; and (3) Youth Action Teams to address neighborhood and school-wide issues. The control group was eligible to receive D.A.R.E. Plus in 2001.^75^

Students received D.A.R.E. and D.A.R.E. Plus for about 8 months from September 1999 through April 2000.^75^ The researchers collected baseline measures from seventh graders in fall 1999; the first followup was in spring 2000 (i.e., at the end of the intervention); and the final data collection occurred among eighth-grade students in spring 2001 (i.e., 12 months following the intervention). Self-reported smoking status was reported through surveys.^75^

The investigators used a three-level, linear, random-coefficient model to test for significant differences over time; they reported group slopes. No outcomes comparing D.A.R.E. with the control schools were significant. Boys in the D.A.R.E. Plus condition were significantly less likely than those in the control schools to show increases in tobacco use and intentions to use tobacco (P = 0.04). Boys in the D.A.R.E. Plus condition were significantly less likely than those in the D.A.R.E. condition to show increases in tobacco use and intentions to use tobacco (P = 0.04). No effects for tobacco use among girls were significant.^75^

Interventions implemented within a school year were able to reduce tobacco initiation among adolescents shortly after the completion of the intervention.^68,^ ^71^ Two studies reviewed in this report found effects for boys but not girls; one of these studies, the culturally sensitive intervention, reduced tobacco initiation exclusively among Hispanic boys.^75,^ ^81^

Several school-based interventions (in the United States, Australia, Canada, and Norway) occurred over multiple school years.^70,^ ^72,^ ^74,^ ^76,^ ^82^ The interventions included classroom instruction, teacher training, parent involvement, extracurricular school activities, community assessment, advocacy, and projects.^70,^ ^72,^ ^74,^ ^76,^ ^82^ Students ranged from seventh graders through 12th graders. Study populations varied. One study implemented the intervention in a primarily Latino population;^82^ another involved both rural and urban communities with a high percentage of Native Americans (12.5 percent nonwhite);^72^ and the other studies did not specify ethnicity of the population.^70,^ ^74,^ ^76^ The sample size for the five multiple-year studies ranged from 22 to 99 schools and 813 to 4,276 students.

Students were exposed to smoking prevention interventions from 2 to 3 years. Investigators collected follow-up measures at the end of the interventions^70,^ ^72,^ ^74,^ ^76,^ ^82^ and up to 6 months following conclusion of the interventions.^82^ Two studies used control groups that were later eligible for the intervention;^72,^ ^76^ other control groups received some type of prevention activities.^70,^ ^74,^ ^82^ Only two multiple-year studies relied significantly on classroom instruction;^72,^ ^74^ the other tobacco prevention studies used multicomponent interventions that included school, family, and community activities.^70,^ ^76,^ ^82^

Project ALERT, a well-known adolescent drug prevention program, aims to change students' perceptions of drug norms and the social, emotional, and physical consequences of drug use. A revised version of Project ALERT emphasizes curbing alcohol misuse (rather than abstinence), increases attention to current smokers, and brings parents into the prevention process.^72^

In urban and rural communities in South Dakota, Project ALERT was evaluated in 55 middle schools with seventh- and eighth-grade students (13 percent nonwhite; 51 percent male).^72^ The curriculum included 11 lessons in seventh grade and three lessons in 8th grade that used interactive teaching methods focusing on motivation and resistance skill-building. Another important element of this program was home learning, which sought to involve parents in substance use prevention. The control schools receive a delayed experimental program at the conclusion of the study.

Students completed surveys at baseline in the fall of seventh grade and 18 months later in the spring of 8th grade. Self-reported smoking status was validated by collecting salivary cotinine levels for a random subsample of 654 students. At 18 months, cigarette initiation rates in Project ALERT (25.5 percent) were significantly lower than in the control group (31.6 percent, P < 0.01). From the baseline assessment to the 18-month followup, Project ALERT reduced the proportion of new smokers by 19 percent (P < 0.01).^72^

BE smokeFREE comprises an intensive intervention conducted over 3 school years. The program delivered classroom sessions at least five times per year from sixth through 8th grade.^74^ A nationally representative sample of 99 secondary schools in Norway implemented this program.^74^ Three treatment groups—the model intervention (i.e., classroom instruction, teacher in-service training, and parent involvement), the model intervention without the teacher in-service, and the model intervention without parent involvement—were each compared with a control group. The classroom instruction contained nontraditional school activities such as videos, games, and group work. The intervention used 8 hours in seventh grade, 5 hours in eighth grade, and 6 hours in ninth grade. During eighth grade, however, students and teachers requested adjustments to the intervention. Therefore, in ninth grade, students developed, carried out, and evaluated their own campaign to promote a smokefree lifestyle among the seventh graders. Parent involvement (not described) was included in the intervention. The control group received education on smoking and health but only for about half the number of hours as the intervention groups.^74^

Students self-reported smoking behaviors on surveys administered by teachers at the end of each of the 3 academic years. The proportions of smokers were significantly higher in the control group than in the model intervention for all 3 follow-up years (1995, F = 5.66; P < 0.01; 1996, F = 7.19; P < 0.001; 1997, F = 4.05; P < 0.05). In both the interventions without teacher in-service training and without parent involvement, the proportions of smokers on all follow-up occasions were higher than in the model intervention but lower than in the control group (1995, F = 2.84; P < 0.01; 1996, F = 3.98; P < 0.001; 1997, F = 2.46; P < 0.05). The odds of becoming a smoker during the intervention period were significantly lower in the model intervention than in the control group for daily smoking (Wald's 9.81, P = 0.02), for weekly smoking (Wald's 15.65, P = 0.0001), and for any smoking (Wald's 16.54, P = 0.0001).^74^

Several school-based tobacco prevention programs not only involve students but also include parents and surrounding communities. In one particular intervention, students were recruited from elementary schools with tobacco prevention programs.^70^ Thirty Canadian high schools selected for the study enrolled at least 30 students who had participated in an elementary school smoking prevention study; receiving such students was an eligibility requirement for schools.^70^

In the 15 intervention schools, the investigators recruited teachers, staff, students, and community members to participate in antismoking activities. Teachers helped students, staff, and community members to plan and implement prevention and cessation activities tailored to each intervention school to build commitment and strengthen school social norms toward not smoking. The research staff provided consultation, conducted semiannual workshops for teachers and student leaders, developed resources for dissemination to all intervention schools, produced newsletters, and provided a $1,000 per school annual budget.

Students in the ninth and tenth grades were exposed to the intervention for 1 year; data on smoking status were collected by survey at the end of the year. Investigators collected a “bogus” biochemical verification using carbon monoxide (CO) breath samples to enhance validity of the self-reported data. The control schools had “usual” programs but these were not described.^70^

Extracurricular activities produced by the intervention schools consisted of quit-and-win contests, poster contests, displays, health fairs, and smoking surveys (not associated with the study survey). On average, 3.8 intervention activities occurred in the 9th grade and 3.5 activities in 10th grade. At baseline, intervention schools had a marginally higher proportion of students who had previously been in the elementary intervention condition (P = 0.10). After adjusting for the baseline difference, male nonsmokers at baseline were significantly less likely to be “regular” smokers in 10th grade in the intervention schools than males in the control schools (9.8 percent vs. 16.4 percent, P = 0.02). Among females, intervention and control groups did not differ.^70^

High schools from San Francisco and San Jose, California, were randomly allocated in a school-based intervention study conducted in 10 continuation high schools.^82^ Advocacy activities related to advertising, availability, and use of tobacco were implemented in the intervention school to reduce tobacco initiation among students. Twenty-five 11th and 12th grade students volunteered to participate from each school (43 percent Latino, 21 percent white, 15 percent of mixed ethnicity, 13 percent Asian or Pacific Islander, 4 percent African American, and 4 percent other).^82^

The three-phase intervention lasted 2 years. It included advocacy and empowerment classes that dispelled misconceptions about cigarette smoking and raised students' awareness of environmental influences (e.g., tobacco company advertising). It also helped students to develop advocacy skills (e.g., by practicing persuasive communication) and to conduct a community assessment and advocacy project. The control groups received an existing substance abuse curriculum not specific to tobacco that was developed for continuation high school students.^82^

Students completed surveys at baseline, at the end of the semester, and 6 months after the end of the intervention. The two groups differed slightly at baseline for smoking and sociodemographic characteristics, but the investigators did not report percentages. The results, reported as net percentage changes from baseline smoking to after intervention, showed no significant changes after the intervention or at 6-month followup for nonsmokers (0.2 percent net change, P = 0.93).^82^

Using community organization theory, one group studied 7th through 10th grade students in 22 schools in New South Wales, Australia; the researchers encouraged intervention schools to adopt their own Health Promoting Schools (HPS) program.^76^ A key individual identified for each school took responsibility for planning, implementing, and monitoring HPS strategies such as developing a minimum set of health promotion actions for the school.

The schools received this community-based tobacco prevention intervention for 2 years. In November 1995, the investigators collected baseline data; in November 1997, they administered a posttest survey to the same cohort. They used a self-reported retrospective diary; students reporting having smoked any amount of cigarettes within the past 7 days were considered smokers.

In the final analysis, the research team matched pre-post data, which considerably reduced the sample size (N = 1,852). The odds of males smoking at posttest were almost half the odds of females (AOR, 0.55; 95% CI, 0.35–0.87). The proportion of students who had smoked in the last week did not differ significantly by treatment condition, indicating that the intervention was not effective.^76^

Provider-based interventions to reduce tobacco initiation. Only one study (Table 9) used providers to reduce tobacco initiation.^80^ The study participants were survivors of pediatric cancer from St. Jude Children's Research Hospital in Memphis, Tennessee, who were currently disease-free and at least 1 year from completion of antineoplastic therapy. On enrollment, the investigators randomly assigned 103 patients, stratified by age (ages 10 to 13 years and ages 14 to 18 years), gender, and race, to the tobacco-risk counseling intervention or a standard care group. The intervention occurred in a single session with periodic reinforcement of tobacco goals by telephone. A physician feedback letter reinforced the antitobacco messages, and tobacco literature was mailed to the patient. To reinforce previously established goals and address barriers, the investigators did follow-up telephone counseling at 1 and 3 months. Patients in the control group were asked about their tobacco use and briefly advised about the health risks associated with tobacco use. All tobacco users were advised to stop; nonsmokers were encouraged to continue to resist tobacco.^80^

Table 9 Effective provider-based interventions

Author Year | Design | Intervention | N | Results | Quality Rating
Setting | Exposure
| Followup
Tyc et al., 2003^80^ | RCT | G1: Self-help, individual counseling, health professional telephone counseling, video | 103 cancer survivors (10 to 18 years of age) | Intervention group had higher mean knowledge and perceived vulnerability scores and lower intention-to-use tobacco scores | Fair
United States | Education and counseling over 3 months | C1: Brief advice to stop smoking or continue not smoking
St Jude's Children's Research Hospital, Memphis, Tennessee | 6 and 12 months

C, Control Group; G, Intervention Group; RCT, randomized controlled trial.

Patients in the intervention and control groups were assessed by questionnaire at baseline and at 6 months and 12 months following the intervention.^80^ Baseline measures were similar across the two groups; 95.1 percent of the participants were classified as nonsmokers. At 12 months, multivariate comparison of difference scores for patient smoking status (12-month scores minus baseline scores) found no differences (all were P > 0.10), indicating the intervention had no effect on smoking initiation.

## KQ 2. Effective Strategies for Increasing Consumer Demand For and Use of Proven Individually Oriented Cessation Treatments

We discuss KQ 2 in two main parts: evidence concerning interventions aimed at increasing the number of smokers who attempt to quit, and evidence about strategies for improving the impact of those interventions. As with KQ 1, in both cases we first review the existing information from recent systematic reviews, and then we turn to the new literature uncovered by our searches. Appendix C ^‡^ presents the two evidence tables (Evidence Tables 4 and 5) with the details of studies from the current literature.

‡ Appendixes cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/tobusetp.htm.

### Increasing the Number of Users Who Attempt to Quit

Spontaneous and unassisted rates of tobacco use cessation among tobacco users are low (3 percent to 10 percent).^5^ Interventions to increase the number of tobacco users who seek assistance in quitting and who successfully quit include efforts to increase the number of users who attempt to quit, improve the success rate for quit attempts, and achieve both of these goals.^7^

Proven individual strategies for helping smokers to quit include counseling, behavioral therapy, and, except when contraindicated, the use of first-line and second-line medications.^5^ More often than not, individuals are trying to quit without assistance that can double or, in some cases, triple their chances of success.^5^

Synthesis of prior systematic reviews. Reviews of population-wide interventions to increase tobacco use cessation have focused on five elements: (1) multicomponent efforts to increase patient tobacco use cessation, which include telephone information or counseling support; (2) mass media campaigns combined with other interventions; (3) mass media cessation series; (4) mass media cessation contests; and (5) increases in the unit price of tobacco products. The Task Force on Community Preventive Services (hereafter, Task Force) focused on all five issues.^7^ The 2000 update of the 1996 Agency for Health care Policy and Research (AHCPR) guideline (Treating Tobacco Use and Dependence)^5^ and a 2003 Cochrane Review concentrated on the first topic (multicomponent efforts).^66^

Multicomponent efforts. Based on a systematic review of 32 studies evaluating the effectiveness of telephone cessation support, the Task Force found strong evidence of effectiveness for telephone cessation support to increase tobacco use cessation when implemented with other interventions such as educational approaches or clinical therapies in clinical and community settings.^7^ Telephone support was coordinated with additional interventions, including client education, provider-delivered counseling, nicotine replacement, a smoking cessation clinic, and a televised cessation series. Effective telephone counseling interventions combined either proactive telephone support (i.e., the provider initiated contact) or reactive telephone support (i.e., the caller initiated contact, with provider followup) and client cessation materials. In the 30 studies comparing differences in cessation of tobacco use based on use of or exposure to telephone support, tobacco use cessation increased 2.6 percentage points (range, -3.4 to +23) in follow-up periods of 5 weeks to 34 months (median, 12 months).^7^

On the basis of a meta-analysis of various formats of psychosocial treatments (e.g., self-help, proactive telephone counseling, group counseling, and individual counseling), Fiore et al. found proactive telephone counseling to be effective at increasing abstinence rates relative to no intervention (OR, 1.2; 95% CI, 1.1–1.4).^5^ The estimated abstinence rate based on this meta-analysis was 13.1 percent (95% CI, 11.4–14.8). The guideline update also found, as did the Task Force, that interventions delivered in multiple formats increased abstinence rates compared with no format. Odds ratios for one format were 1.5 (95% CI, 1.2–1.8); for two, 1.9 (95% CI, 1.6–2.2) and for three or four, 2.5 (95% CI, 2.1–3.0). Estimated abstinence rates were 15.1 (95% CI, 12.8–17.4), 18.5 (95% CI, 15.8–21.1), and 23.2 (95% CI, 19.9–26.6), respectively, compared with a no-counseling format.

In another meta-analysis using all less-intensive intervention arms as the control (as opposed to those providing tailored self-help materials), telephone counseling increased quit rates (OR, 1.56; 95% CI, 1.38–1.77).^66^ Investigators found no differences in quit rates in four trials that added telephone counseling support to a face-to-face intervention, in four trials that added telephone counseling support for users of nicotine replacement therapy, or in trials comparing different types of telephone counseling.

Mass media campaigns combined with other interventions. Mass media educational campaigns employ brief, recurring messages over time to provide information or motivation to tobacco users and others (e.g., family members, households, peers) with the goal of increasing or improving efforts to stop using tobacco products. Campaigns can focus on cessation, include cessation themes within a broader range of tobacco messages, or be combined with other interventions such as an excise tax increase or other related, community-wide education efforts.

Mass media campaigns, when combined with other activities, were effective in increasing tobacco use cessation by approximately 2 percentage points, in reducing overall tobacco consumption measured on a population basis by almost 13 percent, and in lowering the prevalence of tobacco use by approximately 3 percentage points.^7^ Mass media campaigns can also increase the number of people who seek telephone support for quitting smoking. The Task Force found “strong” evidence of the effectiveness of such campaigns when combined with activities to increase tobacco use cessation and reduce tobacco consumption; activities include excise tax increases or other community-wide educational efforts.^7^

Mass media cessation series. Mass media cessation series consist of broadcasted instructional segments designed to recruit, inform, and motivate users of tobacco products to try quitting and to succeed.^7^ Cessation series can be coordinated with broadcasts or print promotions that precede the series itself, community education, or organization of cessation groups in the community. Such series can last a period of several weeks to several months.

After reviewing nine studies evaluating cessation series, the Task Force found insufficient evidence to determine the effectiveness of such interventions in increasing the number of people who successfully stop using tobacco products.^7^ Studies included cessation series combined with other interventions such as community education, organized cessation groups or programs, or telephone support.

Mass media cessation contests. Cessation contests are community-wide events of short duration that use mass media to recruit and motivate users of tobacco products to participate in a program to quit by a certain date or during a specified time period. Mass media and small media (e.g., posters and flyers) promote available services and recruit tobacco product users.

The Task Force found insufficient evidence to determine the effectiveness of such contests in increasing the number of people who quit using tobacco products.^7^ This conclusion was based on only one study that showed some improvement in self-reported cessation at 6-month followup.

Summary. Proactive telephone counseling is effective in increasing tobacco use cessation. Mass media education campaigns combined with other interventions are also effective in increasing tobacco use cessation. However, other types of mass media education, such as media cessation series and cessation contests, were not found to be effective.

Synthesis of current literature. Seven randomized trials describing multicomponent interventions to increase tobacco use cessation met inclusion criteria (Table 10). Four involved counseling support; of these, three investigated proactive telephone counseling and support for cessation,^84^–^86^ and one trial of genetic susceptibility counseling incorporated smoking cessation counseling.^87^ Two other studies were long-term follow-up studies of intervention effect; one study included participants in a randomized trial of a computer-tailored smoking intervention^88^ and the other included participants in a randomized trial of the Lung Health Study (LHS) smoking intervention.^89^ The final study focused on adolescents to examine the effectiveness of a family-directed program addressing tobacco and alcohol use among teens.^90^ We did not find any new articles meeting our criteria that addressed the effects of mass media and tobacco price on increasing the number of tobacco users who attempt to quit or who are successful in quitting.

Table 10 Multicomponent interventions to increase the number of users who quit smoking

Author Year | Design | Intervention | N | Results | Quality Rating
Setting | Exposure
| Followup
Bauman et al., 2000^90^ | RCT | G1: Mailing of booklets and telephone counseling | 85 parent-adolescent pairs | No statistically significant difference in tobacco use between control and treatment for baseline cigarette users | Fair
United States | 2 months | C1: NR
Population-based | 3 and 12 months postcompletion or dropout
Etter et al., 2004^88^ | RCT | G1: Tailored counseling letters and booklets | 2,934 adults | At 7 months, significantly more people in the intervention than in the control group were abstinent for at least 1 month (G1: 5.8%; C1: 2.2%; P ≤ 0.001) | Fair
Switzerland, Western Europe | 12 months | C1: A single letter identifying person as part of the control group | | No difference between groups at 24 months.
Population-based | 7 and 24 months post-baseline
Lipkus et al., 2004^84^ | RCT | G1: 2 self-help booklets in mail; 6-minute video; | 402 adolescents | No differences in abstinence at 4- or 8-month followup or for sustained abstinence | Fair
United States | 2 months | 3 telephone counseling | | Participants completing more counseling calls were more likely to report cessation at 4 and 8 months (8-month OR = 1.54, 95% CI, 1.15–2.07, P < 0.007)
Community-based | 4 and 8 months post-baseline | C1: 2 self-help booklets in mail; 6-minute video;
| | no telephone counseling
McBride et al., 2002^87^ | RCT | G1: Provider advice to quit smoking; referral to smoking specialist; self-help guide; if eligible, nicotine patches | 557 adults; low SES; African American | Significantly more participants of G2 than G1 were not smoking at 6 months (G1: 10%, G2: 19%; P = 0.03) and had sustained abstinence | Fair
United States | 10 weeks | G2: Self-help guide; if eligible, nicotine patches and refills; biomarker feedback and tailored booklet | | (G1: 5%, G2: 11%; P = 0.08)
Practice/ provider settings | 6 and 12 months
Murray et al., 2002^89^ | RCT | G1: Ipratropium bromide inhaler, placebo inhaler | 4,517 adults | More participants in G1 than in C1 had sustained abstinence (G1: 21.9%, C1: 6.0%; P ≤ 0.001) | Fair
United States, | 3 months | C1: Usual care
Canada | 11 years
Practice/ provider settings
Rabius et al., 2004^85^ | RCT | G1: ACS booklets and standard advice plus up to 5 sessions of proactive telephone counseling | 3,522 young adults, adults | G1 group had higher rates of 48-hour abstinence than C1 group at 3 months (18–25 years: G1: 19.6%, C1: 9.3%; P < 0.005; over 25 years: G1: 15.1%, C1: 9.6%; P < 0.001) | Fair
United States | Varies by quit date, up to 5 followup calls, up to 2 weeks postquit date | C1: ACS booklets and standard advice | | Participants abstinent at 3 months were called at 6-month followups: (18–25 years: G1: 9.8%, C1: 3.2%; P < 0.01;over-25 years: G1: 8.8%, C1: 5.3%; P < 0.005)
Population-based | 3 and 6 months
Smith et al., 2004^86^ | RCT | G1: Telephone counseling, 2 follow-up calls, booklet | 632 adults | Intervention groups combined (G1, G2, G3) had significantly higher continuous abstinence rates than control group: | Fair
Canada | 3, 6, and 12 months | G2: Telephone counseling, 2 follow-up calls, pamphlet | | (G1, 2, 3: 5%, C1: 1%; P ≤ 0.05)
Population-based | | G3: Telephone counseling, 6 follow-up calls, booklet
| | G4: Telephone counseling, 6 follow-up calls, pamphlet
| | C1: Print materials only

ACS, American Cancer Society; C, control group; G, intervention group(s); NR, not reported; OR, odds ratio; RCT, randomized controlled trial; SES, socioeconomic status.

Adults were the target group in four studies,^86^–^89^ and adolescents and young adults were the target group in the other three.^84,^ ^85,^ ^90^ Trials enrolling only adults examined interventions designed to increase tobacco use cessation by providing proactive telephone counseling support^86^ and incorporating genetic susceptibility to lung cancer into smoking cessation counseling.^87^ Of the studies enrolling only adolescents and young adults, one tested the efficacy of self-help materials with or without proactive telephone counseling to increase cessation among teen smokers;^84^ the other examined the effects of telephone counseling on smoking cessation among smokers 18 to 25 years of age and smokers over 25 years of age.^85^

For the trials, recruitment strategies included radio and newspaper advertisements,^86^ contact with youth in shopping malls and an amusement park,^84^ telephone calls to a random sample of families with children 12 to 14 years of age,^90^ chart review and clinician referral,^87^ and a survey of callers to a national quit line.^85^ In the studies of persistent intervention effect, investigators recruited the original subjects in one study by mailed announcements to a random sample of residents in a defined area^88^ and, in the other, by random sample of an unspecified population for a multicenter trial.^89^

Smokers were defined in various ways at intake: daily smokers;^86^ daily smokers for 1 year and with an expired CO level of greater than 8 parts per million (ppm);^89^ having smoked a cigarette within the last week;^84^ more than an occasional smoker;^88^ current, daily smokers willing to make a quit attempt within the next 2 weeks;^85^ smokers with some level of lung impairment;^87^ and use of tobacco on 1 or more days during the past 30 days.^90^

Interventions were very different across trials, although all involved distribution of self-help print materials. Some interventions were tailored to stages of change; others were not. The intervention in one trial had five conditions involving combinations of counseling with variable numbers of follow-up calls (two or six) and different print materials (booklet or pamphlet).^86^ In another intervention group, participants received an eight-page personal counseling letter written by a computer according to answers that participants gave on a 62-item enrollment questionnaire and two 16-page self-help booklets corresponding to their current stage of change and the next stage of change.^88^ At 2, 4, and 12 months after entering the study, intervention participants could answer tailoring questions again to receive a new letter. In another trial, content of calls was customized and based on each participant's stage of readiness to quit.^84^ Calls were designed to encourage use of self-help booklets, move the participant toward quitting, and assist those ready to quit.^84^ In another study, the intervention used three booklets with standard advice plus up to five sessions of proactive telephone counseling.^85^ One study incorporated genetic susceptibility for lung cancer counseling and related print material (an eight-page test result booklet) into usual smoking cessation counseling.^87^ Only one trial included nicotine replacement therapy as part of the study, but the therapy was made available to both the intervention and control groups.^87^

Followup to assess smoking status occurred at various times in the current trials: 3 and 6 months;^85^ 3 and 12 months;^90^ 3, 6, and 12 months;^86^ 4 and 8 months;^84^ and 6 and 12 months.^87^ In the persistence of effect studies, followup occurred at 7 and 24 months^88^ and at 11 years.^89^ Followup occurred at the specified time after baseline in three studies,^84,^ ^87,^ ^88^ after the quit date in one,^85^ and after completion of the intervention in another.^90^

Outcome measures included various definitions of abstinence: 1-month abstinence (not smoking even a puff of a tobacco cigarette, cigar, or pipe in the last 4 weeks);^88^ 1-week abstinence (not smoking even a puff of a tobacco cigarette, cigar, or pipe in the past 7 days);^84,^ ^86^–^88^ no smoking in the past 48 hours;^85^ and self-reported cessation with no time frame specified.^89^ Continuous abstinence, which five studies used as a primary outcome, was defined as abstinence at all reporting periods.^84^–^87,^ ^89^

Smoking status results. Of the four trials of counseling support, three focused on telephone counseling and associated print materials.^84^–^87^ One study reported statistically significant increases in continuous abstinence among those receiving telephone counseling compared with control participants receiving only print materials (5 percent vs. 1 percent, P < 0.05).^86^ Another study reported statistically significant higher rates of prevalence of reported abstinence during the past 48 hours for participants in the treatment group compared with those in the control group in two age categories (younger than 18 years of age and 18 to 25 years of age). At 3-month followup, differences by age were 19.6 percent vs. 9.3 percent (P < 0.005) for younger smokers and 15.1 percent vs. 9.6 percent for older smokers.^85^ The trial of counseling support showed that smoking cessation was greater for the group receiving genetic feedback and counseling than for controls at 6 months but not at 12 months.^87^ Finally, one trial failed to show any significant group differences in either abstinence at each follow-up assessment or in continuous abstinence.^84^

Other outcomes. Beyond smoking status, four studies also assessed other primary and secondary outcomes associated with multicomponent interventions: quit attempts, days of smoking abstinence, and use of nicotine replacement. One study of persistent effect found that more participants in the intervention group than in the control group reported making a 1-month quit attempt and having more days of smoking abstinence.^88^ More participants in the intervention group than in the control group had used nicotine replacement products in two studies.^85,^ ^88^ Two studies showed no difference in nicotine replacement therapy use across groups.^86,^ ^87^

Adolescents and young adults. Two studies in this review showed that telephone counseling that targets youths achieved success comparable to that shown for adult smokers.^84,^ ^85^ This finding suggests that younger smokers can benefit from telephone counseling. Three-month quit rates were 19.6 percent for persons 18 to 25 years of age who received telephone counseling and 9.3 percent for those who received self-help booklets only (P < 0.005). The proportions reporting abstinence during the preceding 48 hours at both the 3- and 6-month follow-up interviews were also significantly different in the treatment group for this age cohort (9.8 percent vs. 3.2 percent, P < 0.01)^85^

Persistence of effect. Two studies reported long-term follow-up results of previous RCTs. The trial of a computer-tailored smoking cessation program showed, at the 7-month assessment, a significant increase in 4-week abstinence rates and 7-day quit rates compared with rates for controls. At 24 months after intervention, these differences had disappeared.^88^ The second follow-up study found that smokers exposed to an aggressive smoking intervention program who sustained abstinence for a 5-year period were very likely to still be abstinent after 11 years.^87,^ ^89^

### Improving the Success Rate of Quit Attempts

Synthesis of prior systematic reviews. Self-help approaches. In a meta-analysis including self-help as one format for assisting smokers in their quit attempts, Fiore et al. showed that self-help was of marginal efficacy.^5^ Further meta-analysis of studies in which self-help constituted the sole difference in treatment arms also indicated that self-help is of marginal efficacy. Little evidence supported the view that providing multiple types of self-help, when offered without any person-to-person intervention, significantly enhanced treatment outcomes.

Lancaster and Stead reported that providing smokers with materials to support quit attempts is of limited benefit unless the materials take into account each smoker's individual characteristics.^59^ Advice and behavioral counseling can help smokers to quit.^59^ Giving the same type of support via written materials or other media has not been found to be very helpful, although people given no other support may experience a small benefit.

These same authors examined 33 trials that compared self-help materials to no intervention or tested materials used in addition to advice.^59^ In 11 trials in which self-help was compared with no intervention, a pooled effect just reached statistical significance (N = 13,733; OR, 1.24, 95% CI, 1.07–1.45). Four other trials in which the control group received alternative written materials did not show an effect for the smoking self-help materials. The review failed to find evidence of benefit from adding self-help materials to either face-to-face advice or to nicotine replacement therapy.

Seventeen trials used materials tailored for the characteristics of individual smokers; meta-analysis by Lancaster and Stead supported a small benefit for tailored materials (N = 20,414; OR, 1.42; 95% CI, 1.26–1.61).^59^ The evidence was strongest for tailored materials compared with no intervention, but it also showed that tailored materials were more helpful than standard materials. A small number of other trials failed to detect benefits from using additional materials or targeted materials or to find differences between different self-help programs.

Counseling. In another review, Lancaster and Stead looked at trials of counseling by a trained therapist in one or more face-to-face sessions (separate from medical care).^60^ All trials involved sessions lasting more than 10 minutes, with most including further telephone contact for support. A review of 21 trials with more than 7,000 participants showed that individual counseling for smoking cessation was more effective than the control (OR, 1.56; 95% CI, 1.32–1.84). In a subgroup of three trials in which counseling had been tested as an adjunct to nicotine replacement therapy, the point estimate of effect was smaller and did not reach significance (OR, 1.34; 95% CI, 0.98–1.83). Meta-analysis did not detect a greater effect of intensive counseling than brief counseling, although the confidence intervals are wide and do not exclude the possibility of a clinically useful dose-response effect (OR, 0.98; 95% CI, 0.61–1.56).

In another review by Stead and Lancaster of 16 studies that compared a group program with controls receiving no intervention, cessation increased with the use of a group program (N = 4,395; OR, 2.04; 95% CI, 1.60–2.60).^65^ In seven trials, group programs were more effective than no intervention controls (N = 815; OR, 2.17; 95% CI, 1.37–3.45). No evidence emerged that group therapy was more effective than a similar intensity of individual counseling. Also, limited evidence suggested that programs with components for increasing cognitive and behavioral skills and avoiding relapse were more effective than programs of the same length or shorter without these components.

Group therapy was shown to more than double the chances of quitting as compared with self-help and other less intensive interventions.^65^ Evidence is insufficient to evaluate whether groups are more effective than intensive individual counseling and to support the use of particular psychological components in a program beyond the support and skills training normally included. Only limited evidence suggests that adding group therapy to other forms of treatment (adjunctive group therapy), such as advice from a health professional or nicotine replacement, produced extra benefit.^65^ Not all smokers making a quit attempt want to attend group meetings, but those who do are likely to find the meetings helpful if such activities offer assistance equivalent to intensive individual counseling.^65^

In updating the 1996 AHCPR clinical practice guideline, Fiore et al. found that minimal interventions lasting less than 3 minutes increased overall tobacco abstinence rates.^5^ They also reported a strong dose-response relation between length of person-to-person contact during a counseling session and successful treatment outcomes. In general, intensive interventions were more effective than less intensive interventions.

The Fiore et al. review also indicated that intensive interventions for smoking cessation should include an assessment to ensure that tobacco users are willing to make a quit attempt using an intensive treatment program.^5^ Other assessments can provide information useful in counseling (e.g., stress level, presence of comorbidity), but little consistent evidence exists to show that a smoker's status on a specialized assessment is useful in treatment matching. Regardless of their standing on specialized assessments, all smokers have the potential to benefit from cessation interventions. Tailored interventions based on specialized assessments (e.g., stages of change) do not consistently produce higher long-term quit rates than nontailored interventions of equal intensity. Because of the evidence of a strong dose-response relation, the intensity of a smoking cessation program should be defined as a session lasting longer than 10 minutes, with four or more sessions, for a total contact time longer than 30 minutes.

In terms of format, Fiore et al. used meta-analysis to compare self-help, proactive telephone counseling, group counseling, and individual counseling with no format.^5^ All four formats increased the likelihood of success in quitting; group counseling (OR, 1.3; 95% CI, 1.1–1.6) and individual counseling (OR, 1.7; 95% CI, 1.4–2.0) had the two highest odds ratios.

The use of adjuvant self-help material is optional, but follow-up assessment intervention procedures should be used.^5^ Smoking cessation interventions that used more than two formats were more effective than interventions that used a single format.

Particular types of counseling and behavioral therapies are especially effective.^5^ Practical counseling (e.g., problem-solving and skills-training approaches) and the provision of intratreatment social support and extratreatment social support (e.g., help in securing social support outside of treatment) are associated with significant increases in abstinence rates, as are aversive smoking techniques (e.g., rapid smoking). Tobacco dependence treatments are effective across diverse populations (e.g., populations varying in gender, age, and ethnicity).

The review in the 2000 Surgeon General's report found that pharmacologic treatment of nicotine addiction, combined with behavioral support, enabled 20 percent to 25 percent of users to remain abstinent at 1 year after treatment.^2^ Even less intense measures, such as physicians' advising their patients to quit smoking, produced cessation rates of 5 percent to 10 percent.

Evidence was mixed on the efficacy of self-help manuals as an aid to smoking cessation. Programs using advice and counseling—whether minimal or more intensive—have helped a substantial proportion of people quit smoking. The success of counseling and advice rises with the intensity of the program and may be improved by increasing the frequency and duration of contact.

Pharmaceuticals. Fiore et al. found that pharmacotherapies such as bupropion sustained release (SR) or nicotine replacement therapies (e.g., nicotine gum, nicotine inhaler, nicotine patch, nicotine nasal spray) consistently increased abstinence rates.^5^ They conducted two sets of meta-analyses. One meta-analysis examined first-line pharmacotherapies (i.e., those agents found to be safe and effective for smoking cessation and approved by the US Food and Drug Administration [FDA] for such use). The other was for second-line pharmacotherapies (i.e., agents where evidence of their efficacy for treating tobacco dependence exists, but they have a more limited role than first-line pharmacotherapies both because the FDA has not approved them for a tobacco dependence treatment indication and because they raise more concerns about potential side effects than first-line medications).

First-line pharmacotherapies, which include bupropion and the nicotine replacement therapies, consistently increased abstinence rates.^5^ Second-line pharmacotherapies, including clonidine and nortriptyline, also demonstrated efficacy. The combination of the nicotine patch with a self-administered form of nicotine replacement therapy (either gum or nasal spray) was more effective than a single form of nicotine replacement. Evidence was inconsistent on effectiveness of other pharmaceutical treatments (e.g., antidepressants other than bupropion SR and nortriptyline, anxiolytics, benzodiazepines, beta-blockers, silver acetate, and mecamylamine).

The Surgeon General's report indicated strong, consistent evidence that pharmacologic treatments for smoking cessation (nicotine replacement therapies and bupropion, in particular) can help people quit smoking.^2^ Clonidine and nortriptyline may have some utility for smoking cessation, but, as noted, the FDA has not approved them for this indication.

Synthesis of current literature. We identified 31 studies not covered by earlier publications that involved self-help, counseling, and pharmaceutical therapies. (Table 11).^91^–^121^ Of these, we rated 10 articles as poor quality and do not discuss them further in this section.^92^–^96,^ ^108,^ ^110,^ ^111,^ ^117,^ ^118^ Detailed data on all studies can be found in Evidence Table 5.

Table 11 Strategies to improve success rates for quit attempts for general and special populations

Author Year | Design | Intervention | N | Results | Quality Rating
Setting | Exposure
| Followup
Aveyard et al., 2003^105^ | RCT | G1: Pro-Change self-help system with workbook and 3 questionnaires to generate tailored feedback | 2471 adults | No statistically significant difference in quit rates between intervention and control groups (G1=11%, G2=12%, G3=10%, C1=10%) in biochemically-confirmed abstinence for 6-months sustained abstinence and 12-months point prevalence | Fair
United Kingdom | 9 months | G2: G1 plus three telephone calls
Practice/Provider Settings | 12 months post baseline | G3: G1 plus three nurse visits
| | C1: 2 standard self-help quit guides and 2 tip cards
Bohadana et al., 2000^91^ | RCT | G1: Nicotine inhaler and nicotine patch | 400 adults | Abstinence was greater at 3 months for intervention group than control group (P = 0.02) | Fair
France, Western Europe | 26 weeks | C1: Nicotine inhaler and placebo patch | | No significant difference between groups at 6- and 12-month followups
Practice/provider settings | 6 weeks; 3, 6, and 12 months
Canga et al., 2000^119^ * | RCT with systematic randomization | G1: Interview with nurse; self-help materials; 3 months of transdermal NRT if eligible; 5 follow-up contacts | 280 young adults, adults | Those in the intervention were significantly more likely than those in the control to quit at 6-month followup (validated): | Fair
Spain, Western Europe | 6 months | C1: Usual care for diabetic smokers established in the Navarre diabetes care program | | (P ≤ 0.001)
Practice/provider settings | 6 months
Hospital
Carpenter et al., 2004^98^ | RCT | G1: Telephone-based reduction counseling and NRT and brief advice to quit | 616 adults | At 6 months, those receiving either intervention had greater percentages of “24 hour quit attempts” (G1: 43% and G2: 51%) than those who received no treatment (C1: 16%) | Fair
United States | 24 weeks | G2: Motivational advice (5Rs) and brief advice | | (P < 0.01)
Population-based | 3, 6, 12 and 24 weeks | C1: No treatment
Clark et al., 2004^109^ | RCT | G1: Internet cessation resources handout with Web site addresses | 171 adults, > 50 years of age | No statistically significant differences in smoking status found at 1-month or 1-year followup | Fair
United States | Given materials at time of chest CT scan | C1: Standard self-help material—NCI handout, ACS booklet
Hospital | 1 and 12 months
Practice/provider settings
Dalsgareth et al., 2004^106^ | RCT | G1: 2 motivating phone calls, 5 clinic visits, and sustained-release bupropion hydrochloride | 336 adult hospital employees | Continuous abstinence at 26 weeks: | Fair
Denmark | 7 weeks | C1: 2 motivating phone calls, 5 clinic visits, and placebo | | G1 = 18%
Hospital | 26 weeks post-baseline | | | C1 = 7%
| | | | P = 0.008
Garvey et al., 2000^107^ | RCT | All subjects received Self help booklet and brief behavioral counseling, (5–10 minutes per visit, for 1 year) | 608 adults | At 1 year follow-up quit rates for low dependence were Placebo 11.2% | Fair
United States | 2 months | G1: Low dependence 2 mg gum | | 2 mg gum 19.5%
Population-based | 1, 7, 14, 30 days and 2, 3, 6, 9, and 12 months post-cessation | G2: Low dependence 4 mg gum | | 4 mg gum 18.4% (NS)
| | G3: High dependence 2 mg gum | | High dependence smokers quit rates at 1 year
| | G4: High dependence 4 mg gum | | 2 mg gum compared to placebo (15.7% vs. 6.1%, P = 0.02)
| | | | 4 mg gum compared to placebo (20.7% vs. 6.1% P = 0.002)
Hall et al., 2004^97^ | RCT | G1: Brief nortriptyline: nortriptyline for 12 weeks; 5 counseling sessions and NRT patch at week 5 | 160 adults | At 12 weeks nortriptyline was more effective than placebo (OR = 0.69, 95% CI; 0.49–0.92, P = 0.02) and placebo at 52 weeks (OR = 0.47; 95% CI; 0.30–0.75, P = 0.001); however 52 weeks of nortriptyline did not differ significantly from placebo at that same time frame | Fair
United States | Brief: 12 weeks | C1: Brief placebo: placebo for 12 weeks; 5 counseling sessions and NRT at week 5
Population-based | Extended: 52 weeks | G2: Extended nortriptyline: G1 + extended pharmacotherapy and counseling (1/month) for 52 weeks
| 12, 24, 36, 52 weeks | C2: Extended placebo: G2 but used placebo instead of nortriptyline
Hennrikus et al., 2005^112^ * | RCT | G1: 2 smoking cessation manuals; community resources directory; medical record label to cue to providers; postdischarge letter | 2,095 adults | Cotinine corrected intention-to-treat analysis found percentage of abstinence at 12-month followup (P > 0.05) NS | Fair
United States | 6 months | G2: G1 plus extended bedside counseling session and 3 to 6 telephone calls for 6 months postdischarge
Hospital | 7 to 18 days, 12 months postdischarge | C1: 2 cessation manuals and community resources directory
Hitsman et al., 1999^113^ | RCT | G1: Individual cognitive behavioral therapy, fluoxetine 30mg for 10 weeks, fluoxetine compliance level set at | 253 adults | No significant results found at 1, 3, and 6 month followup. | Fair
United States | 10 weeks | < 150ng/ml | | Individual differences that predict cessation when fluoxetine is combined with CBT include higher levels of weight concern, degree of depression, and levels of nicotine dependence
Population-based | 1 week, 1, 3, and 6 months postquit date | G2: Same as G1, except fluoxetine dose of 60mg and fluoxetine compliance level set at 300ng/ml
| | C1: Individual cognitive behavioral therapy plus placebo
Holt et al., 2005^114^ * | RCT | G1: Bupropion; counseling | 134 adolescents; young adults; adults | People in the intervention group were significantly more likely than those in the control to be continuously abstinent at 3 months | Fair
New Zealand | 2 months | C1: Placebo and counseling
Community-based | 3 and 7 weeks, 3, 6, 9, and 12 months posttarget quit date
Population-based
Jones et al., 2001^115^ * | RCT | G1: Verbal encouragement to patients to remain nonsmokers and for immediate family not to smoke in the same room as the patient, plus self- help manual | 61 adults | Of the smokers pre-ICU admission, more returned to smoking in the control group at 6-mos followup | Fair
United Kingdom | 6 months | C1: G1 without the manual
Hospital | 8 weeks, 6 months post ICU discharge
Jorenby et al., 1999^116^ | RCT | G1: bupropion and nicotine patch | 893 adults | Those receiving buproprion and patch were most likely | Fair
United States | 9 weeks | G2: bupropion and placebo patch | | (P ≤ 0.001) to be abstinent at 6 and 12 months
Community-based | 10 weeks, 3, 6, and 12 months | G3: placebo tablets and nicotine patch
| post start of study | C1: placebo tablets and placebo patch
Killen et al., 2000^99^ | RCT | G1: NRT transdermal system patch for 8 weeks plus 20 mg paroxetine for 9 weeks | 224 adults | No significant differences in abstinence groups found between groups at any follow up time period | Good
United States | 17 weeks | G2: NRT transdermal system patch for 8 weeks plus 40 mg paroxetine for 9 weeks
Population-based | 4, 10 and 26 weeks | C1: NRT transdermal system patch for 8 weeks plus placebo for 9 weeks
Lancaster et al., 1999^121^ | RCT with systematic randomization | G1: Brief advice to quit from general practitioner, plus: extended counseling a nurse; leaflet on cessation; fact sheet on NRT; invitation to contact the research nurse for more intensive, tailored counseling; NRT if necessary | 497 adults | No significant differences found between groups at 3 and 12 month followups | Fair
United Kingdom | 6 weeks | C1: Brief advice to quit from the patients' general practitioners
Practice/provider settings | 3 and 12 months postquit date
Lerman et al., 2004^100^ | RCT | G1: 8 weeks of nicotine nasal spray and 7 sessions of behavioral group counseling | 299 adults | No statistically significant difference found between treatment groups at 6 months (G1: 12.2%, G2: 15%, NS) | Fair
United States | 8 weeks | G2: 8 weeks of transdermal nicotine therapy (i.e., patch) and 7 sessions of behavioral group counseling | | Smokers who were highly dependent, obese, or members of minority groups achieved higher rates of abstinence with nasal spray
Population-based | 8 weeks and 6 months
MacLeod et al., 2003^104^ | RCT | G1: Nicotine Patch and 5 telephone counseling calls | 854 adults | Telephone counseling improves cessation rates when used in conjunction with the patch | Good
Australia | 10 weeks | C1: Nicotine Patch only | | 28-day continuous abstinence rates at 6-months: G1 30.6%, C1 22.4%, P = 0.01
Population-based | 1, 2, 3 and 6 months | | | 90-day continuous abstinence rates G1 26.7%, C1 18.6%, P = 0.004
McBride et al., 2004^122^ † | RCT | G1: Usual care plus late pregnancy relapse kit, and 6 counseling calls | 583 Pregnant women and their partners | No statistically significant difference between groups at any follow up point | Fair
United States | First trimester to delivery and 12 months postpartum | G2: G1 plus the partners received telephone counseling and support guide (partners who smoked received cessation aids and counseling) | | In late pregnancy, more partners abstinent in G2 group (15%) than C1 group (5%) P = 0.02
Military Medical Center | 28 weeks pregnant | C1: Usual Care: provider
| Postpartum
| 2, 6, and 12 months
Peterson 2004^120^ * | RCT | G1:Brief physician counseling and usual care plus nurse managed, cognitive behavioral relapse prevention intervention given pre-discharge, <5 structured telephone contacts discharge, and relapse management counseling as needed | 277 adults women | No significant differences between groups at 12 month follow ups | Fair
United States | 3 months | C1: Brief physician counseling, a self-help pamphlet, and list of community resources
Hospital | 12 months
Quist-Paulsen et al., 2003^123^ † | RCT | G1: Self-help booklet on how to quit smoking plus cardiac nurse consultation during in-patient days and phone consultation for up to 5 months following discharge | 240 adults | At one year, the quit rate was far greater (57%) in the intensive nurse intervention versus the minimal intervention group (37%) (absolute risk reduction 20%, 95% CI 6.4–33.0; P = 0.004) | Good
Norway | 5 months | C1: Group sessions with nurses with minor emphasis on smoking cessation and no further advice or instruction on how to quit
Hospital - cardiac ward | 12 months
Ratner et al 2004^124^ † | Randomized pretest-posttest control group experiment | G1: 2 face to face counseling sessions and 9 telephone counseling sessions | 237 surgical patients | Those receiving the counseling (73%) were more likely to be abstinent than the controls (53%) (P = 0.003) at 6 months but the difference is not significant at 12 months after surgery | Fair
Western Canada | NR | C1: Standard hospital treatment
Teaching hospital | 6 and 12 months
Reid et al 2003^125^ † | RCT | G1: Self-help booklet given in the hospital, then follow-up by nurse counselor at 4 weeks after discharge; if patient smoking, nurse provides 3 twenty minute face to face sessions over 8 weeks and offered nicotine patch therapy | 254 coronary artery disease hospitalized patients | Smoking cessation rates increased from 42% at hospitalization to 53% at 3 month follow up (P = 0.05), but not significant at 1 year follow up | Good
Canada | 8 weeks
Hospital, tertiary care cardiac facility | 3 months and 1 year
Simon et al., 2004^101^ | RCT | G1: 7 week course of Bupropion, 2 months transdermal nicotine replacement therapy, 1 visit with counselor (30–60 minute session), and 5 telephone follow-up calls | 244 adults (86% male) | No statistically significant differences in smoking cessation rates at end of medication 3, 6, and 12 months | Fair
United States | 7 weeks | C1: Same as G1 except participants received placebo instead of Bupropion | | The addition of 7-week treatment with Bupropion did not significantly increase quit rates over NRT and counseling
Hospital | 7 weeks, 3, 6 and 12 months
Swan et al; 2003 and 2003^102,103^ | RCT | All participants received Bupropion SR for 7 weeks | 1524 adults | Abstinence significantly greater at both 3 months and 1 year for those receiving intensive counseling and higher dose of bupropion (G4) vs (G1, G3) and (G3) at higher dose with brief counseling | Fair
United States | 12 months | G1: 150 mg Bupropion SR, brief counseling call day after quit date, personalized intervention materials, and access to 24 hour automated support line | | The 300 mg dose was associated with more adverse events
Practice/provider settings | 3 and 12 months | G2: G1 except 300 mg Bupropion SR
| | G3: 150 mg Bupropion SR, self-help materials, support materials for family and friends, an in-depth telephone counseling session, 4 brief telephone counseling calls, and access to toll free quitline for 1 year
| | G4: G3 with 300 mg of Bupropion SR

ACS, American Cancer Society; C, Control Group; CBT, cognitive behavioral therapy; CT, computed tomography; ICU, intensive care unit; G, Intervention Group(s); NCI, National Cancer Institute; ng/ml, nanogram per milliliter; NRT, nicotine replacement therapy, RCT, randomized controlled trials.

* : General and special populations

† : Special populations only

Self-help approaches. Two studies examined a self-help approach to improving cessation rates. One study involved patients recently discharged from intensive care units (ICUs).^115^ This intervention included (1) verbal encouragement to remain nonsmoking at ICU discharge and at 8-week and 6-month clinic follow-up visits, (2) instructions for patient's immediate family not to smoke in the same room as the patient, and (3) a 6-week self-help ICU rehabilitation manual for the patient and his or her relatives. The manual emphasized the importance of remaining nonsmoking and provided practical tips for smoking cessation along with other general tips.

Patients receiving an ICU rehabilitation package were much less likely to return to smoking after discharge from the ICU than control patients, even though control patients received verbal encouragement to quit smoking during the recovery period.^115^ The investigators could not determine whether the smoking cessation advice in the ICU rehabilitation package or the whole package in general was responsible for the high quit rate. Including an exercise program in the package may have enhanced the likelihood of quitting smoking.

The other trial included patients undergoing lung cancer screening.^109^ Participants in one intervention group received a handout with a list of 10 Internet sites related to stopping smoking and a brief description of each site; those in another group received two self-help booklets for smoking cessation, one of which provided up-to-date information on available pharmacotherapies for nicotine dependence.

In this trial, the groups did not differ significantly in 7-day point prevalence quit rates or in advancement in motivational readiness.^109^ At 1-year followup, more of the subjects receiving Internet-based resources reported making a stop attempt (68 percent vs. 48 percent; P = 0.011).

Counseling. Five studies evaluated the effects of counseling—two studies in the hospital setting,^112,^ ^120^ one in a combination of primary care clinics and hospitals,^119^ and two in private practices.^105,^ ^121^ All female adult smokers were eligible for enrollment in one hospital-based studies^120^ and all adult smokers in the other.^112^ All diabetic adult and young adult smokers were eligible for enrollment in the combined-setting study.^119^ All interventions included nurse counseling, self-help materials, and follow-up contact either in person or by telephone, and all interventions were compared with usual care of brief advice to quit smoking, related self-help materials, or both. In the trial for women admitted to hospital with cardiovascular or peripheral vascular disease, the nicotine patch was offered (if not contraindicated) to those women who were smoking more than 19 cigarettes per day and who had not succeeded after trying to quit at least once.^119^

One hospital-based study examined the effects of three smoking cessation counseling interventions for inpatients. Interventions included modified usual care, brief advice, and brief advice plus more extended counseling during and after hospitalization.^112^ Pharmacological aids were not provided. Inpatients in four hospitals were randomly assigned to each condition and followed up at 7 days and 12 months after discharge. Another hospital-based intervention involved smoking cessation and relapse prevention among women admitted to the hospital with cardiovascular or peripheral vascular disease.^119^ Neither of these hospital-based interventions increased biochemically verified abstinence rates at 12 months postdischarge, although self-reported abstinence rates were significantly higher for the most comprehensive intervention group.^112^

In the combined-setting study of diabetic patients seen in primary clinics and hospitals compared with a control group, those receiving nurse-managed assistance in quitting were, at 6-month followup, significantly more likely to quit smoking.^119^ This work, biochemically validated, produced quit rates of 17.0 percent for the intervention group and 2.3 percent for the control group (P = 0.001). Among those who did not quit, the intervention significantly decreased the mean number of cigarettes smoked per day (for the experimental group, 20.0 at baseline and 15.5 at followup; for the control group, 19.7 and 18.1, respectively, at the two measurements; P < 0.001).

The two different interventions for adults in private practices showed no significant differences in quit rates at 12-month followup.^105,^ ^121^ One of these studies also showed no significant differences in quit rates at 3 months or in continuous abstinence between 3- and 12-month followups.^121^ The other study found no significant differences in biochemically confirmed quit rates between intervention and control groups at 6-month followup, 6-month sustained abstinence, or 12-month followup.^105^

The three studies in this section among hospitalized patients are also included in a separate section of this report about interventions among hospitalized patients.^112,^ ^119,^ ^120^

Single pharmaceutical therapy. Five studies examined the effect of a single pharmaceutical treatment on smoking cessation.^100,^ ^101,^ ^106,^ ^107,^ ^114^ Three studies evaluated the effect of bupropion, one studied the effect of nicotine gum and of different doses of nicotine gum, and one the comparative efficacy of transdermal nicotine and nicotine nasal spray. Two studies were based in hospitals: one accepting adults age 20 and over^101^ and the other involving adults employed by the hospital.^106^ Three studies were population-based and enrolled only adults.^100,^ ^107,^ ^114^ One study examined efficacy of bupropion use in the indigenous Maori population in New Zealand.^114^

A 6-month, multicenter, parallel group, randomized, double-blind, placebo-controlled study compared 7-week treatment with bupropion SR (Zyban®) with placebo as an aid to smoking cessation in health care workers.^106^ All participants were motivated to quit smoking and received behavioral counseling. Continuous smoking abstinence at week 7 was achieved by 43 percent in the bupropion group and 18 percent in the placebo group (P < 0.001). Side effects, although frequent, were simple and reversible in both groups and generally consistent with the findings of previous studies. Dizziness, insomnia, and pruritus appeared more frequently in the bupropion group than in the placebo group.

A randomized blinded trial examined the efficacy of bupropion SR for smoking cessation among an outpatient population. Of the 244 participants, 121 received a 7-week course of bupropion and 123 received placebo.^101^ All participants received 2 months of transdermal nicotine replacement therapy and 3 months of cognitive behavioral counseling. During treatment the investigators observed a trend toward increased quit rates among participants randomized to bupropion. The self-reported end-of-medication quit rates were 64 percent for the bupropion group and 57 percent for the placebo group (P = 0.23). The trend favoring bupropion persisted at 3 months of followup (P = 0.12) but was not apparent at 6 months and 1 year of followup (both P = 0.78). The 12-month quit rates, validated by either saliva cotinine or spousal proxy, were 22 percent in the bupropion group and 28 percent in the placebo group (P = 0.31). Based on biochemical validation, 19 percent of the bupropion group and 24 percent of the placebo group had quit smoking by 1 year (P = 0.36).

Holt et al. attempted to determine whether bupropion combined with smoking cessation counseling was effective for the indigenous Maori population of New Zealand.^114^ At 3- and 6-month followup, rates of abstinence in the bupropion group were significantly higher than rates in the placebo group. A model-based secondary analysis found a risk ratio of 2.44 in favor of bupropion for all time points. Bupropion was also safe and generally well tolerated, although three subjects did not complete treatment with bupropion because of a rash.

Garvey et al. used the Heaviness of Smoking Index, a subset of the Fagerstrom Test for Nicotine Dependence, to classify smokers planning a cessation attempt as low or high in nicotine dependence.^107^ Subjects within each level of dependence were then randomly assigned to placebo, 2-mg, or 4-mg nicotine gum treatment. Subjects were also provided brief (5 to 10 minutes per visit) behavioral counseling during a 1-year period of followup. At 1 year postcessation, quit rates were 11.2 percent, 19.5 percent, and 18.4 percent for low-dependence smokers receiving placebo, 2-mg, and 4-mg gum, respectively (P linear trend = 0.20). For high-dependence smokers, quit rates at 1 year were 6.1 percent, 15.7 percent, and 20.7 percent for the placebo, 2-mg, and 4-mg gum conditions, respectively (P linear trend = 0.002). The interaction of nicotine-gum dose and dependence group was not significant (P = 0.42). The 2-mg and 4-mg doses did not differ significantly in effectiveness, although both doses were significantly more effective than placebo gum. Other variables related to abstinence at 1 year postcessation were a longer period of abstinence on a prior quit attempt, being married, higher education level, and having a nonsmoking spouse or significant other. Results indicate that nicotine gum is a significant aid to smoking cessation, more than doubling the odds of successful cessation compared with the odds for placebo gum users. The 4-mg dose provided a nonsignificant increase in cessation rates for high-dependence smokers.

Lerman et al. conducted a randomized, open-label clinical trial to evaluate the comparative efficacy of transdermal nicotine and nicotine nasal spray and identify predictors of treatment outcome in two university-based smoking cessation research programs.^100^ Intervention consisted of behavioral group counseling and 8 weeks of therapy with nicotine nasal spray or transdermal nicotine. Abstinence rates for the transdermal nicotine and nicotine nasal spray groups were not significantly different at 6-month followup (15.0 percent vs. 12.2 percent, respectively; P > 0.2). Interactions in abstinence rates for subgroups of smokers were statistically significant (P < 0.05). Smokers who had low to moderate dependence levels, were not obese, and were white achieved higher abstinence rates with transdermal nicotine, whereas smokers who were highly dependent, obese, or members of minority groups achieved higher abstinence rates with nasal spray.

Combined pharmacotherapies. Three studies examined the effect of combined pharmacotherapies on smoking cessation.^91,^ ^99,^ ^116^

In one, Bohadana and colleagues recruited subjects through a local newspaper and randomized them to either the intervention group (which received a nicotine inhaler and nicotine patch) or a control group (which received a nicotine inhaler and placebo patch).^91^ Smoking at intake was defined as smoking 10 or more cigarettes per day for 3 or more years and an expired CO level of 10 ppm or more.

Abstinence rates at 6 weeks, measured as expired CO of 10 ppm or more, were significantly higher for those receiving the nicotine inhaler and the nicotine patch than for those receiving the nicotine inhaler and placebo patch (60.5 percent vs. 47.5 percent, P = 0.09).^91^ At 6-month and 12-month followup, however, the groups did not differ significantly in continuous abstinence. One-year survival analysis showed a significant association between abstinence and treatment with nicotine inhaler plus nicotine patch (P = 0.04). In an examination of weight gain, subjects in the intervention group had gained less weight than the control group by week 2 (P < 0.01), but after 12 months, differences in mean weight gains were not significant. Mean nicotine substitution at week 6 was 60.1 percent in the intervention group and 24.6 percent in the control group (P < 0.001). At 12 months, the frequency of respiratory symptoms in abstinent subjects had fallen significantly compared with their baseline (for morning cough, P < 0.001; for morning phlegm, P = 0.002; for wheezing, P < 0.001; and for shortness of breath, P < 0.001). A trend toward improved lung function was observed but not significant at 12-month followup compared with baseline. Subjects in the control group reported significantly more intense withdrawal symptoms at week 1 (P < 0.001) and craving symptoms at week 6 (P = 0.04) than those in the intervention group. The most common adverse events were throat irritation (from the inhaler) and itching (from the patch).

Jorenby et al. recruited adult subjects through media advertisements.^116^ They randomized those in the intervention group to three conditions: bupropion only, nicotine patch only, or both bupropion and nicotine patch. Subjects in the control group received placebo pills and a placebo patch. Smoking at intake was defined as smoking at least 15 cigarettes per day. Self-report of smoking status and expired CO were used to assess smoking status at 6- and 12-month followups.

The abstinence rates at 12 months were 15.6 percent in the placebo group compared with 16.4 percent in the nicotine patch group, 30.3 percent in the bupropion-only group (P < 0.001), and 35.5 percent in the group given bupropion and the nicotine patch (P < 0.001).^116^ Abstinence rates were higher with combination therapy than with bupropion alone, but the difference was not statistically significant. By week 7, participants in the placebo group had gained an average of 2.1 kg. Weight gain in the other groups was 1.6 kg in the nicotine patch group, 1.7 kg in the bupropion-only group, and 1.1 kg in the combined treatment group (P < 0.05). Subjects in the combined therapy group had gained significantly less weight than those in the placebo group (P < 0.05) or the bupropion-only group (P < 0.05). Groups did not differ significantly in mean weight changes after week 7. Adverse events were rare and tolerable; they included insomnia and headache.

In the third trial, Killen and colleagues recruited participants by placing program announcements in local newspapers and examined the efficacy of a smoking cessation treatment that combined nicotine replacement therapy via a transdermal system (TNS) with the antidepressant paroxetine (a selective serotonin reuptake inhibitor [SSRI]).^99^ Smokers (N = 224) were randomized to one of three groups: (1) TNS and placebo; (2) TNS and 20 mg paroxetine; and (3) TNS and 40 mg paroxetine. Assignment to treatment was double-blind. TNS treatment was provided for 8 weeks; paroxetine or placebo was provided for 9 weeks.

Abstinence rates at weeks 4, 10, and 26 were as follows: (1) TNS and placebo: 45 percent, 36 percent, and 25 percent; (2) TNS and 20 mg paroxetine: 48 percent, 33 percent, and 21 percent; and (3) TNS and 40 mg paroxetine: 57 percent, 39 percent, and 27 percent.^99^ The differences were not statistically significant. The combined treatment was more effective in reducing both craving and depression symptoms associated with smoking cessation. A subgroup analysis compared outcomes only among compliant participants. Abstinence rates at weeks 4, 10, and 26 were as follows: (1) TNS and placebo: 46 percent, 35 percent, and 24 percent; (2) TNS and 20 mg paroxetine: 64 percent, 43 percent, and 33 percent; and (3) TNS and 40 mg paroxetine: 74 percent, 51 percent, and 38 percent. The differences between paroxetine groups and the control group at week 4 were statistically significant.

Pharmacotherapy and psychological interventions. We identified six studies designed to examine the effect on cessation rates of interventions that had both pharmacotherapy and psychological counseling.^97,^ ^98,^ ^102^–^104,^ ^113^ Four studies were population-based studies of adults; two studies included members of a large health care system.

The population-based trial examined the effectiveness of the combination of fluoxetine (another SSRI antidepressant) and cognitive behavioral treatment (CBT).^113^ One and 3 months after the quit date, fluoxetine increased the likelihood of abstinence, as compared with placebo, among smokers with minor depression but not among those with little or no depression. As an adjunct to CBT, fluoxetine increased cessation by selectively benefiting medication-compliant smokers who displayed even subclinical levels of depression. Investigators were unable to predict cessation outcome on the basis of drug assignment, individual differences, or their interaction. Thus, they would not suggest that an interventionist could simply use the personal attributes they studied to predict which smokers might benefit from adjunctive fluoxetine before knowing something about whether a smoker is likely to adhere to an intensive treatment regimen involving medication plus CBT.

No evidence suggested that the more nicotine-dependent smokers derived special benefit from fluoxetine.^113^ The moderating effect of depression on fluoxetine responsiveness was independent of the effect of nicotine dependence; this effect persisted even after the variance explained by nicotine dependence was removed. These findings suggest that adjunctive antidepressant treatment offers little selective benefit for highly nicotine-dependent smokers.

Carpenter et al. studied the efficacy of smoking reduction aided by nicotine replacement therapy compared to motivational advice or no treatment by using a telephone-only intervention among smokers not currently interested in quitting.^98^ They randomized these smokers (N = 616) to receive (1) telephone-based reduction counseling plus nicotine replacement therapy plus brief advice to quit, (2) telephone-based motivational advice plus brief advice, or (3) no treatment.

Over 6 months, more smokers in the reduction-counseling arm (43 percent) and the motivational arm (51 percent) made a 24-hour quit attempt than smokers in the no-treatment arm (16 percent; P ≤ 0.01).^98^ The two active intervention groups, however, did not differ on this outcome variable (P ≥ 0.05). Similarly, 18 percent, 23 percent, and 4 percent in each group were abstinent (7-day point prevalence) at 6 months (P ≤ 0.01). Results indicated that smoking reduction using nicotine replacement does not undermine cessation; rather, it increases the likelihood of quitting to a degree similar to that from motivational advice.

Using a chronic disease model of smoking, Hall et al. undertook to determine the effects of long-term antidepressant and psychological treatment.^97^ They randomly assigned 160 subjects who smoked at least 10 cigarettes a day to one of four treatment groups in a two-by-two design (nortriptyline [a tricyclic antidepressant] versus placebo by brief versus extended treatment). All subjects received 8 weeks of a transdermal nicotine patch, five group counseling sessions, and active drug or placebo treatment. Interventions for subjects in brief treatment ended at this point. Subjects in extended treatment continued taking nortriptyline or placebo to week 52 and received 9 monthly counseling sessions, with checkup telephone calls midway through each session. Subjects were assessed at baseline and weeks 12, 24, 36, and 52.

At week 52, point-prevalence abstinence rates with missing subjects imputed as smokers were 30 percent for placebo brief treatment, 42 percent for placebo extended treatment, 18 percent for active brief treatment, and 50 percent for active extended treatment.^97^ With missing subjects omitted, these rates were 32 percent, 57 percent, 21 percent, and 56 percent, respectively. Differences were significant for the active extended condition at each of 24, 36, and 52 weeks.

In a randomized controlled trial, Macleod et al. investigated the effectiveness of telephone counseling as an adjunct to nicotine replacement therapy by transdermal patch in smoking cessation.^104^ Smokers were randomized to either replacement therapy alone or replacement therapy plus telephone counseling (five sessions spaced according to a relapse-sensitive call schedule). Continuous abstinence rates over 28 days among participants receiving telephone counseling were significantly greater than among those not receiving telephone counseling at both 3 and 6 months (31.6 percent vs 25.1 percent; P = 0.04 at 3 months; and 30.1 percent vs 22.4 percent; P = 0.01 at 6 months). Similarly, 90-day continuous abstinence rates at 6 months were significantly greater for participants receiving counseling (26.7 percent v 18.6 percent; P = 0.004).^104^

Two studies from the same research team examined characteristics associated with more clinically relevant smoking endpoints following treatment with bupropion SR in a large health care system.^102,^ ^103^ In both studies, the researchers randomized smokers to receive one of four combinations of bupropion (150 mg or 300 mg) and behavioral counseling (tailored mailings or proactive telephone counseling); they assessed point-prevalent smoking status at 3 and 12 months. The Swan, Jack, et al. study focused on predictors of outcome;^102^ the Swan, McAfee, et al. study focused on group differences.^103^

Findings related to smoking abstinence were the same in both studies. Bupropion dose was not associated with rates of smoking at 12 months. However, the odds ratio for 12-month smoking was 24 percent higher for those who received the tailored mail program than those enrolled in the proactive telephone-counseling program (OR, 1.24; 95% CI, 1.06–1.47).

### Strategies to Improve the Success Rate for Quit Attempts for Special Populations

Synthesis of prior systematic reviews. Hospitalized patients. In a meta-analysis of four studies meeting selection criteria and relevant to the analysis comparing augmented smoking cessation treatment with usual care for hospitalized patients, Fiore et al. found that smoking cessation treatments have been shown to be effective for hospitalized patients.^5^ Augmented smoking cessation interventions among hospitalized patients increased rates of smoking abstinence. Because the meta-analysis was limited to four studies, the investigators made no attempt to categorize the augmented treatment with respect to type or intensity. For reference only, the augmented interventions in the analyzed studies included elements such as self-help via brochure or audio/videotape, chart prompts that reminded physicians to advise smoking cessation, pharmacotherapy, hospital counseling, and postdischarge counseling telephone calls.

In the Rigotti et al. review of interventions for smoking cessation in hospitalized patients, intensive intervention (inpatient contact plus followup for at least 1 month) was associated with a significantly higher quit rate than control (Peto OR, 1.82; 95% CI, 1.49–2.22, six trials).^63^ Interventions with less than a month of followup produced no significant benefit (Peto OR, 1.09; 95% CI, 0.91–1.31, seven trials). They found no evidence to judge the effect of very brief interventions (<20 minutes) delivered only during the hospital stay. Longer interventions delivered only during the hospital stay were not significantly associated with a higher quit rate (Peto OR, 1.07; 95% CI, 0.79–1.44, three trials). Although the interventions increased quit rates irrespective of whether nicotine replacement therapy was used, the results for replacement therapy were compatible with other data indicating that it increases quit rates.^63^

Pregnant women. Prior reviews included studies with substantial variation in the intensity of the intervention and the extent of reminders and reinforcement through pregnancy. All three reviews concluded that participants in intervention conditions experienced significant reduction in continued smoking in late pregnancy.^5,^ ^37,^ ^61^

Racial and ethnic minorities. A prior review of interventions specifically designed for particular racial or ethnic groups demonstrated the efficacy of a variety of smoking cessation interventions for minority populations. The resultant recommendation is that members of racial and ethnic minorities should be provided treatments shown to be effective in the Treating Tobacco Use and Dependence guideline.^5^

Synthesis of current literature. We identified 13 studies not covered by prior reviews dealing with special populations; 10 studies dealt with hospitalized patients,^112,^ ^115,^ ^119,^ ^120,^ ^123^–^128^ two studies dealt with pregnant women,^122,^ ^129^ and one with indigenous Maori.^114^ We described one of these studies in the self-help portion of this chapter and two in the counseling portion, but, because they dealt with hospitalized patients, we included them here as well.^115,^ ^119,^ ^120^ Of these, we rated four articles as poor quality (three for hospitalized patients^126^–^128^ and one for pregnant women^129^) and do not discuss them further in this section. Detailed data on all studies can be found in Evidence Table 5.

Hospitalized patients by diagnosis. Three studies focused on improving cessation rates among hospitalized patients with specific smoking-related diagnoses.^119,^ ^120,^ ^123^ One study involved smoking cessation and relapse prevention among women admitted to the hospital with cardiovascular or peripheral vascular disease,^120^ one included diabetic smokers,^119^ and one involved patients under the age of 78 years admitted for myocardial infarction, unstable angina, or care after coronary bypass surgery performed at other hospitals.^123^ All interventions included nurse counseling, self-help materials, and follow-up contact either in person or by telephone, and all interventions were compared with usual care of brief advice to quit smoking and/or related self-help materials. In the trial for women admitted to hospital with cardiovascular or peripheral vascular disease, the nicotine patch was offered (if not contraindicated) to those women who were smoking more than 19 cigarettes per day and who had not succeeded after trying to quit at least once.^119^

All three of these hospital-based interventions failed to increase biochemically verified abstinence rates at 12 months after discharge. One, however, showed significant differences in self-reported abstinence at 12-month followup.^123^

Hospitalized patients by intensity of intervention. Four studies examined the effect of varying the intensity of smoking cessation intervention among hospitalized patients.^112,^ ^115,^ ^124,^ ^125^ One study involved patients recently discharged from intensive care units (ICUs).^115^ This intervention included (1) verbal encouragement to remain nonsmoking at ICU discharge and at 8-week and 6-month clinic follow-up visits, (2) instructions for patient's immediate family not to smoke in the same room as the patient, and (3) a 6-week self-help ICU rehabilitation manual for the patient and his or her relatives that emphasized the importance of remaining abstinent and provided practical tips for smoking cessation along with other general tips. In the study of recently discharged ICU patients, those receiving the intervention were much less likely to return to smoking after discharge from the ICU than control patients who received only the first component of the intervention. Investigators could not determine whether the smoking cessation advice in the ICU rehabilitation package or the whole package in general was responsible for the high quit rate.^115^ Including an exercise program in the package may have enhanced the likelihood of quitting smoking.

Reid et al. evaluated the efficacy of a stepped-care approach to smoking cessation treatment among smokers with coronary artery disease (CAD).^125^ Stepped care refers to the practice of initiating treatment with low-intensity intervention and then exposing treatment failures to successively more intense interventions. Smokers hospitalized with CAD were provided a brief cessation intervention. The participants then were assigned randomly to either a more intensive stepped-care treatment (counseling and nicotine patch therapy) or no additional treatment.

In the second study of this type, Ratner et al. designed an intervention to help smokers abstain from smoking before surgery, maintain abstinence postoperatively, and achieve long-term cessation.^124^ Their intervention included counseling and nicotine replacement therapy. Finally, one study examined the effects of three smoking cessation counseling interventions for hospital patients: (1) modified usual care, (2) brief advice, and (3) brief advice plus more extended counseling during and after hospitalization.^112^ Pharmacological aids were not provided. Inpatients in four hospitals were randomly assigned to each condition and followed up at 7 days and 12 months postdischarge.

None of these studies showed significant differences in 12-month abstinence. In two studies, significant differences in abstinence emerged for the short term (i.e., 3 months and 6 months). In the stepped-care intervention study, treatment increased smoking cessation rates from 42 percent to 53 percent during a 3-month follow-up period (P = 0.05).^125^ In the Ratner et al. study, treatment group participants (73.0 percent) were more likely to abstain from smoking before surgery than were controls (53.0 percent) (X^2^ [1, N = 228] = 8.89; P = 0.003), and they were also more likely to be abstinent 6 months after surgery (31.2 percent vs. 20.2 percent) after controlling for covariates in a logistic regression analysis.^124^

Pregnant women. A three-group randomized controlled trial was conducted from 1996 to 2001, with 583 women and their partners randomized to usual care (UC), a woman-only (WO) intervention, or a partner-assisted (PA) intervention.^122^ Followups occurred at 28 weeks of pregnancy and 2-, 6-, and 12-months postpartum. Women in the UC condition received provider advice to quit and a self-help guide. The WO group received UC components plus a late-pregnancy relapse prevention kit (booklet and gift items) and six counseling calls (three in pregnancy and three postpartum) initiated by a health advisor. Women in the PA group received the WO intervention, and their partners received telephone counseling and a support guide emphasizing skills to help the woman build and maintain her confidence to quit smoking. Partners who smoked also received cessation aids and related counseling.

Intent-to-treat analyses showed no significant differences by condition in women's reports of abstinence at any followup.^122^ In late pregnancy, more partners were abstinent in the PA condition (15 percent) than in the UC condition (5 percent) (P = 0.02).

Racial and ethnic minorities. In a study of whether bupropion combined with smoking cessation counseling was effective in treatment of tobacco use in indigenous Maori in New Zealand, the investigators found quit rates similar to those observed in other trials of bupropion and no special problems related to bupropion use.^114^

## KQ 3. Implementation of Proven Population-Level Tobacco Use Cessation Strategies

Understanding and implementing evidence-based interventions remain major challenges for public health and clinical practice. Adoption and implementation of population-level tobacco use cessation strategies are no exception. Here we summarize current research on the efficacy of community and health care systems interventions to increase the implementation of such strategies. As elsewhere, we present information from prior systematic reviews and then summarize current literature. We start first with population-based strategies and then consider strategies based in provider settings and health care systems.

### Population-Based Strategies

Tobacco users are more likely to quit using tobacco if they are engaged in community-wide, comprehensive programs that use multiple channels to engage individuals.^7,^ ^130^ Comprehensive evidence-based programs usually include cessation services, policy initiatives such as smoke-free environments, increases in the unit price of tobacco products, worksite initiatives to increase cessation, and mass media education campaigns.^7^ Cessation services range broadly: widespread mass media campaigns to encourage quitting, provision of printed self-help materials, and intensive group or individual-based cessation therapies offered in-person or over the telephone or Internet.^131^

Synthesis of prior systematic reviews. A Cochrane review was the only previous report that evaluated the effectiveness of community-wide interventions to increase the implementation of proven population-level strategies for tobacco use cessation. The report defined a community intervention as a coordinated, multidimensional program aimed at changing adult smoking behavior, which involves several segments of the community and is conducted in defined geographical areas, such as town, city, county, or other administrative district. The aim was to identify factors in the design, implementation, or evaluation of such programs that may have influenced the smoking behavioral outcomes. The review included 32 studies that met inclusion criteria and two additional studies that compared more intensive with less intensive interventions but not with an “untreated” community.

The authors examined changes in smoking prevalence using cross-sectional follow-up data in 27 studies. For all adults, the net decline in smoking prevalence ranged from -1.0 percent to +3.0 percent per year in 10 studies.^36^ Analyses for women showed a net decline ranging from -0.2 percent to +3.5 percent per year (11 studies); those for men indicated a net decline ranging from -0.4 percent to +1.6 percent per year (12 studies). The authors were unable to provide estimates for changes in cigarette consumption or quit rates because their included studies reported such measures in different ways and, in the case of quit rates, over different time periods. In sum, little convincing evidence exists that community interventions reduce smoking among adults.

Synthesis of current literature. We identified three new studies that met inclusion criteria (Table 12). Two randomized trials aimed to deliver effective strategies to large numbers of smokers at a low cost.^131,^ ^132^ A pretest-posttest controlled group study investigated the effects of community intervention on smoking behavior and its determinants.^133^

Table 12 Community strategies to increase the implementation of proven population-level tobacco use cessation strategies

Author Year | Design | Intervention | N | Results | Quality Rating
Setting | Exposure
| Followup
Borland et al., 2003^131^ | RCT | G1: Offered self-help “Quit Pack”; 3 computer-generated tailored letters | 528 adolescents, young adults, and adults | No difference in smoking prevalence at 12-month followup | Good
Australia | 6 months | G2: Offered self-help “Quit Pack”; 3 computer-generated tailored letters; callback counseling service
Population-based | 3, 6, and 12 months baseline | C1: Offered printed, self-help “Quit Pack”
Maguire et al., 2001^132^ | RCT | G1: Initial interview with pharmacist; smoking cessation contract; NRT offered if appropriate; leaflet; weekly followup for 4 weeks, then monthly followup for 3 months | 484 adults | Significantly more participants in G1 had a validated (urinary cotinine) nonsmoking status at 12 months (G1: 14.3% C1: 2.7%; P ≤ 0.001) | Fair
United Kingdom | 3 months | C1: Normal pharmaceutical service (including the provision of NRT, as appropriate) provided by pharmacist
Community-based | 3, 6, 9, and 12 months
Ronda et al., 2004^133^ | Pretest-posttest control | G1: Regional mass Media-led smoking cessation campaign; local activities organized by local interested working groups | 8,939 adults | No significant differences between interventions regarding smoking status and determinants of smoking behavior | Fair
Netherlands, Western | | C1: Older mass media-led smoking cessation campaign, no local activities
Europe
Community-based

C, comparison group; G, intervention group(s); NRT, nicotine replacement therapy; RCT, randomized controlled trials.

One RCT (rated good) examined the effectiveness of a computer-tailored advice program for callers to a reactive telephone help line service in Australia. The RCT assessed whether the computer-tailored advice enhanced a series of callback telephone counseling sessions as an alternative and complementary effort to proactive telephone callbacks.^131^ This strategy was designed not only to reach larger numbers of smokers but also to test whether varying the intensity of the intervention and personalizing cessation assistance influenced cessation. Slightly more of the participants who received a combined intervention, namely, the computer-tailored advice plus callback telephone counseling, made an attempt between baseline and 3-month followup than did the other two groups (computer-tailored advice only; control group receiving no extra help).^131^ Significantly more people in the combination program who tried to quit in fact succeeded. The difference in point prevalence between the groups declined over time. It was not significant at the 12-month followup because of a nonsignificant trend among the groups that did not receive callbacks to start quitting.

Use of nicotine replacement therapy varied across the groups.^131^ The group receiving only computer-tailored advice reported significantly lower use rates than the other two groups (i.e., the control and the group that received the combination intervention). The investigators analyzed the potential effect of replacement therapy on smoking status at 3 months using logistic regression. Nicotine replacement significantly improved outcomes (OR, 2.04; 95% CI, 1.22–2.73; P < 0.001), as did callback telephone counseling (OR, 1.84; 95% CI, 1.36–3.02; P < 0.001); computer-tailored advice had no effect (OR, 1.11; 95% CI, 0.72–1.72; P = 0.63).

The results indicate the questionable value of computer-tailored cessation materials, but they are largely consistent with other research showing an association between the greater likelihood of quitting smoking and the use of nicotine replacement therapy or callback counseling. The ineffectiveness of the computer-tailored advice program was most probably attributable to the fact that the program did not meet the needs of smokers who were already motivated to quit and actively seeking help.^131^ No evidence suggested that combining the two interventions (i.e., the computer advice and telephone counseling) was effective because, in an earlier trial of the callback service, the quit rates were marginally higher than those observed in this study.^131^

The other trial (rated fair), seeking to deliver effective strategies to large numbers of people, evaluated whether a structured smoking cessation program based in community pharmacies in Northern Ireland and London would result in a higher smoking cessation rate compared with ad hoc advice from pharmacists.^132^ The intervention package, “Pharmacists' Action on Smoking” (PAS), used a one-to-one counseling format with structured followup; the intervention was compared with brief, unstructured advice. Study site pharmacies displayed a poster on smoking cessation throughout the study; television, radio, and newspaper media were used to advertise the project to the general public. Smoking cessation was promoted to those using the pharmacy for nonmedical reasons, those asking for advice on minor ailments, and those being dispensed medicine by prescription.

Significantly more subjects assigned to the PAS intervention had abstained for 12 months (cotinine-confirmed) than those not assigned to the PAS intervention: 14.3 percent vs. 2.7 percent (X^2^ = 16.2; P < 0.001).^132^ Use of nicotine replacement therapy was similar in both groups initially, but data were insufficient to estimate the contribution of either replacement therapy or counseling about replacement therapy use (or both) to overall cessation rates. Pharmacy type and size had no impact on the 12-month cessation rates.

The pretest-posttest control group design with two posttests (rated fair) evaluated the effects of a regional Dutch Heart Health Community intervention on smoking behavior and its determinants.^133^ The community intervention included a regional mass media-led smoking cessation campaign (“Congratulations!”) using radio commercials, advertisements, and messages in papers, billboards, posters, and postcards in waiting rooms and public buildings. Smaller local activities arranged by representatives of local organizations supplemented these regional efforts. The investigators hypothesized that this combination of regional and local strategies would be more effective than a national mass media-led smoking cessation campaign consisting of various television programs, an information line, nonsmoking courses, mailings to various organizations, billboards in bus shelters, brochures, posters, and other materials.

The researchers found no significant differences between the intervention region and the control region on smoking behavior and its determinants at either 24 months or 36 months after baseline.

### Provider and Health Care System-Based Strategies

Interventions in health care systems focus on two main approaches. One approach involves changing provider behavior relative to offering tobacco treatment services through provider education alone or with feedback and assessment. Another approach involves changing health care systems so that health care providers will be more likely to offer effective strategies either proactively or in response to client demand.^37^

Synthesis of prior systematic reviews. Two reviews provide information on this issue in terms of interventions based in settings other than full communities. One report is from the Task Force on Community Preventive Services;^7^ the other is the 2000 update of the 1996 AHCPR guideline.^5^

Zaza et al. reviewed six interventions that health care systems can use to increase cessation of tobacco use by their members.^7^ They reported “strong” evidence of effectiveness for provider reminder systems with provider education, with or without client education, and for multicomponent interventions that include client telephone support. Provider reminders with provider education include efforts to educate and prompt providers to identify and intervene with tobacco-using clients and to provide supplementary educational materials when appropriate. “Sufficient” evidence of effectiveness enabled the Task Force to recommend use of health care provider reminders alone and reductions in patient out-of-pocket costs. Provider reminders can carry various types of information and can be delivered by a variety of methods, including chart stickers, vital sign stamps, medical record flowsheets, and checklists. Lowering patient out-of-pocket costs reduces financial barriers that impede access to effective cessation therapies. Finally, the authors reported “insufficient” evidence of effectiveness to recommend provider education alone and provider feedback and assessment.

To facilitate adoption of effective tobacco treatment in health care settings, the AHCPR guideline update used meta-analyses to identify six effective systems strategies.^5^ These included (1) implementing a tobacco user identification system in every clinic; (2) providing education, resources, and feedback to promote provider intervention; (3) dedicating staff to provide tobacco dependence treatment and assessing the delivery of this treatment in staff performance evaluations; (4) promoting hospital policies that support tobacco dependence services; (5) including tobacco dependence treatments (both counseling and pharmacotherapy) identified as effective as paid or covered services for all subscribers or members of health insurance packages; and (6) reimbursing clinicians and specialists for delivery of effective tobacco dependence treatments and including those interventions among the defined duties of the clinicians.

Synthesis of current literature. Twelve new studies met all inclusion criteria (Table 13).^134^–^145^ Of these studies, three were RCTs;^140,^ ^142,^ ^144^ four, cluster RCTs;^134,^ ^138,^ ^139,^ ^145^ four, cross-sectional designs,^135,^ ^136,^ ^141,^ ^143^ and one, a time series design.^137^

Table 13 Strategies to increase implementation of population-level tobacco use cessation: provider-based and health care settings

Author Year | Design | Intervention | N | Results | Quality Rating
Setting | Exposure
| Followup
Cornuz et al., 2002^134^ | RCT with cluster randomization | G1: Active learning training program for residents; received the control training 4 months later | 251 young adult and adult patients | Those patients seen by intervention group residents more likely to be abstinent for at least 1 week at 1-year followup (P = 0.005) | Fair
Switzerland, Western Europe | 3 months | C1: Traditional didactic training program on management of dyslipidemia; received the intervention training 4 months later | 35 residents
Practice/provider settings | 1 year
Goldstein et al., 2003^141^ | Cross-sectional | G1: Physicians provided “4 As” to patients | 2,346 adults | At 2-year followup, patients who received the “4 As” were significantly more likely to quit smoking (P = 0.006) | Fair
United States | NR | G2: Smokers provided with computer-generated, stage-tailored cessation information at home
Practice/provider settings, community-based | 6, 12, 18, and 24 months | G3: Physician delivered “4 As” to patients, and patients received computer-generated, stage-tailored smoking cessation information at home
| | C1: No intervention
Joseph et al., 2004^143^ | RCT | G1: Organizational support, 2 day training sessions, smoking cessation medication | 5,678 adults | No effect on change scores between groups reporting whether their physician asked about smoking or provided counseled | Fair
United States | 2 days | C1: NR
Practice/provider settings | 6 and 12 months
Katz et al., 2004^142^ | RCT | G1: Study personnel worked with intake clinicians to implement guideline intervention; clinicians completed survey prior to implementation; After clinic visit, study personnel interviewed patients to evaluate whether they received cessation counseling | 1,221 adult patients | Intervention group RNs were the most likely to ask about smoking, assess willingness to quit, advise patients to quit, and assist patients in quitting (P = NR) | Fair
United States | 2 months | C1: Intake clinicians completed survey just before tutorial session at end of intervention period, but had no help with guideline implementation | 72 clinicians
Practice/provider settings | Immediate
Community-based
Katz et al., 2004^144^ | RCT | G1: Multicomponent office based intervention including a tutorial for intake clinicians on the AHRQ Guideline, performance feedback, offer of free NRT, and proactive counseling | 2,163 adult patients | Significantly more patients from practices who received the intervention were more likely to be asked by their clinician about their smoking status, willingness to quit, given literature about quitting, assisted in setting a quit date, engaged in a discussion about pharmacotherapy, or remain abstinent | Good
United States | 10.5 months | C1: Staff received general information on the AHRQ Guideline
Practice/provider settings | 2 and 6 months
Pbert et al., 2004^139^ | RCT with cluster randomization | G1: Clients visited community health centers and WIC offices that received provider training, an office reminder system, and establishment of program boards to coordinate the transfer of documentation among clinics | 550 adult pregnant women | Women in the intervention group more likely than those in the control to be abstinent at the end of pregnancy (G1: 26%; C1: 12%; OR: 2.57; P = 0.05) and 1 month postpartum | Fair
United States | 10 months | C1: Usual care | | (G1: 26%; C1: 11%; OR: 3.01; P = 0.04)
Practice/provider settings | End of pregnancy, 1, 3, and 6 months postpartum | | | No effect remained at 3- and 6-month followup
Pieterse, 2001^140^ | RCT with simple randomization | G1: Brief physician counseling; self-help manual; follow-up sessions | 530 young adults, adults | At 12 months, smoking abstinence rates were greater among those in the intervention compared with controls (G1: 13.4%; C1: 7.3%; OR = 1.51, CI: 1.1, 2.1; P < 0.05), as were consecutive abstinence rates (G1: 8.2%; C1: 3.1%; OR = 3.04, CI: 1.7, 5.6l; P < 0.001) | Fair
The Netherlands, Western Europe | NR | C1: Usual treatment—no counseling or advice on smoking except when initiated by the patient or when indicated by the contact reason
Practice/provider settings | 1 and 12 months
Piper et al., 2003^145^ | RCT | G1: Smoking added to vital sign stamp | 1,611 adult smokers | Significant increase (31%) in asking behavior of physicians in the smoking plus vital sign clinics (P = 0.0002); no difference in abstinence rates | Fair
United States | NR | C1: Usual vital sign stamp without smoking
Practice/provider settings | 12 months
Russos et al., 1999^135^ | Cross-sectional | G1: Orthodontists given antitobacco materials, training session on tobacco prevention, written antitobacco prescriptions and reimbursement for distribution, quarterly visits and calls; office staff asked to make office tobacco-free | 126 adults | In a typical week more clinicians in G1 vs. C1 provided prevention counseling to patients (Mean: 25.4% vs. 3%, Mann-Whitney U = 696.5, z = -7.0, P < 0.01) and at least some cessation counseling (91% vs. 72%, X^2^ = 8.4, P < 0.01) | Fair
United States | 2 years | C1: Orthodontists given no training, materials, or visits, nor asked to change their offices or practices
Practice/provider settings | 2 years postbaseline
Slama et al., 1999^136^ | Cross-sectional | G1: NA | 372 adult patients | None of the GPs' smoking-related attitudes and reported behaviors were significantly related to their participation in the study or to their patients' rates of smoking cessation at 1 or 12 months | Fair
France, Western Europe | NA | C1: NA | 2,680 general practitioners
Practice/provider settings | 1 and 12 months
Smith et al., 2002^137^ | Time series | G1: During hospitalization: physician advice on smoking cessation, bedside education and counseling with nurse, take-home materials, NRT if requested or indicated, 4 nurse-initiated postdischarge phone counseling calls | 1,077 adults | Including only those who were reached at 12 months, 49% reported being smoke-free for the previous 7 days. | Fair
United States | 3 months | C1: NA | | Including the 211 who were not reached at 12 months (intent to treat) and counting them as smokers, self-reported smoking cessation rate was 35%
Hospital | 1 year
Young et al., 2002^138^ | RCT with cluster randomization | G1: Family physicians received three academic detail visits, resources for FPs, resources for practices. and resources for patients | 1,788 adult patients | Improvements between baseline and posttest in patient recall of FP advice about nicotine replacement patches and gum were significantly greater in the intervention than the control group (P = 0.0056 and P = 0.0002, respectively) | Fair
Australia | 4 months | C1: Similar intervention to G1 in terms of intensity and format, but focused on cervical screening | 60 family practitioners
Practice/provider settings | 6 months postbaseline

“4 As” approach to tobacco-cessation counseling: (1) ask about tobacco use; (2) advise to quit; (3) assist with quitting; and (4) arrange for followup; C, control group; FP, family practitioner; G, intervention group; GP, general practitioner; NR, not reported; RN, registered nurse; WIC, Women, Infants, and Children program

Four randomized trials, three rated fair quality and one rated good, investigated efforts to train providers in effective strategies.^134,^ ^140,^ ^142,^ ^144^ One study also trained general medicine residents.^134^ Eight studies describing interventions conducted in health care systems to improve use of effective cessation strategies met all inclusion criteria and received quality ratings of fair.^135^–^139,^ ^141,^ ^143,^ ^145^ Six of these studies used some variation of an academic detailing approach (i.e., personal educational visits to clinicians in their own practice setting) to increase system support for cessation interventions.^135,^ ^138,^ ^139,^ ^141,^ ^143,^ ^145^ One study examined the effect of physician attitudinal and behavioral variables on participation and effectiveness of general practitioners in offering a minimal smoking cessation intervention.^136^ The group effectiveness study evaluated how a previously proven effective smoking cessation intervention is integrated into standard hospital practice.^137^

Provider-based interventions. Researchers in one study designed training programs to help general practitioners and their practice assistants^140^ and general medicine residents.^134^ The aim was to help providers acquire and apply skills to help their patients quit smoking. Two other studies implemented AHCPR strategies^5^ in practice and internal medicine clinics to facilitate adoption of effective tobacco treatment in health care settings.^142,^ ^144^

Both training programs included skills training in counseling approaches tailored to smokers' readiness to quit smoking and instruction in the use of written self-help materials for patients. General practitioners' office assistants were also trained to apply the randomization and informed consent procedures.^140^ To evaluate the effects of the training, Pieterse et al. randomized eligible smokers into two groups.^140^ One group received brief (10-minute) counseling sessions with the physician that are based on the stages of change model, a self-help manual, and follow-up sessions led by practice assistants; the other group received usual care consisting of no counseling or advice on smoking except when initiated by the patient or when indicated by the contact reason (in which case, counseling was limited to straightforward stop-smoking advice and possibly referral to local municipal health organizations).

At 1-month followup, smoking abstinence rates were greater among those in the intervention group than among controls (OR, 2.56; 95% CI, 1.8–3.8).^140^ This relationship held at the 12-month followup (OR, 1.51; 95% CI, 1.1–2.1). Continuous abstinence was also greater among intervention group subjects than among controls (OR, 3.04; 95% CI, 1.7–5.6).

In evaluating training for general medicine residents, Cornuz et al. stratified residents by clinic either in an intervention group trained in smoking cessation or in a control group trained in dyslipidemia.^134^ The control group received training in the intervention 4 months later, after the 3-month patient recruitment period had ended. Eligible patients identified as smokers were randomly assigned to intervention (i.e., residents trained in smoking cessation) or control clinics (i.e., residents trained in managing dyslipidemia).

According to smokers' self-reports, trained residents used all counseling strategies significantly more often than control residents.^134^ These strategies included assessing motivation to quit (29 percent vs. 19 percent, P = 0.05), offering help to quit (23 percent vs. 7 percent, P = 0.003), discussing benefits of cessation (21 percent vs. 12 percent, P = 0.05) and obstacles to cessation (16 percent vs. 6 percent, P = 0.01), giving a brochure (14 percent vs. 1 percent, P < 0.001), discussing strategies to prevent relapse (15 percent vs. 6 percent, P = 0.01), and setting a quit date (8 percent vs. 2 percent, P = 0.02). Compared with control residents, trained residents expressed significantly higher self-confidence (mean scores of 7.7 vs. 5.2; P = 0.002) and also a nonsignificantly higher level of self-perceived effectiveness in smoking cessation counseling (mean scores of 6.8 vs. 5.4; P = 0.09) 3 months after training.^134^ At 12-month followup, 1-week smoking abstinence was significantly higher in the intervention group than in the control group (13 percent vs. 5 percent, cluster-adjusted OR, 2.8; 95% CI, 1.4–5.5). The proportion of smokers willing to quit was significantly higher in the intervention group than in the control group (94 percent vs. 80 percent; P = 0.007). Daily cigarette consumption tended to be lower in the intervention than in the control group, but the groups did not differ significantly. The groups also did not differ significantly in the proportion of smokers in the precontemplation stage or the proportion of smokers who moved forward one stage, applying the principles of educational outreach to improve clinical decisionmaking.

Katz et al. tested the effectiveness of a multimodality intervention to implement the AHCPR Smoking Cessation Clinical Practice Guideline in six family practice and two internal medicine clinics.^144^ The intervention consisted of a tutorial for intake clinicians that instructed them on how to assess the patient's smoking status and how to provide brief smoking cessation messages to each smoker with feedback on performance, real-time reminders (i.e., modified vital sign stamp), onsite pharmacotherapy, and proactive telephone counseling.

Face-to-face interviews were conducted with clinic patients immediately after their office visit to assess how the clinic staff had performed guideline-recommended activities. In addition, clinic patients were contacted by telephone by study personnel, blinded to treatment group, and asked about their smoking habits at 2 and 6 months following the exit interview. Clinic patients who reported not smoking at 6 months were mailed kits for saliva collection to verify biochemically self-reported abstinence.^144^

During the intervention period, more patients at intervention clinic sites were asked about their smoking status (OR, 3.1; 95% CI, 1.2–8.2; P = 0.02) and their willingness to quit smoking (OR, 6.4; 95% CI, 3.7–10.8; P < 0.001), were given literature about quitting (OR, 21; 95% CI, 8.8–49; P < 0.001), were assisted with setting a quit date (OR, 33; 95% CI, 11–100; P < 0.001), or were engaged in a discussion about pharmacotherapy (OR, 3.9; 95% CI, 2.5–6.3; P < 0.001). Among patients treated during the intervention period, those at intervention clinic sites were more likely than those at control sites to report being abstinent at the 2-month mark (16.4 percent vs. 5.8 percent, adjusted OR, 3.3; 95% CI, 1.9–5.6; P < 0.001) and the 6-month mark (15.4 percent vs. 9.8 percent; adjusted OR, 1.7; 95% CI, 1.2–2.6; P = 0.009) and to report continuous abstinence (10.9 percent vs. 3.8 percent). Although planned collection of confirmatory salivary cotinine tests of self-report cessation had very low response rates, the confirmed abstinence rates at 6 months showed no difference between intervention clinics and controls.^144^

A secondary analysis^142^ of data from the same RCT of guideline implementation determined whether intake clinicians (registered nurses [RNs] and less costly personnel (licensed practical nurses [LPNs] and medical assistants [MAs]) are similar when performing smoking cessation activities that AHCPR guidelines had recommended.^5^ Using patient exit interviews, the investigators obtained information on differences in performance among RNs compared with MAs, RNs compared with LPNs, and LPNs compared with MAs. Patients were queried whether their intake clinician asked about their smoking, assessed their willingness to quit, gave them advice about quitting, and assisted them in quitting.

Performance of all guideline-recommended counseling activities was significantly greater for all types of nursing personnel at test sites than at control sites.^142^ MAs were significantly less likely to assess willingness to quit (adjusted OR, 0.4; 95% CI, 0.2–0.8, P = 0.005); they also tended to offer advice and assistance in quitting less often than RNs. Similar findings were observed for LPNs assessing willingness to quit (adjusted OR, 0.5; 95% CI, 0.3–1.0; P = 0.03). After accounting for personal beliefs, self-efficacy, and role satisfaction in cessation counseling, subset analysis in subjects with complete survey data revealed that being seen by an MA was no longer associated with statistically significant differences in performance. These results indicate that MAs and LPNs were less likely than RNs overall to perform actions recommended by the AHRQ smoking cessation recommendations.

Health care systems interventions. Practice sites for academic detailing interventions included community health centers, clinics in the Women, Infants, and Children (WIC) program, orthodontists' offices, primary care clinics, and family physician practices. Specific elements of an academic detailing approach varied across the six studies, but included

- An in-service training for staff members on how to asses and document smoking status as a part of regular collection of vital signs;^145^
- A 1.5-hour workshop, antitobacco materials, reimbursement for provision of antitobacco prescriptions, and quarterly check-up visits;^135^
- Provider training to deliver a smoking intervention based on national clinical practice guidelines tailored to the woman's stage of change and delivered through three channels (obstetric, pediatric, and WIC providers);^139^
- An office practice management system to routinely screen for smoking status, prompt/remind providers to intervene, document the encounter, distribute materials and arrange followup;^139^
- Establishment of program boards to coordinate the transfer of documentation among clinics, including periodic meetings with representatives from all clinics;^139^
- Two to three day site visits designed to communicate with Directors, Pharmacy Service Chief, smoking cessation coordinators and primary care nurses about barriers to implementation of AHCPR Smoking Cessation Guidelines;^143^
- Audit, feedback, and academic detailing for family physicians;^138^ and
- Four or five physician-centered office visits in the intervention counties to encourage physician adoption of a smoking cessation strategy based on the “4As” model from the National Cancer Institute (NCI) and distribution of a copy of the NCI manual How to Help Your Patients Stop Smoking.^141^

Studies examined whether significant effects were achieved on clinician uptake and use of cessation strategies, on cessation rates among patients served by these clinicians, or both. Investigators used various approaches to assess clinician uptake and use of cessation guidelines and other evidence-based strategies, including exit, telephone, and other interviews of patients, medical record audit, and mail or telephone provider surveys. Study designs included three randomized trials with cluster randomization,^138,^ ^145^ two cross-sectional^139^ studies,^135,^ ^143^ and a community-based quasi-experimental study.^141^

A multifaceted, practice-based intervention involving audit, feedback, and academic detailing to improve family physicians' use of evidence-based smoking cessation strategies enrolled 60 family physicians from 39 practices.^138^ Their provision of smoking cessation advice was measured by patient recall, medical record audit, and self-report. Improvements between baseline and posttest in patient recall of physician advice about nicotine replacement patches and gum were significantly greater in the intervention group (P = 0.0056) than in the control group (P = 0.002).^138^ Substantial increases occurred in patients' recall of assessment of smoking status and family physicians' use of quit dates, behavioral advice, and written materials in the intervention group, but these changes were not significantly greater than those in the control group. Notation of patient's smoking status and smoking cessation advice in medical records remained suboptimal in both groups.

Providers in community health centers and WIC offices received training to deliver a smoking intervention based on national clinical practice guidelines.^139^ The program included (1) provider training tailored to the woman's stage of change and delivered through three channels (obstetric, pediatric, and WIC providers); (2) an office practice management system to screen routinely for smoking status, prompt/remind providers to intervene, document the encounter, distribute materials, and arrange followup; and (3) establishment of program boards to coordinate the transfer of documentation among clinics, including periodic meetings with representatives from all clinics. Providers in control clinics provided usual care. Five community health centers were randomized to intervention or usual care. Subjects were pregnant or postpartum women who were current smokers or smokers who had quit during pregnancy.

The intervention and usual care groups differed significantly in 30-day abstinence rates at the end of pregnancy among women who had not quit spontaneously upon learning of their pregnancy (26 percent vs. 12 percent; OR, 2.57; P = 0.05).^139^ This effect remained at 1 month postpartum but was lost at 3- and 6-month postpartum followups.

Staff members in outpatient primary care clinics who usually take vital signs for each patient received in-service training on how to assess and document smoking status as part of the regular collection of patient information.^145^ On exiting the clinic, patients were asked questions about their smoking habits and smokers were asked to participate in a follow-up telephone interview in 1 year. These later interviews revealed no statistically significant difference between either the intervention or control clinics for point-prevalence abstinence from baseline to the intervention phase. Chi square analysis indicated that abstinence was independent of being asked about smoking, receiving advice to quit, being prescribed nicotine replacement therapy, or having a follow-up appointment.

Orthodontists in private practice offices participating in a controlled trial to decrease the incidence of tobacco use among adolescents were enrolled in a cross-sectional interview study to determine the rate and determinants of tobacco prevention and cessation counseling to youth.^135^ The experimental group received a 1.5-hour workshop, antitobacco materials, reimbursement for provision of antitobacco prescriptions, and quarterly check-up visits. Control group clinicians did not receive training materials or visits.

Orthodontists in the experimental group were more likely than those in the control group to ask their patients whether they use tobacco (4.8 percent vs. 2.9 percent; P < 0.01), to provide at least some cessation counseling to their patients who smoked (91 percent vs. 70 percent; X^2^, 8; P < 0.01), and to report mostly positive reactions from tobacco users for cessation counseling (X^2^, 7.8; P < 0.05).^135^ Demographic, office, and clinic practice variables were not associated with cessation counseling. Higher rates of cessation counseling were associated (all P < 0.05) with asking patients whether they used tobacco, belief that counseling is important, belief that clinicians should receive counseling training, intention to attend training, and disagreement that counseling is not part of their job description.

The study that tested implementation of the tobacco guideline randomized 20 Veterans Affairs Medical Centers to an intervention or control group.^143^ A multicomponent intervention was designed to increase three specific guideline recommendations: (1) documentation of tobacco use status in medical records, (2) delivery of cessation intervention to all smokers, and (3) liberal use of pharmacotherapy for smoking cessation. In a 2-day training meeting, the three target strategies were presented to physicians, nurses, psychologists, and pharmacists. The training recommended using electronic medical records to identify smokers, giving smoking cessation treatment within the primary care setting rather than using referral-based care, and removing restrictions to prescriptions of smoking cessation aids. Site visits by an interventionist provided academic detailing on barriers to implementation strategies.^143^

Cross-sectional surveys were conducted at baseline and 1 year later (i.e., after the intervention) among a sample of randomly selected patients who had seen their primary care provider within 6 weeks. A cohort of current cigarette smokers identified at baseline also completed a follow-up survey 1 year after the intervention. At the 1-year point, medical records showed a significant effect on smoking status documentation (intervention medical records were more likely to document smokers than were those of the control group, 67 percent vs. 60 percent, P = 0.0007). The groups did not differ in quit rates, providers asking about smoking status, or being counseled to quit smoking.

In a community-based quasi-experimental study, Goldstein et al. delivered an academic detailing intervention to physicians in intervention counties during a 15-month period. The multicomponent office-based intervention aimed to increase primary care physicians' adoption, implementation, and maintenance of the NCI “4As” as a smoking cessation strategy. The intervention included four or five physician-centered visits and distribution of a copy of the NCI manual How to Help Your Patients Stop Smoking. The program was implemented through personal educational visits to clinicians in their own practice settings.^141^

Among smokers reporting a physician visit during the study period, the investigators reported a borderline significant effect at 24-month followup for those residing in intervention areas compared with those residing in control areas (OR, 1.35; 95% CI, 0.99–1.83; P = 0.057).^141^ Patients of experimental group physicians reported that about 60 percent of their doctors talked to them about smoking and advised them to quit; the figure was about 55 percent for control group physicians (X^2^, 13.8; P = 0.000 [sic]).^141^ In a subgroup analysis, after controlling for confounding factors, Goldstein et al. also reported that, among smokers who visited an enrolled physician, those residing in physician intervention counties were significantly more likely than those residing in control counties to quit smoking at 24 months (adjusted OR, 1.80; 95% CI, 1.16–2.75, P = 0.008). Stage of change at baseline was the only other significant predictor of smoking cessation at 24 months (adjusted OR, 2.75; 95% CI, 1.89–3.98; P = 0.000 [sic]).

One interview-based study (rated fair) examined the effect of physician attitudinal and behavioral variables on participation and effectiveness of general practitioners (GPs) to offer a minimal smoking cessation intervention.^136^ Attitudinal variables included (1) individual GP assessments of the influence of GPs in general, and of themselves in particular, on prevention efforts aimed at both smokers and other patients and (2) assessments of the potential that modern medicine has to affect disease outcome through screening and treatment. Behavioral variables included individual reports of knowing their own cholesterol level, being careful about diet, exercising regularly, and watching their weight. Matched pairs of smoking and nonsmoking GPs were invited to participate in a regional smoking cessation intervention.

Among the GPs who initially accepted, a significantly higher proportion of GP nonsmokers than GP smokers participated in the study (54.1 percent vs. 45 percent, X^2^, 5.147; P < 0.05).^136^ Nonetheless, those GP smokers who did participate achieved results similar to those of nonsmokers when comparing the success or lack of success in their patients' reports of quitting smoking. The smoking status of GPs was not significantly related to either point prevalence smoking status at 1 and 6 months or to sustained abstinence. These findings suggest that when minimal advice has an effect, that effect can be attributed more to the systematic nature of the intervention provision than to the attitudes or reported practices of the provider offering the advice.

A group effectiveness study (rated fair) evaluated how an RCT smoking cessation intervention, previously proven effective, was integrated into standard hospital practice.^137^ Although this study had no comparison group, it provides useful, detailed data about continuation of a smoking cessation program. The intervention examined a nurse-managed smoking cessation program for general hospitalized patients, which continued for 3 years after trial completion. The intervention included physician advice, bedside education and counseling by a nurse specially trained in smoking cessation techniques, take-home materials (i.e., a videotape, workbook, and relaxation audiotape), nicotine replacement therapy if requested or indicated, and four nurse-initiated, postdischarge telephone counseling calls.

Of the patients identified as smokers, 50 percent enrolled in the program, 18 percent wanted to quit on their own, 20 percent did not want to quit, and 10 percent were ineligible.^137^ The 12-month self-reported cessation rate (7-day point prevalence) was 35 percent if patients lost to followup were considered smokers and 49 percent if they were not. Patients hospitalized for cancer, cardiovascular, or pulmonary reasons were most likely to participate, and they had the highest self-reported cessation rates (cancer: 63 percent, cardiovascular: 57 percent, and pulmonary: 46 percent).

## KQ 4. Effect of Smokeless Tobacco Product Marketing and Use on Population Harm from Tobacco Use

In our systematic review of the effects of smokeless tobacco product marketing and use on population harm from tobacco use, we specifically examined three issues: (1) whether substituting smokeless tobacco for smoking leads to less smoking-related harm on a population basis, (2) whether smokeless tobacco marketing leads to greater use or substitution of smokeless tobacco for smoking (or both), and (3) whether data on harms and harm reduction associated with smokeless tobacco are used to model the potential health effects of substituting smokeless tobacco for smoking. As elsewhere, we present information from prior systematic reviews and then summarize current literature.

### Effects of Smokeless Tobacco Product Marketing and Use

Adolescents and young adults continue to be a strategically important market segment for the tobacco industry.^15^ During 2001, the largest tobacco manufacturers spent $236.7 million on smokeless tobacco advertising and promotion, using images that portray the attractiveness of tobacco products.^18^ Growth in sales of smokeless tobacco moist snuff has been attributed to advertising and marketing campaigns that encourage young nonusers to experiment with low-nicotine starter products. Once adolescents or young adults begin to use smokeless tobacco, the tobacco companies' intent is to move new users to higher nicotine brands as nicotine dependence progresses.^2^ An estimated 7 percent of high school students are current users of smokeless tobacco; males are the primary consumers.^20^ Adolescents who use smokeless tobacco are more likely than nonusers to become smokers.^15^

Recently, tobacco companies have begun to market their smokeless tobacco products as less harmful alternatives to smoking tobacco, emphasizing that smokeless tobacco does not carry the same risks to others that are associated with smoking (i.e., secondhand and environmental tobacco smoke).^46^ We believe it is too early to determine whether these harm reduction approaches to smokeless tobacco marketing are effective in increasing product use; however, we have included this issue in our literature search for KQ 4.

Synthesis of past literature reviews. Two types of smokeless tobacco are sold in the United States: chewing tobacco (i.e., loose leaf tobacco, plug, or twist) and snuff (i.e., finely ground tobacco that can be dry, moist, or in sachets).^18,^ ^19^ Smokeless tobacco can lead to nicotine addiction and dependence.^17^ Evidence from the Surgeon General and others has linked smokeless tobacco causally with oral leukoplakia and oral cancers.^2,^ ^39^ Since 1964, the Surgeons General reports have continuously examined the role cigarettes and smokeless tobacco play in developing cancers of the oral cavity and pharynx. As research has progressed, conclusions indicate that all forms of tobacco use (i.e., cigarettes, pipes, cigars, snuff, chewing tobacco, betel, and other smoked and smokeless products) can cause malignancies in any part of the oral cavity and pharynx except the salivary glands.^1,^ ^2,^ ^6^ Specific risks associated with the use of smokeless tobacco products are advanced periodontal disease, tooth decay, leukoplakia, stomach and pancreatic cancers, and heart disease.^1^

Treating nicotine addiction (from cigarettes, pipes, cigars, and smokeless tobacco) will help prevent most of the approximately 30,200 new cases of cancer and 7,800 deaths from these cancers that occur annually in the United States. Eliminating smokeless tobacco use will prevent 12,300 new cases of esophageal cancer alone and 12,100 deaths from esophageal cancer annually.^1^

Limited research indicates that increases in smokeless tobacco prices will reduce the use of smokeless tobacco, particularly by adolescents and young adults. Nonetheless, the tax on smokeless tobacco is well below that on cigarettes. Although increases in cigarette prices may reduce smoking among youth, increases may also boost the likelihood of smokeless tobacco use.^2^

Recommendations from the updated AHCPR tobacco cessation guideline advise treating users of smokeless tobacco with the same counseling cessation interventions recommended for smokers.^5^ Studies of pharmacotherapies to address nicotine dependence on tobacco have not provided sufficient evidence showing long-term abstinence among users; specifically, gum and nicotine patches have not increased abstinence rates.^5^ Because oral lesions caused by smokeless tobacco use are common, dental clinicians are in a suitable position to use minimal interventions to reduce smokeless tobacco use.^2,^ ^5^ Recently, behavioral interventions by dental clinicians using oral examinations with feedback about the mucosal changes associated with smokeless tobacco use have had positive effects on abstinence (OR, 2.41; 95% CI, 1.79–3.24).^57^ This finding suggests that dental health clinicians are in an opportune position to deliver brief but efficacious interventions to smokeless tobacco users.

Prior systematic reviews did not address issues relevant to KQ 4. Past reviews focused on risks associated with the use of smokeless tobacco and on the potential offered by smokeless tobacco cessation treatments. Information on tobacco product marketing is more likely to be disseminated in editorials, summary articles, and newspaper articles that were excluded from this review.

Synthesis of current literature. Our review of smokeless tobacco product marketing and use found no studies evaluating whether substituting smokeless tobacco for smoking results in less smoking-related harm; we also did not identify any studies indicating that any researchers have used data on harm and harm reduction associated with smokeless tobacco to model the potential health effects of substituting smokeless tobacco for smoking. We found two studies (both rated fair) that assessed whether smokeless tobacco marketing leads to greater use of these products or to substitution of smokeless tobacco for smoking (Table 14).^146,^ ^147^ Both studies were population-based, used a cross-sectional design, and recruited only adolescent boys or young adult males.

Table 14 Characteristics and results of studies assessing the effects of smokeless tobacco marketing

Author Year | Design | Survey | N | Results | Quality Rating
Setting
Choi et al., 1995^146^ | Cross-sectional | Youth Attitudes and Practice Survey | 2,814 adolescents, young adult males | Among adolescent boys, recall of smokeless tobacco advertisements was associated with smokeless tobacco use: | Fair
California | | | | OR, 7.5; 95% CI, 3.1–18.1
Population-based
Tomar et al., 2003^147^ | Cross-sectional | Teenage Attitudes and Practice Survey (TAPS-I and -II) | 3,996 adolescents, young adult males | Significantly more users than nonusers of smokeless tobacco became smokers during 4 years of followup: | Fair
United States | | | | OR, 3.45; 95% CI, 1.84–6.47
Population-based

CI, confidence intervals; OR, odds ratio.

In the larger study (N = 3,996 responders; response rate 62 percent), adolescent and young adult males 11 to 19 years of age provided information on their smoking and smokeless tobacco use behavior through responses on the Teenage Attitudes and Practice Survey (TAPS-I and -II) in 1989 and 1993.^147^ The investigator used responses on these US-wide surveys to assess 4-year initiation rates of smokeless tobacco use and cigarette smoking in relation to each other; the investigator also examined switching between products.

In a multiple logistic regression analysis, which was adjusted for age and race, males who had been regular users of smokeless tobacco were more than three times as likely as never-users of smokeless tobacco to become smokers (OR, 3.45; 95% CI, 1.84–6.47). Current smokers were not different from never-smokers in the rate of initiating current regular use of smokeless tobacco (OR, 1.45; 95% CI, 0.5–4.22). Among males who were regular smokeless tobacco users but not smokers at baseline, 44.8 percent continued to exclusively use smokeless tobacco at followup, 25.5 percent switched to smoking at followup, 14.3 percent continued to use smokeless tobacco while also smoking at followup, and 15.2 percent were no longer using tobacco. Of the smokers at baseline who were not users of smokeless tobacco, 78.7 percent were still smokers 4 years later, 0.8 percent switched to using smokeless tobacco exclusively, 3.6 percent continued to smoke but also used smokeless products, and 16.9 percent stopped using tobacco altogether.^147^

The other study (N = 2,814) assessed susceptibility to smokeless tobacco advertising in terms of risk factors in a study among adolescent and young adult males in California.^146^ This analysis used the Youth Attitudes and Practice Survey (conducted in 1990, 1992, and 1993); the majority of the analysis was based on data from 1993. The investigators contacted a stratified random sample of young adults and adolescents 12 to 17 years of age through random-digit dialing and interviewed them to assess trends in smokeless tobacco use. The researchers specifically identified risk factors that distinguished youth who used or were at risk of using smokeless tobacco. Risk factors included current tobacco use, exposure to tobacco advertising and other smokeless tobacco users, susceptibility to use smokeless tobacco, level of rebelliousness, peers' use of drugs or alcohol, and peer norms.

Findings from the 1993 survey documented that the highest rate of smokeless tobacco use occurred among subjects 16 and 17 years of age (6.6 percent; 95% CI, 4.1–9.1). Exposure to smokeless tobacco advertisements was twice as high among males 16 to 17 years of age than among those 12 to 13 years of age (43.8 percent [95% CI, 38.8–48.8] and 21 percent [95% CI, 17.4–24.6], respectively). Recall of smokeless tobacco advertisements was significantly associated with smokeless tobacco use (AOR, 7.5; 95% CI, 3.1–18.1; P < 0.001). In addition, cigarette smokers were at greater risk of being smokeless tobacco users than youth who did not smoke (AOR, 3.3; 95% CI, 1.9–5.7; P < 0.001).^146^

## KQ 5. Effectiveness of Prevention and Cessation Interventions in Populations with Co-Occurring Morbidities and Risk Behaviors

Our final systematic review investigated smoking prevention and cessation interventions in populations with co-occurring morbidities and risk behaviors. For this report, we define a person with co-occurring disorders as one who has a psychiatric condition and a nicotine addiction. Psychiatric conditions include depression, anxiety, personality disorders, traumatic stress disorder, attention deficit disorder, eating disorders, disruptive behavioral disorders, and schizophrenia. We also identify risk behaviors as behaviors that trigger or exacerbate tobacco use, such as alcohol abuse and other chemical dependencies.

As with other sections, we present information on previous systematic reviews as the background or context for recommendations to date. We then examine specific studies identified over and beyond those reviews.

### Populations with Psychiatric Conditions

People with psychiatric conditions are twice as likely to smoke as the general population and to smoke more heavily than other smokers.^30^ As many as 30 percent of smokers seeking cessation treatment have a history of depression.^5^ Smoking cessation rates reported for the psychiatric population are lower than rates reported for the nonpsychiatric population.^30^

People with psychiatric conditions may use nicotine to self-medicate. Neurobiological and psychosocial factors reinforce the use of nicotine in populations with co-occurring disorders. Traditional antipsychotics used for certain psychiatric conditions may result in increased smoking, whereas patients taking atypical antipsychotics may smoke less.^148^ Smoking improves processing of auditory stimuli in patients and may lessen negative symptoms by increasing dopamine in the prefrontal and frontal cortex.^148^ Smoking is also an integral part of psychiatric culture because it provides a daily pastime for patients who may otherwise have few activities to pursue.^30^ With new smoking bans enforced in health care facilities, more information on the outcomes of smoking cessation strategies tailored to these specific populations is needed.

Synthesis of prior systematic reviews. Approaches to increase quit rates among individuals with psychiatric conditions include medications, educational strategies, and cognitive behavior modifications.^30^ Smoking behavior in psychiatric populations remains a challenge, with health concerns and costs similar to those for nonpsychiatric populations. Although psychiatric populations have lower smoking cessation rates than nonpsychiatric populations, in the absence of relevant RCTs on smoking cessation for populations with psychiatric comorbidities, experts agree that clinicians should use smoking cessation treatments recommended for the general population, such as pharmacotherapies and counseling.^5,^ ^30^

Synthesis of current literature. We found six studies related to KQ 5; all relate to cessation efforts.^113,^ ^149^–^153^ We found no studies on prevention per se; as this question is phrased, the populations of interest are already smoking. Table 15 presents information on five of these six studies. One study^153^ was graded as poor because of postrandomization of exclusions and other major flaws, so it is not discussed further. Detailed information is presented in Evidence Table 9 (Appendix C).^§^ Of the studies discussed for KQ5, we rated one as good and the other four as fair.

§ Appendixes cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/tobusetp.htm.

Table 15 Tobacco cessation interventions for persons with co-occurring morbidities and risk behaviors

Author Year | Design | Intervention | N | Results | Quality Rating
Setting | Exposure
| Followup
Studies in Psychiatric Populations
Brown et al., 2001^150^ | RCT | G1: Group CBT for smoking cessation plus additional CBT on coping for depression | 179 formerly depressed adults | In the main analysis, smoking abstinence did not differ when CBT tailored for depression was added; in a secondary analysis CBT tailored for depression had significant interactions with both heavy smoking and recurrent depression | Fair
United States | 6 weeks | C1: Group CBT for smoking cessation alone
Population-based | 1, 6, and 12 months
Brown et al., 2003^151^ | RCT | G1: In-person motivational interviewing sessions, offer of nicotine patch, postdischarge telephone counseling (MI) | 191 hospitalized adolescents for psychiatric disorders | 7-day point prevalence rates | Fair
United States | Variable, dependent upon the length of stay | C1: Brief in-person advice, on cessation, pamphlet and shorter course of nicotine patch (BA) | | At 1 month; - MI arm: 11%; - BA arm: 11%
Psychiatric hospital | 1,3,6,9, and 12 months | | | At 6 months; - MI arm: 13.3%; - BA arm: 8.5%
| | | | At 12 months; - MI arm: 14%; - BA arm: 9.9%
| | | | P = NS
| | | | Anxiety disorders increased odds for quit attempts in adolescents with psychiatric disorders (AOR, 1.99; 95% CI, 1.08–3.71)
Hitsman et al., 1999^113^ | RCT | G1: Individual behavioral therapy; fluoxetine 30mg; quit date set, compliance level at 150ng/ml | 253 adults | At 1 and 3 months, for treatment-compliant patients, fluoxetine had a positive association with degree of depression and likelihood of abstinence (OR, 1.35; 95% CI, 1.00–1.81) | Fair
United States | 10 weeks | G2: Same as G1 except fluoxetine is a 60mg dose and compliance level set at 300ng/ml
Population-based | 1 week; 1, 3, and 6 months | C1: Same as G1 except received placebo
Studies in Substance-Addicted Populations
Joseph et al., 2004^149^ | RCT | G1: Individual behavioral therapy; recommended nicotine patches (21 mg for 6 weeks, 14 mg for 2 weeks, and 7 mg for 2 weeks) for smokers; combination of patches and nicotine gum for smokers of >20 cigarettes per day | 499 substance use disorder adults | At both 3 and 6 months, smoking abstinence rates were significantly greater in the treatment groups than the temporary control group | Good
United States | 10 weeks | C: Temporary control group with treatment delayed for 6 months | | (P < 0.000 and P = 0.02, respectively)
Residential substance use disorder treatment program | 3, 6, 9,12, and 18 months
Joseph, 1993^152^ | Prospective cohort study | G1: No specific information on smoking or cessation; smoking allowed in designated rooms and not during group sessions | 706 adults enrolled in a substance abuse treatment program | Patients who want to quit smoking | Fair
United States | 3 weeks | G2: Upon admission, patient signed contract to abstain from nicotine during stay; cessation program provided; clonidine patches available | | At 3-week followup; - Prepolicy: 24%; - Postpolicy: 61%
Hospital | 1 year after hospitalization | | | (P < 0.001)
| | | | Patients who quit smoking
| | | | At 1-year followup; - Prepolicy: 3%; - Postpolicy: 8%
| | | | (P < 0.05)

AOR, adjusted odds ratio; C, control group; CBT, cognitive behavioral therapy; G, intervention group(s); ng/ml, nanogram per milliliter; NS, not significant; OR, odds ratio; RCT, randomized controlled trials.

Three studies addressed smoking cessation interventions for populations with co-occurring morbidities.^113,^ ^150,^ ^151^ These RCTs, all rated fair, were conducted in the United States. One study implemented a smoking cessation intervention in a psychiatric hospital;^151^ the others were population-based interventions.^113,^ ^150^ One trial included adolescents and the other two enrolled adults; the sample sizes ranged from 179 to 253.

Brown and colleagues compared the efficacy of a standard CBT smoking cessation treatment with standard smoking cessation treatment combined with CBT for depression.^150^ Through newspaper, radio, and television advertisements, the study recruited regular smokers (i.e., smoked cigarettes for at least 1 year and currently smoke 10 cigarettes each day) between ages 18 and 70 years with a history of major depressive disorder (MDD) determined by structured interviews using the DSM-III-R. The 179 participants enrolled in the study received eight group counseling sessions over 6 weeks and standard CBT. Participants in the treatment group received “The Coping with Depression Course,” which served as the basis for the CBT.^150^

Self-report of smoking status was collected and verified by expired CO at each treatment session from the quit date to the end of treatment; follow-up data were collected by telephone at 1, 6, and 12 months. No statistical differences were identified in 7-day point prevalence abstinence rates at 1, 6, and 12 months for the standard CBT (30.1 percent, 24.7 percent, and 24.7 percent, respectively) compared with the depression-based CBT (39.5 percent, 24.4 percent, and 32.5 percent, respectively). In the final steps of the generalized estimating equations (GEE) analysis, significant interactions occurred between treatment and heavy smoking (OR = 3.73; P = 0.02) and between treatment and recurrent depression (OR = 3.62; P = 0.02).^150^

A second study from Brown and colleagues randomly assigned adolescent smokers between 13 and 17 years of age who had been hospitalized for psychiatric and substance use disorders into either a motivational interviewing (MI) or a brief advice (BA) tobacco cessation intervention.^151^ The MI arm consisted of two in-person, 45-minute motivational interviews during hospitalization.^151^ Participants in the MI arm received comprehensive manuals about relapse prevention and coping skills for mood management. Additionally, two courses of free transdermal nicotine patch therapy were offered to medically eligible participants. At the end of the MI intervention, participants received up to six postdischarge telephone counseling sessions, and their parents received up to four brief telephone counseling sessions. BA participants received 5 to 10 minutes of advice to quit smoking by one of the student therapists, a copy of the “I Quit!” self-help pamphlet, and (for those who were eligible) a one-time offer of a transdermal nicotine patch treatment regime.

The MI arm had 116 participants and the BA arm had 75 participants. The population was primarily female (62.3 percent) and white (94.8 percent). The mean age of participants was 15.4 years, and 68.6 percent met the Diagnostic and Statistical Manual for Mental Disorders, Fourth Edition (DSM-IV) criteria for nicotine dependence. Psychiatric disorders included mood, anxiety, disruptive behavior, attention deficit, and substance-related disorders. The investigators assessed nicotine dependence at 1, 3, 6, 9, and 12 months. Smoking abstinence, measured by self-report, was confirmed through biochemical verification using saliva cotinine.^151^

To assess whether MI would lead to more and longer quit attempts, reduced smoking, and more abstinence from smoking, Brown et al. employed hierarchical linear modeling, GEE analyses, and logistic regression.^151^ The findings did not show higher quit attempts for those receiving MI than those receiving BA (mean quit attempts = 1.1 vs. 1.3, P = not significant [NS]). Seven-day point prevalence abstinence at 1, 6, and 12 months was not significantly different between the groups (see Table 15 for point prevalence rates). The mean number of days for the longest quit attempt was 48.2 days for the MI group and 60.9 days for the BA group; however, this difference was not significant.

Two findings were associated with significantly less smoking among adolescent psychiatric patients.^151^ Examination of covariates revealed that having an anxiety disorder increased the odds for quit attempts (AOR, 1.99; 95% CI, 1.08–3.71); in the hierarchical linear model, higher discharge self-efficacy scores were associated with less smoking during followup (b_1_ = -0.02, standard error = 0.007; P = 0.007). MI and BA were equally ineffective smoking cessation interventions for this population.

Hitsman et al. hypothesized that smokers with greater depressive symptoms and those with elevated weight concerns would be more likely to achieve tobacco abstinence when receiving fluoxetine (combined with CBT) than when receiving a placebo (and CBT).^113^ The first arm involved nine 1-hour, individual CBT sessions plus 30 mg fluoxetine for a total of 10 weeks. Participants were required to set a quit date within 2 weeks of drug treatment initiation. Participants quit smoking at the third CBT session, and medication stopped at the ninth CBT session, at which time the 6-month follow-up period began. Patients with fluoxetine levels less than or equal to 150 ng/ml were considered compliant. The second arm was the same as the first arm except that the fluoxetine dose was 60 mg, and fluoxetine blood levels less than or equal to 300 ng/ml were considered compliant. The third arm of the trial was also the same as the first except that participants received a placebo.

Participants were considered to be smoking if expired CO was greater than 8 ppm and saliva cotinine values were greater than 10ng/ml. Level of depression, nicotine dependence, weight concerns, and self-efficacy about quitting were also assessed. Baseline measures were similar across all treatment groups. Hitsman et al. applied predictive models using logistic regression with a hierarchical approach to variable selection to analyze the data. Separate hierarchical logistic regression using intent-to-treat analysis failed to yield any stable predictive models for smoking status at 1 week and 1, 3, and 6 months after the quit date.^113^

An interaction between fluoxetine treatment and the depression score occurred at 1- and 3-month followup for treatment-compliant patients only (n = 169). Participants treated with fluoxetine had a positive association between degree of depression and likelihood of abstinence (OR, 1.35; 95% CI, 1.00–1.81); for controls, the opposite was true, and increasing depression scores were associated with decreasing likelihood of abstinence. The fluoxetine effect was greater for individuals with depression scores in the upper quartile of the depression scale (Hamilton Rating Scale for Depression [HRSD], 3; OR, 2.0; 95% CI, 0.85–4.7) than for individuals in the lower quartile of the depression scale (HRSD, 1; OR, 1.10; 95% CI, 0.38–3.19). At 3 months, the interaction effect was sustained; fluoxetine selectively benefited smokers with higher initial levels of depression (OR, 1.39; 95% CI, 1.02-0.89) and patients receiving fluoxetine showed a positive association between degree of depression and likelihood of abstinence (highest quartile HRSD = 3; OR, 1.44; 95% CI, 0.53–3.91). Smoking characteristics predicting treatment compliance were nicotine intake at baseline, saliva cotinine (X^2^, 11.4; P < 0.001), and expired CO (X^2^, 5.3; P < 0.05).^113^

### Populations with Substance Addictions

Smoking rates for alcohol and drug users are well above those for the average population, exceeding 70 percent.^5^ The risk of death is significantly higher for individuals with concurrent addictions of alcohol and nicotine than for individuals who abuse only alcohol or tobacco. Consequently, alcoholics are thought to be more likely to die from cigarette-related diseases than from alcohol-related diseases.^154^

The best way to approach smoking cessation treatment with people who have chemical addictions remains controversial. Additionally, some in the substance abuse treatment community argue (on the basis of untested assumptions) that smoking cessation treatment threatens the process of alcohol rehabilitation.^154^ Others claim that the opportunity to engage this population in smoking cessation treatment may be lost by delaying treatment until after sobriety.^24^

Synthesis of prior systematic reviews. Multimodal strategies using nicotine replacement therapy in conjunction with psychosocial intervention strategies are effective in treating tobacco addiction in patients with alcohol and other substance abuse problems.^9^ Fiore et al. report that people with chemical and nicotine dependency should receive counseling and pharmacotherapy to assist with smoking cessation.^5^ Although these types of interventions had positive short-term effects for stopping smoking, maintaining long-term abstinence was not successful.^9^ Evidence is clear that smoking cessation treatment does not interfere with recovery from chemical dependency.^9^ This finding eliminates obstacles to providing this population with concurrent treatment for substance abuse and nicotine dependency.

Synthesis of current literature. Three studies examined smoking cessation treatments for alcohol and substance abusers; we excluded one study from this discussion because of a quality rating of poor.^149,^ ^152,^ ^153^ The other two studies, both conducted in the United States, received a good^149^ and a fair^152^ rating. One study used a prospective cohort study design;^152^ the other was a RCT.^149^ Both enrolled adults in substance use disorder programs; the samples size ranged from 706 to 499.

To examine long-term smoking cessation outcomes, Joseph evaluated the feasibility of a smoke-free policy and a nicotine treatment program implemented in a drug and alcohol treatment hospital.^152^ Patients admitted to the treatment facility were consecutively enrolled in the study. In 1988, before implementation of the smoke-free policy, patients were not provided with specific information about smoking or cessation. Patients in the facility when the smoke-free policy changed (i.e., those admitted to the hospital between May and July 1988) were excluded from the study. After implementation of the smoke-free policy, patients were required upon admission to acknowledge the smoke-free policy, sign a contract agreeing to abstain from nicotine during their treatment period, and agree to attend a smoking cessation program specifically designed for substance use patients. The program included (1) didactic lectures on the pharmacology of nicotine, (2) films, and (3) a discussion group.

Joseph used a one-page, standardized, self-administered questionnaire to assess smoking status and motivation to quit at admission and again during the third week of hospitalization.^152^ Structured telephone interviews at 1 year after hospitalization assessed substance use other than nicotine. The prepolicy patients (n = 156) completed posthospitalization telephone interviews at 16.2 months, and postpolicy patients (n = 163) at 10.7 months. Approximately 55 percent of the sample was lost to followup. The telephone interview assessed the long-term outcome of the patient's chemical dependency. Improvement in chemical dependency was defined as less or no use of the substance for which patients were treated at the time of hospitalization. Other outcomes were smoking status, motivation to quit, and use of substances other than nicotine.

At 3-week followup, the 24 percent of patients in the prepolicy group and 61 percent in the postpolicy group “want[ed] to quit” smoking (P ≤ 0.001).^152^ The proportion of patients who abstained from smoking for more than 1 week was significantly higher in the postpolicy group than in the prepolicy group (41 percent vs. 9 percent, P < 0.001). Postpolicy patients cut down significantly more on the number of cigarettes smoked while in the hospital than did the prepolicy patients (93 percent vs. 46 percent, P < 0.001). At the 1-year follow-up interview, 8 percent of the postpolicy patients and 3 percent of the prepolicy patients had quit smoking (P < 0.05). The groups did not differ significantly at the 1-year followup for nonnicotine substance use.

Joseph and colleagues compared the effects of treatment for nicotine dependence and intensive treatment for alcohol dependence, delivered concurrently, with the same nicotine dependence treatment delayed by 6 months.^149^ Eligible participants included both men and women between the ages of 21 and 75 who met the criteria for alcohol dependence or abuse according to the DSM-IV and who smoked more than five cigarettes each day for a year. Participants with no interest in quitting were excluded from the study.

The nicotine dependence intervention included a combination of behavioral and pharmacological treatments. A 1-hour individual counseling session and up to three followup sessions conducted in person or by telephone were offered to participants. Participants in the action stage of change received a free prescription for nicotine replacement therapy unless they declined or had a medical contraindication. A combination of patches and nicotine gum was offered to participants who smoked more than 20 cigarettes per day. The intervention was identical in both treatment arms but delayed in one, which effectively established a temporary control group.^149^

Biochemically validated self-reports were collected for both smoking and alcohol outcomes. Seven-day point prevalence abstinence rates were assessed at 3, 6, 12, and 18 months; 30-day and 6-month alcohol abstinence was measured at 6, 12, and 18 months. Using a simple likelihood ratio chi-square test and intent-to-treat analysis, the 7-day point prevalent smoking abstinence rates at 3 months were 15.5 percent in the concurrent treatment group and 4.4 percent in the delayed group (P < 0.0001). At 6 months, abstinence rates were 10.5 percent in the concurrent treatment and 5.2 percent in the delayed treatment group (P = 0.02); the delayed group, however, had not received the intervention at 3 and 6 months. Thereafter, at 9 and 12 months, the treatment groups did not differ significantly. The rate of prolonged smoking abstinence at 18 months for both groups was similar: 8.8 percent for concurrent treatment and 8.9 percent for delayed treatment. However, the participation rate in the concurrent treatment was significantly higher than in the delayed treatment (78.5 percent vs. 64.5 percent, P = 0.005; OR = 2.01; 95% CI, 1.35–2.99).

The alcohol abstinence outcomes at 6, 12, and 18 months for 6-month alcohol abstinence was lower in the concurrent treatment group (41 percent, 33 percent, and 41 percent, respectively) than in the delayed treatment group (56 percent, 42 percent, and 48 percent; P = 0.004, P = 0.11, and P = 0.01, respectively).