# Methods

In this chapter, we document the procedures the RTI International-University of North Carolina Evidence-based Practice Center (RTI-UNC EPC) used to develop this comprehensive evidence report on tobacco use prevention, cessation, and population harm. To provide a framework for the review, we first present the key questions and their underlying analytic framework. We then discuss the previous publications and analyses on which we built our systematic review. Following that section, we describe our strategy for identifying articles relevant to our key questions, our inclusion/exclusion criteria, and the process we used to abstract relevant information from eligible articles and generate our evidence tables. We also discuss our criteria for grading the quality of individual articles and rating the strength of the evidence as a whole. Finally, we explain the peer review process.

## Key Questions and Analytic Framework

This report spans key questions regarding prevention of tobacco use among youth, tobacco cessation for diverse populations of adults in a variety of settings, and population harm resulting from smokeless tobacco marketing. Table 1 lists the key questions (KQs) as they were related from the Agency for Healthcare Research and Quality (AHRQ).

Table 1 Final Key Questions

KQ 1. | What are the effective population- and community-based interventions to prevent tobacco use among adolescents and young adults, including among diverse populations?
KQ 2. | What are effective strategies for increasing consumer demand for and use of proven individually oriented cessation treatments, including among diverse populations?
KQ 3. | What are effective strategies for increasing the implementation of proven population-level tobacco use cessation strategies, particularly by health care systems and communities?
KQ 4. | What is the effect of smokeless tobacco product marketing and use on population harm from tobacco use?
KQ 5. | What is the effectiveness of prevention and cessation interventions in populations with co-occurring morbidities and risk behaviors?
KQ 6. | What research is needed to make the most progress and greatest public health gains nationally and internationally (based on work for questions 1–5)?

### Key Questions

KQ 1 seeks to understand how to use community- and population-based interventions to prevent initiation of tobacco use among adolescents and young adults across diverse populations. For those individuals who do become dependent on tobacco products, eventual disease, disability, and death can be avoided if they quit using tobacco products. KQ 2 seeks to identify strategies that increase the likelihood that tobacco users will want and use effective individual treatments. Because creating demand for tobacco use cessation is insufficient as a strategy if tobacco users do not respond by using these services or if effective treatments and strategies are not available in communities and health care systems, KQ 3 asks for a summary of proven strategies to increase the implementation of proven population-level tobacco use cessation strategies in health care systems and communities.

Although consensus exists around some tobacco use cessation strategies, controversy surrounds other suggested strategies for harm reduction, such as the use of smokeless tobacco products. Arguing that the harm associated with smoking cigarettes is much greater for both the individual and for those around the smoker than the harm associated with products that are not directly smoked, marketers are promoting smokeless tobacco use as a safer and much less costly alternative to smoking. KQ 4 asks about the effect of smokeless tobacco product marketing and use on population harm. This complex question requires us to assess, with regard to tobacco-related morbidity and mortality, (1) the impact of smokeless tobacco marketing on smokeless tobacco initiation, (2) the prevalence of smokeless tobacco use alone and/or the substitution of smokeless tobacco for cigarette smoking, and (3) the association of smokeless tobacco use with overall harm and changes in harm (either positive or negative).

Although most cessation strategies are appropriate for most special populations, recent reviews have highlighted issues of effectiveness with some populations, such as those with co-occurring morbidities and risk factors;^30^ this population is the focus of KQ 5. Finally, KQ 6 focuses on directions for future research prompted by answers to the above topics.

Recent systematic reviews have identified effective strategies at the individual, community, and population levels for preventing initiation, helping tobacco users to quit, and implementing strategies within the health care system and communities that help tobacco users to quit. These reviews dealt with issues affecting diverse populations, including populations with co-occurring morbidities and risk behaviors. The issues driving these recent reviews are similar to those issues addressed in KQs 1, 2, 3, and 5 of this review. Therefore, we updated or expanded searches completed for these recent reviews or undertook entirely new searches for issues not addressed in recent reviews. We explain our search and synthesis strategy in more detail below.

### Analytic Frameworks

Our overall analytic framework (Figure 1), describes the progression from tobacco initiation to tobacco dependence to tobacco-related morbidity and mortality, along with populations of interest, intervention strategies, and possible associations and outcomes for all KQs except KQ 6 (on research).

Figure 1. Overall analytic framework for tobacco use initiation and cessation

Figure 2 depicts in more detail the relationship of our overall model to issues relating to each of the KQs. The framework indicates the population of interest, the level of intervention (individual or population), activities evaluation (e.g., prevention, cessation, marketing), and the expected outcomes of the intervention. To understand what is known about how to interrupt this progression from initiation to dependence to disease, disability, and death, we focused this systematic review on individual, community, and population strategies for tobacco use prevention, cessation, and control.

Figure 2. Analytic framework for smoking cessation

## Previous Reviews

A good deal of research has been published on these issues, and some has been compiled in previous overviews and syntheses. Where possible, we elected to include systematic reviews as updates. We selected previous reviews that specifically covered all or parts of the key questions above as the basis for this report (see Chapter 3, Table 5). As a result, if studies already evaluated in existing reviews that met our inclusion criteria addressed the same outcomes of interest for the KQs, we did not reabstract data from them. By contrast, we did examine and extract data from studies published after these existing reviews for this report. To make this approach clear, we briefly describe existing appraisals of the evidence on each KQ (as depicted in Figures 1 and 2) before presenting our specific methods of literature searches and analysis.

Table 5 Systematic reviews and meta-analysis used for this report

Review Type | Authors | Topic | Included Research
Cochrane | Ebbert JO, Rowland LC, Montori V, Vickers KS, Erwin PC, Dale LC, Stead, LF^57^ | Interventions for smokeless tobacco use cessation | 1992 to Mar. 2004
Cochrane | Lancaster T, Stead LF^58^ | Physician Advice for Smoking Cessation | 1974 to 2003
Cochrane | Lancaster T, Stead L^59^ | Self-help interventions for smoking cessation | 1981 to Apr. 2005
Cochrane | Lancaster T, Stead LF^60^ | Individual behavioural counseling for smoking cessation | 1984 to Feb. 2005
Cochrane | Lumley J, Oliver SS, Chamberlain C, and Oakley L^61^ | Interventions for promoting smoking cessation during pregnancy | 1976 to Mar. 2004
Cochrane | Moher M, Hey K, Lancaster T^62^ | Workplace interventions for smoking cessation | 1981 to Feb. 2005
Cochrane | Rigotti NA, Munafo MR,Murphy MFG, Stead LF^63^ | Interventions for smoking cessation in hospitalised patients | 1974 to 2002
Cochrane | Secker-Walker RH, Gnich W, Platt S, Lancaster T^36^ | Community interventions for reducing smoking among adults | 1970 to Jan. 2002
Cochrane | Sowden A, Arblaster L^33^ | Mass media interventions for preventing smoking in young people | 1983 to Aug. 1998
Cochrane | Sowden A, Stead L^64^ | Community interventions for preventing smoking in young people | 1983 to Sept. 2002
Cochrane | Stead LF, Lancaster T^65^ | Group behaviour therapy programmes for smoking cessation | 1981 to Feb. 2005
Cochrane | Stead LF, Lancaster T, Perera R^66^ | Telephone counseling for smoking cessation | 1991 to Oct. 2002
Cochrane | Thomas R^34^ | School-based programmes for preventing smoking | 1980 to Jan. 2002
Systematic review | el-Guebaly N, Cathcart J, Currie S, Brown D, Gloster S^30^ | Smoking cessation approaches for persons with mental illness or addictive disorders | 1990 to 2000
Meta-analysis | Fiore MC, Bailey WC, Cohen SF, et al.^5^ | Clinical practice guideline update: Treating Tobacco Use and Dependence | 1995 to 1999
Meta-analysis | Prochaska JJ, Delucchi K, Hall SM^9^ | A meta-analysis of smoking cessation interventions with individuals in substance abuse treatment or recovery | 1991 to 2003
Systematic review | Lynch BS, Bonnie RJ^32^ | Growing up tobacco free: preventing nicotine addiction in children and youths | 1990 to 1993
Systematic review | Melvin, CL, Gaffney, C^37^ | Treating nicotine use and dependence of pregnant and parenting smokers: An update | 1994 to 2003
Systematic review | US Department of Health and Human Services | Reducing tobacco use: a report of the Surgeon General | Not reported
Systematic review | Zaza S, Briss PA, Harris KW^7^ | The Community Preventive Services Guide: Tobacco (Chapter 1) | 1976 to May 2000

### KQ 1. Effective Population- and Community-Based Interventions to Prevent Tobacco Use

For KQ 1, we focused our review on five main strategies:

1 Unit price increases on tobacco products,
2 Mass media education campaigns combined with other interventions to reduce tobacco use initiation,
3 Interventions to reduce youth access to tobacco products (i.e., laws that regulate and enforce bans on sales of tobacco products to, or their purchase or consumption by, children and adolescents),
4 School-based education interventions to prevent tobacco use, and
5 Tobacco industry and product restrictions (i.e., laws that regulate the content, labeling, promotion, and advertising of tobacco products).^31^

Recently, the Guide to Community Preventive Services (hereafter, Community Guide) reviewed strategies 1, 2, and 3 and studies that combined two or more interventions in a coordinated effort to restrict minors' access to tobacco products.^7^ The Institute of Medicine's report, Growing Up Tobacco Free,^32^ and the 2000 report of the Surgeon General, Reducing Tobacco Use,^2^ reviewed all five strategies. The Cochrane Collaboration reviewed strategies 2^33^ and 4.^34^

We undertook new searches for strategies not yet reviewed by the Community Guide (i.e., numbers 4 and 5), updated the searches for strategies 1 through 3, and searched for strategies other than those identified above. We explored the literature for the differential effect of prevention strategies among diverse populations, including those among adolescents and young adults who are most likely to initiate tobacco use and become regular users.

### KQ 2. Effective Strategies for Increasing Consumer Demand for and Use of Individually Oriented Cessation Treatments

Interventions to increase the number of tobacco users who seek assistance in quitting and who successfully quit include efforts to increase the number of users who attempt to quit, to improve the success rate for quit attempts, and to support both of these goals.^7^ This question focuses on both sets of interventions.

Proven individual strategies for helping smokers to quit include counseling and behavioral therapy and, except when contraindicated, the use of firstline and secondline medications.^5^ More often than not, individuals are trying to quit without the type of assistance that can double or even triple the chances of success.^5^ Other strategies intended to motivate tobacco users to attempt to quit or to reduce relapse among recent quitters include telephone support and mass media interventions.

Telephone support provides an option for individuals reluctant to discuss tobacco use with their health care providers. In some cases, telephone support also allows on-demand assistance, provides a no-cost service, or includes provision of pharmacotherapies. These features remove or at least mitigate some of the barriers that tobacco users may perceive or experience in their attempts to receive assistance from their health care providers.

Mass media interventions are designed and implemented to provide cessation information and motivation for tobacco users who are trying to quit.^7^ The three main subtypes of mass media interventions are campaigns, cessation series, and cessation contests. Mass media campaigns provide brief, recurring messages; cessation series consist of broadcasted instructional segments; and cessation contests are community-wide events of short duration that recruit and motivate users of tobacco products to participate in a program to quit by a certain date.^7^ Mass media intervention strategies can also drive tobacco users to call telephone quit lines, thereby increasing the number of smokers who seek help.^7^

Reviews of community interventions to increase tobacco use cessation have focused on four main approaches: (1) multicomponent efforts to increase patient tobacco use cessation, which include telephone information or counseling support; (2) mass media campaigns combined with other interventions; (3) mass media cessation series; and (4) mass media cessation contests. The Community Guide focused on all four issues,^7^ the 2000 Surgeon General's Report focused on only the second and third,^2^ the Clinical Practice Guideline focused on the first,^5^and the Centers for Disease Control and Prevention (CDC) Best Practices publication focused on the second.^35^

Using the searches in the sources identified above as a base, we updated the searches for all strategies. We expanded searches for interventions lacking sufficient evidence at the time of the most recent review, for new interventions or strategies introduced in the literature since the most recent review, and, to the extent possible, for the differential impact of all strategies on diverse populations. Our cessation searches specifically looked for studies related to the following factors: race or ethnicity, socioeconomic status, education level, gender, age (i.e., adolescents and adults), hospitalization, and pregnancy.

### KQ 3. Effective Strategies for Increasing Implementation of Population-Level Tobacco Use Cessation Strategies

The Cochrane Collaboration published a systematic review focused on community interventions.^36^ Reviews of health care system interventions to implement effective treatments appear in the Community Guide,^7^ the 2000 Surgeon General's report,^2^ the Clinical Practice Guideline,^5^ and Melvin and Gaffney.^37^

The Cochrane Collaboration review assesses the effectiveness of community interventions in reducing the prevalence of smoking among adults (18 years of age and older).^36^ It addressed two main questions: (1) Do community-based interventions reduce smoking (measured by prevalence, cigarette consumption, quit rates, or initiation rates) compared with no intervention in comparison communities? (2) Which characteristics of these studies are related to their efficacy? Selected studies evaluated the effectiveness of community interventions in which smoking behavior change was a part of the intervention program using either a controlled trial that randomized communities or geographical regions or a nonrandomized controlled trial that allocated communities or geographical regions.

Even when tobacco users feel comfortable approaching their providers, they may not receive effective treatments. Some providers indicate that they do not know how to intervene effectively with smokers,^38^ that they experience disappointment and discouragement given the cyclical nature of relapse and remission they observe among smokers,^5^ and that they are not trained to deal with co-occurring morbidities and risk behaviors. Finally, for both providers and tobacco users, the costs associated with providing or receiving effective treatment are barriers. For example, many providers are not reimbursed for cessation counseling, and tobacco users may have no health insurance or only limited health insurance coverage for cessation treatments.

Recent reviews of interventions that help providers and health care systems implement strategies to increase cessation of tobacco use by clients highlight numerous, sometimes multifaceted programs. Among programs studied are provider reminder systems with or without client education,^2,^ ^5,^ ^36,^ ^37^ health care provider education alone or with feedback and assessment,^5,^ ^7,^ ^36,^ ^37^ reduction of client out-of-pocket costs for effective cessation therapies,^2,^ ^5,^ ^7^ and multicomponent interventions that include client telephone support.^5,^ ^7,^ ^36,^ ^37^ Melvin and Gaffney reviewed the literature for interventions that increase the likelihood that health care providers will provide effective strategies to pregnant and postpartum women either proactively or in response to client demand.^37^

We updated and expanded, as necessary, the recently completed reviews on both community and health care interventions. The existing reviews on these topics were comprehensive and needed little expansion. We expanded searches for interventions lacking sufficient evidence at the time of the most recent review and for new interventions or strategies introduced in the literature since the most recent review.

### KQ 4. Effect of Smokeless Tobacco Product Marketing and Use

KQ 4 asks us to examine whether substituting smokeless tobacco for smoking results in less smoking-related harm on a population basis and whether smokeless tobacco marketing leads to greater use and/or substitution of smokeless tobacco for smoking. Evidence in reports of the Surgeons General and other sources link smokeless tobacco causally with oral leukoplakia and oral cancers.^2,^ ^39^ Smokeless tobacco may also increase the risk of cancers in other sites.^17^ We examined the harms associated with smokeless tobacco use and determined whether others have used data on these harms to model the potential health effects of substituting smokeless tobacco for smoking. Some studies' approaches to promoting smokeless tobacco use are related to current use of these products.^40^–^45^

We are unaware of any studies that have followed the entire analytic framework we suggest—assessing (1) the impact of marketing smokeless tobacco on its use or its substitution for smoking cigarettes, (2) the impact of smokeless tobacco use on overall harm, and (3) the possibility of reduced harm associated with smokeless tobacco use in terms of overall tobacco-related morbidity and mortality. We reviewed the relevant literature to determine whether any studies describe any or all of these relationships. We believe that assessing the public health significance of harm reduction associated with smokeless tobacco use will be difficult given that only 3.4 percent of Americans ages 12 and older used these products in the past month.^2^ Also, this statistic includes women's smokeless tobacco use and deflates the importance of this health issue because most of these users are young men. The current rate of smokeless tobacco use is 6 percent among men and only 0.3 percent among women.^20^

We also note that recently some tobacco companies have begun to market their smokeless tobacco products directly as less harmful alternatives to tobacco, likening them to nicotine replacement products and emphasizing that smokeless tobacco does not carry the same risks to others as smoking does with secondhand or environmental tobacco smoke.^46^ We searched for studies examining this harm reduction relationship. The review for KQ 4 focuses on adolescents, young adults, and adults, especially in relation to harm reduction for tobacco-related morbidity and mortality. We focused on studies of marketing approaches for adolescents and young adults given their routine and repeated targeting by the tobacco industry and their greater likelihood of using smokeless tobacco products. However, we believe that it is too early to determine if these harm reduction approaches to smokeless tobacco marketing are effective in increasing its use.

### KQ 5. Effectiveness of Interventions in Populations with Co-Occurring Morbidities and Risk Behaviors

The term “psychiatric comorbidity,” as used in the Treating Tobacco Use and Dependence clinical practice guideline, refers to the co-occurrence of smoking with another psychiatric disorder.^5^ We use this narrow definition because individuals with psychiatric illnesses are approximately twice as likely as the general population to smoke tobacco. These individuals also tend to smoke more heavily than other smokers.^47^–^50^

Co-occurring risk behaviors include those behaviors that trigger tobacco use, such as alcohol or other substance use or abuse. As many as 20 percent of patients seeking smoking cessation services may have a history of alcohol abuse or dependence.^48^–^50^ Among abusers of alcohol and drugs, smoking occurs at rates well above population averages (e.g., greater than 70 percent).^51^–^53^

Treatment of individuals with these co-occurring morbidities or other risk behaviors remains a controversial topic, because some believe that smoking cessation and nicotine withdrawal exacerbate a patient's comorbid condition and, thereby, present unique case management challenges.

The clinical practice guideline examined the efficacy of tobacco treatment among patients with psychiatric comorbidity.^5^ Another recent review of smoking cessation approaches for individuals with mental illness or addictive disorders examined empirical studies conducted between 1991 and 2000.^30^ The majority of interventions combined medication and psychoeducation. We updated and expanded these reviews to examine the effectiveness of cessation interventions in populations with co-occurring morbidities and risk behaviors.

No previous review addressed the effectiveness of prevention interventions in this population. We examined studies identified through searches focused on populations with co-occurring morbidities and risk behaviors to determine if any analyses reported smoking prevention and cessation outcomes. We found few studies on smoking cessation and no studies on prevention (because the population is already smoking).

### KQ 6. Needed Research

Current systematic reviews include recommendations for further research and areas of insufficient evidence. Through this newer review, we identified findings that are both consistent and inconsistent with previously identified needs for research, and we pinpointed important gaps in research.

## Literature Review Methods

### Inclusion and Exclusion Criteria

After discussions with our Technical Expert Panel (TEP), we generated a list of article inclusion and exclusion criteria (Table 2) for these KQs. We limited our review to human studies conducted in developed countries and published in English. We considered studies with participants ages 13 and older of both genders from diverse racial and ethnic populations.

Table 2 Tobacco use: inclusion/exclusion criteria

Category | Criteria
Study population | Humans, all races, ethnicities, and cultural groups
| KQ 1: Adolescents (13–18 years of age), young adults (18–24 years of age), and diverse populations
| KQ 2: Adolescents, young adults, adults (18 years of age and older), and diverse populations
| KQ 3: Adults and diverse populations
| KQ 4: Adolescents, young adults, and adults
| KQ 5: Adolescents, young adults, and adults with comorbidities and risk behaviors
Study outcomes | KQ 1: Reduced initiation of tobacco use
| KQ 2: Increased quit rates; greater numbers of smoking cessation participants (i.e., increased participation)
| KQ 3: Increased quit rates; change in provider behaviors concerning smoking cessation
| KQ 4: Increased use; increased substitution of smokeless tobacco for smoking; harm reduction
| KQ 5: Reduced initiation of tobacco use; increased quit rates
Study geography | Developed countries: United States, Canada, United Kingdom, Western Europe, Australia, and New Zealand
Time period | KQ 1: Studies that addressed prevention of adolescent and youth tobacco use: January 1, 2000, to June 10, 2005
| Studies that addressed product restrictions in the tobacco industry aimed at countering youth tobacco use: January 1, 1980, to June 10, 2005
| KQ 2 and KQ 3: January 1, 1999, to June 10, 2005
| KQ 4 and KQ 5: January 1, 1980, to June 10, 2005
Publication languages | English only
Admissible evidence (study design and other criteria) | Original research studies that provide sufficient detail regarding methods and results to enable use and adjustment of the data and results; relevant outcomes must be able to be abstracted from data presented in the papers.
| Eligible study designs include; - Randomized controlled trials (RCTs);; - Nonrandomized controlled trials; and; - Observational studies: prospective and retrospective cohort studies, case-control studies, and cross-sectional studies.
| Single case reports or small case series are excluded.
| Sample sizes must be appropriate for the study question addressed in the paper.
| RCTs: 30 or more participants
| Observational studies and nonrandomized controlled trials: 100 or more participants

KQ, key question

We excluded editorials, letters, commentaries, articles that did not report outcomes related to our key questions, and studies that did not provide sufficient information to be abstracted. To avoid reporting short-term fluctuations among the populations and to ensure sufficient sample sizes to observe changes over time, we limited our review to randomized controlled trials (RCTs) with 30 or more individuals or observational studies and nonrandomized controlled trials with 100 or more individuals, followed for a minimum of 6 months, with or without comparison groups. Our TEP concurred with this plan.

### Literature Search and Retrieval Process

Databases and search terms. To identify the relevant literature for our review, we conducted systematic searches based on search terms and hand-searched reference lists. We searched standard electronic databases: MEDLINE®, the Cumulative Index to Nursing and Applied Health (CINAHL), Cochrane Collaboration libraries, Cochrane Clinical Trials Register, Psychological Abstracts, and Sociological Abstracts.

Based on the inclusion/exclusion criteria specified above, we generated a list of Medical Subject Heading (MeSH) search terms, supplemented by key word searches to search MEDLINE® (Table 3). Comparable terms were used to search other databases. Finally, we asked our TEP and external peer reviewers to suggest articles that we might have missed.

Table 3 Medical subject headings and text words

Medical Subject Headings
Tobacco use cessation | Marketing
Smoking cessation | Social marketing
Smoking/prevention and control | Choice behavior
Smoking (and as text term) | Advertising
Primary prevention
Community networks | Tobacco, smokeless
Community health services | Spit tobacco (text term)
Community health planning | Chewing tobacco (text term)
Community health aides | Dip tobacco (text term)
Community health nursing | Oral tobacco (text term)
Community health centers | Comorbidity
Community mental health services | Risk-taking
Community medicine | Risk factors
Community mental health centers | Depressive disorder
Randomized controlled trials | Depression
Single-blind method | Bipolar disorder
Double-blind method | Attention deficit disorder with
Random allocation | hyperactivity
Consumer satisfaction | Stress disorders, post-traumatic
Consumer participation | Diabetes mellitus
Health services needs and demand | Hypertension
Health plan implementation | Heart diseases
Diffusion of Innovation | Asthma
Patient education | Obesity

Article selection process. Once we had identified articles through the electronic database search, review articles, and bibliographies, we examined abstracts and the full text of the articles to determine whether the studies met our inclusion criteria. Two reviewers initially evaluated abstracts for inclusion or exclusion; only one reviewer was needed to include an article, but two reviewers were required to exclude an article. Dr. Ranney, the Study Director, reconciled all conflicts. As articles appeared that met inclusion criteria at the abstract review stage, we obtained the article's full text. For the full text review, two reviewers read each article and determined whether it met our eligibility criteria. Again, Dr. Ranney adjudicated any disagreements. Dr. Ranney and Dr. Cathy Melvin, our Scientific Director, reviewed articles excluded by the first two reviewers and assigned reasons for exclusion or, when appropriate, included them in the pool for abstraction.

## Literature Synthesis

### Development of Evidence Tables and Data Abstraction Process

Senior staff for this systematic review jointly developed evidence tables using two designs: one design for primary data collection studies and one for systematic reviews. The designs are intended to provide sufficient information so that readers can understand the study and determine its quality; we emphasized presenting information essential to answering the main questions. The formats of the two sets of evidence tables were based on successful designs used for prior systematic reviews.

The primary data collection evidence tables contain information on

- Study characteristics (author, year, study setting, funding source, time period covered);
- Research objective, population, and study design (inclusion, exclusion criteria);
- Sample design (technique and size);
- Definitions of smoking;
- Intervention methods, description, and assessment;
- Baseline data;
- Statistical analysis, data verification, and dependent variables;
- Results (outcome measures); and
- Quality rating and comments.

The evidence tables for systematic reviews report on

- Study demographics (author, year, geographic area, funding source, time period covered);
- Study characteristics (inclusion criteria, population, characteristics of studies, method of review, study design, what studies are included in the meta-analysis);
- Aim of review;
- Main results; and
- Quality rating (adverse events).

For this work, the RTI-UNC EPC team decided to abstract data from included articles directly into a proprietary systematic review database program, TRIALSTAT. We trained data abstractors intensively, thoroughly familiarizing them with the abstraction form design (Appendix B ^†^), required information and formats, and examples of abstracted articles. As the work progressed, we shared various reporting requirements with abstractors to ensure that information appeared in a consistent and easily understandable manner.

† Appendixes cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/tobusetp.htm.

For the primary data literature, the first reviewer (a research assistant from the University of North Carolina at Chapel Hill) entered data from the article into the database. The second, senior reviewer (either Dr. Ranney or Dr. Melvin) read the article and edited the initial table entry for accuracy, completeness, and consistency. For the systematic review literature, Dr. Ranney entered data from the review into the database, and Dr. Melvin read the article and edited the initial table entry for accuracy, completeness, and consistency. In both cases, the two abstractors reconciled all disagreements by consensus discussion.

The final evidence tables are presented in their entirety in Appendix C. Below are the table titles for each question. Within each evidence table, entries are listed alphabetically by the last name of the first author. Abbreviations and acronyms used in the tables appear in a glossary at the beginning of the appendix.

- KQ 1
  - Evidence Table 1. Effective population-based interventions
  - Evidence Table 2. Effective school-based interventions
  - Evidence Table 3. Effective provider-based interventions
- KQ 2
  - Evidence Table 4. Multicomponent interventions to increase the number of users who quit smoking
  - Evidence Table 5. Strategies to improve success rates for quit attempts for general and special populations
- KQ 3
  - Evidence Table 6. Population-based strategies to increase the implementation of proven population-level tobacco use cessation strategies
  - Evidence Table 7. Provider and health care systems strategies to increase implementation of population-level tobacco use cessation
- KQ 4
  - Evidence Table 8. Effect of smokeless tobacco product marketing and use on population harm from tobacco use
- KQ 5
  - Evidence Table 9. Tobacco cessation interventions for persons with co-occurring morbidities and risk behaviors
- Systematic Review and Meta-analysis
  - Evidence Table 10. Systematic and meta-analysis reviews

### Quality and Strength of Evidence Evaluation

Quality of studies. We assessed the internal validity (i.e., quality) of trials based on predefined criteria developed by the US Preventive Services Task Force (ratings are good, fair, or poor)^54^ and the National Health Service Centre for Reviews and Dissemination.^55^ We assessed and reported external validity (i.e., generalizability) but did not use these judgments in our quality ratings.

We developed three quality rating forms, two for the primary data literature (one for randomized controlled trials and one for observational studies and non-randomized controlled trials) and the other for the systematic review literature. We tested several drafts of these forms, revising them as needed to ensure that they efficiently captured the desired information. The final grading forms can be found in Appendix B. Elements of internal validity assessment for primary data literature included, among others, randomization and allocation concealment, similarity of compared groups at baseline, use of intention-to-treat analysis, and overall and differential attrition. The assessment of the systematic review literature focused on issues of validity, such as whether the search strategy was systematic and comprehensive, and issues of reliability, including whether the authors used a standard method of critical appraisal.

Two independent reviewers assigned quality ratings; they resolved any disagreements by discussion and consensus or by consulting a third, independent party. Primary data articles that had one or two minor study design issues were considered “good”; an example of such an article is one in which an intention-to-treat analysis was not conducted, but the author addressed the issue of loss to followup by surveying those who did not complete the study. We had a wide and diverse range of “fair” articles, which were articles that had several minor study design issues, such as lack of reporting on baseline group differences or a weak sampling technique. Articles that had multiple major study design issues, such as postrandomization of exclusions, high refusal rates, high attrition rates, no comparison of groups at baseline, and lack of information about control or comparison groups, received a quality grade of “poor.”

All but one of the systematic literature reviews and meta-analyses were of good quality; the exception was “fair.” The systematic reviews assessed were primarily from the Cochrane Collaboration, which is known for conducting comprehensive literature searches and employing stringent appraisal criteria. The two meta-analyses were of high quality; one is recognized in the field of tobacco control as the “gold standard,” and the other was rated “good.”

Strength of the available evidence. We rated the strength of the evidence for the interventions based on the criteria developed for the Task Force on Community Preventive Services,^56^ which we deemed most applicable to the study designs in this review (Table 4). Our evaluation employed three domains to determine the strength of the evidence for each intervention: quality of the research, including design suitability and study execution; quantity of studies, including the number of studies and the adequacy of the sample size; and consistency of findings among the studies. The available evidence for an intervention was determined to be strong, “sufficient,” or “insufficient.”

Table 4 Modified body of evidence assessment table from Guide to Community Preventive Services

Evidence of Effectiveness | Execution of Study Design | Design Suitability | Number of Studies
Strong | Good | Greatest | At least 2 studies
| Good | Greatest or moderate | At least 5 studies
| Good or fair | Greatest | At least 5 studies
Sufficient | Good | Greatest | At least 1 study
| Good or fair | Greatest or moderate | At least 3 studies
| Good or fair | Greatest, moderate, or least | At least 5 studies
Insufficient | Insufficient designs or execution | | Too few studies

Task Force on Community Preventive Services, 2005^56^

Bodies of evidence rated as strong included an adequate number of studies that were of good or fair quality, had study designs that were appropriate for the intervention being evaluated or issue being addressed, and were consistent in the direction of their findings. Sufficient bodies of evidence also contained studies of good or fair quality, but the suitability of the studies' designs was not as consistently appropriate and, therefore, more relevant studies were required to rate the evidence in the category. As per the Task Force model, the reasons for determining that a body of evidence was “insufficient” included unsuitable study designs, too few studies to determine the effectiveness of an intervention, too small an effect size, and inconsistent findings among studies of an intervention.^56^ We graded the strength of evidence applicable to each of the key questions separately.

## Peer Review Process

Among the more important activities involved in producing a credible evidence report is conducting an unbiased and broadly based review of the draft report. External reviewers for this report included clinicians and representatives of professional societies and advocacy groups, including TEP members (see Appendix D).^‡^ We charged peer reviewers with commenting on the content, structure, and format of the evidence report and asked them to complete a peer review checklist. We revised the report, as appropriate, based on their comments.

‡ Appendixes cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/tobusetp.htm.