# Introduction

## Scope of the Problem

Tobacco use is the leading cause of preventable illness and death in the United States: it causes numerous cancers, heart disease, stroke, complications of pregnancy, and chronic obstructive pulmonary disease.^1,^ ^2^ Each year, 440,000 deaths and $157 billion in health-related economic costs result from tobacco use.^3^ Approximately 44.5 million people, or 20.9 percent of the adult population, reported smoking in 2004.^4^ Almost one-third of all tobacco users will die prematurely because of their dependence on tobacco.^5^

## Tobacco Use and Its Impact

The morbidity and mortality caused by tobacco use, documented by the reports of the Surgeons General since 1964, are clear and pervasive.^1,^ ^2,^ ^6^ Tobacco use begins primarily in adolescence and frequently leads to nicotine addiction.^7^ High rates of tobacco initiation among adolescents,^8^ variable smoking cessation rates in general and at-risk populations,^9^ and inconsistent implementation of smoking cessation interventions underscore the need for evidence-based research outlining recommended tobacco prevention and cessation strategies. With aggressive marketing of tobacco products, particularly smokeless tobacco, continuing to expand and build market share through product development,^10^ smoking cessation interventions must maximize their exposure to tobacco users during critical periods of transition or “teachable moments” to reduce the significant morbidity and mortality rates associated with tobacco use.

Many factors affect an individual's tobacco use and associated tobacco-related mortality and morbidity. Disparities in both are reported by race and ethnicity, gender, level of education, socioeconomic status, and geographic region.^2,^ ^11^ Individuals most likely to smoke and to suffer and die from smoking-related disease are less educated, more likely to live in poverty, and more likely to be American Indians and Alaska Natives.^8^

Most adult smokers (98 percent) began smoking as adolescents or young adults; 82 percent started before age 18, and 16 percent started between the ages of 18 and 24.^12^ Each day more than 3,000 additional children and adolescents become regular tobacco users; one-third of them will die from tobacco-related causes.^13,^ ^14^

Predictors for smoking initiation vary by race and ethnicity; for example, black males are more responsive to peer pressure than other groups. Overall, children most likely to begin smoking are those engaged in other unhealthy or risky activities such as drinking, truancy, and delinquency.^12^ Preventing youth tobacco initiation and the transition from experimentation to addiction are both difficult. Adolescents are more susceptible than people in other age groups to influences from their families, friends, peers, society, and the tobacco industry that encourage tobacco use.^15^

Half of American youth have tried cigarettes by the time they are seniors in high school, and nearly one-quarter (23 percent) of seniors are current smokers. The prevalence of current smoking among high school seniors peaked in 1997 before beginning a decline that continued through 2004. However, this important decline in smoking has decelerated sharply. Among 8th graders the decline has halted and, because of strong cohort effects for smoking, the decline is predicted to stop in the upper grades as well. The slowdown in price increases for tobacco products together with reductions in funding at both the national and state levels for antismoking campaigns have contributed to these developments.^16^

The smoking rate among young adults ages 18 to 24 is 23.8 percent, slightly higher than that among high school seniors. The national health objective for 2010 is to reduce the prevalence of cigarette smoking among adults to 12 percent or lower.^8^ Because data suggest that smoking initiation is a problem among both adolescents and young adults, a strong focus on preventing tobacco use initiation among these age groups is needed.

Smokeless tobacco can also lead to nicotine addiction and dependence.^17^ Two types of smokeless tobacco are sold in the United States: chewing tobacco (i.e., loose-leaf tobacco, plug, or twist) and snuff (i.e., finely ground tobacco that can be dry, moist, or in sachets).^18,^ ^19^ These products, which contain 28 carcinogens, are known to increase the risk of developing oral cancers.^19^ An estimated 7 percent of high school students are current users of smokeless tobacco.^20^

Once users are dependent on tobacco, whether cigarettes or smokeless products, quitting is very difficult, although an estimated 70 percent of smokers would like to quit.^8,^ ^21^ The drug dependence resulting from tobacco use hampers efforts to sustain abstinence from tobacco for either a prolonged period or a lifetime.^5^ As a result, many users make multiple attempts to quit.

In 2004, an estimated 14.6 million (40.5 percent) US adult smokers reported trying to quit by stopping smoking for at least 1 day during the preceding 12 months.^8^ In 2000, an estimated 70 percent of smokers said they wanted to quit, but few succeeded without help.^22^ Tobacco use treatment doubles quitting success rates.^5^

The rate of smoking is higher among people with psychiatric conditions and substance abuse problems.^9,^ ^23^ Populations with co-occurring morbidities have shown a lack of responsiveness to smoking cessation treatments; fewer than 15 percent of psychiatric patients quit.^23^ For people suffering from alcoholism, quitting tobacco before achieving sustained abstinence is particularly difficult.^24^ People with comorbidities often have overlapping conditions such as multiple addictions and/or psychiatric, cognitive, or medical conditions that may require more sensitive or specialized strategies and services for smoking cessation.^9^

Barriers to the use of these services exist for both tobacco users and health care providers. Some smokers are reluctant to disclose their smoking status to their clinicians, do not believe that their clinicians can help them to quit smoking, or assume that they will get “attitude” from their clinicians instead of help with quitting tobacco use.^25^ More than one-third of current smokers report that they were never asked about their smoking status or urged to quit by their clinician.^26,^ ^27^ Fewer than 15 percent of smokers who saw a physician in the past year reported being offered assistance in quitting.^28^ Among current smokers and former smokers who were trying to quit and had seen a health care provider in the past year, only 61.8 percent received advice to quit from those providers.^29^

Individuals who continue to use tobacco products put themselves and their families at considerable risk of harm associated with tobacco use. By continuing to use tobacco, they are increasing their risk of smoking-attributable mortality and morbidity. They also expose members of their families and households to secondhand smoke and its health and safety consequences.

## Need and Purpose of This Systematic Review

The National Institutes of Health (NIH) Office of Medical Applications of Research (OMAR) reviews and evaluates clinically relevant NIH research program information and promotes the effective transfer of this information to the health care community. OMAR accomplishes this objective through its Consensus Development Program. This includes major Consensus Development conferences and State-of-the-Science (SOS) conferences when only less definitive evidence is available.

As background for an upcoming SOS meeting, OMAR commissioned this systematic review on “Tobacco Use: Prevention, Cessation, and Control” through the Agency for Healthcare Research and Quality (AHRQ). The aim is to summarize the available literature, frame the discussions regarding benefits and harms, and highlight the limitations of the entire evidence base. Through this report, OMAR seeks to increase the scientific rigor of the June 2006 SOS conference.

The findings of our review clarify what is known about effective interventions and strategies for tobacco prevention and treatment as a means of providing authoritative background information for participants at the SOS conference. More broadly, we expect that our findings will be useful to major stakeholders in this arena, including policymakers, advocacy groups and community organizations, directors of smoking prevention and cessation programs, health care providers, smokers, and adolescents and young adults. We also identify future research priorities useful to government agencies and private sector funding organizations.

## Uses of This Report

Quite apart from its use at the OMAR SOS conference in June 2006, we anticipate that this report will be of value to members of the various professional organizations whose missions include the prevention and cessation of tobacco use in all populations. These organizations include the American Legacy Foundation, the American Cancer Society, the American Heart Association, the Campaign For Tobacco-Free Kids, the March of Dimes, the National Heart, Lung and Blood Institute, the National Cancer Institute, and the Indian Health Service in the Department of Health and Human Services. More generally, the report will assist these and other organizations in their mission to inform and educate practitioners, policymakers, insurers, media representatives, high-risk populations, youth, and the general public.

From this review, NIH and relevant institutes can guide funding policies by identifying serious gaps in the research on tobacco prevention and cessation strategies in diverse populations, strategies for implementing proven tobacco cessation treatments, and the effects of smokeless tobacco product marketing on population use. This review can also inform practitioners on the current evidence about outcomes associated with tobacco initiation and cessation, as well as tobacco implementation practices and smokeless tobacco marketing and use. Researchers will benefit from the concise analysis of the current status of the field, which will enable them to design future studies to address deficiencies in the field. Health educators can use this report to improve health communication. Finally, policymakers can use this report to allocate resources toward future research and initiatives that are likely to be successful.

## Production of This Evidence Report

### Technical Expert Panel

We identified experts in the field of tobacco use, prevention, cessation, and control to provide assistance throughout the project. The Technical Expert Panel (TEP) (see Appendix E)^*^ contributes to AHRQ's broader goals of (1) creating and maintaining science partnerships and public-private partnerships and of (2) meeting the needs of an array of potential customers and users of this product. The TEP served as both a resource and a sounding board during the project. Our TEP comprised seven individuals: one clinical educator, three representatives from professional and advocacy groups concerned with smoking and health, and three experts in social marketing, media campaigns, and prevention.

* Appendixes cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/tobusetp.htm.

To ensure accountability and scientifically relevant work, we asked the TEP for advice at all stages of the project. TEP members participated in conference calls and e-mail exchanges to

- Refine the analytic framework and key questions at the beginning of the project,
- Refine the scope of the project, and
- Discuss inclusion and exclusion criteria.

Because of their extensive knowledge of the literature on these topics and their active involvement in professional organizations and in the clinical field, we also asked TEP members to participate in external peer review of the draft report.

### A Note on Terminology

Adolescents are defined as individuals ages 13 to 18, and young adults are defined as college age, approximately 18 to 24 years of age. Adults are defined as individuals ages 18 and older and overlap the young adult category. Comorbidity and co-occurring morbidities refer to a dual diagnosis of concurrent disorders such as depression and nicotine addiction.

### Organization of this Report

Chapter 2 describes our methods, including the development of key questions and their analytic framework, our search strategies, and inclusion/exclusion criteria. In Chapter 3, we present the results of our literature search and synthesis on five of the six key questions that OMAR posed for this review. We also report on the numbers of publications reviewed, present findings on prior reviews and current literature, and grade the quality of all articles. Chapter 4 discusses these findings further, rates the overall strength of the bodies of literature, and highlights methodological shortcomings of the extant research; the chapter also offers recommendations for future research (of particular interest to NIH and AHRQ) and restates the major conclusions. Appendices (available electronically at http://www.ahrq.gov/clinic/tp/tobusetp.htm) begin with a detailed description of our search strings (Appendix A), followed by our quality rating forms (Appendix B), detailed evidence tables (Appendix C), a list of excluded studies (Appendix D), and acknowledgments, including the TEP and peer reviewers (Appendix E).