# Appendix E. Acknowledgments

This study was supported by Contract 290-02-0016 from the Agency for Healthcare Research and Quality (AHRQ), Task No. 6. We acknowledge the support of Kenneth Fink, M.D., M.G.A., M.P.H., former Director of the AHRQ Evidence-Based Practice Center (EPC) Program, and Ernestine Murray, B.S.N., R.N., M.A.S., the AHRQ Task Order Officer for this project.

The investigators deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at RTI International and the University of North Carolina (UNC). From UNC, we thank EPC Co-Director, Timothy S. Carey, M.D., M.P.H.; EPC Literature Search Specialist, B. Lynn Whitener, Ph.D., Gerald Gartlehner, M.D., M.P.H., Research Coordinator and Laura Morgan, Research Assistant. We also express our gratitude to Lisa Hund, M.P.H.; Abstractor, Tammeka Swinson, B.A.; Project Manager and Loraine Monroe, EPC word processing specialist, at RTI International.

## Technical Expert Panel

We also extend our appreciation to the members of our Technical Expert Panel (TEP), who provided advice and input during our research process. The RTI-UNC EPC team solicited the views of TEP members from the beginning of the project. TEP members also provided insights into and reactions to work in progress and advice on substantive issues or possibly overlooked areas of research. TEP members participated in refining the analytic framework and key questions and discussing the preliminary assessment of the literature, including inclusion/exclusion criteria, and also provided input on the information and categories, including evidence tables. The TEP was both a substantive resource and a “sounding board” throughout the study. It was also the body from which expertise was formally sought at several junctions. TEP members are listed below

- Kathleen Adams, Ph.D.
- Associate Professor, Department of Health Policy & Management, School of Public Health, Emory University
- Atlanta, Georgia

- Dianne C. Barker, M.H.S.
- Founder and Principal, Barker BiCoastal Health Consultants (BBHC)
- Los Angeles, California

- Matthew P. Barry, M.P.A.
- Senior Policy Analyst, Campaign for Tobacco-Free Kids
- Washington, D.C.

- Cecelia Gaffney, M.Ed.
- Instructor in Family and Community Medicine, Norris Cotton Cancer Center, Dartmouth Medical School
- White River Junction, New Hampshire

- Harry Lando, Ph.D.
- Professor, Division of Epidemiology, School of Public Health
- University of Minnesota, Minneapolis

- Herbert H. Severson, Ph.D.
- Senior Research Scientist, Oregon Research Institute
- Eugene, Oregon

## Peer Reviewers

We gratefully acknowledge the following individuals who reviewed the initial draft of this report and provided us with constructive feedback. External reviewers comprised clinicians, researchers, representatives of professional societies, and potential users of the report. We would also like to extend our appreciation to David Atkins, M.D., from AHRQ for contributing peer review comments. Our peer review panel also includes five members of the TEP. Peer review was a separate duty for these individuals and not part of their commitment as TEP members. All are active professionals in the field. The peer reviewers were asked to provide comments on the content, structure, and format of the evidence report and to complete a checklist. The peer reviewers' comments and suggestions formed the basis of our revisions to the evidence report. Acknowledgments are made with the explicit statement that this does not constitute endorsement of the report.

- Kathleen Adams, Ph.D.
- Associate Professor, Department of Health Policy & Management, School of Public Health, Emory University
- Atlanta, Georgia

- Dianne C. Barker, M.H.S.
- Founder and Principal,
- Barker BiCoastal Health Consultants
- Los Angeles, California

- Matthew P. Barry, M.P.A.
- Senior Policy Analyst
- Campaign for Tobacco-Free Kids
- Washington, D.C.

- Lois Biener, Ph.D.
- Senior Research Fellow
- Center for Survey Research,
- University of Massachusetts
- Boston, Massachusetts

- Brian Flay, Ph.D.
- University Distinguished Professor, Department of Public Health
- Oregon State University
- Corvallis, Oregon

- Cecelia Gaffney, M.Ed.
- Instructor in Family and Community Medicine, Norris Cotton Cancer Center, Dartmouth Medical School
- White River Junction, New Hampshire

- Nancy Kaufman, R.N., M.S.
- Aurora Health Care

- Harry Lando, Ph.D.
- Professor, Division of Epidemiology, School of Public Health,
- University of Minnesota
- Minneapolis, Minnesota

- Sharon Phelan, M.D.
- Chair/Professor Obstetrics & Gynecology, University of New Mexico
- Albuquerque, NM

Author | Title | Year
Sinclair, HK, C. M. Bond, A. S. Lennox, J. Silcock, A. J. Winfield and P. T. Donnan | Training pharmacists and pharmacy assistants in the stage-of-change model of smoking cessation: a randomised controlled trial in Scotland | 1998
Stevens VJ, R. E. Glasgow, J. F. Hollis, E. Lichtenstein and et al. | A smoking-cessation intervention for hospital patients | 1993
Ward Jand R. Sanson-Fisher | Does a 3-day workshop for family medicine trainees improve preventive care? A randomized control trial | 1996
Wilson, DM, D. W. Taylor, J. R. Gilbert, J. A. Best, E. A. Lindsay, D. G. Willms and J. Singer | A randomized trial of a family physician intervention for smoking cessation | 1988