# Appendix D List of Excluded Studies

Exclusion Codes:

X1: Foreign language

X2: Wrong outcome/off topic

X3: Sample size too small

X4: Outside specified geographic area

X5: Wrong publication type

X6: Wrong study design

X7: Follow-up too short

X8: Wrong date

## Excluded articles

Oral snuff: a preventable carcinogenic hazard. Lancet 1986; 2(8500):198–200. Notes: 2873443 KQ4 Search Editorial User Define 1: I User Define 2: X5
Smokeless tobacco sales increasing. ASDC J Dent Child 1991; 58(2):90. Notes: 2050882 KQ4 Search News User Define 1: I User Define 2: X5
Smoking--getting the message across. Midwives Chron 1989; 102(1215):110. Notes: 2761435 KQ3 Search Journal Article User Define 1: I User Define 2: X5
Summary for patients. Effect of a training program for resident physicians in improving success rate in helping patients quit smoking. Ann Intern Med 2002; 136(6):I31. Notes: 11900514 KQ1 Search Clinical Trial User Define 1: I User Define 2: X5
Tobacco and health. CMAJ 1997; 156(2):240A–F. Notes: 9012730 KQ4 Search Journal Article User Define 1: I User Define 2: X5
Tobacco-use prevention and cessation. For infants, children, adolescents, and adults. Institue for Clinical Systems Integration. Postgrad Med 1997; 101(3):292–300, 302. Notes: 9074566 KQ3 Search Guideline User Define 1: I User Define 2: X5
Abel M. Substance misuse among young people in the Pacific. Promot Educ. 1997;4(3):41-2. Notes: 9438308. KQ2 Search Journal Article KQ2 Search. User Define 1: I. User Define 2: X5. [pmid: 9438308].
Abernathy TJ. Compliance for Kids: a community-based tobacco prevention project. Can J Public Health. 1994;85(2):82-4. Notes: 8012922. KQ2 Search Journal Article KQ2 Search. User Define 1: I. User Define 2: X8. [pmid: 8012922].
Adelman WP, Duggan AK, Hauptman P, Joffe A. Effectiveness of a high school smoking cessation program. Pediatrics. 2001;107(4):E50. Notes: 11335771. KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X7.
Allen TW. Eliminating tobacco use, a continuing challenge. J Am Osteopath Assoc. 2004;104(8):313. Notes: 15345698. KQ3 Search Comment. User Define 1: I. User Define 2: X5. [pmid: 15345698].
Altman DG, Feighery EC. Future directions for youth empowerment: commentary on application of youth empowerment theory to tobacco control. Health Educ Behav. 2004;31(5):641-7. Notes: 15358895. KQ2 Search Journal Article KQ2 Search. User Define 1: I. User Define 2: X5. [pmid: 15358895].
American Academy of Pediatrics Committee on Environmental Hazards. Smokeless tobacco--a carcinogenic hazard to children. Pediatrics. 1985;76(6):1009-11. Notes: 4069845. KQ4 Search Journal Article. User Define 1: I. User Define 2: X5. [pmid: 4069845].
Amos A, White DA, Elton RA. Is a telephone helpline of value to the workplace smoker. Occup Med (Lond). 1995;45(5):234-8. Notes: 7579297. KQ2 Search Journal Article KQ2 Search. User Define 1: I. User Define 2: X8. [pmid: 7579297].
Andrews S. The challenge of teenage smoking. Nurs Times. 2004;100(6):52-3. Notes: 15000030. KQ3 Search Journal Article. User Define 1: I. User Define 2: X5. [pmid: 15000030].
Ashley MJ, Northrup DA, Ferrence R. The Ontario ban on smoking on school property: issues and challenges in enforcement. Can J Public Health. 1998;89(4):229-32. Notes: 9735514. KQ3 Search Journal Article. User Define 1: I. User Define 2: X5. [pmid: 9735514].
Aveyard P, Markham WA, Almond J, Lancashire E, Cheng KK. The risk of smoking in relation to engagement with a school-based smoking intervention. Soc Sci Med. 2003;56(4):869-82. Notes: 12560019. KQ5 Search KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X2. [pmid: 12560019].
Aveyard P, Markham WA, Lancashire E, et al. The Influence of School Culture on Smoking among Pupils. Social Science & Medicine. 2004;58(9):1767-80. Notes: Sociological Abstracts Search. User Define 1: I. User Define 2: X2. [pmid: 14990377].
Barker GJ, Williams KB. Tobacco use cessation activities in U.S. dental and dental hygiene student clinics. J Dent Educ. 1999;63(11):828-33. Notes: 10608929. Journal Article. User Define 1: I. User Define 2: X5. [pmid: 10608929].
Basen-Engquist K, O'Hara-Tompkins N, Lovato CY, Lewis MJ, Parcel GS, Gingiss P. The effect of two types of teacher training on implementation of Smart Choices: a tobacco prevention curriculum. J Sch Health. 1994;64(8):334-9. Notes: 7844976. KQ3 Search Clinical Trial. User Define 1: I. User Define 2: X8. [pmid: 7844976].
Bennett SE. Effectiveness of three different methods of intervention by physical therapists to motivate patients to quit smoking. Dissertation Abstracts International. 1989;50(5-B):1835. Notes: 1990-53659-001. Psychological Abstracts Search Dissertation-Abstract. User Define 1: I. User Define 2: X5.
Biberman R, Neumann R, Katzir I, Gerber Y. A randomized controlled trial of oral selegiline plus nicotine skin patch compared with placebo plus nicotine skin patch for smoking cessation. Addiction. 2003;98(10):1403-7. Notes: 2004042556. CINAHL Search Using Smart Source Parsing. User Define 1: I. User Define 2: X4. [pmid: 14519177].
Biglan A, Ary DV. Methodological issues in research on smoking prevention. NIDA Res Monogr. 1985;63:170-95. Notes: 3934553. KQ1 Search Journal Article. User Define 1: I. User Define 2: X5.
Bobo JK, Davis CM. Cigarette smoking cessation and alcohol treatment. Addiction. 1993;88(3):405-12. Notes: 8384911. CCTR Search 0965–2140. User Define 1: I. User Define 2: X6. [pmid: 8384911].
Bolinger C. Smoking prevention in childhood cancer survivors. J Pediatr Oncol Nurs. 1994;11(4):167-71. Notes: 7946148. KQ3 Search Journal Article. User Define 1: I. User Define 2: X5. [pmid: 7946148].
Bolman C, de Vries H, van Breukelen G. Evaluation of a nurse-managed minimal-contact smoking cessation intervention for cardiac inpatients. Health Educ Res. 2002;17(1):99-116. Notes: 2002-10595-008. Psychological Abstracts Search Peer-Reviewed-Journal. User Define 1: I. User Define 2: X2. [pmid: 11888048].
Borrelli B, McQuaid EL, Becker B, et al. Motivating parents of kids with asthma to quit smoking: the PAQS project. Health Educ Res. 2002;17(5):659-69. Notes: 12408210. KQ5 Search KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X6. [pmid: 12408210].
Borum ML. Impact of two ambulatory care training programs on smoking-cessation activities. South Med J. 1999;92(10):977-80. Notes: 10548170. Journal Article. User Define 1: I. User Define 2: X6. [pmid: 10548170].
Botvin GJ, Dusenbury L, Baker E, James-Ortiz S, Botvin EM, Kerner J. Smoking prevention among urban minority youth: assessing effects on outcome and mediating variables. Health Psychol. 1992;11(5):290-9. Notes: 1425546. KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X8. [pmid: 1425546].
Botvin GJ, Dusenbury L, Baker E, James-Ortiz S, Kerner J. A skills training approach to smoking prevention among Hispanic youth. J Behav Med. 1989;12(3):279-96. Notes: 2634104. KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X8. [pmid: 2634104].
Bovet P, Perret F, Cornuz J, Quilindo J, Paccaud F. Improved smoking cessation in smokers given ultrasound photographs of their own atherosclerotic plaques. Prev Med. 2002;34(2):215-20. Notes: 11817917. User Define 1: I. User Define 2: X4. [pmid: 11817917].
Bowen DJ, Orlandi MA, Lichtenstein E, Cummings KM, Hyland A. Intervention effects on youth tobacco use in the community intervention trial (COMMIT). J Epidemiol Community Health. 2003;57(2):159-60. Notes: 2003155816. CINAHL Search Using Smart Source Parsing. User Define 1: I. User Define 2: X5.
Buchanan LM, El-Banna M, White A, Moses S, Siedlik C, Wood M. An exploratory study of multicomponent treatment intervention for tobacco dependency. J Nurs Scholarsh. 2004;36(4):324-30. Notes: 15636412. KQ3 Search KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X3. [pmid: 15636412].
Burtner AP, Wakham MD, McNeal DR, Garvey TP. Tobacco and the institutionalized mentally retarded: usage choices and ethical considerations. Spec Care Dentist. 1995;15(2):56-60. Notes: 8619164. KQ4 Search Journal Article. User Define 1: I. User Define 2: X2. [pmid: 8619164].
Burton D, Fahs M, Chang JL, et al. Community-based participatory research on smoking cessation among Chinese Americans in Flushing, Queens, New York City. J Interprof Care. 2004;18(4):443-5. Notes: 15801560. KQ2 Search Journal Article KQ2 Search. User Define 1: I. User Define 2: X3. [pmid: 15801560].
Butterfield RM, Park ER, Puleo E, et al. Multiple Risk Behaviors Among Smokers in the Childhood Cancer Survivors Study Cohort. Psychooncology. 2004;13(9):619-29. Notes: 2004-18621-003. Psychological Abstracts Search Peer-Reviewed-Journal. User Define 1: I. User Define 2: X2. [pmid: 15334530].
Byars JA, Frost Pineda K, Jacobs WS, Gold MS. Naltrexone Augments the Effects of Nicotine Replacement Therapy in Female Smokers. J Addict Dis. 2005;24(2):49-60. Notes: 2005-04417-005. Psychological Abstracts Search Peer-Reviewed-Journal. User Define 1: I. User Define 2: X7.
Byrd JC, Meade CD. Smoking cessation among pregnant women in an urban setting. Wis Med J. 1993;92(11):609-12. Notes: 8303896. KQ3 Search KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X8. [pmid: 8303896].
Campbell IA, Lyons E, Prescott RJ. Stopping smoking. Do nicotine chewing-gum and postal encouragement add to doctors' advice. Practitioner. 1987;231(1423):114-7. Notes: 3671317. KQ3 Search KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X8. [pmid: 3671317].
Canto MT, Kawaguchi Y, Horowitz AM. Coverage and quality of oral cancer information in the popular press: 1987-98. J Public Health Dent. 1998;58(3):241-7. Notes: 10101701. KQ4 Search Journal Article. User Define 1: I. User Define 2: X2. [pmid: 10101701].
Capone DAL. An emotion-focused problem-solving smoking cessation intervention for depression-prone college students. Dissertation Abstracts International: Section B. The Sciences and Engineering. 2003;64(5-B):2374. Notes: 2003-95022-249. Psychological Abstracts Search Dissertation-Abstract. User Define 1: I. User Define 2: X5.
Caswell RJ. Measuring the impact of P.L. 99–252: an economist's view. J Public Health Dent. 1990;50(1):77-83. Notes: 2104932. KQ4 Search Journal Article. User Define 1: I. User Define 2: X2. [pmid: 2104932].
Chalmers K, Gupton A, Katz A, et al. The description and evaluation of a longitudinal pilot study of a smoking relapse/reduction intervention for perinatal women. J Adv Nurs. 2004;45(2):162-71. Notes: 14706001. KQ2 Search Journal Article KQ2 Search. User Define 1: I. User Define 2: X2. [pmid: 14706001].
Chapin J, Root W. Improving obstetrician-gynecologist implementation of smoking cessation guidelines for pregnant women: An interim report of the American College of Obstetricians and Gynecologists. Nicotine and Tobacco Research. 2004;6(Suppl2):S253-S257. Notes: 2004-14492-013. Psychological Abstracts Search Peer-Reviewed-Journal. User Define 1: I. User Define 2: X2. [pmid: 15203825].
Chapman S, Wakefield M. Tobacco control advocacy in Australia: reflections on 30 years of progress. Health Educ Behav. 2001;28(3):274-89. Notes: 11380049. KQ4 Search Journal Article. User Define 1: I. User Define 2: X6. [pmid: 11380049].
Chou CP, Montgomery S, Pentz MA, et al. Effects of a community-based prevention program on decreasing drug use in high-risk adolescents. Am J Public Health. 1998;88(6):944-8. Notes: 9618626. KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X8. [pmid: 9618626]. [pmcid: 1508235].
Christen AG. Tobacco chewing and snuff dipping. N Engl J Med. 1980;302(14):818. Notes: 7188785. KQ4 Search Letter. User Define 1: I. User Define 2: X5. [pmid: 7188785].
Cinciripini PM, Wetter DW, Fouladi RT, et al. The effects of depressed mood on smoking cessation: mediation by postcessation self-efficacy. J Consult Clin Psychol. 2003;71(2):292-301. Notes: 12699023. abstract search result. User Define 1: I. User Define 2: X2. [pmid: 12699023].
Clements-Thompson M, Klesges RC, Haddock K, Lando H, Talcott W. Relationships between stages of change in cigarette smokers and healthy lifestyle behaviors in a population of young military personnel during forced smoking abstinence. J Consult Clin Psychol. 1998;66(6):1005-11. Notes: 9874914. KQ5 Search Clinical Trial. User Define 1: I. User Define 2: X2. [pmid: 9874914].
Cohen SJ, Christen AG, Katz BP, et al. Counseling medical and dental patients about cigarette smoking: the impact of nicotine gum and chart reminders. Am J Public Health. 1987;77(3):313-6. Notes: 3812837. KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X8. [pmid: 3812837]. [pmcid: 1646917].
Connolly GN, Orleans CT, Blum A. Snuffing tobacco out of sport. Am J Public Health. 1992;82(3):351-3. Notes: 1536348. KQ4 Search Journal Article. User Define 1: I. User Define 2: X5. [pmid: 1536348]. [pmcid: 1694387].
Cornuz J, Zellweger JP, Mounoud C, Decrey H, Pecoud A, Burnand B. Smoking cessation counseling by residents in an outpatient clinic. Prev Med. 1997;26(3):292-6. Notes: 9144752. KQ3 Search KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X8. [pmid: 9144752].
Corrigan M, Cupples ME, Stevenson M. Quitting and restarting smoking: cohort study of patients with angina in primary care. BMJ. 2002;324(7344):1016-7. Notes: 11976245. User Define 1: I. User Define 2: X5. [pmid: 11976245]. [pmcid: 102779].
Cox LS, Clark MM, Jett JR, et al. Change in smoking status after spiral chest computed tomography scan screening. Cancer. 2003;98(11):2495-501. Notes: 14635086. abstract search result. User Define 1: I. User Define 2: X6. [pmid: 14635086].
Cox LS, Patten CA, Niaura RS, et al. Efficacy of bupropion for relapse prevention in smokers with and without a past history of major depression. J Gen Intern Med. 2004;19(8):828-34. Notes: 15242467. abstract search result. User Define 1: I. User Define 2: X2. [pmid: 15242467]. [pmcid: 1492503].
Croll TP, Swanson BZ Jr. 19th century dentistry advertising trade cards. J Hist Dent. 2004;52(3):130. Notes: 15666503. KQ4 Search Historical Article. User Define 1: I. User Define 2: X5. [pmid: 15666503].
Cronan TA, Conway TL, Hervig LK. Evaluation of smoking interventions in recruit training. Mil Med. 1989;154(7):371-5. Notes: 2503780. KQ3 Search Journal Article. User Define 1: I. User Define 2: X8. [pmid: 2503780].
Cronin C. Consumers and the AHCPR smoking cessation guideline. Tob Control 1997; 6 Suppl 1:S57–9.Notes: 9396126 KQ2 Search Journal Article KQ2 Search User Define 1: I User Define 2: X5
Croucher R, Islam S, Jarvis MJ, et al. Oral tobacco cessation with UK resident Bangladeshi women: a community pilot investigation. Health Educ Res. 2003;18(2):216-23. Notes: 12729180. CCTR Search 0268–1153. User Define 1: I. User Define 2: X7. [pmid: 12729180].
Cullen JW, McKenna JW, Massey MM. International control of smoking and the US experience. Chest. 1986;89(4 Suppl):206S-18S. Notes: 3956298. KQ4 Search Journal Article. User Define 1: I. User Define 2: X5. [pmid: 3956298].
Dalack GW, Glassman AH, Rivelli S, Covey L, Stetner F. Mood, major depression, and fluoxetine response in cigarette smokers. Am J Psychiatry. 1995;152(3):398-403. Notes: 7864266. KQ5 Search Clinical Trial. User Define 1: I. User Define 2: X2. [pmid: 7864266].
Davies SL. Using the Transtheoretical Model of Change as a framework for understanding smoking behavior in a sample of low-income, hospitalized, African-American smokers. Dissertation Abstracts International: Section B. The Sciences and Engineering. 1997;58(5-B):2378. Notes: 1997-95022-350. Psychological Abstracts Search Dissertation-Abstract. User Define 1: I. User Define 2: X5.
DePue JD, Goldstein MG, Schilling A, et al. Dissemination of the AHCPR clinical practice guideline in community health centres. Tob Control. 2002;11(4):329-35. Notes: 2003097857. CINAHL Search Using Smart Source Parsing. User Define 1: I. User Define 2: X2. [pmid: 12432158]. [pmcid: 1747684].
Des Vaux Oakes J. Forming community coalitions: “smoking stinks”. Tob Control. 1998;7(Suppl):S27-8. discussion S32–5. Notes: 10093193. KQ2 Search Journal Article KQ2 Search. User Define 1: I. User Define 2: X5. [pmid: 10093193]. [pmcid: 1766238].
DiFranza JR, Coleman M, St Cyr D. A comparison of the advertising and accessibility of cigars, cigarettes, chewing tobacco, and loose tobacco. Prev Med. 1999;29(5):321-6. Notes: 10564622. KQ4 Search Journal Article. User Define 1: I. User Define 2: X2. [pmid: 10564622].
Dijkstra A, De Vries H, Roijackers J. Targeting smokers with low readiness to change with tailored and nontailored self-help materials. Prev Med. 1999;28(2):203-11. Notes: 10048112. User Define 1: I. User Define 2: X2. [pmid: 10048112].
Dolan TA, McGorray SP, Grinstead-Skigen CL, Mecklenburg R. Tobacco control activities in U.S. dental practices. J Am Dent Assoc. 1997;128(12):1669-79. Notes: 9415764. KQ3 Search Journal Article. User Define 1: I. User Define 2: X8. [pmid: 9415764].
Donaldson SI, Graham JW, Hansen WB. Testing the generalizability of intervening mechanism theories: understanding the effects of adolescent drug use prevention interventions. J Behav Med. 1994;17(2):195-216. Notes: 8035452. KQ5 Search KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X8. [pmid: 8035452].
Dowdell EB. Urban seventh graders and smoking: a health risk behavior assessment. Issues Compr Pediatr Nurs. 2002;25(4):217-29. Notes: 12542884. KQ3 Search Journal Article. User Define 1: I. User Define 2: X2. [pmid: 12542884].
Downes EJ. Are you watching out for your patients. N Y State Dent J. 2002;68(7):32. Notes: 12243091. KQ3 Search Editorial. User Define 1: I. User Define 2: X5. [pmid: 12243091].
Duffy J, Coates TJ. Reducing smoking among pregnant adolescents. Adolescence. 1989;24(93):29-37. Notes: 2728972. KQ3 Search Journal Article. User Define 1: I. User Define 2: X5. [pmid: 2728972].
Dunn CL, Pirie PL, Hellerstedt WL. The advice-giving role of female friends and relatives during pregnancy. Health Educ Res. 2003;18(3):352-62. Notes: 2003-06139-008. Psychological Abstracts Search Peer-Reviewed-Journal. User Define 1: I. User Define 2: X2. [pmid: 12828236].
Eckhardt L, Woodruff SI, Elder JP. Related effectiveness of continued, lapsed, and delayed smoking prevention intervention in senior high school students. Am J Health Promot. 1997;11(6):418-21. Notes: 10168261. KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X8. [pmid: 10168261].
Edwards CC, Elder JP, de Moor C, Wildey MB, Mayer JA, Senn KL. Predictors of participation in a school-based anti-tobacco activism program. J Community Health. 1992;17(5):283-9. Notes: 1401235. KQ2 Search Journal Article KQ2 Search. User Define 1: I. User Define 2: X8. [pmid: 1401235].
Emmons KM, Butterfield RM, Puleo E, et al. Smoking among participants in the childhood cancer survivors cohort: the Partnership for Health Study. J Clin Oncol. 2003;21(2):189-96. Notes: 12525509. KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X2. [pmid: 12525509].
Epps RP, Manley MW, Grande D, Lynch BS. How clinicians can affect patient smoking behavior through community involvement and clinical practice. J Am Med Womens Assoc. 1996;51(12):43-7. Notes: 8868548. KQ3 Search KQ2 Search Journal Article. User Define 1: I. User Define 2: X5. [pmid: 8868548].
Escoffery C, McCormick L, Bateman K. Development and process evaluation of a web-based smoking cessation program for college smokers: innovative tool for education. Patient Educ Couns. 2004;53(2):217-25. Notes: 15140462. KQ3 Search KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X3. [pmid: 15140462].
Etter J, Prokhorov AV, Perneger TV. Gender differences in the psychological determinants of cigarette smoking. Addiction. 2002;97(6):733-43. Notes: 2002173901. CINAHL Search Using Smart Source Parsing. User Define 1: I. User Define 2: X2. [pmid: 12084143].
Etter JF, le Houezec J, Landfeldt B. Impact of messages on concomitant use of nicotine replacement therapy and cigarettes: a randomized trial on the Internet. Addiction. 2003;98(7):941-50. Notes: 12814500. KQ3 Search KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X6. [pmid: 12814500].
Etter JF, Rielle JC, Perneger TV. Labeling smokers' charts with a “smoker” sticker: results of a randomized controlled trial among private practitioners. J Gen Intern Med. 2000;15(6):421-4. Notes: 10886477. User Define 1: I. User Define 2: X6. [pmid: 10886477]. [pmcid: 1495475].
Evans WD, Ulasevich A, Blahut S. Adult and group influences on participation in youth empowerment programs. Health Educ Behav. 2004;31(5):564-76. Notes: 15358890. KQ2 Search Evaluation Studies. User Define 1: I. User Define 2: X2. [pmid: 15358890].
Fawcett SB, Lewis RK, Paine-Andrews A, et al. Evaluating community coalitions for prevention of substance abuse: the case of Project Freedom. Health Educ Behav. 1997;24(6):812-28. Notes: 9408793. KQ2 Search Journal Article KQ2 Search. User Define 1: I. User Define 2: X8. [pmid: 9408793].
Feigelman W, Lee J. Probing the Paradoxical Pattern of Cigarette Smoking among African-Americans: Low Teenage Consumption and High Adult Use. American Sociological Association (ASA) 1994. Notes: Sociological Abstracts Search User Define 1: I User Define 2: X2
Feinberg ME, Greenberg MT, Osgood DW. Readiness, Functioning, and Perceived Effectiveness in Community Prevention Coalitions: A Study of Communities That Care. Am J Community Psychol. 2004;33(34):163-76. Notes: Sociological Abstracts Search. User Define 1: I. User Define 2: X2. [pmid: 15212176].
Fisher S. Inpatient intervention with intensive contact after discharge improved smoking cessation rates [commentary on Miller NH, Smith PM, DeBusk RF, et al Smoking cessation in hospitalized patients ARCH INTERN MED 1997 Feb 24;157:409–15]. Evidence Based Nursing 1998; 1(1). Notes: 1999033375 CINAHL Search Using Smart Source Parsing User Define 1: I User Define 2: X5
Frankel HH. Another cowboy selling cancer. West J Med. 1979;130(3):270-1. Notes: 570763. KQ4 Search Letter. User Define 1: I. User Define 2: X5. [pmid: 570763].
Franzgrote M, Ellen JM, Millstein SG, Irwin CE Jr. Screening for adolescent smoking among primary care physicians in California. Am J Public Health. 1997;87(8):1341-5. Notes: 9279272. KQ1 Search Journal Article. User Define 1: I. User Define 2: X8. [pmid: 9279272]. [pmcid: 1381097].
Freedman LS, Gail MH, Green SB, Corle DK. The efficiency of the matched-pairs design of the Community Intervention Trial for Smoking Cessation (COMMIT). Control Clin Trials. 1997;18(2):131-9. Notes: 9129857. CCTR Search 0197–2456. User Define 1: I. User Define 2: X8. [pmid: 9129857].
Freels SA, Warnecke RB, Parsons JA, Johnson TP, Flay BR, Morera OF. Characteristics associated with exposure to and participation in a televised smoking cessation intervention program for women with high school or less education. Preventive Medicine: An International Journal Devoted to Practice and Theory. 1999;28(6):579-88. Notes: 1999-05724-004. Psychological Abstracts Search Peer-Reviewed-Journal. User Define 1: I. User Define 2: X2.
Froelicher ES, Christopherson DJ, Miller NH, Martin K. Women's initiative for nonsmoking (WINS) IV: description of 277 women smokers hospitalized with cardiovascular disease. Heart Lung. 2002;31(1):3-14. Notes: 11805744. KQ5 Search Clinical Trial. User Define 1: I. User Define 2: X2. [pmid: 11805744].
Gaffney M. Ethical responsibilities of physicians in tobacco control. Indiana Med. 1996;89(2):196-8. Notes: 8867423. KQ3 Search Journal Article. User Define 1: I. User Define 2: X5. [pmid: 8867423].
Gelskey SC. Impact of a dental/dental hygiene tobacco-use cessation curriculum on practice. J Dent Educ. 2002;66(9):1074-8. Notes: 12374268. User Define 1: I. User Define 2: X6. [pmid: 12374268].
Gil KM, Schrop SL, Kline SC, et al. Stages of change analysis of smokers attending clinics for the medically underserved. J Fam Pract. 2002;51(12):1018. Notes: 12540324. KQ2 Search Journal Article KQ2 Search. User Define 1: I. User Define 2: X2. [pmid: 12540324].
Gingiss PL, Gottlieb NH. A comparison of smokeless tobacco and smoking practices of university varsity and intramural baseball players. Addict Behav. 1991;16(5):335-40. Notes: 1776549. User Define 1: I. User Define 2: X2. [pmid: 1776549].
Glasgow RE, Stevens VJ, Vogt TM, Mullooly JP, Lichtenstein E. Changes in smoking associated with hospitalization: quit rates, predictive variables, and intervention implications. Am J Health Promot. 1991;6(1):24-9. Notes: 10148681. KQ3 Search Journal Article. User Define 1: I. User Define 2: X8. [pmid: 10148681].
Goldberg ME, Liefeld J, Madill J, Vredenburg H. The effect of plain packaging on response to health warnings. Am J Public Health. 1999;89(9):1434-5. Notes: 10474569. KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X5. [pmid: 10474569]. [pmcid: 1508782].
Gonzales DH. A comparison of smoking patterns between counseling-assisted and unassisted heavy smokers with early chronic obstructive pulmonary disease. Dissertation Abstracts International. 1992;53(2A):406. Notes: 1993-72449-001. Psychological Abstracts Search Dissertation-Abstract. User Define 1: I. User Define 2: X5.
Gregorio DI. Counseling adolescents for smoking prevention: a survey of primary care physicians and dentists. Am J Public Health. 1994;84(7):1151-3. Notes: 8017543. KQ3 Search Journal Article. User Define 1: I. User Define 2: X8. [pmid: 8017543]. [pmcid: 1614763].
Greydanus DE. Routing a modern Pied Piper of Hamelin. JAMA. 1989;261(1):99-100. Notes: 2909004. KQ2 Search Editorial KQ2 Search. User Define 1: I. User Define 2: X5. [pmid: 2909004].
Gritz ER, Prokhorov AV, Hudmon KS, et al. Cigarette smoking in a multiethnic population of youth: methods and baseline findings. Prev Med. 1998;27(3):365-84. Notes: 9612827. CCTR Search 0091–7435. User Define 1: I. User Define 2: X2. [pmid: 9612827].
Gritz ER, Prokhorov AV, Hudmon KS, et al. Predictors of susceptibility to smoking and ever smoking: a longitudinal study in a triethnic sample of adolescents. Nicotine Tob Res. 2003;5(4):493-506. Notes: 12959787. 1462–2203. User Define 1: I. User Define 2: X2. [pmid: 12959787].
Gruder CL, Warnecke RB, Jason LA, Flay BR, et al. A televised, self-help, cigarette smoking cessation intervention. Addict Behav. 1990;15(6):505-16. Notes: 1991-13657-001. Psychological Abstracts Search Peer-Reviewed-Journal. User Define 1: I. User Define 2: X2. [pmid: 2075848].
Haas AL, Munoz RF, Humfleet GL, Reus VI, Hall SM. Influences of mood, depression history, and treatment modality on outcomes in smoking cessation. J Consult Clin Psychol. 2004;72(4):563-70. Notes: 15301640. abstract search result. User Define 1: I. User Define 2: X6. [pmid: 15301640].
Hahn EJ, Simpson MR, Kidd P. Cues to parent involvement in drug prevention and school activities. J Sch Health. 1996;66(5):165-70. Notes: 8735580. KQ2 Search Journal Article KQ2 Search. User Define 1: I. User Define 2: X2. [pmid: 8735580].
Hajek P, Stead LF, West R, Jarvis M. Relapse prevention interventions for smoking cessation. Cochrane Database Syst Rev 2005; (1):CD003999. Notes: 15674921 Journal Article User Define 1: I User Define 2: X2
Hamilton G, O'Connell M, Cross D. Adolescent smoking cessation: development of a school nurse intervention. J Sch Nurs. 2004;20(3):169-74. Notes: 15147225. KQ3 Search KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X3. [pmid: 15147225].
Hammond D, McDonald PW, Fong GT, Borland R. Do smokers know how to quit? Knowledge and perceived effectiveness of cessation assistance as predictors of cessation behaviour. Addiction. 2004;99(8):1042-8. Notes: 15265101. KQ3 Search Journal Article. User Define 1: I. User Define 2: X7. [pmid: 15265101].
Harris KJ, Ahluwalia JS, Okuyemi KS, et al. Addressing cultural sensitivity in a smoking cessation intervention: Development of the Kick It At Swope Project. J Community Psychol. 2001;29(4):447-58. Notes: 2002-17026-005. CCTR Search Psychological Abstracts Search Peer-Reviewed-Journal. User Define 1: I. User Define 2: X6.
Hartmann KE, Espy A, McPheeters M, Kinsinger LS. Physicians taught as residents to conduct smoking cessation intervention: A follow-up study. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2004;39(2):344-50. Notes: 2004-16768-009. Psychological Abstracts Search Peer-Reviewed-Journal. User Define 1: I. User Define 2: X5.
Haslam C, Draper ES, Goyder E. The pregnant smoker: a preliminary investigation of the social and psychological influences. J Public Health Med. 1997;19(2):187-92. Notes: 9243434. KQ3 Search Journal Article. User Define 1: I. User Define 2: X8. [pmid: 9243434].
Haviland L, Thornton AH, Carothers S, et al. Giving infants a great start: launching a national smoking cessation program for pregnant women. Nicotine Tob Res. 2004;6(Suppl 2):S181-8. Notes: 15203820. KQ3 Search Journal Article. User Define 1: I. User Define 2: X5. [pmid: 15203820].
Healey BJ. The use of prevalence data to unite the community in prevention programs. J Public Health Manag Pract. 1998;4(6):88-92. Notes: 10187082. KQ2 Search Journal Article. User Define 1: I. User Define 2: X2. [pmid: 10187082].
Heit P, Gibson J. Treatment vs. prevention of smoking. Health Educ. 1978;9(3):8-9. Notes: 418049. KQ3 Search Journal Article. User Define 1: I. User Define 2: X5. [pmid: 418049].
Hinnant LW, Nimsch C, Stone-Wiggins B. Examination of the relationship between community support and tobacco control activities as a part of youth empowerment programs. Health Educ Behav. 2004;31(5):629-40. Notes: 15358894. KQ2 Search Evaluation Studies. User Define 1: I. User Define 2: X2. [pmid: 15358894].
Holden DJ, Crankshaw E, Nimsch C, Hinnant LW, Hund L. Quantifying the impact of participation in local tobacco control groups on the psychological empowerment of involved youth. Health Educ Behav. 2004;31(5):615-28. Notes: 15358893. KQ2 Search Evaluation Studies. User Define 1: I. User Define 2: X2. [pmid: 15358893].
Holden DJ, Messeri P, Evans WD, Crankshaw E, Ben-Davies M. Conceptualizing youth empowerment within tobacco control. Health Educ Behav. 2004;31(5):548-63. Notes: 15358889. KQ2 Search Journal Article KQ2 Search. User Define 1: I. User Define 2: X2. [pmid: 15358889].
Hopkins PJ, Walsh RA. How to help patients stop smoking. Med J Aust. 1992;157(10):688-92. Notes: 1435412. KQ3 Search Journal Article. User Define 1: I. User Define 2: X5. [pmid: 1435412].
Houpt MI. Time to stop smoking. Pediatr Dent. 1998;20(1):6. Notes: 9524966. KQ3 Search Editorial. User Define 1: I. User Define 2: X5. [pmid: 9524966].
Hudmon KS, Hemberger KK, Corelli RL, Kroon LA, Prokhorov AV. The pharmacist's role in smoking cessation counseling: perceptions of users of nonprescription nicotine replacement therapy. J Am Pharm Assoc (Wash DC). 2003;43(5):573-82. Notes: 14626749. 1544–3191. User Define 1: I. User Define 2: X2.
Hughes JR, Frances RJ. How to help psychiatric patients stop smoking. Psychiatr Serv. 1995;46(5):435-6. Notes: 7627666. Journal Article. User Define 1: I. User Define 2: X5. [pmid: 7627666].
Hunt MK, Fagan P, Lederman R, et al. Feasibility of implementing intervention methods in an adolescent worksite tobacco control study. Tob Control. 2003;12(Suppl 4):IV40-5. Notes: 14645939. KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X3. [pmid: 14645939].
Hymowitz N, Schwab J, Eckholdt H. Pediatric residency training on tobacco. Pediatrics. 2001;108(1):E8. Notes: 11433087. KQ3 Search Journal Article. User Define 1: I. User Define 2: X3. [pmid: 11433047].
Iglehart JK. The campaign against smoking gains momentum. N Engl J Med. 1986;314(16):1059-64. Notes: 3960078. KQ4 Search Journal Article. User Define 1: I. User Define 2: X5. [pmid: 3960078].
Johnson CA, Hansen WB, Collins LM, Graham JW. High-school smoking prevention: results of a three-year longitudinal study. J Behav Med. 1986;9(5):439-52. Notes: 3795263. KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X8. [pmid: 3795263].
Johnson J, Ballin S. The power to regulate tobacco. Circulation. 1995;92(8):2021. Notes: 7554173. KQ4 Search News. User Define 1: I. User Define 2: X5. [pmid: 7554173].
Jolicoeur DG, Richter KP, Ahluwalia JS, Mosier MC, Resnicow K. Smoking cessation, smoking reduction, and delayed quitting among smokers given nicotine patches and a self-help pamphlet. Subst Abus. 2003;24(2):101-6. Notes: 12766377. User Define 1: I. User Define 2: X6. [pmid: 12766377].
Jones DL, Mobley CC. Treatment of nicotine addiction. Tex Dent J. 2000;117(6):26-32. Notes: 11857853. KQ3 Search Journal Article. User Define 1: I. User Define 2: X5. [pmid: 11857853].
Jones TL. Taking action on teen smoking. Texas physicians back tobacco regulations, counsel teens. Tex Med. 1996;92(3):33-5. Notes: 8820257. KQ3 Search Journal Article. User Define 1: I. User Define 2: X5. [pmid: 8820257].
Jones-Webb R, McKiver M, Pirie P, Miner K. Relationships between physician advice and tobacco and alcohol use during pregnancy. Am J Prev Med. 1999;16(3):244-7. Notes: 10198665. KQ3 Search Journal Article. User Define 1: I. User Define 2: X2. [pmid: 10198665].
Joossens L. EC oral snuff ban and Sweden. Lancet. 1992;340(8810):57. Notes: 1351637. KQ4 Search Letter. User Define 1: I. User Define 2: X5. [pmid: 1351637].
Josefson D. Company plans to sell snuff as “smokeless tobacco”. BMJ. 2003;327(7409):247. Notes: 12896920. KQ4 Search News. User Define 1: I. User Define 2: X5. [pmid: 12896920].
Kaplan CP, Perez-Stable EJ, Fuentes-Afflick E, Gildengorin V, Millstein S, Juarez-Reyes M. Smoking cessation counseling with young patients: the practices of family physicians and pediatricians. Arch Pediatr Adolesc Med. 2004;158(1):83-90. Notes: 14706964. KQ1 Search Journal Article. User Define 1: I. User Define 2: X2. [pmid: 14706964].
Katz DA, Muehlenbruch DR, Brown RB, Fiore MC, Baker TB. Effectiveness of a clinic-based strategy for implementing the AHRQ smoking cessation guideline in primary care. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2002;35(3):293-302. Notes: 2002-18488-005. Psychological Abstracts Search Peer-Reviewed-Journal. User Define 1: I. User Define 2: X6.
Katz RC, Robisch CM, Telch MJ. Acquisition of smoking refusal skills in junior high school students. Addict Behav. 1989;14(2):201-4. Notes: 2728956. KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X3. [pmid: 2728956].
Kelder SH, Prokhorov A, Barroso CS, Murray N, Orpinas P, McCormick L. Smoking differences among African American, Hispanic, and White middle school students in an urban setting. Addict Behav. 2003;28(3):513-22. Notes: 12628623. 0306–4603. User Define 1: I. User Define 2: X2. [pmid: 12628623].
Kentala J, Utriainen P, Pahkala K, Mattila K. Can brief intervention through community dental care have an effect on adolescent smoking. Prev Med. 1999;29(2):107-11. Notes: 10446036. CCTR Search KQ5 Search KQ3 Search KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X8. [pmid: 10446036].
Kessler DA, Natanblut SL, Wilkenfeld JP, et al. Nicotine addiction: a pediatric disease. J Pediatr. 1997;130(4):518-24. Notes: 9108846. KQ4 Search Journal Article. User Define 1: I. User Define 2: X5. [pmid: 9108846].
Keuthen NJ, Niaura RS, Borrelli B, et al. Comorbidity, smoking behavior and treatment outcome. Psychother Psychosom. 2000;69(5):244-50. Notes: 10965289. KQ5 Search Clinical Trial. User Define 1: I. User Define 2: X6. [pmid: 10965289].
Killen JD, Robinson TN, Ammerman S, et al. Major depression among adolescent smokers undergoing treatment for nicotine dependence. Addict Behav. 2004;29(8):1517-26. Notes: 15451121. KQ5 Search Clinical Trial. User Define 1: I. User Define 2: X2. [pmid: 15451121].
Killen JD, Robinson TN, Telch MJ, et al. The Stanford Adolescent Heart Health Program. Health Educ Q. 1989;16(2):263-83. Notes: 2732068. KQ5 Search KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X8. [pmid: 2732068].
Kim JR, Lee MS, Hwang JY, Lee JD. Efficacy of a smoking cessation intervention using the AHCPR guideline tailored for Koreans: a randomized controlled trial. Health Promot Int. 2005;20(1):51-9. Notes: 15681592. KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X4. [pmid: 15681592].
Korhonen T, Uutela A, Korhonen HJ, Puska P. Impact of mass media and interpersonal health communication on smoking cessation attempts: a study in North Karelia, 1989-1996. J Health Commun. 1998;3(2):105-18. Notes: 10977248. KQ2 Search Journal Article KQ2 Search. User Define 1: I. User Define 2: X8. [pmid: 10977248].
Krevor BS, Lieberman A, Gerlach K. Application of consumer protection authority in preventing tobacco sales to minors. Tob Control. 2002;11(2):109-11. Notes: 12035002. KQ2 Search Journal Article KQ2 Search. User Define 1: I. User Define 2: X5. [pmid: 12035002]. [pmcid: 1763837].
Kronenfeld JJ, Jackson K, Blair SN, et al. Evaluating health promotion: a longitudinal quasi-experimental design. Health Educ Q. 1987;14(2):123-39. Notes: 3597106. KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X8. [pmid: 3597106].
Kury SP, Rodrigue JR, Perri MG. Smokeless tobacco and cigarettes: differential attitudes and behavioral intentions of young adolescents toward a hypothetical new peer. J Clin Child Psychol. 1998;27(4):415-22. Notes: 9866078. KQ4 Search Journal Article. User Define 1: I. User Define 2: X2. [pmid: 9866078].
Kviz FJ, Crittenden KS, Warnecke RB. Factors associated with nonparticipation among registrants for a self-help, community-based smoking cessation intervention. Addict Behav. 1992;17(6):533-42. Notes: 1993-23255-001. Psychological Abstracts Search Peer-Reviewed-Journal. User Define 1: I. User Define 2: X2. [pmid: 1488934].
Lamkin L, Davis B, Kamen A. Rationale for tobacco cessation interventions for youth. Prev Med. 1998;27(5 Pt 3):A3-8. Notes: 9808812. KQ3 Search Journal Article. User Define 1: I. User Define 2: X5. [pmid: 9808812].
Lando HA, Pirie PL, Dusich KH, Elsen C, Bernards J. Community incorporation of quit and win contests in Bloomington, Minnesota. Am J Public Health. 1995;85(2):263-4. Notes: 7856789. KQ2 Search News KQ2 Search. User Define 1: I. User Define 2: X5. [pmid: 7856789]. [pmcid: 1615321].
Laskin DM. Where there's smokeless, there's also fire. J Oral Maxillofac Surg. 1986;44(5):339. Notes: 3457913. KQ4 Search Editorial. User Define 1: I. User Define 2: X5. [pmid: 3457913].
Lerman C, Gold K, Audrain J, et al. Incorporating biomarkers of exposure and genetic susceptibility into smoking cessation treatment: effects on smoking-related cognitions, emotions, and behavior change. Health Psychol. 1997;16(1):87-99. Notes: 9028818. KQ5 Search KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X7. [pmid: 9028818].
LeRoy L, Benet DJ, Mason T, Austin WD, Mills S. Empowering organizations: approaches to tobacco control through youth empowerment programs. Health Educ Behav. 2004;31(5):577-96. Notes: 15358891. KQ2 Search Evaluation Studies. User Define 1: I. User Define 2: X2. [pmid: 15358891].
Levenson-Gingiss P, Morrow JRJr, Dratt LM. Patterns of smokeless tobacco use among university athletes. J Am Coll Health. 1989;38(2):87-90. Notes: 2778229. KQ4 Search Journal Article. User Define 1: I. User Define 2: X2. [pmid: 2778229].
Levy DT, Mumford EA, Cummings KM, et al. The relative risks of a low-nitrosamine smokeless tobacco product compared with smoking cigarettes: estimates of a panel of experts. Cancer Epidemiol Biomarkers Prev. 2004;13(12):2035-42. Notes: 15598758. KQ4 Search Journal Article. User Define 1: I. User Define 2: X5. [pmid: 15598758].
Lewis RK, Paine-Andrews A, Fawcett SB, et al. Evaluating the effects of a community coalition's efforts to reduce illegal sales of alcohol and tobacco products to minors. J Community Health. 1996;21(6):429-36. Notes: 8912119. KQ2 Search Journal Article KQ2 Search. User Define 1: I. User Define 2: X8. [pmid: 8912119].
Lillington L, Royce J, Novak D, Ruvalcaba M, Chlebowski R. Evaluation of a smoking cessation program for pregnant minority women. Cancer Pract. 1995;3(3):157-63. Notes: 7599672. KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X8. [pmid: 7599672].
Litrownik AJ, Elder JP, Campbell NR, et al. Evaluation of a tobacco and alcohol use prevention program for Hispanic migrant adolescents: promoting the protective factor of parent-child communication. Prev Med. 2000;31(2 Pt 1):124-33. Notes: 10938212. KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X2. [pmid: 10938212].
Litt IF. Managed care organizations and adolescents' smoking. J Adolesc Health. 1999;25(4):247. Notes: 10505841. KQ3 Search Editorial. User Define 1: I. User Define 2: X5. [pmid: 10505841].
Love MB, Thurman QC, Davoli GW. Normative Beliefs of Social Scientists regarding the Psychosocial and Environmental Factors that Influence Health Behavior Change Related to Smoking. Advances in Medical Sociology. 1990;1:153-67. Notes: Sociological Abstracts Search. User Define 1: I. User Define 2: X2.
MacCorquodale DW, Ballweg JA. Awareness of Smoking Consequences during Pregnancy. Family & Community Health. 1991;14(1):36-43. Notes: Sociological Abstracts Search. User Define 1: I. User Define 2: X5.
Mackay J. Battlefield for the tobacco war. JAMA. 1989;261(1):28-9. Notes: 2908981. KQ4 Search Journal Article. User Define 1: I. User Define 2: X5. [pmid: 2908981].
Madeley RJ, Gillies PA, Power FL, Symonds EM. Nottingham mothers stop smoking project -- baseline survey of smoking in pregnancy. Community Med. 1989;11(2):124-30. Notes: 2787722. KQ3 Search Journal Article. User Define 1: I. User Define 2: X8. [pmid: 2787722].
Mainarich K. Help your clients stop smoking. Nurs Spectr (Wash D C). 1997;7(7):12-3. Notes: 9431249. User Define 1: I. User Define 2: X6. [pmid: 9431249].
Malarcher AM, Ford ES, Nelson DE, et al. Trends in cigarette smoking and physicians' advice to quit smoking among people with diabetes in the U.S. Diabetes Care. 1995;18(5):694-7. Notes: 8586010. KQ3 Search Journal Article. User Define 1: I. User Define 2: X8. [pmid: 8586010].
Margolis JA, Meshack AF, McAlister AL, Narendran S, Hu S. Smoking cessation activities in Texas: the role of dentists. Tex Dent J. 2002;119(12):1176-82. Notes: 12592739. User Define 1: I. User Define 2: X6. [pmid: 12592739].
McBride CM, French SA, Pirie PL, Jeffery RW. Changes over time in weight concerns among women smokers engaged in the cessation process. Ann Behav Med. 1996;18(4):273-8. Notes: 1997-04433-006. Psychological Abstracts Search Peer-Reviewed-Journal. User Define 1: I. User Define 2: X2. [pmid: 18425673].
McCann JE. Tobacco logo recognition. J Fam Pract. 1992;34(6):681-684. Notes: 1593239. KQ4 Search Letter. User Define 1: I. User Define 2: X5. [pmid: 1593239].
McCarthy R. Who's in charge of health? State Health Care Am 2002; 18–21, 24. Notes: 12235760 KQ2 Search Journal Article KQ2 Search User Define 1: I User Define 2: X5
McCormick LK, Steckler AB, McLeroy KR. Diffusion of innovations in schools: a study of adoption and implementation of school-based tobacco prevention curricula. Am J Health Promot. 1995;9(3):210-9. Notes: 10150723. KQ3 Search Journal Article. User Define 1: I. User Define 2: X8. [pmid: 10150723].
McDaniel AM, Casper GR, Hutchison SK, Stratton RM. Design and testing of an interactive smoking cessation intervention for inner-city women. Health Educ Res. 2005;20(3):379-84. Notes: 2005-05116-014. Psychological Abstracts Search Peer-Reviewed-Journal. User Define 1: I. User Define 2: X2. [pmid: 15522897].
McDaniel AM, Hutchison S, Casper GR, Ford RT, Stratton R, Rembusch M. Usability testing and outcomes of an interactive computer program to promote smoking cessation in low income women. Proc AMIA Symp 2002; 509–13. Notes: 12463876 KQ3 Search Evaluation Studies User Define 1: I User Define 2: X2
McDaniel AM, Kristeller JL, Hudson DM. Chart reminders increase referrals for inpatient smoking cessation intervention. Nicotine and Tobacco Research. 1999;1(2):175-80. Notes: 2000-14189-006. Psychological Abstracts Search Peer-Reviewed-Journal. User Define 1: I. User Define 2: X2. [pmid: 11072399].
McDonald PW. Population-based recruitment for quit-smoking programs: an analytic review of communication variables. Prev Med. 1999;28(6):545-57. Notes: 10404552. KQ2 Search Journal Article. User Define 1: I. User Define 2: X5. [pmid: 10404552].
McDougal JA, Amerson GG, Royall JA. Do patients with cystic fibrosis need specific smoking prevention education. Pediatr Pulmonol. 1994;18(1):62-3. Notes: 7970913. KQ3 Search Letter. User Define 1: I. User Define 2: X5. [pmid: 7970913].
McIlvain HE, Crabtree BF, Gilbert C, Havranek R, Backer EL. Current trends in tobacco prevention and cessation in Nebraska physicians' offices. J Fam Pract. 1997;44(2):193-202. Notes: 9040523. KQ3 Search Journal Article. User Define 1: I. User Define 2: X8. [pmid: 9040523].
McLeod D, Pullon S, Benn C, et al. Can support and education for smoking cessation and reduction be provided effectively by midwives within primary maternity care. Midwifery. 2004;20(1):37-50. Notes: 15020026. User Define 1: I. User Define 2: X7. [pmid: 15020026].
Mears GN. The effect of a personalized multicomponent smoking cessation intervention on behavioral, physiological, and psychological parameters of cigarette smoking. Dissertation Abstracts International. 1991;51(11A):3640. Notes: 1992-70037-001. Psychological Abstracts Search Dissertation-Abstract. User Define 1: I. User Define 2: X5.
Meis TM, Gaie MJ, Pingree S et al. Development of a tailored, Internet-based smoking cessation intervention for adolescents. Journal of Computer Mediated Communication 2002; 7(3):Np. Notes: 2002-04986-004 Psychological Abstracts Search Peer-Reviewed-Journal User Define 1: I User Define 2: X5
Meyers AW, Klesges RC, Winders SE, Ward KD, et al. Are weight concerns predictive of smoking cessation? A prospective analysis. J Consult Clin Psychol. 1997;65(3):448-52. Notes: 1997-06366-010. Psychological Abstracts Search Peer-Reviewed-Journal. User Define 1: I. User Define 2: X6. [pmid: 9170768].
Minicucci DS. Perceived practitioner motivation for smoking cessation intervention: Applying Gadow's moral framework for nursing to self-determination theory (Sally Gadow). Dissertation Abstracts International: Section B. The Sciences and Engineering. 2002;63(3B):1271. Notes: 2002-95018-251. Psychological Abstracts Search Dissertation-Abstract. User Define 1: I. User Define 2: X5.
Monninkhof E, van der Valk P, van der Palen J, et al. The effect of a minimal contact smoking cessation programme in out-patients with chronic obstructive pulmonary disease: a pre-post-test study. Patient Educ Couns. 2004;52(3):231-6. Notes: 14998591. abstract search result. User Define 1: I. User Define 2: X6. [pmid: 14998591].
Moran S, Thorndike AN, Armstrong K, Rigotti NA. Physicians' missed opportunities to address tobacco use during prenatal care. Nicotine and Tobacco Research. 2003;5(3):363-8. Notes: 2003-06045-002. Psychological Abstracts Search Peer-Reviewed-Journal. User Define 1: I. User Define 2: X6. [pmid: 12791532].
Muchowski K, Paladine H. An ounce of prevention: the evidence supporting periconception health care. J Fam Pract. 2004;53(2):126-33. Notes: 14764295. KQ3 Search Journal Article. User Define 1: I. User Define 2: X5. [pmid: 14764295].
Murphy P. Survey of New York State teenagers prompts drive on smoking, alcohol, drugs. Public Health Rep. 1985;100(3):283-4. Notes: 3923534. KQ1 Search Journal Article. User Define 1: I. User Define 2: X2. [pmid: 3923534]. [pmcid: 1424745].
Murray RP, Anthonisen NR. Interventions for smoking cessation: the outcomes are determined by the questions asked. Eur Respir J. 1999;13(2):231-2. Notes: 10065659. CCTR Search Comment. User Define 1: I. User Define 2: X5. [pmid: 10065659].
Murray RP, Connett JE, Istvan JA, Nides MA, Rempel Rossum S. Relations of cotinine and carbon monoxide to self-reported smoking in a cohort of smokers and ex-smokers followed over 5 years. Nicotine and Tobacco Research. 2002;4(3):287-94. Notes: 2002-18914-007. Psychological Abstracts Search Peer-Reviewed-Journal. User Define 1: I. User Define 2: X6. [pmid: 12215237].
Murray RP, Johnston JJ, Dolce JJ, Lee WW, O'Hara P. Social support for smoking cessation and abstinence: the Lung Health Study. Lung Health Study Research Group. Addict Behav. 1995;20(2):159-70. Notes: 7484310. CCTR Search 0306–4603. User Define 1: I. User Define 2: X8. [pmid: 7484310].
Myers M. Beware the rooster: smokeless tobacco companies who claim they want to help. Tob Control. 2003;12(4):342. Notes: 14660754. KQ4 Search Journal Article. User Define 1: I. User Define 2: X5. [pmid: 14660754]. [pmcid: 1747768].
Myers MG. Smoking intervention with adolescent substance abusers: Initial recommendations. J Subst Abuse Treat. 1999;16(4):289-98. Notes: 1999-05167-002. Psychological Abstracts Search Peer-Reviewed-Journal. User Define 1: I. User Define 2: X5. [pmid: 10349601].
Nelick K. Adolescent smokers: an opportunity for nurses to help snuff out the smoking epidemic. Kans Nurse. 1998;73(6):1-2. Notes: 10603834. KQ3 Search Journal Article. User Define 1: I. User Define 2: X5. [pmid: 10603834].
Nicholson JM, Hennrikus DJ, Lando HA, McCarty MC, Vessey J. Patient recall versus physician documentation in report of smoking cessation counselling performed in the inpatient setting. Tob Control. 2000;9(4):382-8. Notes: 11106707. KQ1 Search Journal Article. User Define 1: I. User Define 2: X2. [pmid: 11106707]. [pmcid: 1748402].
Novelli WD. Tobacco control: the dramatic choice. Science. 1997;278(5336):203. Notes: 9340761. KQ4 Search Editorial. User Define 1: I. User Define 2: X5. [pmid: 9340761].
Novotny TE, Romano RA, Davis RM, Mills SL. The public health practice of tobacco control: lessons learned and directions for the states in the 1990s. Annu Rev Public Health. 1992;13:287-318. Notes: 1599590. KQ3 Search Journal Article. User Define 1: I. User Define 2: X5. [pmid: 1599590].
Nudelman P. “One sure way to break the cycle”. Tob Control. 1998;7(Suppl):S4-7. Notes: 10093186. User Define 1: I. User Define 2: X5. [pmid: 10093186]. [pmcid: 1766242].
O'Neill HK, Gillispie MA, Slobin K. Stages of change and smoking cessation: a computer-administered intervention program for young adults. Am J Health Promot 2000; 15(2):93–6, iii. Notes: 11194701 KQ1 Search Clinical Trial User Define 1: I User Define 2: X3
Okah FA, Choi WS, Okuyemi KS, Ahluwalia JS. Effect of children on home smoking restriction by inner-city smokers. Pediatrics. 2002;109(2):244-9. Notes: 11826202. CCTR Search 1098–4275. User Define 1: I. User Define 2: X2. [pmid: 11826202].
Okah FA, Mundy DC, Sheehan M, Derman RJ. Role of mental illness in drug use by urban pregnant heavy smokers. Am J Perinatol. 2004;21(5):299-304. Notes: 15232764. CCTR Search 0735–1631. User Define 1: I. User Define 2: X2. [pmid: 15232764].
Okah FA, Okuyemi KS, McCarter KS, et al. Predicting adoption of home smoking restriction by inner-city black smokers. Arch Pediatr Adolesc Med. 2003;157(12):1202-5. Notes: 14662576. CCTR Search 1072–4710. User Define 1: I. User Define 2: X2. [pmid: 14662576].
Okuyemi KS, Ahluwalia JS, Ebersole-Robinson M, Catley D, Mayo MS, Resnicow K. Does menthol attenuate the effect of bupropion among African American smokers. Addiction. 2003;98(10):1387-93. Notes: 14519175. Clinical Trial. User Define 1: I. User Define 2: X2. [pmid: 14519175].
Parnes B, Main DS, Holcomb S, Pace W. Tobacco cessation counseling among underserved patients: a report from CaReNet. J Fam Pract. 2002;51(1):65-9. Notes: 11927066. KQ3 Search Journal Article. User Define 1: I. User Define 2: X2. [pmid: 11927066].
Patten CA, Offord KP, Hurt RD, et al. Training support persons to help smokers quit: a pilot study. Am J Prev Med. 2004;26(5):386-90. Notes: 15165654. CCTR Search KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X3. [pmid: 15165654].
Pbert L, Vuckovic N, Ockene JK, Hollis JF, Riedlinger K. Developing and testing new smoking measures for the Health Plan Employer Data and Information Set. Med Care. 2003;41(4):550-9. Notes: 12665718. KQ3 Search Journal Article. User Define 1: I. User Define 2: X2. [pmid: 12665718].
Pearlstein I. Evidence-based practice: A theory-based tobacco dependence treatment at an adolescent health clinic. N J Nurse. 2005;35(1):15. Notes: 15790012. KQ3 Search Evaluation Studies. User Define 1: I. User Define 2: X2. [pmid: 15790012].
Perz CA, DiClemente CC, Carbonari JP. Doing the right thing at the right time? The interaction of stages and processes of change in successful smoking cessation. Health Psychol. 1996;15(6):462-8. Notes: 1996-06991-009. Psychological Abstracts Search Peer-Reviewed-Journal. User Define 1: I. User Define 2: X8. [pmid: 8973927].
Peugeot A, Anderson CU, Fruh S. Teenage tobacco use. Nurse Pract. 1999;24(9):66-69. Notes: 10507072. KQ3 Search Letter. User Define 1: I. User Define 2: X5. [pmid: 10507072].
Pierce JP, Dwyer T, Frape G, Chapman S, Chamberlain A, Burke N. Evaluation of the Sydney “Quit. For Life” anti-smoking campaign. Part 1. Achievement of intermediate goals. Med J Aust. 1986;144(7):341-4. Notes: 3959949. KQ1 Search Journal Article. User Define 1: I. User Define 2: X8. [pmid: 3959949].
Pingree S, Boberg E, Patten C, et al. Helping adolescents quit smoking:a needs assessment of current and former teen smokers. Health Commun. 2004;16(2):185-94. Notes: 15090284. CCTR Search 1041–0236. User Define 1: I. User Define 2: X2. [pmid: 15090284].
Pohl JM, Martinelli A, Antonakos C. Predictors of participation in a smoking cessation intervention group among low-income women. Addict Behav. 1998;23(5):699-704. Notes: 2002-06222-011. Psychological Abstracts Search Peer-Reviewed-Journal. User Define 1: I. User Define 2: X2. [pmid: 9768305].
Poland BD, Taylor SM, White N, Eyles J. Qualitative evaluation of the Brantford COMMIT Intervention Trial: the smokers' perspective. Health and Canadian Society. 1994;2(2):269-316. Notes: 1998015770. CINAHL Search Using Smart Source Parsing. User Define 1: I. User Define 2: X2.
Pollak KI, McBride CM, Scholes D, Grothaus LC, Civic D, Curry SJ. Women's reports of smoking cessation advice during reproductive health visits and subsequent smoking cessation. Am J Manag Care. 2002;8(10):837-44. Notes: 12395952. User Define 1: I. User Define 2: X2. [pmid: 12395952].
Pollak KI, Taiwo B, Lyna P, et al. Reported cessation advice given to African Americans by health care providers in a community health clinic. J Community Health. 2002;27(6):381-93. Notes: 12458781. CCTR Search Journal Article. User Define 1: I. User Define 2: X2. [pmid: 12458781].
Pollak KI, Yarnall KS, Rimer BK, Lipkus I, Lyna PR. Factors associated with patient-recalled smoking cessation advice in a low-income clinic. J Natl Med Assoc. 2002;94(5):354-63. Notes: 12069216. KQ3 Search Journal Article. User Define 1: I. User Define 2: X2. [pmid: 12069216]. [pmcid: 2594330].
Pomerleau OF, Pomerleau CS, Marks JL, et al. Prolonged nicotine patch use in quitters with past abstinence-induced depressed mood. J Subst Abuse Treat. 2003;24(1):13-8. Notes: 12646326. abstract search result. User Define 1: I. User Define 2: X2. [pmid: 12646326].
Powell DR. A guided self-help smoking cessation intervention with white-collar and blue-collar employees. Am J Health Promot. 1993;7(5):325-6. Notes: 1994-35445-001. Psychological Abstracts Search Peer-Reviewed-Journal. User Define 1: I. User Define 2: X5. [pmid: 10146811].
Prokhorov AV. Theoretically sound approaches to prevention and cessation of cigarette smoking among youths. Pediatr Pulmonol 2001; Suppl 23:57–9. Notes: 11886149 CCTR Search Journal Article User Define 1: I User Define 2: X5
Prokhorov AV, de Moor CA, Hudmon KS, Hu S, Kelder SH, Gritz ER. Predicting initiation of smoking in adolescents: evidence for integrating the stages of change and susceptibility to smoking constructs. Addict Behav. 2002;27(5):697-712. Notes: 12201378. CCTR Search 0306–4603. User Define 1: I. User Define 2: X2. [pmid: 12201378].
Prokhorov AV, Emmons KM, Pallonen UE, Tsoh JY. Respiratory response to cigarette smoking among adolescent smokers: a pilot study. Prev Med. 1996;25(5):633-40. Notes: 8888333. CCTR Search 0091–7435. User Define 1: I. User Define 2: X2. [pmid: 8888333].
Prokhorov AV, Warneke C, de Moor C, et al. Self-reported health status, health vulnerability, and smoking behavior in college students: implications for intervention. Nicotine Tob Res. 2003;5(4):545-52. Notes: 12959792. 1462–2203. User Define 1: I. User Define 2: X2. [pmid: 12959792].
Puska P, Koskela K. Community-based strategies to fight smoking. Experiences from the North Karelia project in Finland. N Y State J Med. 1983;83(13):1335-8. Notes: 6582392. KQ2 Search Journal Article KQ2 Search. User Define 1: I. User Define 2: X8. [pmid: 6582392].
Radecki TE, Zdunich CD. Tobacco sales to minors in 97 US and Canadian communities. Tob Control. 1993;2(4):300-5. Notes: Handsearch. User Define 1: I. User Define 2: X2.
Ramstrom LM. Implications of nicotine dependence: need for revision of tobacco product regulations. Wien Klin Wochenschr. 2003;115(11):401-2. author reply 402. Notes: 12879739. User Define 1: I. User Define 2: X5. [pmid: 12879739].
Raw M, McNeill A, West R. Smoking cessation: evidence based recommendations for the healthcare system. BMJ. 1999;318(7177):182-5. Notes: 9888919. Journal Article. User Define 1: I. User Define 2: X5. [pmid: 9888919]. [pmcid: 1114665].
Reeve K, Calabro K, Adams-McNeill J. Tobacco cessation intervention in a nurse practitioner managed clinic. J Am Acad Nurse Pract. 2000;12(5):163-9. Notes: 11930337. User Define 1: I. User Define 2: X7. [pmid: 11930337].
Ribisl KM, Steckler A, Linnan L, et al. The North Carolina Youth Empowerment Study (NCYES): a participatory research study examining the impact of youth empowerment for tobacco use prevention. Health Educ Behav. 2004;31(5):597-614. Notes: 15358892. KQ2 Search North Carolina Youth Empowerment Study. User Define 1: I. User Define 2: X2. [pmid: 15358892].
Richardson R, Sowden A. Preventing the uptake of smoking in young people. Nurs Times. 2000;96(9):43-4. Notes: 11235386. KQ2 Search Journal Article KQ2 Search. User Define 1: I. User Define 2: X5. [pmid: 11235386].
Richman PB, Dinowitz S, Nashed AH, et al. The emergency department as a potential site for smoking cessation intervention: a randomized, controlled trial. Acad Emerg Med. 2000;7(4):348-53. Notes: 10805622. Clinical Trial. User Define 1: I. User Define 2: X2. [pmid: 10805622].
Richmond R. Opening the window of opportunity: encouraging patients to stop smoking. Heart. 1999;81(5):456-8. Notes: 10212158. Editorial. User Define 1: I. User Define 2: X5. [pmid: 10212158]. [pmcid: 1729031].
Richmond RL, Austin A, Webster IW. Three year evaluation of a programme by general practitioners to help patients to stop smoking. Br Med J (Clin Res Ed). 1986;292(6523):803-6. Notes: 3082450. KQ3 Search Clinical Trial. User Define 1: I. User Define 2: X8.
Rikard-Bell G, Donnelly N, Ward J. Preventive dentistry: what do Australian patients endorse and recall of smoking cessation advice by their dentists?. Br Dent J. 2003;194(3):159-64. discussion 150. Notes: 12598886. KQ3 Search Journal Article. User Define 1: I. User Define 2: X2. [pmid: 12598886].
Rikard-Bell G, Groenlund C, Ward J. Australian dental students' views about smoking cessation counseling and their skills as counselors. J Public Health Dent. 2003;63(3):200-6. Notes: 12962475. KQ3 Search Journal Article. User Define 1: I. User Define 2: X6. [pmid: 12962475].
Ringen K, Anderson N, McAfee T, Zbikowski SM, Fales D. Smoking cessation in a blue-collar population: results from an evidence-based pilot program. Am J Ind Med. 2002;42(5):367-77. Notes: 12382249. User Define 1: I. User Define 2: X6. [pmid: 12382249].
Rissel C, Salmon A, Hughes AM. Evaluation of a (pilot) stage-tailored brief smoking cessation intervention among hospital patients presenting to a hospital pre-admission clinic. Aust Health Rev. 2000;23(3):83-93. Notes: 11186064. KQ3 Search Evaluation Studies. User Define 1: I. User Define 2: X7. [pmid: 11186064].
Rogers T, Feighery EC, Tencati EM, Butler JL, Weiner L. Community mobilization to reduce point-of-purchase advertising of tobacco products. Health Educ Q. 1995;22(4):427-42. Notes: 8550368. KQ4 Search Clinical Trial. User Define 1: I. User Define 2: X2. [pmid: 8550368].
Ronda G, Van Assema P, Ruland E, Steenbakkers M, Brug J. The Dutch Heart Health Community Intervention ‘Hartslag Limburg’: design and results of a process study. Health Educ Res. 2004;19(5):596-607. Notes: 15199007. CCTR Search 0268–1153. User Define 1: I. User Define 2: X2. [pmid: 15199007].
Rosas M, Baptista F. The development of psychological intervention strategies for smoking cessation / Desenvolvimento de estrategias de intervencao psicologica para a cessacao tabagica. Analise Psicologica. 2002;20(1):45-56. Notes: 2002-18615-002. Psychological Abstracts Search Peer-Reviewed-Journal. User Define 1: I. User Define 2: X1.
Royce JM, Orlandi MA, Hymowitz N, Corbett K, Hartwell T. Social Acceptability of Smoking among African-Americans: The Community Intervention Trial for Smoking Cessation (COMMIT). American Sociological Association (ASA) 1990. Notes: Sociological Abstracts Search User Define 1: I User Define 2: X8
Ruggiero L, Rossi JS, Prochaska JO, et al. Smoking and diabetes: readiness for change and provider advice. Addict Behav. 1999;24(4):573-8. Notes: 10466853. CCTR Search 0306–4603. User Define 1: I. User Define 2: X2. [pmid: 10466853].
Ruggiero L, Webster K, Peipert JF, Wood C. Identification and recruitment of low-income pregnant smokers: who are we missing?. Addict Behav. 2003;28(8):1497-505. Notes: 14512073. KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X2. [pmid: 14512073].
Russell MA, Merriman R, Stapleton J, Taylor W. Effect of nicotine chewing gum as an adjunct to general practitioner's advice against smoking. Br Med J (Clin Res Ed). 1983;287(6407):1782-5. Notes: 6416593. KQ3 Search Clinical Trial. User Define 1: I. User Define 2: X8.
Russell MA, Stapleton JA, Hajek P, Jackson PH, et al. District programme to reduce smoking: Can sustained intervention by general practitioners affect prevalence?. J Epidemiol Community Health. 1988;42(2):111-5. Notes: 1989-16986-001. Psychological Abstracts Search Peer-Reviewed-Journal. User Define 1: I. User Define 2: X2. [pmid: 3265427]. [pmcid: 1052702].
Russell MA, Wilson C, Taylor C, Baker CD. Effect of general practitioners' advice against smoking. Br Med J. 1979;2(6184):231-5. Notes: 476401. KQ1 Search Journal Article. User Define 1: I. User Define 2: X8. [pmid: 476401]. [pmcid: 1595592].
Sanders D, Fowler G, Mant D, Fuller A, Jones L, Marzillier J. Randomized controlled trial of anti-smoking advice by nurses in general practice. J R Coll Gen Pract. 1989;39(324):273-6. Notes: 2556540. KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X8. [pmid: 2556540]. [pmcid: 1711904].
Schinke SP, Moncher MS, Singer BR. Native American youths and cancer risk reduction. Effects of software intervention. J Adolesc Health. 1994;15(2):105-10. Notes: 8018682. KQ5 Search Clinical Trial. User Define 1: I. User Define 2: X2. [pmid: 8018682].
Schinke SP, Singer B, Cole K, Contento IR. Reducing cancer risk among Native American adolescents. Prev Med. 1996;25(2):146-55. Notes: 8860279. KQ5 Search Clinical Trial. User Define 1: I. User Define 2: X2. [pmid: 8860279].
Sciamanna CN, Ford DE, Flynn JA, Langford C. An evidence-based interactive computer program to assist physicians in counseling smokers to quit. MD Comput. 1999;16(5):54-60. Notes: 10570612. KQ3 Search Journal Article. User Define 1: I. User Define 2: X3.
Sesney JW, Kreher NE, Hickner JM, Webb S. Smoking cessation interventions in rural family practices: an UPRNet study. J Fam Pract. 1997;44(6):578-85. Notes: 9191631. KQ1 Search Journal Article. User Define 1: I. User Define 2: X8. [pmid: 9191631].
Sherwood NE, Hennrikus DJ, Jeffery RW, Lando HA, Murray DM. Smokers with multiple behavioral risk factors: how are they different?. Prev Med. 2000;31(4):299-307. Notes: 11006054. User Define 1: I. User Define 2: X5. [pmid: 11006054].
Simmons VN, Webb MS, Brandon TH. College-student smoking: an initial test of an experiential dissonance-enhancing intervention. Addict Behav. 2004;29(6):1129-36. Notes: 15236813. KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X2. [pmid: 15236813].
Simpson D. USA: the art of simple dying. Tob Control. 2000;9(2):131-2. Notes: 10841844. User Define 1: I. User Define 2: X5. [pmid: 10841844]. [pmcid: 1748347].
Sinclair H, Bond C, Lennox S, Silcock J, Winfield A. An evaluation of a training workshop for pharmacists based on the Stages of Change model of smoking cessation. Health Educ J. 1997;56(3):296-312. Notes: 1998020708. CINAHL Search Using Smart Source Parsing. User Define 1: I. User Define 2: X2.
Sinha DN, Gupta PC. Tobacco and areca nut use in male medical students of Patna. Natl Med J India. 2001;14(3):176-8. Notes: 11467150. User Define 1: I. User Define 2: X5. [pmid: 11467150].
Skegg JA. Dental programme for smoke-free promotion: attitudes and activities of dentists, hygienists, and therapists at training and 1 year later. N Z Dent J. 1999;95(420):55-7. Notes: 10396928. KQ3 Search Journal Article. User Define 1: I. User Define 2: X2. [pmid: 10396928].
Skegg JA, McGee RO, Stewart AW. Smoking prevention: attitudes and activities of New Zealand dentists. N Z Dent J. 1995;91(403):4-7. Notes: 7746562. KQ3 Search KQ2 Search Journal Article KQ2 Search. User Define 1: I. User Define 2: X8. [pmid: 7746562].
Skinner H, Morrison M, Bercovitz K, et al. Using the Internet to engage youth in health promotion. Promot Educ. 1997;4(4):23-5. Notes: 9560853. KQ2 Search Journal Article KQ2 Search. User Define 1: I. User Define 2: X5. [pmid: 9560853].
Skjoldebrand J, Gahnberg L. Tobacco preventive measures by dental care staff. An attempt to reduce the use of tobacco among adolescents. Swed Dent J. 1997;21(12):49-54. Notes: 9178449. KQ3 Search Journal Article. User Define 1: I. User Define 2: X8. [pmid: 9178449].
Slama K, Redman S, Perkins J, Reid AL, Sanson-Fisher RW. The effectiveness of two smoking cessation programmes for use in general practice: a randomised clinical trial. BMJ. 1990;300(6741):1707-9. Notes: 2202445. KQ3 Search KQ2 Search KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X8. [pmid: 2202445]. [pmcid: 1663307].
Smith SE, Warnakulasuriya KA, Feyerabend C, Belcher M, Cooper DJ, Johnson NW. A smoking cessation programme conducted through dental practices in the UK. Br Dent J. 1998;185(6):299-303. Notes: 9803038. KQ3 Search Journal Article. User Define 1: I. User Define 2: X8. [pmid: 9803038].
Snively TA, Ahijevych KL, Bernhard LA, Wewers ME. Smoking behavior, dysphoric states and the menstrual cycle: results from single smoking sessions and the natural environment. Psychoneuroendocrinology. 2000;25(7):677-91. Notes: 10938448. KQ5 Search Clinical Trial. User Define 1: I. User Define 2: X2. [pmid: 10938448].
Sorensen G, Glasgow RE, Corbett K, Topor M. Compliance with worksite nonsmoking policies: baseline results from the COMMIT study of worksites. Am J Health Promot. 1992;7(2):103-9. Notes: 1993154895. CINAHL Search Using Smart Source Parsing. User Define 1: I. User Define 2: X2. [pmid: 10148714].
Spencer L, Anderson DR. A Minimal-Contact Intervention for Cardiac Inpatients: Long-Term Effects on Smoking Cessation. Am J Health Promot. 2004;18(5):399-400. Notes: 2004-95170-014. Psychological Abstracts Search Peer-Reviewed-Journal. User Define 1: I. User Define 2: X5.
Spoth R. Formative research on smoking cessation program attributes preferred by smokers. Am J Health Promot. 1991;5(5):346-54. Notes: 10148760. KQ2 Search Journal Article KQ2 Search. User Define 1: I. User Define 2: X2. [pmid: 10148760].
Spring B, Pagoto S, Pingitore R, Doran N, Schneider K, Hedeker D. Randomized controlled trial for behavioral smoking and weight control treatment: effect of concurrent versus sequential intervention. J Consult Clin Psychol. 2004;72(5):785-96. Notes: 15482037. User Define 1: I. User Define 2: X2. [pmid: 15482037].
Stead M, MacAskill S, MacKintosh A-M, Reece J, Eadie D. “It's as If You're Locked In”: Qualitative Explanations for Area Effects on Smoking in Disadvantaged Communities. Health & Place. 2001;7(4):333-43. Notes: Sociological Abstracts Search. User Define 1: I. User Define 2: X2. [pmid: 11682332].
Stellman SD, Resnicow K Tobacco smoking, cancer and social class. IARC Sci Publ 1997; (138):229–50. Notes: 9353667 KQ4 Search Journal Article User Define 1: I User Define 2: X2
Stewart A, Orme J. Teenage smoking and health education. Health Visit. 1989;62(3):91-4. Notes: 2703359. KQ3 Search Journal Article. User Define 1: I. User Define 2: X5. [pmid: 2703359].
Stewart MJ, Brosky G, Gillis A, et al. Disadvantaged women and smoking. Can J Public Health. 1996;87(4):257-60. Notes: 8870305. KQ2 Search Journal Article KQ2 Search. User Define 1: I. User Define 2: X2. [pmid: 8870305].
Stjerna M-L, Lauritzen SO, Tillgren P. “Social Thinking” and Cultural Images: Teenagers' Notions of Tobacco Use. Social Science & Medicine. 2004;59(3):573-83. Notes: Sociological Abstracts Search. User Define 1: I. User Define 2: X2. [pmid: 15144766].
Stockton MC, McMahon SD, Jason LA. Gender and smoking behavior in a worksite smoking cessation program. Addict Behav. 2000;25(3):347-60. Notes: 10890289. CCTR Search 0306–4603. User Define 1: I. User Define 2: X2. [pmid: 10890289].
Strachan-Bennett S. Nursing and public health. Nurs Times. 2004;100(46):20-2. Notes: 15595480. KQ3 Search Journal Article. User Define 1: I. User Define 2: X5.
Strong DR, Kahler CW, Ramsey SE, Abrantes A, Brown RA. Nicotine withdrawal among adolescents with acute psychopathology: an item response analysis. Nicotine Tob Res. 2004;6(3):547-57. Notes: 15203788. KQ5 Search Clinical Trial. User Define 1: I. User Define 2: X2. [pmid: 15203788].
Sussman S, Parker VC, Lopes C, Crippens DL, Elder P, Scholl D. Empirical development of brief smoking prevention videotapes which target African-American adolescents. Int J Addict. 1995;30(9):1141-64. Notes: 7591353. KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X8. [pmid: 7591353].
Swartz SH, Cowan TM, DePue J, Goldstein MG. Academic profiling of tobacco-related performance measures in primary care. Nicotine Tob Res. 2002;4(Suppl 1):S38-44. Notes: 11945218. User Define 1: I. User Define 2: X6. [pmid: 11945218].
Taylor CB, Miller NH, Cameron RP, Fagans EW, Das S. Dissemination of an effective inpatient tobacco use cessation program. Nicotine Tob Res. 2005;7(1):129-37. Notes: 15804685. User Define 1: I. User Define 2: X8. [pmid: 15804685].
Thomas RE, Thomas AP. Preventing children from smoking. How family physicians and pediatricians can help. Can Fam Physician. 1995;41:1517-23. Notes: 8520240. KQ3 Search Journal Article. User Define 1: I. User Define 2: X5. [pmid: 8520240]. [pmcid: 2146690].
Thomas SM, Fick AC, Henderson JA. Meeting the needs of special populations: a formative evaluation of a school-based smoking prevention program. J La State Med Soc. 1992;144(4):157-61. Notes: 1613305. KQ2 Search Journal Article KQ2 Search. User Define 1: I. User Define 2: X8. [pmid: 1613305].
Thompson B, Lichtenstein E, Corbett K, Nettekoven L, Feng Z. Durability of tobacco control efforts in the 22 Community Intervention Trial for Smoking Cessation (COMMIT) communities 2 years after the end of intervention. Health Educ Res. 2000;15(3):353-66. Notes: 2000075829. CCTR Search CINAHL Search Using Smart Source Parsing. User Define 1: I. User Define 2: X2. [pmid: 10977382].
Thompson B, Wallack L, Lichtenstein E, Pechacek T. Principles of Community Organization and Partnership for Smoking Cessation in the Community Intervention Trial for Smoking Cessation (COMMIT). International Quarterly of Community Health Education 1990-1991; 11(3):187–203. Notes: Sociological Abstracts Search User Define 1: I User Define 2: X8
Thorogood M, Hillsdon M, Summerbell C. Cardiovascular disorders. Changing behaviour. Clin Evid. 2003;(10):95-117. Notes: 12603872. WE DIDN'T GET THE 2002--VOLUME MISSING FROM LIBRARY SO WE GOT 2003. User Define 1: I. User Define 2: X5. [pmid: 15555088].
Tiffany ST, Martin EM, Baker TB. Treatments for cigarette smoking: an evaluation of the contributions of aversion and counseling procedures. Behav Res Ther. 1986;24(4):437-52. Notes: 3741309. KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X3. [pmid: 3741309].
Townsend J, Wilkes H, Haines A, Jarvis M. Adolescent smokers seen in general practice: health, lifestyle, physical measurements, and response to antismoking advice. BMJ. 1991;303(6808):947-50. Notes: 1755876. KQ5 Search KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X8. [pmid: 1755876]. [pmcid: 1671366].
Truitt L, Hamilton WL, Johnston PR et al. Recall of health warnings in smokeless tobacco ads. Tob Control 2002; 11 Suppl 2:ii59–63. Notes: 12034984 KQ4 Search Journal Article User Define 1: I User Define 2: X2
Tumolo J. Turning the tide. Drawing teens away from tobacco. Adv Nurse Pract. 2001;9(11):55-8. Notes: 12420501. KQ3 Search Journal Article. User Define 1: I. User Define 2: X5.
Ussher M, West R, Hibbs N. A survey of pregnant smokers' interest in different types of smoking cessation support. Patient Educ Couns. 2004;54(1):67-72. Notes: 15210262. KQ3 Search Journal Article. User Define 1: I. User Define 2: X2. [pmid: 15210262].
Ussher M, West R, McEwen A, Taylor A, Steptoe A. Efficacy of exercise counselling as an aid for smoking cessation: a randomized controlled trial. Addiction. 2003;98(4):523-32. Notes: 2003091916. CINAHL Search Using Smart Source Parsing. User Define 1: I. User Define 2: X2. [pmid: 12653822].
Wadlington WB, Moore P, Riley HD. The pediatrician's obligation in smoking cessation. Pediatr Ann. 1996;25(6):306-8. Notes: 8793916. KQ3 Search Letter. User Define 1: I. User Define 2: X5. [pmid: 8793916].
Wakefield M, Roberts L, Rosenfeld E. Prospects for smoking cessation among people with insulin-dependent diabetes. Patient Educ Couns. 1998;34(3):257-66. Notes: 9791529. KQ3 Search Journal Article. User Define 1: I. User Define 2: X2. [pmid: 9791529].
Waller CS, Zollinger TW, Saywell RWJr, Kubisty KD. The Indiana Prenatal Substance Use Prevention Program: its impact on smoking cessation among high-risk pregnant women. Indiana Med. 1996;89(2):184-7. Notes: 8867420. KQ3 Search Journal Article. User Define 1: I. User Define 2: X8. [pmid: 8867420].
Walters DJ. The gathering momentum against tobacco: action by physicians is needed on all fronts. CMAJ. 1991;144(2):134-6. Notes: 1986823. User Define 1: I. User Define 2: X5. [pmid: 1986823]. [pmcid: 1453019].
Warnecke RB, Langenberg P, Gruder CL, Flay BR, Jason LA. Factors in smoking cessation among participants in a televised intervention. Prev Med. 1989;18(6):833-46. Notes: 2626416. CCTR Search 0091–7435. User Define 1: I. User Define 2: X2. [pmid: 2626416].
Warnecke RB, Morera O, Turner L, et al. Changes in Self-Efficacy and Readiness for Smoking Cessation among Women with High School or Less Education. J Health Soc Behav. 2001;2001(42):1. Notes: Sociological Abstracts Search. User Define 1: I. User Define 2: X2.
Watson A, Grove N. Larimer County Tobacco and Youth Project. Am J Public Health. 1999;89(4):597-8. Notes: 10191811. KQ2 Search Journal Article KQ2 Search. User Define 1: I. User Define 2: X5. [pmid: 10191811].
Whitlock EP, Vogt TM, Hollis JF, Lichtenstein E. Does gender affect response to a brief clinic-based smoking intervention?. Am J Prev Med. 1997;13(3):159-66. Notes: 9181202. User Define 1: I. User Define 2: X2. [pmid: 9181202].
Wiist WH. Social networks and peer education. Am J Public Health. 2004;94(8):1293. author reply 1293–4. Notes: 15284025. KQ1 Search Comment. User Define 1: I. User Define 2: X5. [pmid: 15284025].
Wilkinson AV, Spitz MR, Strom SS, et al. Effects of nativity, age at migration, and acculturation on smoking among adult houston residents of mexican descent. Am J Public Health. 2005;95(6):1043-9. Notes: 15914831. 0090–0036. User Define 1: I. User Define 2: X2. [pmid: 15914831]. [pmcid: 1449306].
Wilkinson AV, Spitz MR, Strom SS et al. The Impact of Nativity, Age at Migration, and Acculturation on Smoking Among Adult Houston Residents of Mexican Descent. Am J Public Health 2005. Notes: 15879314 0090–0036 User Define 1: I User Define 2: X2
Willms DG. Hearing a word, sensing what's wrong, finding a way: Physicians' responses to patients' concerns. Assessing Interventions: Traditional and Innovative Methods 1992; 80–8. Notes: 1992-98688-007 Psychological Abstracts Search Chapter User Define 1: I User Define 2: X2
Wilson D, Wood G, Johnston N, Sicurella J. Randomized clinical trial of supportive follow-up for cigarette smokers in a family practice. Can Med Assoc J. 1982;126(2):127-9. Notes: 7037143. KQ1 Search Clinical Trial. User Define 1: I. User Define 2: X8. [pmid: 7037143]. [pmcid: 1862918].
Woodby LL, Windsor RA, Snyder SW, Kohler CL, Diclemente CC. Predictors of smoking cessation during pregnancy. Addiction. 1999;94(2):283-92. Notes: 10396795. KQ5 Search Clinical Trial. User Define 1: I. User Define 2: X2. [pmid: 10396795].
Xaverius PK, Billows WD, Jason LA, King C. Research on the sale of smokeless tobacco to adolescents. Tob Control. 1996;5(1):69-70. Notes: 8795864. KQ4 Search Letter. User Define 1: I. User Define 2: X5. [pmid: 8795864].
Zahnd EG, Coates TJ, Richard RJ, Cummings SR. Counseling medical patients about cigarette smoking: a comparison of the impact of training on nurse practitioners and physicians. Nurse Pract 1990; 15(3):10–3, 17–8. Notes: 2314676 User Define 1: I User Define 2: X3