# Appendix C Evidence Tables

Glossary

# | number
% | percent
2x | 2 times or twice
3x | three times or thrice
ACS | American Cancer Society
ALSAC | American Lebanese Syrian Associated Charities
ANOVA | Analysis of Variance
AOR | adjusted odds ratio
ASH | Action on Smoking and Health database
ASSIS | Applied Social Sciences Index and Abstracts
b | regression coefficient
b/w | between
BA | Brief Advice
C | Control group
Calif | California
CBT | cognitive behavioral therapy
CD | cardiovascular disease
CDC | Centers for Disease Control
C-DISC | Clinical Data Interchange Standards Consortium
Chi sq | Chi square
CI | confidence intervals
CNS | central nervous system
CO | carbon monoxide
COPD | Chronic Obstructive Pulmonary Disease
CSAHS | Central Sydney Area Health Services
CT | computed topography
CVD | CD
d.f. | degrees of freedom
DARE | Drug abuse resistance education
Dec | December
DHSS | Department of Health and Social Services
DSM-IV | Diagnostic and Statistical Manual - Fourth Edition
dz | diagnosis
et al. | et alia
FEV | forced expiratory volume
FP | family physician
FTQ | Fagerstrom Tolerance Questionnaire
FVC | forced vital capacity
g | grams
G | Group
GEE | generalized estimating equations
GLIMMIX | General Linear Model for Mixture Distributions
GP | general practitioner
GSTM1 | glutathione s-transferase, MU-1
HDRS | Hamilton Depression Rating Scale
HMO | Health Maintenance Organization
HPS | health promoting schools
HPS | Health Promotion School
hr(s) | hour(s)
HRSD | Hamilton Rating Scale for Depression
HS | high school
HSPP | Hutchinson Smoking Prevention Project
ICU | intensive care unit
IG | immunoglobins
ITT | intent to treat
kg | kilogram
LCS | Lung Cancer Substudy
LHS 1, 2, or 3 | Lung Health Study
LPN | licensed practical nurse
MA | medical assistant
mg | milligram
MI | Motivational Interviewing
mo(s) | month(s)
N | number
NA | not applicable
NCCTG | North Central Cancer Treatment Group
NCI | National Cancer Institute
ng/ml | nanograms per millileter
NHLBI | National Heart, Lung, and Blood Institute
NHS | National Health Services
NIAS | National Institute Against Smoking
NIDA | National Institute on Drug Abuse
NNS | nicotine nasal spray
NP | nicotine patch
NR | not reported
NRT | nicotine replacement therapy
NS | not significant
NSW | New South Wales
OR | odds ratio
P | p-value
pg | page
ppm | parts per million
PTSD | posttraumatic stress disorder
RCT | randomized controlled trial
RN | registered nurse
RR | relative risk
RS | Spearman's Rank Correlation
SAS | statistical package
SD | standard deviation
SEQ | Self-Efficacy Questionnaire
SES | socioeconomic status
SI | smoking intervention
SLF | Smoke Free Leitrim
SLT | social learning theory
SPSS | Statistical Package for the Social Sciences
ST | smokeless tobacco
SE | Standard error
t | time
TN | Tennessee
TTM | Transtheoretical Model
txt | treatment
UCSF | University of Calif San Francisco
UK | United Kingdom
US | US
VA | Veterans Administration
v. | versus
w/ | with
WIC | Women, Infants, and Children
wk(s) | week(s)
X^2^ | Chi sq
yr(s) | yr(s)

Evidence Table 1. Effective population-based interventions

Study Characteristics | Study Design | Sample Design and Definitions | Intervention Details | Statistical Analysis and Baseline Data | Outcome Measures | Quality Comments
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | - Adolescents in C more than 1.5 times likely to smoke at follow up than family matters group (OR = 1.59, P =0.008, lower bound CI, 1.19); - Program parents significantly more likely to discuss peer and media influences (b = -.76, P < 0.01), set rules about smoking (b = -0.46, P < 0.01); - Non Hispanic white participants only, program parents significantly more likely to encourage their children not to smoke (b=-0.42, P < 0.01), improvements in parent involvement (b = -0.10, P < 0.05), and positive effect on adolescent's intentions to smoke (b = -0.15, P ≤ 0.01) | Quality rating:
Ennett et al., 2001 | To identify mediators through which the Family Matters Program influenced adolescent smoking and drinking | - Probability sample of families throughout 48 contiguous States of US entered into a randomized trial; - Partcipants identified through random-digit dialing; - Eligible families screened; - Offered opportunity to participate in study and told that they had a 50/50 chance of receiving Family Matters program; - 1,316 adolescent-parent pairs agreed to enrolled in study; - Pairs completed baseline interviews by telephone, matched w/ another pair by date and time of completion, and then randomly assigned either to receive Family Matters or to serve as controls | - Self-help; - Telephone counseling w/ parents | - Repeated measures logistic regression w/ GEE using a one sided tail test; - Mediation analysis follows approach outlined by Baron and Kenny to assess whether extent to which change in behavioral outcomes as a result of Family Matters program is accounted for by change in proposed mediators | Mediating effects for full model: stricter parent supervision (b = 0.16, P < 0.01) and decreased parental use of tobacco (b = 0.60, P < 0.01) | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | Expected consequences and intention to use (b = 1.82, and b = 0.85, P < 0.01) decreased smoking | Comments:
US | - Adolescents; - 12 to 14 yr olds and their families | Total: 1,316 adolescent-parent pairs | G1: Family Matters consists of successive mailings 4 mailings over 14 mos of 4 booklets to parents of 12- to 14-yr-old adolescents and telephone discussions b/w parents and health educators after each mailing | Self-report | | - No description of control intervention; - Sample size for G1 and C1 NR
Funding agency: | Study type: | G1: NR | C1: NR | Dependent variables: | | Adequate randomization:
National Institute on Drug Abuse | RCT w/ simple randomization | C1:NR | Method of assessment: | - Smoking status; - Global family mediators (supervision, support, communication and involvment); - Substance specific mediators (expected consequences, parental attitude, parental encouragement, parent substance use, rules about use, monitoring, availability, nonfamily influences) | | Yes
Study setting: | Inclusion criteria: | Definition of smoking: | 3- and 12-month followup via telephone interview w/ parent/guardian and adolescent | | | Attrition rate:
Population-based | Families had to have an adolescent age 12 to 14 yrs old and live in contiguous 48 states | Cigarettes | Baseline data: | | | 26%
| Exclusion criteria: | - Non-user: never smoked, not even a puff; - User: smoked even a puff | Fewer non-Hispanic Whites in G1 than in C1
| NR
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | - 37% of youth perceived easy access to purchase tobacco; - Less likely to perceive easy to purchase w/ ban on free displays AOR = 0.6, 95% (CI 0.5–0.9; P = 0.007); - Youth reported easy access in towns that required tobacco vendors to have a license OR = 1.3, 95% (CI 1.1–1.5, P = 0.009); - Increased perceived access associated w/ being older (P < 0.0001) and male, (P ≤ 0.002); - 33% of 512 youth who smoked a cigarette in past 6 mos reported purchasing cigarettes; - Result associated w/ bans on free samples and single cigarette sales in unadjusted model only; - Attempts to purchase cigarettes: AOR = NS for all ordinances; - Tobacco use: NS in adjusted model | Quality rating:
Thomson et al., 2004 | To test whether community-level youth access ordinances reduce adolescents' perceived access to tobacco, purchase attempts, and tobacco use | - University of Massachusetts obtained a statewide random sample of households by random-digit dialing; - Interview conducted w/ an adult resident to collect demographic data; - Requested permission to interview all youth in household b/w ages 12 to 17 yrs; - Screen interviewers completed 66% of sample and 6,006 eligible youths identified | - Parent involvement; - Implementation of state wide youth tobacco access ordinances | X2uare | | Fair
Geographic area: | Population: | Sample size: | Intervention: | GEE | | Comments:
US | - Adolescents, 12 to 17 yrs | - Total: 3,831 | G1: Community-level tobacco ordinances | Data verification: | | Strengths: accounted for clustering in analyses
Funding agency: | Study type: | Definition of smoking: | C1: NA | Self-report | | Limitations: moderate participation rate; generic data on ordinance enforcement; cross-sectional data
NCI, Flight Attendant Medical Research Institute | Cross-sectional | Cigarettes | Method of assessment: | Dependent variables: | | Adequate randomization:
Study setting: | Describe study design | - Ever smoker: smoked or puffed cigarette in lifetime; - Current smokers: smoked at least one cigarette inpast 30 days | Phone survey | - Youth perceived access to tobacco; - Attempts to purchase tobacco; - Tobacco use | | NR
Population-based | - Representative sample of youth from across Massachusetts | | | Baseline data: | | Attrition rate:
| Inclusion criteria: | | | White: 78% | | 76% of eligible youth had parental consent
| - Age 12 to 17; - Resident of Massachusetts; - Parental consent; - Youth assent | | | Hispani C1: 9%
| Exclusion criteria: | | | Other: 13%
| - Youth report of resident town disagreed w/ ZIP code and phone exchange indicators; - Towns having no identified youth

Evidence Table 2. Effective school-based interventions

Study Characteristics | Study Design | Sample Design and Definitions | Intervention Details | Statistical Analysis and Baseline Data | Outcome Measures | Quality Comments
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | - Twelve months after pretest (posttest 2), in-school intervention successful in preventing vocational school students from continuing to smoke, compared w/ students in control condition OR = 0.49; 95% CI 0.29–0.84; - Eighteen months after pretest (posttest 3), tailored out-of-school intervention successful in preventing smoking initiation, compared w/ students in control (OR = 0.42; 95% CI, 0.18–0.96); - Effect of combined approach not larger than sum of effects of in-school and out-of-school effects. | Quality rating:
Ausems et al., 2004 | To compare effects on smoking prevention among Dutch first grade vocational school children using a newly developed computer-tailored (personalized messages/letters) out-of-school program, an existing in-school program, and a combined approach including both in-school and out-of-school programs | - 19 schools already participating in Healthy Schools and Stimulant Program; - Randomly assigned within regionally defined blocks to in-school and out-of school conditions; - Remaining 17 schools randomlly assigned to out-of school or control conditions | - Computer-based program; - Classroom instruction; - Computer generated letters | - All effect analyses done separately for posttests 1-2-3; - Since running large regression models w/ MIXOR might cause problems, model reduction first applied, using SPSS 9.0 to determine final models containing significant covariates and interaction terms for prediction of smoking at posttests 1-2-3 | | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | | Comments:
Western Europe | - Adolescents; - Vocational school children in the Netherlands | G1: 9 schools | G1: In-school intervention: | Self-reports | | - Refusal rate NR; - Randomization description unclear regarding number of schools in txt groups; - Out-of-school intervention poorly implemented (65% of personalized letters read by participants)
Funding agency: | Study type: | G2: 8 schools | - Three lessons, each lasting about 50 min, student and teacher manuals available; - Each lesson consisted of general introduction by teacher, reading text in workbook, classroom discussion, workbook task and additional task that summarized main points of lesson; - First lesson explained ingredients of tobacco, and physical and mental reactions of smoking, while second discussed norms concerning smoking, and third emphasized pressures to smoke and skills that are helpful in resisting cigarettes | Dependent variables: | | Adequate randomization:
European Commission and the Dutch Cancer Foundation | - RCT w/ cluster randomization; - Six out of 8 area health departments agreed to participate, and within these areas local vocational schools invited to participate | G3: 10 schools | G2: Out of school intervention: | Smoking rates, based on both smoking initiation among never-smokers and smoking continuation among ever-smokers | | Yes
Study setting: | Inclusion criteria: | C1: 9 schools | - Three tailored letters w/ smoking prevention messages, sealed in envelopes and mailed to students' homes at 3-wk intervals; researchers signed letters and added telephone numbers; students' pretest smoking behavior not disclosed in letters; to prevent arguments in students' families, letters tailored to individual characteristics; - Pretest questionnaire on attitudes, social norms, self-efficacy, smoking intention and smoking behavior used to create a database file containing personal information; - Computer program combined database file w/ message file using decision rules that linked students' answers to personal messages; all messages thus selected combined in a letter format; letters illustrated w/ a picture puzzle and several cartoons; and competition included where students could win one of two CD vouchers | Baseline data: | | Attrition rate:
School-based | Dutch vocational schools | Definition of smoking: | G3: Combination of in- and out-of-school interventions | - Smoking behavior:; - Ever smoking: 59.7%; - Current smoking: 19.5%; - Mean age (yrs): 13.1; - Gender (%, male): 52.1; - Origin (w/ both parents Dutch): 73.0%; - Religious (adhering to a religion): 61.4%; - Family composition (w/ two parents): 82.1%; - Father's occupation (paid job): 68.7%; - Pocket money (%, > 6.8 euro): 23.5 | | School level
| Exclusion criteria: | Cigarettes | C1: Control | | | - Posttest 1: 5.6% (2 schools); - Posttest 2: 8.3% (3 schools); - Posttest 3: 18.5% (NR)
| NR | - Never-smokers: students who have never smoked even one cigarette or a puff of one; - Non-current smokers: students who have smoked in past, but not during past month; - Current smokers: students who have smoked during past month | Method of assessment: | | | Student level:
| | | - Questionnaire for students at 6, 12 and 18 months; - After a pretest, teachers questioned about effectiveness of process | | | - Posttest 1: 17.3%; - Posttest 2: 5.4%; - Posttest 3: 24.6%
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | No evidence of change of stage at either 1 yr or 2 yr followup: | Quality rating:
Aveyard et al., 2001 | To re-evaluate whether addition of a TTM-based intervention to existing health education school curriculum would protect young people from becoming smokers and help those who smoked quit compared w/ unknown effect of existing health educationRe-evaluation employed different periods of followup and fully exploring effects of using an ITT analytical approach | - Sampling description referenced from previous study (Aveyard et. al., 1999); - Once schools agreed to participate individuals randomly allocated to intervention or control; - Arms balanced by ordering schools into five groups based on numbers of students in yr 9; allocated each school a number b/w 1 and n (maximum number in group); - Computer program generated n/2 random numbers b/w 1 and n, and schools allocated to intervention; - One school allocated to intervention dropped out after randomisation and before baseline questionnaires administered | - Computer-based program; - Video; - Classroom instruction | - Random effects logistical regression; - Logistical regression; - Bivariate analysis,; - Frequencies; - Kappa assessment; - Sensitivity analysis | G1 vs C1 | Fair
Geographic area: | Population: | All Yr 9 students (aged 13 to 14) in participating schools invited to participate | Intervention: | Data verification: | - 1 yr AOR = 1.13, 95% (CI, 0.91–1.41);; - 2 yr AOR = 1.25, 95% (CI, 0.95–1.64) | Comments:
United Kingdom | - Adolescents, ages 13 to 16; - Living in West Midlands, UK | Sample size: | G1: During Yr 9, received | Self-report | No change in regular smoking at either follow up: | 40% refusal rate; no details on baseline data; C exposure to other prevention programs not assessed
Funding agency: | Study type: | G1: 4,125 | - Three whole class lessons and three interactive computer sessions (including video clips of young people discussing their smoking); - Followed by questionnaires assessing stages of change, smoking uptake or cessation; - Feedback on results of questionnaire, counseling about how to move forward in stages, and feedback on progress over time points | Dependent variables: | - G1 vs C1: 1 yr AOR = 1.14, (95% CI, 0.93, 1.39); - 2-yr AOR = 1.06, (95% CI, 0.86, 1.31) | Adequate randomization:
NR | RCT w/ cluster randomization | C1: 4,227 | C1: Standard lessons on smoking as part of English national curriculum, possibly up to three additional lessons on smoking (already available from teaching resources), which included quizzes and group work on health effects of smoking and different methods of persuading someone to quit smoking, all unrelated to TTM; no data collected on receipt of information | - Movement in stage of change; - Smoking status | Subgroup analysis by initial smoking status NS for benefit for prevention of smoking or smoking cessation | Yes
Study setting: | Inclusion criteria: | Definition of smoking: | Method of assessment: | Baseline data: | | Attrition rate:
School-based | Yr 9 student (age 13 to 14) in participating school, assented and parents consented | Cigarettes | Self-report questionnaire administered at baseline, 1 yr and 2 yr followups | - NR, but stated no large differences b/w groups in these predictors of smoking at baseline; - Predictors included: smoking status, stage of change, and potential confounders, i.e., risk factors for smoking in future | | Yr 1:
| Exclusion criteria: | - Regularly smoking at least one cigarette per wk | | | | G1: 11%
| - Parent or student refusal; - Smoking status could not be assessed at followup(s) | | | | | C1: 10.7%
| | | | | | Yr 2:
| | | | | | G1: 14%
| | | | | | C1: 16.9%
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Grade 10 smoking rates for never smokers:; - Male regular smoking rates lower; G1: 9.8%; C1: 16.4%; P = 0.02 | Quality rating:
Brown et al., 2002 | To evaluate an extracurricular HS tobacco control intervention developed by teachers and students | 30 high schools | - Extra-curricular activities; - Mobilization of staff and students to involvement in anti-smoking activities | Cluster-randomized designs (as discussed in Donner) and applied a procedure that uses a variance term appropriate to randomization of schools (Liang) | Smoking rates despite baseline status (NS):; - Females:; G1: 28.3%; C1: 24.8%; P = NR; - Males:; G1: 21.1%; C1: 26.4%; P = NR; - Overall:; G1: 24.9%; C1: 25.7%; P = NR | Fair
Geographic area: | Population: | Matched pairs prior to randomization by: | Intervention: | Data verification: | | Comments:
Canada | - Adolescents; - Cohort followed from 7–8th grade through 9–10th grade | - Size of school; - Number of students projected to attend who participated in an elementary school study; - Proportion of cohort students from elementary school study control condition | G1: Extracurricular activities: Quit and win contests, poster contests, displays, health fairs, smoking surveys | - Bogus CO breath samples collected to enhance validity of self-reported smoking behavior; - Data collected from absent students by mail or phone, but no bogus CO samples collected | | - Randomization technique incomplete; - Control schools received “usual” care but not described; - Some slight baseline data differences; - Limited generalizability
Funding agency: | Study type: | Sample size: | - Average of 3.8 intervention activities in 9th grade and 3.5 activities in 10th grade; - A teacher facilitated students, staff, and community members in planning and implementing prevention and cessation activities tailored to each intervention school to build committment and strengthen not smoking as a school social norm; - Research staff provided consultation, conducted semiannual workshops for teachers and student leaders, developed resources for dissemination to all intervention schools, produced newsletters, and provided a $1000 per school annual budget | Dependent variables: | | Adequate randomization:
NHLBI | - RCT w/ cluster randomization and paired-matching; - Matched pairs prior to randomization; - Randomized within pairs to Intervention and Cs | G1: 1,563 | C1: Usual care, details NR | - Social model risk score; - Elementary school risk score; - Smoking status | | Yes
Study setting: | Inclusion criteria: | C1: 1,465 | Method of assessment: | Baseline data: | | Attrition rate:
School-based | - School board participated in prior elementary school smoking prevention study; - At least 30 students from elementary school cohort projected to attend HS | Definition of smoking: | Surveys completed by cohort at end of their 9th and 10th grade yrs; data collectors blind to txt status | Baseline data similar except proportion of HS students in elementary school study intervention cohort : | | G1: 5%
| Exclusion criteria: | Cigarettes | | G1: 84% | | C1: 5%
| NR | - Experimental smoker: smoked less than once a wk; - Regular smoker: smoked weekly | | C1: 75%
| | | | (P = 0.10)
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Proportion increase at end of intervention:; - Nonsmokers:; G1: 9.6%; C1: 14.2%; OR 0.61 (95% CI, 0.41–.90); - Smokers:; G1: 2.6%; C1: 7.9%; OR = 0.62 (95% CI, 0.43–0.90) | Quality rating:
Crone et al., 2003 | To assess effect of a peer pressure based antismoking intervention on adolescents in lower secondary (middle) school | Community Health Sources | - Video; - Classroom instruction; - Competition by NIAS that reward class w/ | - Used multilevel techniques to account for clustering;; - Compared intervention and Cs in terms of proportions of smokers before and after intervention and proportion who started smoking, controlling for differences at baseline; - Performed ITT analysis | Perceived social pressure:; - More likely to be smokers; OR = 2.21 (95% CI, 1.53–3.18); - Effects at one yr followup: NS | Fair
Geographic area: | Population: | - 48 school identified; 18 willing to participate; 8 additional schools recruited; - Schools stratified by size and use of national drug education; - Randomized to intervention or control by toss of coin by independent person | < 10% smokers | Data verification: | | Comments:
Western Europe | - Adolescents; - 1st grade of lower secondary education in the Netherlands (mean age 13) | Sample size: | Intervention: | Self-report | | - Refusal rate (62.5%); - Not generalizble; - Significant differences in baseline data; - Very high attrition but used ITT
Funding agency: | Study type: | G1: 14 schools, 1,444 students | G1: Three lessons on knowledge, attitudes, and social influence, followed by a class agreement not to start smoking or to stop smoking for next 5 months | Dependent variables: | | Adequate randomization:
None | RCT w/ stratified randomization | C1: 12 schools, 1,118 students | - Two extra video lessons on smoking and social influence were available as an optional extra during the 5 months; - A competition administered by the NIAS that rewarded classes that had fewer than 10% smokers at the end of the 5 month period; - A photography contest to pick best photos that expressed a non-smoking class | Smoking status | | Yes
Study setting: | Inclusion criteria: | Definition of smoking: | C1: Used drug prevention program normally given to students (which intervention schools used as well) | - Changes in attitude toward smoking; - Perceived social influence; - Self-efficacy; - Intention to remain a smoker | | Attrition rate:
School-based | - Adolescents in lower secondary education in the Netherlands | Cigarettes | - Given option to use intervention program one yr after study | Baseline data: | | Schools:
| Exclusion criteria: | - Smoker: all students who experiment w/ smoking or who smoke weekly or daily | Method of assessment: | Males (%): | | Overall attrition: 11.5% (3/26)
| - If already participating in another study | | Surveys administered at baseline, at end of intervention, and at 1 yr followup | G1: 49.5 | | G1: 7.1% (1/14)
| | | | C1: 60.9 | | C1: 16.7% (2/12) Student attrition:
| | | | P = < 0.001smoker | | Overall: 63.3% (1,621/2,562)
| | | | Mean age: 13 yrs | | G1: 61.4% (887/1,444)
| | | | | | C1: 63.9% (714/1,118)
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | At 18-month followup, cigarette use in the past month:; - Baseline non-users:; G1 + G2: 8.6%; C1: 11.1%; P = < 0.01; - Baseline experimenters:; G1 + G2: 28.9%; C1: 36.6%; P = < 0.05; - Baseline users:; G1 + G2: 56.8%; C1: 70.8%; P = < 0.05 | Quality rating:
Ellickson et al., 2003 | To evaluate revised Project ALERT drug prevention program across a variety of Midwestern schools and communities | - 48 school clusters (high schools and their feeder middle schools); - Schools organized in 3 strata by community size and type (city, town, rural); - Blocks of school clusters consisted of 3 clusters from same stratum located in same geographic region of state., within each block, 1 school cluster randomly assigned to each experimental condition; - Results are combined through 8th grade for this study w/ one C | Classroom instruction | - Adjusted for multiple baseline covariates, including covariates for school geographic location and enrollment size to account for blocking; - Used Bayesian model to impute missing data for covariates; a generalized estimating equation that assumed a linear model for natural logarithm of the odds of use and constant correlation among responses from students from same schools used to account for possible intraschool correlation | At 18-month followup, weekly cigarette use:; - Baseline non-users:; G1+G2: 4.0%; C1: 6.6%; P = < 0.05; - Experimenters:; G1+G2:18.0%; C1: 23.5%; P = < 0.05; - Users:; G1+G2: 45.1%; C1: 56.0%; P = < 0.10 | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | | Comments:
US | - Adolescents, 7th and 8th graders in South Dakota (Urban and rural communities) | G1: 34 middle schools, 2,553 students | G1: 11 lessons in 7th grade and 3 lessons in 8th grade that, using interactive teaching methods, they sought to change students' beliefs about drug norms and social, emotional, and physical consequences of using drugs, to help students identify and resist pro-drug pressures from parents, peers, media, and others, and to build resistance self-efficacy; followed by booster lessons in 9th and 10th grades | Self-reported smoking status validated by assessing salivary cotinine levels for a random subsample of 654 students | | - Slight baseline differences but controlled for in analysis; - Clear description of school assignment; - Possible disruption of randomization process
Funding agency: | Study type: | C1: 21 middle schools, 1,723 students | G2: 11 lessons in 7th grade and 3 lessons in 8th grade that, using interactive teaching methods, they sought to change students' beliefs about drug norms and social, emotional, and physical consequences of using drugs, to help students identify and resist pro-drug pressures from parents, peers, media, and others, and to build resistance self-efficacy; not followed by any booster lessons | Dependent variables: | | Adequate randomization:
NIDA, the BEST Foundation for a Drug-Free Tomorrow; the Conrad N. Hilton Foundation | RCT w/ stratified randomization | Definition of smoking: | C1: Did not receive experimental program; schools could continue other prevention curricula already in place | Cigarette, marijuana, and alcohol use; beliefs about consequences, prevalence and expectations of use, self-efficacy | | Yes
Study setting: | Inclusion criteria: | Cigarettes | Method of assessment: | Baseline data: | | Attrition rate:
School-based | - Middle schools in South Dakota; - Parental consent obtained | - Cigarette use: ever, past month, and weekly | Students completed surveys at baseline and 18 months later | - Non-white: 12.5% (largely Native American); - Female: 50%; - Students in C1 less likely to be White and more likely to have used marijuana than students in G1 and G2 | | 9%
| Exclusion criteria:
| NR
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Proportion of smokers higher in C1 vs G1 for 3 followup yrs: | Quality rating:
Josendal et al 2005 | To evaluate the BEsmokeFREE school-based, smoking-prevention program for adolescents in Norway | - Nationally representative sample of 99 secondary schools from a list of all secondary schools in Norway; - Schools sorted by ascending postal code number, every 11th school included in study; schools allocated to groups by investigators choosing a random number b/w 1 and 44; - Starting w/ that number, every 44th school selected for C and next three schools on list of comparable size (+/- 10%) allocated to three intervention groups | - Video; - Parent involvment; - Classroom instruction | Multilevel, multiple logistic regression analyses used to examine odds of smoking among students in intervention groups compared w/ students in C1, adjusted for gender and smoking habits at baseline | - 1995: F(d.f. = 2.61; 125.49) = 5.66; P < 0.01; - 1996: F(2.34; 114.46) = 7.19; P < 0.001; - 1997: F(2.39; 112.42) = 4.05; P < 0.05 | Good
Geographic area: | Population: | Sample size: | Intervention: | Significance tested w/ Pearson's X^2^, corrected for design effect; correction implies chi sq value converted to an F-value w/ number of d.f. that may deviate from integer values | In G2 and G3, proportion of smokers on all followup occasions higher than G1 but lower then C1 | Comments:
Western Europe | - Adolescents; - Norwegian 7th, 8th, and 9th grade (mean age 13) | G1: 25 schools, 1,125 students | G1: Intervention administered by teachers and other staff at school | Data verification: | - 1995: F(d.f. = 9.74; 886.65) = 2.84; P < 0.01; - 1996: F(7.87; 739.55) = 3.98 P < .001; - 1997: F(6.00; 485.98) = 2.46; P < .05 | - Study design and randomization technique clearly described; - Intervention theoretically anchored; description of scales reported in referenced article; - Explored attrition by surveying drop outs
Funding agency: | Study type: | G2: 25 schools, 933 students | - Given to students in grades 7 and followed cohort through 7, 8, 9 grade; - Number of hrs of intervention: grades 7 thru 9 were 8, 5 and 6 hrs, respectively; - Classroom instruction contained non-traditional school activities such as video, games, and group work; - During grade 8 adjustments to intervention were requested by students and teachers; - In grade 9, students developed and carried out and evaluated their own campaign to promote a smoke free lifestyle among the 7th graders; - Classroom curriculum, teacher in-service course, and parental involvement | Self-report | Odds of becoming a smoker during intervention period statistically lower in G1 compared to C1: | Adequate randomization:
Norwegian Cancer Society | - RCT w/ cluster randomization | G3: 25 schools, 1,005 students | G2: Same as G1 Classroom curriculum and parental involvement but teacher did not receive in-service training on intervention | Dependent variables: | - Daily smoking (Wald's 9.81, d.f. = 3, P = 0.02); - Weekly smoking (Wald's 15.65, d.f. = 3, P = 0.0001); - Any smoking (Wald's 16.54, d.f. = 3, P = 0.0001) | Yes
Study setting: | Inclusion criteria: | C1: 25 schools, 1,092 students | G3: Same as G1 Classroom curriculum w/ teacher in-service course but no parent involvement | - Frequency of smoking; - Number of cigarette hrs; - Number of cigarettes smoked per wk; - Use of cannabis; - Frequency of cannabis use | | Attrition rate:
School-based | After being sampled by technique described, the school had to agree to participate | Definition of smoking: | C1: Education on smoking and health about half the number of hrs as intervention | Baseline data: | | - G1+G2+G3: 11.2% C1: 5.8%; - Smokers more likely to drop out than non-smokers
| Exclusion criteria: | Cigarettes | Method of assessment: | Baseline data reported but limited to smoking frequencies
| NR | - Smokers: daily smokers, and weekly smokers; - Nonsmokers: smoking less than once a wk, and not smoking at all | Surveys administered in classroom by teachers at end of each academic yr (7th, 8th, and 9th grades), then mailed to evaluators. | Mean age: 13 yrs
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Using growth curve analysis: D.A.R.E. Plus less likely than control to show an increase in current smoking for boys | Quality rating:
Perry et al., 2003 | To evaluate effect of middle and junior HS D.A.R.E. and D.A.R.E. Plus programs on drug use and violence | - Targeted Minnnesota school districts w/ schools w/ 7th grade populations of at least 200; - 24 Junior high schools matched on SES, drug use and size; schools randomly assigned to 1 of 3 conditions DARE only, DARE Plus, or C | - Parent involvment; - Extra-curricular activities; - Classroom instruction; - Community-activities | Growth curve analysis; 3-level linear, random-coefficients model | G2: (.28) std = 0.05 | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | C1: (.31), std = 0.05 | Comments:
US | - Adolescents, 7th and 8th grade; - Junior High Schools and communities in Minneapolis-St Paul region, Minnesota | G1: 8 schools; 2226 students | G1: D.A.R.E. middle and junior HS curriculum | Self-report | D.A.R.E. Plus less likely than D.A.R.E. curriculum alone to show an increase in tobacco use behavior and intentions. | - Randomization and sampling technique incomplete; - No baseline comparison data
Funding agency: | Study type: | G2: 8 schools; 2221 students | - 10 sessions taught by police officers in 1999-2001 | Dependent variables: | G1: (.95), std = 0.11 | Adequate randomization:
NIDA | RCT w/ simple randomization | C1: 8 schools; 1790 students | G2: D.A.R.E curriculum and D.A.R.E. Plus program in 1999-2001: | - Use of cigarettes, alcohol, and marijuana; multidrug use; violent behaviors; expectations concerning drug use, perceived access/offer of drugs, parental rules and communication about drugs; - Outcome expectations about tobacco | G2: (.68), std = 0.11 | No, group-randomization method NR; exactly 8 schools per intervention
Study setting: | Inclusion criteria: | Definition of smoking: | - Classroom sessions, peer led, parent involvement; - Community leader involvement program consisting of extra curricular anti-smoking activities in and out of school, including neighborhood activities to address neighborhood issues related to drug use and violent behavior | Baseline data: | C1: (.96), std = 0.12 | Attrition rate:
School-based | Minnesota school district, 7th graders in Fall 1999 | NR | C1: Delayed program: Schools could receive D.A.R.E. Plus programs in 2001-2002, after final followup | Male: 51.6% | NS outcomes for females | - 16% overall; - Minimal differential attrition per authors
| Exclusion criteria: | | Method of assessment: | White: 67.3%
| NR | | Self-administered questionnaire | African American: 7.5%
| | | | Asian American: 12.7%
| | | | HispaniC1: 3.6%
| | | | American Indian: 4.0%
| | | | Mixed or other: 4.9%
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Posttest results: | Quality rating:
Schofield et al., 2003 | To determine whether HPS intervention program led to lower smoking uptake and improved knowledge and attitudes among a cohort of students, and to examine factors independently predicting posttest smoking status | - Intervention randomly allocated to selected secondary schools; - Randomly selected 24 of 31 secondary schools in Hunter and Taree schools districts of New South Wales; - 22 of 24 schools participated, w/ 12 schools assigned to intervention, 10 to control | - Self-help; - Group counseling; - Social support | Univariate analysis | Smoked in last wk: NS | Fair
Geographic area: | Population: | Sample size: | Intervention: | Bivariate analysis | G1: 17.5% | Comments:
Australia | - Adolescents; - 7th -8th grade cohort followed 2 yrs to grades 9–10 in New South Wales | G1: 1,007 | G1: Each school had liaison office responsible for introducing minimum set of actions and facilitating tailoring and implementation of the following actions: | Multivariate analysis | C1: 20.5% | - Refusal rate: 40%; - High attrition; - Intervention not consistently implemented across schools, though high fidelity in implementing “key components” of intervention, authors mention potential contamination via control schools w/ personnel supportive of HPS intervention program, but no data to support/refute; - Study properly addressed clustering issue through analytical methods
Funding agency: | Study type: | C1: 845 | - Ensure curriculum covers smoking effects, distribute parent smoking pamphlet, implement school smoking policy, distribute letters to tobacco retailers, discussion group/survey w/ parents, followup action from discussion group, and training of SRC/peer leaders to deal w/ smoking issues; - Schools also encouraged to take over other additional anti smoking activities of their choice | Logistic regression | Crude OR for G1 = 0.82 (0.65, 1.04) | Adequate randomization:
National Health and Medical Research Council (Australia); Hunter Centre for Health Advancement | - RCT w/ cluster randomization (cohort prepost design) | Definition of smoking: | C1: Control schools not offered any of the resources or actions to reduce smoking that intervention schools received, but if they requested assistance, project team offered support for other health-related issues and promised smoking-specific support at completion of study period | Data verification: | Maximum knowledge score: | Yes
Study setting: | - Students followed over two yr period; cohort prepost design used to evaluate intervention effectiveness | Cigarettes | Method of assessment: | Self-report | G1: 64% | Attrition rate:
School-based | Inclusion criteria: | - Smoking status at posttest: having smoked any amount of cigarettes within past 7 days | Self-reported retrospective diary (of having smoked within past 7 days), as assessed via questionnaire | Dependent variables: | C1: 60% | G1: 48%
| Students in Yr 7–8 at one of participating schools who gave assent, whose parent(s) gave active consent, and whose pre and posttests could be matched for comparison | | | - Smoked in last wk; - Smoking knowledge; - Smoking attitudes towards schools | Prepost change: | C1: 52%
| Exclusion criteria: | | | Baseline data: | G1: 12% | (Authors mention more smokers than non-smokers lost to follow up)
| NR | | | Large variations in baseline smoking rates (11–33%) so smoking and school controlled for in regression (details NR) | C1: 7%
| | | | At pretest, smokers had: | P = 0.001
| | | | - Less positive attitudes than nonsmokers (mean for smokers: 4.3; mean for non-smokers 4.7, mean difference = 0.4, 95% CI-0.3, 0.5); - Fewer perceived negatives about smoking (smokers' mean: 3.6, non-smoker's mean = 3.9, mean difference = 0.2, 95% CI, 0.1, 0.3) | Smoking attitudes:
| | | | | NS at pre or posttest
| | | | | Solely among smokers (from combined groups), positive attitudes to smoking decreased from pretest to posttest (P = 0.01), but not among non-smokers
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Tried smoking: | Quality rating:
Share et. al., 2004 | To evaluate impact of a school-based intervention-SFL-which aimed to involve the community, increase tobacco knowledge, strenghthen refusal skills, and improve decision-making ability | SLF program participant cohort matched w/ a C located in North Western Health Board area (not defined) | Classroom instruction | - SPSS; - Pearsons chi sq; - Spearman's Rank correlation | G1: 59% | Poor
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | C1: 55% | Comments:
Western Europe | - Adolescents, ages 13 to 15; - Leitrim, Sligo, and Donegal County, Ireland students | G1: 450 | G1: Primary school phase: materials about smoking, healthy lifestyle, and growing up provided for classroom instruction; | Self-report | Current smoking: | - No information on selection of subjects from primary intervention; - Unable make inferences from original baseline data because followup instrument not compatible; - No reliability testing of instrument; - No information on randomization, or C; - No baseline data and analytical methods not well described
Funding agency: | Study type: | C1: NR | - Teachers determined order/timing of lessons; visits from health promotion staff,and yr end celebration;; - Postprimary school phase: quizzes, competition, visits by health promotion staff, newsletter, website, peer education project, smoke free school buses campaign, and annual events day(no classroom materials provided) | Dependent variables: | G1: 19% | Adequate randomization:
Europe Against Cancer Programme | RCT w/ simple randomization | Definition of smoking: | C1: NR | - Smoking experimentation; - Current smoking; - Smoking knowledge; - Attitudes about smoking; - Family member smoking; - Reasons for continued smoking | C1: 24% | NR
Study setting: | Inclusion criteria: | NR | Method of assessment: | Baseline data: | Females in C 2× as likely to smoke everyday and 50% more likely to currently smoke than females in intervention group, (P < 0.05) | Attrition rate:
School-based | - SLF program participants; - Aged 9 to 10yrs attending 4th grade (1996-97) in North Western Health Board area (not defined) | | Self-report questionnaire at study's end (administered face to face in intervention group and 11 control schools; “posted” (mailed) to other control schools) | Baseline data (i.e: at age 9 to 10) NR | Feel grown if smoke: | G1: 22%
| Exclusion criteria: | | | Male | G1: 30% | C1: NR
| NR | | | G1: 52% | C1: 43%
| | | | C1: 45% | (P < 0.01)
| | | | Age 13: | Don't mind if friends smoke:
| | | | G1: 12% | G1: 72%
| | | | C1: 14% | C1: 67%
| | | | Age 14: | (P < 0.05)
| | | | G1: 72% | Family: correlation b/w student smoking experimentation and parent/sibiling smoking:
| | | | C1: 77% | - Mother (rs = 0.165, P < 0.01); - Father (rs = 0.172, P < 0.05); - Both parents (rs = 0.346, P < 0.01); - Brother (rs = 0.162, P < 0.01); - Sister (rs 0.277, P < 0.01)
| | | | Age 15+:
| | | | G1: 16%
| | | | C1: 9%
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Final sample: | Quality rating:
Simons-Morton et al.,2004 | To examine associations b/w initial and continuing peer affiliation and parent influences and smoking stage progression | - Seven middle schools (in 1 Maryland school district) recruited and randomized:; - 3 to txt condition and 4 to control; - Starting w/ 1996 school yr., 2 successive cohorts of 6th-grade students recruited and followed through 9th-grade | - Video; - Classroom instruction | LGC analysis (Curran, 2000): structural equation modeling + hierarchical linear modeling | - White: 66%; - Black: 25%; - Other: 9%; - Variance of intercept factor in linear LGC model 2.23 (SE = 2.05; P < 0.001) indicating significant differences in tobacco use at beginning of 6th grade; - Variance of slope factor 0.289 (SE = 0.038; P < 0.01) indicating significant differences in smoking stage progression over time; - Path coefficients: intercept of adolescent smoking to slope of friends who smoke variable = 0.31(P < 0.01) indicating adolescents at higher initial smoking stages had increased # of friends smoking over time; - Path coefficient b/w parent involvement and adolescent smoking = -0.15, (P < 0.01) indicating parent monitoring and expectations overtime are negatively associated w/ smoking stage progression; - Path coefficient directly leading from parent involvement (-.15) and indirectly to the slope of adolescent smoking stage (-.46) through the slope of friends who smoke (.66) indicating that parenting practices overtime protect against smoking progression both directly and indirectly by limiting the adoption of friends that smoke P < 0.01 | Poor
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | | Comments:
US | - Adolescents, 6th, 7th, and 8th graders | Total: 3,039 at start, 1,320 final | G1: The Going Places Program: parent education (materials sent home), school media, social skills curriculum (to increase school engagement and prevent multiple problem behavior such as substance use, aggression, and antisocial behavior) | Self-report | | - Baseline data NR; - C sample size NR; - No txt vs comparison group data reported; - 151 special education students excluded after assessment 1, suggested possibility of post randomization of exclusions
Funding agency: | Study type: | C1: NR | - 18 class sessions in 6th grade, 10 in 7th grade, 6 in 8th grade | Dependent variables: | | Adequate randomization:
NR | RCT w/ simple randomization | Definition of smoking: | C1: NR | - Background variable; - Smoking; - Friends w/ problem behaviors; - Parenting practices | | NR
Study setting: | Inclusion criteria: | Cigarettes | Method of assessment: | | | Attrition rate:
School-based | - 6th grader in 1996 or 1997 at one of 7 schools in un-named Maryland School District; - Consent by parents | - Never: no smoking in past 30 days or past 12 months + no intention of smoking in HS; - 12-month smoker: smoking in past 12 months but not in past 30 days; - Recent smoker: smoking 1 to 2 times in past 30 days; - Frequent smoker: smoking 3+ times in past 30 days; - Intent to smoke: none in past 30 days or past 12 months but intent to smoke in HS | - Students surveyed at beginning and end of 6th grade, toward end 7th & 8th grades, and beginning of 9th grade; - Two trained proctors collected data; teachers not involved w/ survey | | | 36.30%
| Exclusion criteria: | | Baseline data:
| Special education students | | NR
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Initiation among never smokers (yr 1 followup): | Quality rating:
Unger et al., 2004 | Determine whether a multicultural curriculum prevents initiation of smoking among middle school children at 1-yr followup | Sixteen middle schools in Southern Calif randomly assigned to receive multicultural curriculum or standard curriculum (8 schools in each group) | Classroom instruction | - X^2^ and ANOVA analyses assessed prevention equivalence of 2 groups; - Logistic regression used to examine attrition based on experimental condition, baseline smoking, and experimental condition x baseline smoking; - Multi-level logistic regression w/ school as a random effect to control for intraclass correlation assessed effect of intervention on smoking initiation b/w sixth and seventh grades | G1: 8% | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | C1: 11% | Comments:
US | - Adolescents | G1: 1,040 students, 8 schools | G1: Project FLAVOR (Fun Learning about vitality, origins, and respect) provided 8 weekly classroom sessions conducted by health educators that addressed smoking-related psychosocial concepts through activities such as role-playing, trivia games and art projects, relating these issues to values of several cultures, such as Asian Yin-Yang concepts, and telenovela (soap opera) role play | Self-report | P = NR | - Randomization scheme NR; - No ITT analysis
Funding agency: | Study type: | C1: 930 students, 8 schools | C1: 8 weekly classroom sessions conducted by health educators that addressed smoking-related psychosocial concepts through activities such as role-playing, trivia games and art projects, but without cultural references | Dependent variables: | Among male, Hispanic, never smokers, OR of smoking intitation by 7th grade: OR = 0.49 (95% CI, 0.27–.88) | Adequate randomization:
National Institutes of Health and the Calif Tobacco-Related Disease Research Program | RCT w/ cluster randomization | Definition of smoking: | Method of assessment: | Smoking status | Overall intervention effect NS: OR = 0.75 (95% CI, 0.48, 1.18) | NR
Study setting: | Inclusion criteria: | Cigarettes | Surveys at baseline and 1 yr followup | Baseline data: | | Attrition rate:
School-based | Students participated if they and their parents provided active written consent | - Smokers: trying smoking b/w 6th and 7th grade | | - Groups similar at baseline; - No significant differences in demographics or lifetime smoking prevalence b/w intervention and Cs; - Hispani C1: 57%; - Asian American: 27%; - Other: 16% | | G1: 16.83%
| Exclusion criteria: | | | | | C1: 16.77%
| NR | | | | | Higher among baseline ever smokers (22%) than never smokers (16%),
| | | | | | P = < 0.05

Evidence Table 3. Effective provider-based interventions

Study Characteristics | Study Design | Sample Design and Definitions | Intervention Details | Statistical Analysis and Baseline Data | Outcome Measures | Quality Comments
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Mean K score: | Quality rating:
Tyc et al., 2003 | To evaluate efficacy of a tobacco risk counseling intervention vs standard care for preadolescent and adolescent cancer survivors | - Stratified RCT w/ patients who were pediatric cancer survivors treated at St. Jude Children's Research Hospital, Memphis, TN, currently receiving txt there; - Recruited during outpatient visits; - Asked to participate and told participation did not depend on smoking status; - On enrollment patients randomly assigned (stratified by age, sex, race, and self-reported smoking status); - Randomization scheme proposed by Zelen (1974) | - Self-help; - Individual counseling by health professional; - Telephone counseling; - Video | - Descriptive; - Multivariate analysis of variance,; - Repeated measures; - Mixed-model analysis of variance and regression | G1: 24 | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | C1: 22.7 | Comments:
US | - Adolescents who were cancer survivors age 10 to 18 (treated at St. Jude Children's Research Hopital, Memphis, TN) | G1: 53 | G1: Administered in single session w/ periodic reinforcement of tobacco goals by telephone | Self-report | Mean PV score: | - No psychometric validation of researcher-designed scales to measure knowledge and perceived positive effects of tobacco; - No verification or definition of tobacco use; - Limited generalizability to primarily white cancer patience; - Possible ceiling and floor effects on Knowledge and intention measures makes it difficult to access meaningful changes
Funding agency: | Study type: | C1: 50 | - Educational video discussed short- and long-term physical and social consequences of tobacco use; - Late effects risk counseling focused on potential chemotherapy and radiation txt related toxicities exacerbated by tobacco use and survivors' increased vulnerability to tobacco-related health risks relative to their healthy peers; - Goal setting involving tobacco abstinence or cessation depending on survivor's smoking status; - A physician feedback letter that reinforced antitobacco message delivered in intervention; - Tobacco literature and followup telephone counseling at 1 and 3 months after intervention; - Face-to-face counseling component of intervention conducted by a master's level psychologist over a 50- to 60-minute period, and followup telephone counseling conducted by a research nurse trained by V.L.T. | Dependent variables: | G1: 35.9 | Adequate randomization:
NCI, ALSAC | RCT w/ stratified randomization | Definition of smoking: | Intervention delivered using scripted protocol tailored to patients' individual responses to questions posed during intervention and individual goal setting. | - Knowledge (of adverse consequences of tobacco use generally and for cancer survivors); - Perceived Vulnerability (to tobacco related health risks); - Intentions (I) (to use tobacco); - Perceived PPE | C1: 32.5 | Yes
Study setting: | Inclusion criteria: | NR | C1: Patients asked about their tobacco use and briefly advised about health risks associated w/ tobacco use; all tobacco users advised to stop and nonsmokers encouraged to continue to resist tobacco | Baseline data: | I scores: | Attrition rate:
Practice/provider settings | - Between 10 to 18 yrs old; - Survivor of pediatric cancer; - Currently disease-free; - At least 1 yr from completion of antineoplastic therapy at St. Jude Children's Research Hospital (TN) | | Method of assessment: | Baseline demographic and questionnaire data collected for both groups w/ no significant differences b/w groups | G1: 7.8 | At 6 months:
| Exclusion criteria: | | Knowledge scale: | | C1: 10.0 | Overall: 30% (31/103)
| Patients who had brain tumors (due to cognitive, functional impairments that often result from txt) | | - 25 true-false questions regarding adverse effects of tobacco use and w/ questions focused on increased risks of youth treated for cancer; - 8-item scale measuring patients' perceptions of their vulnerability to tobacco-related health risks | | P = 0.002 | G1: 32.1% (17/53)
| | | | | No significant differences in PPE at 12 mos, nor in any of dependent variables at 6 months | C1: 28% (14/50)
| | | | | | At 12 months:
| | | | | | Overall: 21.5% (22/103)
| | | | | | G1: 20.1% (11/53)
| | | | | | C1: 22% (11/50)

Evidence Table 4. Multi-component interventions to increase the number of users who quit smoking

Study Characteristics | Study Design | Sample Design and Definitions | Intervention Details | Statistical Analysis and Baseline Data | Outcome Measures | Quality Comments
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Of 85 baseline smokers, 74 completed followup at 3 months (62.2% still smoked) and 80 completed followup at 12 months (66.3% still smoked) | Quality rating:
Bauman et al., 2000 | To report effectiveness of a universal family-directed program (Family Matters) for reducing/eliminating cigarette and alcohol use by adolescent users | - Eligible parent-adolescent pairs matched (by date and time of baseline interview) then randomly assigned to either Family Matters or C; - Random digit dialing and basic query used to identify families w/ 12- to 14-yr old children | - Self-help; - Telephone counseling | GEE method, one-tailed test (alpha 0.05), controlled for background variables. | No statistically significant difference in tobacco use b/w control and txt for baseline cigarette users (OR = 1.42, lower bound CI, 0.57, P = 0.2846). | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | | Comments:
US | Adolescents | G1: 37 baseline tobacco users | G1: Family Matters:; - Successive mailing of 4 booklets and telephone discussion w/ health educator 2 wks after each mailing; - Adult family members read booklets and do 15 activities w/ adolescent; - Booklet topics: (1) motivation, (2) family characteristics, (3) tobacco and alcohol variables, (4) variables outside family | NR | | - Include only baseline users in analyses in order to focus on cessation; - Only compare entire baseline groups to US or previous study population rather than each other; - Used one-tailed tests; - Attrition high among tobacco users; - No biochemical measure of use; - Small sample size
Funding agency: | Study type: | C1: 48 baseline tobacco users | C1: NR | Dependent variables: | | Adequate randomization:
NIDA Grant | RCT w/ simple randomization | Definition of smoking: | Method of assessment: | Smoking 30 days before interview | | No
Study setting: | Inclusion criteria: | Cigarettes | Telephone interviews at 3 and 12 months postcompletion or dropout | Baseline data: | | Groups not similar at baseline by age and race
Population-based | - In contiguous US state; - Consent; - Child age 12 to 14 yrs; - Completion of baseline interview | - Use on one or more days during past 30 days | | Groups similar on all measures except txt had younger and fewer non-Hispanic white participants | | Attrition rate:
| Exclusion criteria: | | | Overall: | | 14% overall; 40.5% among tobacco users in txt group(Control NR)
| NR | | | 12 yrs: 30.6%
| | | | 13 yrs: 35.3%
| | | | 14 yrs: 34.1%
| | | | Male: 49%
| | | | Non-Hispanic white: 73.4%
| | | | In 2-parent home: 78.8%
| | | | Among smokers:
| | | | - 21.6%, 40.5%, and 37.8% were 12,13, and 14 yrs old respectively in txt; - 10.4%, 29.2%, and 60.4% were 12,13,and 14 yrs old respectively in control; - 35.1% male (txt) vs 47.9% male (control);; - 70.3% vs 95.8% non-Hispanic white in txt vs control; - 75.7% vs 68.8% in 2-parent home in txt vs control
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | At 7 mo followup: | Quality rating:
Etter et al., 2004 | To determine whether effects of a computer-tailored smoking cessation program were maintained at 2-yr followup | - Baseline questionnaire sent to 20,000 18–60 yr old residents of French-speaking Switzerland, 3,124 agreed to participate in study; - 2,934 randomized to txt or Cs | Self-help | X^2^ to compare proportions; t-tests to compare means | 1 mo Abstinence rates: | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | G1: 5.8% | Comments:
Western Europe | Adults | G1: 1,467 | G1: After baseline questionnaire: | NR | C1: 2.2% | NR
Funding agency: | Study type: | C1: 1,467 | - Received 8-pg personal counseling letters written by a computer according to answers given by participants on a 62 item questionnaire; - Received 2 16-pg booklets corresponding to their current stage of change and next stage of change; - Two, four, and 12 mos after entering study, participants could answer tailoring questions again to receive new letter | Dependent variables: | P = < 0.001 | Adequate randomization:
Swiss National Science Foundation, the Swiss Cancer League, the Swiss Federal Office of Public Health, and the Health Authority of the Canton of Geneva | RCT w/ simple randomization | Definition of smoking: | C1: After completing baseline questionnaire, C participants received a letter telling them that they were in C, and not contacted again until 6- and 23-mo followup surveys | - Demographic characteristics; - Stage of change; - Level of tobacco dependence; - Perceived drawbacks of smoking; - Self efficacy; - Use of self help strategies; - Current use; - Intention to use NRT | 1 wk Abstinence rates: | NR
Study setting: | Inclusion criteria: | Cigarettes | Method of assessment: | Baseline data: | G1: 8.0% | Attrition rate:
Population-based | - 18 to 60 yrs old; - Resident of French-speaking Switzerland; - More than an occasional smoker; - Have a postal address | - 1 mo Abstinence: not smoking even a puff of a tobacco cigarette, cigar, or pipe in last 4 wks; - 1 wk Abstinence: not smoking even a puff of a tobacco cigarette, cigar, or pipe in last 7 days | Surveys at 7- and 24-mos postbaseline | Groups similar at baseline | C1: 3.3% | 7-mo followup: 16%
| Exclusion criteria: | | | | P = < 0.001 | 24-mo followup: 12%
| NR | | | | At 24-mo followup:
| | | | | 1 mo and 1 wk abstinence rates similar for both groups, differences NS
| | | | | Proportion of those who quit for at least 1 mo during study:
| | | | | G1: 30.9%
| | | | | C1: 24.7%
| | | | | P = < 0.001
| | | | | Proportion of those who used > 1 nicotine replacement product:
| | | | | G1: 24.9%
| | | | | C1: 20.8%
| | | | | P = < 0.008
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | No group differences observed in abstinence at either time point or for sustained abstinence | Quality rating:
Lipkus et al., 2004 | To test efficacy of self-help materials w/ or without proactive telephone counseling to increase cessation among teen smokers. | - Teen smokers recruited from 11 shopping malls and 1 amusement park in Southeastern US; - Teens stratified on stage of readiness to quit, then randomized to (1)self-help materials + video (C) or (2) self-help materials + video + telephone counselors (experimental group). | - Self-help; - Telephone counseling; - Video | ITT; logistic regression | G1: Abstinence rates: 16% and 21% for 4 and 8 mos, respectively | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | C1: Abstinence rates: 11% and 19% for 4 and 8 mos, respectively | Comments:
US | Adolescents | G1: 193 | G1: Two self-help booklets by mail and 6 minute video and 3 telephone counseling sessions | Saliva cotinine kit mailed at month 4 postbaseline if teen denied smoking in last 7 days; otherwise selfreport. | Outcome Measures unchanged after adjusting for multiple variables | - Methods described in good detail (except randomization scheme); - Major limitation is high attrition rates
Funding agency: | Study type: | G2: 209 | C1: Two self-help booklets by mail, 6 minute video, no telephone counseling | Saliva kits retruned by 40% of those reporting cessation; rates of return did not differ by group | Sustained abstinence rates (C1) 7% and (G1) 9% | Adequate randomization:
NCI grant | RCT w/ simple randomization | Definition of smoking: | Method of assessment: | Dependent variables: | Participants completing more counseling calls more likely to report cessation at 4 and 8 mos postbaseline w/ ITT: (OR = 1.59, 95% CI, 1.14–2.22 for 4 mos and OR = 1.54, 95% CI, 1.15–2.07 for 8 mos) and to have sustained abstinence (OR = 2.03, 95% CI, 1.14–2.22 | NR
Study setting: | - 2-arm randomized intervention trial | Cigarettes | 6-item revised Fagerstrom Nicotine Tolerance Scale; self report (validated by saliva cotinine if denied smoking in last wk); Shadel and Mermelstein's 5-item scale | Point-prevalent abstinence at 4 and 8 mos postbaseline; sustained abstinence (proportion reporting not smoking at both followups) and predictors of cessation | Intervention group less likely to watch some/all of video (44% vs 62%, P < 0.05) and read some/all of booklet (57% vs 78%, P < 0.01) | Attrition rate:
Community-based | Inclusion criteria: | - Smoked 1 or more within last wk | | Baseline data: | Teens completing more calls more likely to report quitting at 4 and 8 mos (4 mos: OR = 1.59, 95%CI, 1.14–2.22, P < 0.007; 8 mos: OR = 1.54, 95% CI, 1.15–2.07, P < 0.007) and have sustained abstinence (OR = 2.03, 95%CI, 1.14–2.22, P < 0.006) | Control: 49%
| - Age 15 to 18; - Smoked a cigarette within last wk; - Gave verbal consent; - Obtained parental consent if < 18 yr | | | No arm differences on sample characteristics | The more calls teens accepted, the more negative they felt about smoking (r = 0.23, P < 0.05) and the more they reported wanting to stop (r = 0.23, P < 0.05) | Intervention: 66%
| Exclusion criteria: | | | Age 17 or older: | Compared w/ teens who smoked more than the median number of cigarettes per day (>8), teens who smoked equal to or less than the median number of cigarettes a day more likely to have quit smoking at 4-mo (OR = 3.3, 95% CI, 1.7–5.0, P < 0.0004) and at 8-mo followup (OR = 2.0, 95% CI, 1.2–3.3, P < 0.007) and to have sustained abstinence at both followups (OR = 2.5, 95% CI, 1.2–5.0, P < 0.01) | Abstinence rates:
| NR | | | G1: 55% | Teens in preparation stage more likely than precontemplators to have quit at 4-mo (OR = 2.4, 95% CI, 1.0–5.4, P < 0.05) and at 8-mo (OR = 2.9, 95% CI, 1.4–6.0, P < 0.005) followups | 4 mos:
| | | | C1: 59% | Stage of readiness not related to sustained abstinence | G1: 16%
| | | | Male: | | C1: 11%
| | | | G1: 47% | | 8 mos:
| | | | C1: 51% | | G1: 21%
| | | | High School: | | C1: 19%
| | | | G1: 85%
| | | | C1: 78%
| | | | 82% white, 10% black in both groups
| | | | 3 (SD 2) mean yrs smokingin both groups
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Proportion of participants not smoking at 6-mo followup: | Quality rating:
McBride et al; 2002 | To assess whether a multicomponent intervention that included feedback about genetic susceptibility to lung cancer increased risk perceptions and rates of smoking cessation compared w/ a standard cessation intervention | African-American patients (seen in adult medicine, dental, urgent care and specialty clinics) current smokers, and identified by chart abstraction and provider referral | - Self-help; - Individual counseling by health professional; - Telephone counseling; - Pharmaceuticals; - Genetic susceptibility feedback | - Baseline characteristics compared by intervention arm w/ X^2^ statistic for discrete variables and t-tests for normally distributed continuous and ordinal variables; - Wilcoxon test statistic used when variables not normally distributed; - Logistic regression used for main binary outcomes of trial, abstinence from smoking in prior 7 days at 6- and 12-mo followups, and continuous abstinence (not smoking at both 6- and 12-mo followups); - All analyses done twice, first unadjusted and then adjusted by adding baseline variables that differed (P < 0.05) by arm and known to be associated w/ smoking cessation, including number of chronic illnesses (0 v. 1 or more), smoking within 30 min of rising (no v. yes), and desire to quit (below or equal to median v. above median) | G1: 10% | Fair
Geographic area: | Population: | Those eligible and agreed to participate called within 7 days of visits to complete participant intake assessment | Intervention: | Data verification: | G2: 19% | Comments:
US | - Adults; - African Americans; - Low SES | Sample size: | G1: Enhanced Usual Care: participants received provider advice to quit smoking and referred to smoking specialist who assessed stage of readiness to quit and appropriateness of NRT | - Salivary cotinine levels assessed for self-report of not smoking at 12-mo followup; - Efforts to biochemically confirm self-reported cessation unsuccessful; - 39% (24/61) of those who reported abstinence and agreed to provide a saliva sample returned one; - Rates of return did not differ b/w two arms (P = 0.78) | Unadjusted P = 0.006 | NR
Funding agency: | Study type: | G1: 185 | - Within 2 wks after clinic visit, all smokers sent a self-help smoking cessation guide especially designed for African-American smokers, “Pathways to Freedom”; - If eligible (smoked at least five cigarettes/day and in preparation stage of readiness to quit), a 14-day supply of 15 mg nicotine patches; - Refill kits included a 7-day supply of patches provided as needed;; - Participants allowed to request up to eight refills over study period (for a total of 10 wks of therapy) | Data verification: | Adjusted P = 0.03 | Adequate randomization:
NCI | NR | G2: 372 | G2: Biomarker Feedback: | Salivary cotinine levels assessed for those who self-reported not smoking at 12-mo followup | Proportion of participants not smoking at 12-mo followup is NS: | Yes
Study setting: | Eligible smokers randomized in a 1:2 ratio to enhanced usual care group or biomarker feedback (that included tailored feedback of genetic susceptibility to lung cancer based on presence or absence of GSTM1 and telephone counseling) group | Definition of smoking: | - Participants offered opportunity to have their blood tested for GSTM1; - Within 2 wks after clinic visit, participants priority mailed an eight-pg test result booklet written at a fifth grade reading level that included test result, information about chemical constituents of tobacco smoke and harms of exposure, regardless of genetic make-up; - Those who declined test were sent an identical booklet that included same graphical displays along w/ a generic description of test and a question mark in result box; - Within 1 wk after test result booklet mailed, participants called to discuss GSTM1 test and their result; counselors attempted a total of four calls w/ each participant over a 12-wk period; b/w first and second calls, participant sent “Pathways” selfhelp guide and nicotine patches, if appropriate | Efforts to biochemically confirm self-reported cessation unsuccessful; 39% (24 of 61) of those who reported abstinence and agreed to provide a saliva test | G1: 10% | Attrition rate:
Practice/provider settings | Inclusion criteria: | Cigarettes | C1: NR | Dependent variables: | G2: 15% | - 6-month followup: 26%; - 12-month followup: 36%
| - Self-identify as African American; - Smoked at least one cigarette/day in prior 7 days; - Would consider genetic testing for GSTM1 | - Smoking: At least 1 cigarette in past 7 days | Method of assessment: | Primary: | Unadjusted P = 0.12 | No difference in attrition b/w groups
| Exclusion criteria: | | Self-report of 7-day point prevalence smoking status | - smoking status | Adjusted P = 0.34
| - Not African American; being treated for substance abuse; - Smoked less than 7 cigarettes/wk; - Did not have a telephone; - Have medical conditions that contraindicate participation, e.g., Alzheimer's disease, alcohol dependence; - Non-English speaking; - < 18 yrs of age | | Salivary cotinine levels assessed at 6 and 12-mo followup | Secondary: | Continuous abstinence of participants:
| | | Blood analyzed for G2 group to evaluate whether or not GSTM1 present | - risk perceptions; - worry; - depression | G1: 5%
| | | | Baseline data: | G2: 11%
| | | | Groups similar at baseline except: G1 arm participants had: | Unadjusted P = 0.02
| | | | - more chronic illnesses; - less desire to quit smoking; - more likely to smoke within 30 min of waking | Adjusted P = 0.08
| | | | than those in G2 arm | Rates of prevalent and sustained abstinence for those w/ enzyme missing or present did not differ significantly at followup:
| | | | | - 6 mos, 17 and 23%, respectively; - 12 mos, 18 and 15%; sustained, 12 and 12%
| | | | | Among those who declined test, rates of prevalent abstinence at 6 and 12 mos and sustained abstinence substantially lower (11, 11, and 5% for each outcome and time point, respectively
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Biochemically validated smoking status at LHS 3 baseline - Percent quit: | Quality rating:
Murray et al., 2002 | To evaluate long-term persistence of effects on smoking and quitting on participants in the LHS intervention aimed at smoking cessation and to describe characteristics that distinguish those who quit smoking from those continuing to smoke | Original LHS recruited, in 10 clinics in U.S. and Canada, 5,887 adult volunteer smokers w/ some evidence of lung function impairment | Pharmaceuticals | Comparisons b/w groups for quantitative variables are based on t-tests, while those for categorical variables are based on X^2^or Fisher's exact test; Logistic regression used to analyze multiple predictors of LHS 3 cross-sectional smoking status and sustained abstinence status | G1: 51.7 | Fair
Geographic area: | Population: | Following LHS 1, LCS enrolled 5,008 of original cohort, and followed at 6-mo intervals w/ telephone interviews to ascertain smoking status and morbidity | Intervention: | Data verification: | C1: 42.9 | Comments:
US | - Adults | Recruits randomized equally to three study arms | G1: SI(described in other articles) w/ ipratropium bromide inhaler and SIwith placebo inhaler - both groups combined for analysis because ipratropium bromide inhaler had no effect on smoking cessation | Expired air CO levels used to validate non-smoking status | P = < 0.001 | NR
Canada | Study type: | Sample size: | C1: usual care (described in other articles) | Dependent variables: | Sustained abstinence since LHS 1 baseline: | Adequate randomization:
Funding agency: | RCT w/ systematic randomization | G1: 3,040 | Method of assessment: | Smoking status | G1: 21.9% | Yes
NIH | Inclusion criteria: | C1: 1,477 | - Interviews in-person and via telephone; - Expired air CO levels | Baseline data: | C1: 6.0% | Attrition rate:
Study setting: | - Smokers who had some evidence of lung function impairment (at baseline, their ratio of FEV to FVC less than 0.70 and their FEV b/w 55 and 90% of predicted normal for their age, gender, height, and race); - Willingness to participate in a smoking cessation program if randomized to smoking intervention | Definition of smoking: | | Groups similar at baseline | P = < 0.001 | 16.7%
Practice/provider settings | Exclusion criteria: | Sustained abstainers: | | | OR of abstinence in participants assigned to G1 as opposed to
| - Serious health conditions likely to affect participation in followup visits and lung function measurement; - Use of prescribed medications that might alter lung function | - participants who had been sustained quitters in LHS 1; - gave no report of smoking during LCS; - if not enrolled in LCS, recalled no month w/ as much as one cigarette per day in interval b/w LHS 1 and LHS 3; - ex-smokers at LHS 3 baseline, validated by expired air CO levels | | | C1 = 4.45
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Prevalence of reported 48 hr abstinence at 3 mo followup among 18–25 yr olds: | Quality rating:
Rabius et al., 2004 | To examine effects of telephone counseling on smoking cessation among smokers 18 to 25 yrs old and smokers over 25 yrs old | - Cessation assistance offered to smokers from anywhere in US that called ACS' general toll-free number for information about cessation; - Adult current daily smokers willing to make a quit attempt in next 2 wks and gave consent, interviewed and randomized to 2 txt or control; - All participants received three ACS booklets that provide standard advice; half of participants randomized to receive an offer of telephone counseling | - Self-help; - Telephone counseling | - Logistic regression for studies of factors predicting study retention and quitting success, t-tests for comparing means; - X^2^ for comparing proportions | G1: 19.6% | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | C1: 9.3% | Comments:
US | - Young adults; - Adults | Total: 3,522 | G1: Three ACS booklets w/ standard advice plus up to five sessions of proactive telephone counseling | NR | P = < 0.005 | Adequate randomization:
Funding agency: | Study type: | G1: Half of participants; exact N NR | C1: Three ACS booklets w/ standard advice | Dependent variables: | Prevalence of reported 48 hr abstinence at 3 mo followup for over-25 yr olds: | NR
ACS | RCT w/ simple randomization | C1: Half of participants; exact N NR | Method of assessment: | Study retention by intervention; abstinence; use of NRT or Zyban | G1: 15.1% | Attrition rate:
Study setting: | Inclusion criteria: | Definition of smoking: | Interview at 15 wks after enrollment (approximately 3 mos postquit date); if participants reported abstinence at 3 mo interview, then interviewed again at 6 mos postquit date | Baseline data: | C1: 9.6% | Overall: 36%
Population-based | Of those who called a toll-free ACS number to inquire about cessation, adult current daily smokers willing to make a quit attempt in next two wks | Cigarettes | | Proportion of participants in younger age group (18–25 yrs old): | P = < 0.001 | Attrition at 3-mo followup:
| Exclusion criteria: | - Current smoking: any smoking within last 48 hrs | | 12% (n = 420), similar to larger population | Proportion of 18–25 yr olds reporting 48 hr abstinence at both 3 and 6-mo followups: | 18–25 yr olds: 48%
| NR | | | Women outnumbered men overall | G1: 9.8% | Over-25 yr olds: 34%
| | | | Proportion of men: | C1: 3.2% | P = < 0.001
| | | | 18–25 yrs: 39% | P = < 0.01 | Attrition among those abstinent and eligible for followup at 6 mos:
| | | | Over 25 yrs: 33% | Proportion of over-25 yr olds reporting 48 hr abstinence at both 3 and 6-mo followups: | 18–25 yr olds: 36%
| | | | P = < 0.01 | G1: 8.8% | Over-25 yr olds: 15%
| | | | Proportion of married men: | C1: 5.3% | P = < 0.001
| | | | 18–25 yrs: 19% | P = < 0.005 | Logistic regression found that successfully followed participants more likely to be female (P = < 0.01) and better educated (P = < 0.01) than those not retained in study
| | | | over 25 yrs: 49% | Estimate of prolonged abstinence at 6 mo followup (reported 48 hr abstinence plus 5 or fewer
| | | | P = < 0.001 | - Logistic regression analysis examining relationships b/w demographic variables, smoking behavior and history, and txt condition found the following: among 18–25 yr olds, txt condition only significant predictor of 48 hr abstinence at 3-mo followup(P = < 0.01); - Among over-25 yr olds, 48 hr abstinence at 3-mo followup significantly higher in txt group (P = < 0.001), those w/ more education(P = < 0.01), and those w/ lower baseline smoking rates(P = < 0.001)
| | | | Frequency of cigarette use:
| | | | 18–25 yrs: 18 cigarettes
| | | | Over 25 yrs: 24 cigarettes
| | | | P = < 0.001
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Point abstinence at 3 mos: | Quality rating:
Smith et al.; 2004 | To examine options for use, efficiency, and effectiveness of telephone counseling for structuring a population-based telephone smoking cessation service | Counselors answered incoming toll-free calls and determined study eligibility of callers; ineligible callers sent cessation materials designed to respond to their needs (e.g., pregnancy); eligible callers randomized (stratified within communities) to one of five conditions | - Self-help; - Telephone counseling; - Pharmaceuticals | NR | G1: (1, 2, 3, 4 collapsed) = 15% | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | C1: 13% | Comments:
Canada | - Adults | Total: 632 | G1: Initial 50 minute telephone counseling, 2 five to 10 minute followup calls, booklet | No biochemical validation of self-reported smoking status performed | P = < 0.05 | NR
Funding agency: | Study type: | Definition of smoking: | G2: Initial 50 minute telephone counseling, 2 five to 10 minute followup calls, pamphlet | Dependent variables: | Point abstinence at 6 mos: | Adequate randomization:
Ontario Ministry of Health; Heart and Stroke Foundation of Ontario | RCT w/ stratified randomization | Cigarettes | G3: Initial 50 minute telephone counseling, 6 five to 10 minute followup calls, booklet | - Smoking status; - Participant rating of print materials; - Participant rating of telephone counseling | G1: (1, 2, 3, 4 collapsed) = 15% | Yes
Study setting: | Inclusion criteria: | - Point abstinence: 7-day abstinence at time of followup call; - Continuous abstinence: 7-day abstinence at all followup calls | C1: Print materials only | Baseline data: | C1: 14% | Attrition rate:
Population-based | - Current smokers; - At least 18 yrs of age; - Daily smokers; - Non pregnant; - Intend to quit within 7–20 days; - Live in specified geographic recruitment areas; - Consent to participate in study | | Method of assessment: | No significant differences across the 5 groups at baseline | P = < 0.05 | Attrition: 30.6%
| Exclusion criteria: | | Research staff, blind to txt conditions, called participants in all 5 conditions at 3,6, and 12 mos to assess smoking status; 7 attempts made at each followup call before recording it as missed | | Point abstinence at 12 mos: | - Died: 0.003%; - Withdrew: 7.1%; - Lost to followup: 23.2%
| NR | | | | G1: (1, 2, 3, 4 collapsed) = 17%
| | | | | C1: 20%
| | | | | P = < 0.05
| | | | | Continuous abstinence:
| | | | | G1: (1, 2, 3, 4 collapsed) = 5%
| | | | | C1: 1%
| | | | | P = < 0.05

Evidence Table 5. Strategies to improve success rates for quit attempts for general and special populations

Study Characteristics | Study Design | Sample Design and Definitions | Intervention Details | Statistical Analysis and Baseline Data | Outcome Measures | Quality Comments
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | No statistically significant difference in quit rates between intervention and control groups (G1=11%, G2=12%, G3=10%, C1=10%) in biochemically-confirmed abstinence for 6-months sustained abstinence and 12-months point prevalence | Quality rating:
Aveyard et al., 2003 | To examine the population impact and effectiveness of the Pro-Change smoking cessation course based on the Transtheoretical Model (TTM) compared to standard self-help smoking cessation literature | - 3 wave recruitment process - wanted to estimate the proportion of smokers that could be recruited from British general practice; - 1st wave: used random sampling. West Midlands GP practices were selected with probability proportional to size and then a fixed number of patients (300) were selected for invitation; - From wave 1, became clear that insufficient patients would be recruited so invited originally recruited practices to repeat the process (2nd wave); - When 2nd wave failed to reach target number, non-randomly selected new practices approached to participate.; - In all waves, potential participants were sent invitation packs containing a cover letter from GP to patients expressing concern about smoking, assuring patients never to late to quit, and offering to help stop smoking at the surgery, if not by trial entry.; - Participants signaled consent by returning baseline questionnaire; - On receipt of baseline questionnaire, participants then randomly assigned either to control group (standard self-help literature), manual intervention group (received Pro-Change system), the telephone group (received Pro-Change system plus 3 telephone calls) or the nurse group (received Pro-Change system, 3 telephone calls and 3 visits to practice nurse | - Self-help quit guides and tip cards; - Workbook and questionnaires; - Telephone counseling; - Nurse visits | - Recruitment of new practices in wave 3 where participants only allocated to 3 arms (no one allocated to G3) complicated analysis, b/c no guarantee overall that participants' characteristics balanced b/w arms - therefore, analyzed the data as 2 separate trials - calculated the percentage quitters in each arm and performed an overall chi-square test to calculate differences between arms; - Odds ratios for the risk of quitting relative to control arm and the percentage and OR for quitting in 3 intervention groups (G1, G2, G3) combined vs. control arm were calculated; - To examine if difference b/w 4-arm and 3-arm trials in effectiveness of intervention arms relative to control arm, added a multiplicative term for trial x trial arm to a logistic regression model; - The study reported results using intent-to-treat analysis, as well as results that used only those that followed-up | | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | | Comments:
United Kingdom | Patients of general pracitioners employed at 65 West Midlands general practices | G1: 683 | G1: Pro-Change self-help system with workbook and 3 questionnaires to generate tailored feedback | Self-report, salivary cotinine (values >14.2 ng/ml taken as indicative of active smoking) | | - Authors conclude Pro-Change system unlikely to provide important alternative to current network of smoking cessation clinics and prescription of NRT
Funding agency: | Study type: | G2: 685 | G2: G1 plus three telephone calls | Dependent variables: | | Adequate randomization:
West Midlands health authorities | RCT | G3: 413 | G3: G1 plus three nurse visits | - Point prevalence of being quit at 12 months; - Point prevalence of sustained abstinence of at least 6 months | | Yes
Study setting: | Inclusion criteria: | C1: 690 | C1: 2 standard self-help quit guides and 2 tip cards | | | Attrition rate:
Practice/provider settings | Current smokers | Definition of smoking: | Method of assessment: | | | 29%
| Exclusion criteria: | Cigarettes | Asked the question “are you currently a smoker?” at 12 months post baseline - verified by salivary cotinine, obtained by visit to participant house or by mail
| All selected patients were eligible unless terminally ill, violent or other unusual circumstances pertained | - Current Smoker - NR | Baseline data:
| | | No significant differences b/w any of the groups
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Not Smoking (%) at 18 months | Quality rating:
Bier et al., 2002 | To examine the effect of acupuncture alone and in combination with education on smoking cessation and cigarette consumption | Blind random assignment to groups | Individual counseling by health professional | - Power analyses for sample size (.05 for power of .80); - Mixed model with repeated measures; - Covariance between any 2 periods considered autoregressive | G1: 20% | Poor
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | G2: 40% | Comments:
NR | Age 18 years or older | G1: 38 | G1: Acupuncture, 20 sessions over 4 weeks (5 per week) | Self report | C1: 53% | - Very high attrition rate; - Group has a higher pack year history than in other studies
Funding agency: | Study type: | G2: 45 | G2: Same as GI, but also received 5 weeks educational smoking cessation program (multisession, multicomponent behavioral training, education, social support, relapse prevention, 1.5 hours twice per week for first week, then once per week for next 4 weeks) | Dependent variables: | NS | Adequate randomization:
Arizona Disease Control Research Commission | Prospective, quasi factorial design | C1: 58 | C1: Sham accupuncture, 20 sessions over 4 weeks (5 per week) plus 5 weeks educational smoking cessation program (multisession, multicomponent behavioral training, education, social support, relapse prevention, 1.5 hours twice per week for first week, then once per week for next 4 weeks) | - Beck Depression Inventory score; - Zung Self-Rating Anxiety Scale; - # of cigarettes smoked per day; - Age of initiation; - # of years smoking; - Smoking or not smoking at visit; - % decrease in smoking; - Decrease in # of cigarettes smokes; - VAS Score; - Pack year history | Greater the estimated pack year history before treatment, the greater the decrease in total number of cigarettes smoked per day following treatment | Yes
Study setting: | Inclusion criteria: | Definition of smoking: | Method of assessment: | | | Attrition rate:
NR | - Aged 18 years or older; - Attempted to stop smoking at least once without success | NR | Cigarette pack self monitoring chart, recording number and times cigarettes smoke in past 7 days, pre and post intervention; asked about smoking at clinic visit | | | At 18 months
| Exclusion criteria: | | Baseline data: | | | Total: 66%
| - Actively psychotic; - Suffering from any neurological or physical illness or other impairment that would prevent understanding of research consent form; - Not able to read and write sufficiently to understand and complete the forms; - Not willing to participate in a treatment protocol involving acupuncture; - Currently taking phenothiazine, tricyclic antidepressants, lithium carbonate or beta blocking medication; - Chronically using sympathomimetic drugs such as ephedra, ephedrine, amphetamines, or sedative medication | | No significant differences | | | G1: 68%
| | | | | | G2: 65%
| | | | | | C1: 66%
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Percentage of participants completely abstinent at 6-wk followup: | Quality rating:
Bohadana et al; 2000 | To investigate whether short-term (6-wk) addition of a NPto nicotine inhaler txt improves early smoking cessation rates, and whether this txt combination improves likelihood of abstinence at 6 and 12 months | - Subjects from Nancy, France, and surrounding towns recruited by means of local newspaper; - First subject enrolled in March 1996, and followup completed in February 1998; - Approximately 1,000 people who contacted the Centre Hospitalier Universitaire de Nancy-Brabois, 462 underwent a prospective telephone screen to enroll 400 subjects who met inclusion criteria | - Individual counseling by health professional; - Pharmaceuticals | - Data analyzed on an ITT basis (ie, all subjects who entered study and received medication, irrespective of medication use or outcome); Intergroup differences in ITT abstinence rates at all time points calculated by X^2^ (or Fisher exact test if necessary); - Proportions of participants remaining abstinent over time calculated by comparing relapse w/ smoking curves of 2 groups by means of log rank test; - Continuous variables compared b/w groups by parametric t-tests whenever possible, and Mann-Whitney rank sum test used for data non-normally distributed | G1: 60.5 | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | C1: 47.5 | Comments:
Western Europe | - Adults | Total: 400 | G1: Nicotine inhaler (plastic tube containing a perforated plastic plug impregnated w/ 10 mg of nicotine, approximately 4 mg of which is available for inhalation, and menthol to reduce irritant effect of nicotine) plus 30-cm2 NPcontaining 0.83 mg of nicotine per square centimeter, delivering 15 mg per 16 hrs | Self-reported smoking status validated by blood cotinine levels and expired air CO levels | P = 0.009 | Attrition rate NR
Funding agency: | Study type: | Definition of smoking: | C1: Nicotine inhaler (plastic tube containing a perforated plastic plug impregnated w/ 10 mg of nicotine, approximately 4 mg of which is available for inhalation, and menthol to reduce irritant effect of nicotine) plus placebo patch that contained no nicotine | Dependent variables: | 3-mo followup: | Adequate randomization:
Pharmacia and Upjohn Consumer Healthcare | - RCT w/ systematic randomization; - Double-blind, randomized, placebo-controlled trial | Cigarettes; - 3-mo cessation rate, rate of continuous abstinence at all time points: self-reported nonsmoking b/w wk 2 and mo 12 and an expired CO level less than 10 ppm at each followup visit | Method of assessment: | 3-mo cessation rate, rate of continuous abstinence at all time points, nicotine inhaler use, nicotine substitution, incidence of withdrawal symptoms, adverse events, and changes in body weight | G1: 42.0 | Yes
Study setting: | Inclusion criteria: | | Baseline assessments included patient characteristics, vital signs, patient weight, smoking history, expired CO, blood cotinine, psychological status, SES, pulmonary measures (symptoms and function) and medical history; during txt and followup, weight measured, smoking history and expired CO assessed, blood cotinine measured, craving and withdrawal symptoms and all adverse events; pulmonary measures (symptoms and function) collected at 12 mos | Baseline data: | C1: 31.0 | Attrition rate:
Practice/provider settings | - Aged 18 to 70 yrs; - Smoked 10 or more cigarettes per day for 3 or more yrs; - Expired CO level of 10 ppm or more; - Made 1 or more previous attempts to quit; - Personally motivated to stop smoking; - Fluent in French | | | No significant differences b/w 2 groups except for a greater number of cigarettes per day in G1 | P = 0.02 | 1 person withdrew from study due to a serious adverse event, but overall attrition rate NR
| Exclusion criteria: | | | | No significant difference in complete abstinence b/w G1 and C1 at 6- and 12-mo followups
| - History of myocardial infarction within past 3 mos; - Unstable angina; - Severe cardiac arrhythmia; - Serious renal, pulmonary, endocrine, or neurological disorders; - Pregnancy or breastfeeding; - Use of any form of ST or nicotine substitution; - Participation in any smoking cessation program during past 6 mons; - Alcoholic or illegal drug user; - Use psychoactive drugs; - Have generalized dermatological diseases | | | | Pulmonary findings confirm beneficial respiratory effects of smoking cessation and that slowing down of decline in FEV volume in 1 second appears to be relatively rapid in those who quit smoking
| | | | | Mean body weight gain significantly higher inC1thanG1by wk 2 (0.49 kg v. 0.99 kg) (P = 01)
| | | | | No significant difference in mean body weight gain at 1 yr (4.22 kg and 5.06 kg P = 0.14)
| | | | | Subjects in C1 reported significantly more intense withdrawal symptoms at wk 1 (P < 0.001) and craving symptoms at wk 6 (P = 0.04) than those in G1
| | | | | Adverse events rare and tolerable
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Proportion of smokers who quit at 6-month followup (validated): | Quality rating:
Canga et al., 2000 | Evaluate effectiveness of a nurse-managed smoking cessation intervention aimed at helping diabetic smokers quit smoking | - Type 1 and 2 diabetics at 2 hospitals and 15 primary care clinics randomized to receive either usual care or a nurse-led, face-to-face cessation counseling intervention; - All clinical records of Type 1 & 2 diabetics registered at 15 primary care clinics and 2 hospitals b/w Dec 1997 and Dec 1998 reviewed to confirm smoking status; - Smokers contacted through a letter and telephone call to participate in a general lifestyle study of diabetic patients; - Smokers randomly assigned to intervention or C using computer-generated allocation; randomized assignment blinded | - Self-help; - Individual counseling by health professional; - Pharmaceuticals | - Two-tailed Fisher's exact tests used to compare proportion of quitters b/w both groups; - Two-tailed t-tests used to compare change in average number of cigarettes smoked daily; - Incidence ratio, incidence difference, and number needed to treat w/ their respective 95% CIs used to estimate effect of intervention | G1: 17.0% | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | C1: 2.3% | Comments:
Western Europe | - Young adults; - Adults | G1: 147 | G1: Initial 40 min face-to-face interview w/ a research nurse that included personalized advice about benefits of quitting and strategies that may be useful, based on patient's clinical condition, smoking history, and personal interests; self-help materials w/ quitting cues; 3 months of transdermal NRT offered to those w/ no contraindications who smoked > 19 cigarettes per day and those who had not succeeded after trying to quit at least once; followup program of 5 contacts scheduled according to negotiated cessation date: 1) telephone call the day before quit date, 2) a followup visit 2 wks post quit date, 3) a letter 3 wks post quit date, 4) a followup visit 2 months post quit date, and 5) a final evaluation carried out 6 months post quit date | Urinary cotinine levels obtained from self-reported quitters and analyzed using method developed by Jarvis, et al | Difference: 14.7 (CI, 8.2, 21.3) | NR
Funding agency: | Study type: | C1: 133 | C1: Usual care for diabetic smokers that is routinely provided by hospital or primary care clinic and is established in the Navarre diabetes care program, including advice to quit smoking | Dependent variables: | P = < 0.001 | Adequate randomization:
NR | RCT w/ systematic randomization | Definition of smoking: | Method of assessment: | - Urinary cotinine validated cessation; - Mean number of cigarettes smoked daily; - Stage of change according to Prochaska's model | 6-mo followup, change in mean cigarettes per day: | Yes
Study setting: | Inclusion criteria: | Cigarettes | Followup interview conducted by a nurse at 6 months after initial interview; urinary cotinine levels obtained from those who self-reported quitting | Baseline data: | G1: -4.6 (CI, -3.2, -6.0) | Attrition rate:
Hospital | - Type 1 and 2 diabetic patients registered in centers under study who were either current smokers or who had quit < 1 yr ago | Current smoking: having smoked > 100 cigarettes during a subject's lifetime and having smoked at least 1 cigarette in last wk | | Intervention and Cs similar at baseline in demographic characteristics, diabetes history, and history of tobacco use | C1: -1.6 (CI, -0.4, -2.8) | Overall = 0.71%
Practice/provider settings | Exclusion criteria: | | | | Difference: -3.0 (CI, -1.1, -4.9) | G1: 0.68%
| - Had quit smoking for over 1 yr or was misclassified in medical record as a diabetic smoker | | | | P = < 0.001 | C1: 0.75%
| | | | | 6-mo followup, patients in precontemplation stage:
| | | | | G1: 39.5%
| | | | | C1: 56.4%
| | | | | Difference: -16.9%
| | | | | (CI, -5.3, -28.9)
| | | | | P = < 0.001
| | | | | 6-month followup, patients in contemplation stage:
| | | | | G1: 9.5%
| | | | | C1: 29.3%
| | | | | Difference: -19.8%
| | | | | (CI, -10.7, -34.1)
| | | | | P = < 0.001
| | | | | 6-mo followup, patients in action and maintence stages:
| | | | | G1: 17.0%
| | | | | C1: 2.3%
| | | | | Difference: 14.8%
| | | | | (CI, 8.2, 21.3)
| | | | | P = < 0.001
| | | | | 6-mo followup, patients in relapse stage:
| | | | | G1: 33.3%
| | | | | C1: 10.5%
| | | | | Difference = 22.8%
| | | | | (CI, 13.6, 32.0)
| | | | | P = < 0.001
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Percentage with “24-hour Quit Attempts” over 6 months | Quality rating:
Carpenter et al., 2004 | To assess whether a behavioral treatment to reduce smoking combined with NRT followed by brief advice to quit versus motivational advice plus brief advice to quit produces a greater incidence of quit attempts | Randomized | Telephone counseling | - Logistic regression | G1: 43% | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | G2: 51% | Comments:
USA | NR | G1: 212 | G1: Telephone based reduction counseling and NRT and brief advice to quit | Self report | C1: 16% | - Source of database used to recruit people for study is unclear; - No biochemical verification
Funding agency: | Study type: | G2: 197 | G2: Motivatiiona advide (5Rs) and brief advice | Dependent variables: | G1 vs G2: NS | Adequate randomization:
National Institute on Drug Abuse | RCT | C1: 207 | C1: No treatment | - # of cigarettes per day over previous 7 days; - Intention to quit in next 1 to 6 months; - Stage of change; - Self-efficacy; - Quit attempts within past 24 hours; - Point prevalence abstinence (no smoking at all in past 7 days) | G1 + G2 vs C1:P < 0.01 | NR
Study setting: | Inclusion criteria: | Definition of smoking: | Method of assessment: | | Percentage with “24-hour Quit Attempts” at 6 weeks (when intervention was completed) | Attrition rate:
Population-based | - Not Interested in quitting | Abstinence: greater than or equal to 3 cigarettes per day | Mailed questionnaire at 0,3,6,12 and 24 weeks | | G1: 36% | NR
| Exclusion criteria: | | Baseline data: | | G2: 18%
| - No current smoker in household (96%); - Smokes less than 10 cigarettes a day; - Less than 18 years of age; - Secondary Exclusion; - Nursing, pregnant, planning to become pregnant in next 9 months; - Cardiovascular disease or high blood pressure not controlled by medication; - Currently taking prescription medications for depression or asthma (79%); - Not accessible by telephone throughout duration of the study | | - Smoking habits; - Urine cotinine levels; - Fagerstrom Test for Nicotine dependence; - Stage of change; - Demographics; - Parity; - Proportion having a partner; - Proportion whose partner smoked; - Educational achievement; - Household net income | | C1: NR
| | | | | Percentage with “24-hour Quit Attempts” after 6 weeks (when intervention was completed)
| | | | | G1: 64%
| | | | | G2: 82%
| | | | | C1: NR%
| | | | | Abstinence Rates
| | | | | G1: 18%
| | | | | G2: 23%
| | | | | C1: 4%
| | | | | Seven-day Point Prevalence at 6 months:
| | | | | P<0.01
| | | | | Smoking reduction using NRT does not undermine cessation but rather increases likelihood of quitting to a degree similar to motivational advice
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Statistically significant changes at 8 wks in nurses' smoking practices found on number of nurses continuing to smoke, mean number of cigarettes smoked, and movement in stage of behavioral change | Quality rating:
Chalmers et al., 2001 | Smoking reduction and cessation program implemented w/ registered nurses | Advertised study in a variety of medium and participants allowed to select intervention type | - Self-help; - Group counseling | - SAS and Excel used; - Descriptive statistics obtained and t-tests used in pre and posttest analyses; - Variance difference considered across 4 time periods; - Duncan's Multiple Range test implemented for all post hoc comparisons; - Time-study analysis techniques used to organize data and observe and test for trends | | Poor
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | | Comments:
Canada | - Adults; - Women (only) | G1: 75 | G1: Group participation | None | | No ITT, self-selection of intervention, no comparisons b/w groups.
Funding agency: | Study type: | G2: 44 | G2: Self-study | Dependent variables: | | Adequate randomization:
Health Canada, Tobacco Programs Unit, Health Promotion Directorate and the Canadian Lung Association | Self-selected intervention | Definition of smoking: | G3: NR | Stage of quiting | | No
Study setting: | Inclusion criteria: | Cigarettes | C1: NR | Baseline data: | | Not randomised!
Practice/provider settings | - RN | NR | Method of assessment: | No comparisons made | | Attrition rate:
| Exclusion criteria: | | Questionnaires administered prior to and at end of 8-wk interventions and at 6 and 12 months postintervention | | | Pretest: 0 (0%)
| - No other type of nurses | | | | | 8 wks: 27 (23%)
| | | | | | 6 months: 47 (40%)
| | | | | | 12 months: 62(53%)
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | No statistically significant differences in smoking status found at 1-mo (13 vs 7%, P = 0.248) or 1-yr followup (5 vs 10%, P = 0.166, OR = 0.4, 95% CI, 0.1–1.4) | Quality rating:
Clark et al; 2004 | To examine effectiveness of standard written self-help materials for nicotine dependence compared to written materials consisting of internet-based resources on smoking abstinence rates in a lung cancer screening population | Community informed about low-dose fast spiral chest CT screening study by local and regional television and newspaper coverage carrying information on general outline of study and eligibility requirements, as well as funding by NCI | - Self-help; - Computer-based program | Responses from 1-mo followup survey, and tobacco use variables collected at 1-yr followup, compared b/w txt groups using X^2^ | At yr 1 followup more subjects receiving internet-based resources, compared to C1, reported that they had made an attempt to stop smoking in last yr (68 vs 48%, P = 0.011) | Fair
Geographic area: | Population: | Sample size: | Intervention: | For 1-yr smoking abstinence outcome, subjects that missed the visit or failed to provide tobacco use information, classified as smoking | Recommendation of additional followup from chest CT screening exam not found to be associated w/ abstinence (OR = 0.5, P = 0.267), making a quit attempt (OR = 0.8, P = 0.412) or advancement in state of change from baseline to 1-yr (OR = 0.6, P = 0.222) | Comments:
US | - Adults | Total: 171 | G1: Received handout w/ a list of 10 Internet sites related to stopping smoking and a brief description of each site; Web sites included: the American Heart Association, ACS, NCI, Cancer Information Service, CDC Tips, Tobacco Information/Prevention Source, Mayo Clinic Nicotine Dependence Center, Quit Now! (the National Tobacco Campaign), the No Smoke Caf, Massachusetts Quitline, Nicotine Anonymous, and the American Lung Association; these sites include information on health risks related to tobacco use, benefits of stopping smoking, specific behavioral strategies, support for stopping, review of stop smoking medications, and references to local resource | All other analyses performed using available data w/ no imputation of missing values | | NR
Funding agency: | Study type: | Definition of smoking: | C1: Received a copy of Clearing the Air: How to Quit Smoking and Quit for Keeps (24-pg self-help manual describing multiple behavioral strategies for stopping smoking), a publication of the National Cancer Institute; participants also given the American Lung Association booklet, Quit Smoking Action Plan, which provides up to date information on available pharmacotherapies for nicotine dependence | For biochemically confirmed 7-day smoking abstinence, exact binary confidence intervals calculated for each txt group and a logistic regression analysis performed using smoking abstinence as dependent variable and txt group as independent variable | | Adequate randomization:
NCI | RCT w/ simple randomization | Cigarettes; - Abstinence: no cigarettes in last 7 days | Method of assessment: | Logistic regression used to assess whether screening recommendations associated w/ 1-yr tobacco use outcomes | | Yes
Study setting: | Inclusion criteria: | | Questionnaire at 1-mo followup: | In all cases, two-sided tests performed w/ P-values; < 0.05 used to indicate statistical significance | | Attrition rate:
Hospital | - Asymptomatic; - Men and women 50 yrs of age or older; - Current cigarette smokers w/ at least a 20 pack-yr history of smoking; - Access to a computer w/ Internet service; - Written informed consent to participate | | - Smoking status self-reported In-person visit at 1 yr followup:; - Smoking status and expired air CO levels assessed | Data verification: | | No attrition at 1-yr followup (study followup coincided w/ 1-yr followup for lung cancer screening)
Practice/provider settings | Exclusion criteria: | | | Self-reported smoking status confirmed w/ expired air CO levels at 1 yr followup
| - History of any cancer within five yrs, other than non-melanomatous skin cancer, cervical cancer in situ, or localized prostate cancer; - Mentally incompetent; - Not healthy enough to potentially undergo pulmonary resection (i.e., have congestive heart failure or disabling dyspnea at time of enrollment); - Serious illness that decreased life expectancy to less than 5 yrs | | | Dependent variables:
| | | | Biochemically-confirmed smoking status
| | | | Baseline data:
| | | | Both groups similar at baseline
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | At the end of treatment, abstience rates were 28.8% for C1 and 33.8% for G1, this was not significant | Quality rating:
Covey et al., 2002 | To evaluate sertraline as an effective aid to smoking cessation for smokers with a history of major depression | - Respondents were first screened by telephone, those who met initial criteria were seen at the first clinical visit; - Eligible participants obtained a 1 week single-blind washout phase of one placebo tablet per day; - Once medically confirmed to meet criteria, participants were randomly assigned in a double blind fashion to receive sertraline (50mg tablet) or placebo | Pharmacotherapy | Chi square and t-tests of significants | At 6 months, the abstience rates were G1=11.8 and C1=16.7%, NS | Poor
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | No modifying effects of depressed mood at baseline, nicotine dependence level, or gender were observed | Comments:
US | Adults | G1: 68 | G1: Received sertraline for 11.3 weeks: 1 week placebo washout, 3 weeks for medication buildup before quit day, 6 weeks at full dose (200mg), and a 9 day taper period. | Self-report and cotinine tested | | Similar to a run-in periods this study participants if not motivated to quit after week 1 (9%)
Funding agency: | Study type: | C1: 66 | C1: Same as G1 but used placebo | Dependent variables: | | Adequate randomization:
Pfizer, Inc | RCT, double blind, placebo control study | Definition of smoking: | Method of assessment: | - Abstience; - Nicotine dependence level; - Depression; - Withdrawal symptoms; - Compliance with NRT treatment | | Yes
Study setting: | Inclusion criteria: | - Smoking measured by cotinine level, non-smokers < 25 ng/ml | 7-Day point prevelance self-report (biochemically verified by cotinine levels less than 25 ng/ml) | | | Attrition rate:
Population-based | - Subjects required to meet DSM-III-R criteria for at least one episode of major depression, which must have remitted more than 6 months befor the start of the study; - Age 18 to 70; - Daily use of 20 or more cigarettes for at least a year; - One prior attempt to quit | | Baseline data: | | | 25.40%
| Exclusion criteria: | | Lower nicotine dependence scores for participants in G1; no other baseline differences
| - Serious medical illnesses; - Use of a psychotropic medication; - Major depression, alcohol or drug dependence, panic disorders, post-tramatic stress disorder, anorexia nervosa, or bulimia nervosa within the past 6 months; - Life time diagnosis of bipolar disorder, antisocial or schizotypal personality disorder, severe borderline personality disorder, obsessive-compulsive disorder, or psychosis including schizophrenia; - Pregnancy or lactation
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | CO confirmed 7-day point-prevalence smoking abstinence rates at 6-wks after initial quit date: | Quality rating:
Croghan et al; 2003 | To determine whether combined use of NP and a NNS would improve smoking abstinence rates compared to either therapy alone without behavioral counseling; to determine frequency and severity of adverse events experience | After dissemination of a local news release (radio and print), interested smokers contacted their regional NCCTG cancer control site and underwent telephone screening | Pharmaceuticals | Tests of balance in baseline characteristics across txt arms carried out via X^2^ procedures for categorical variables, Kruskal-Wallis tests for ordinal-level data, and ANOVA for interval- and continuous-level variables; effect of sociodemographic variables on abstinence rate comparison investigated via logistic regression modeling | G1: 20.7% | Poor
Geographic area: | Population: | Brief discussion of study provided, informed consent obtained, demographic information collected, and an interview based on inclusion and exclusion criteria conducted over phone | Intervention: | Standard equality of binomial proportions, logistic regression modeling | G2: 13.6% | Comments:
US | Adults | Study subjects who fulfilled basic study entry criteria were invited to attend an information meeting, at which time details of study were explained and an informed consent signed | G1: 15 mg transdermal NPfor 16 hr a day; new patch each morning; initiated within 7 days of randomization and continued for 6 wks | Data verification: | G3: 27.1% | Attrition quite high at 6 mos (70%); overall, 45% of participants non-compliant w/ study protocols - a larger proportion than were compliant (34%); study may not have had enough power
Funding agency: | Study type: | Sample size: | G2: NNS that delivered 0.5 mg of nicotine per spray; recommended dose one puff per nostril as needed to a maximum of five doses per hr or 40 doses per day; initiated within 7 days of randomization and continued for 6 wks | CO levels of expired air collected to verify self-reported smoking status Expired CO < 8 ppm confirmed smoking abstinence | P = < 0.001 | Baseline data not given by txt group
NCI, Public Health Service and NCI, DHHS | RCT w/ stratified randomization; - Multi-center, randomized, open-label clinical trial; - Txt assignment carried out using a dynamic allocation procedure that balanced marginal distributions of stratification factors among three txt groups; - Stratification factors used gender, number of cigarettes smoked per day reported at time of study entry (15–39 vs 40 or more cigarettes per day), and total yrs of smoking (fewer than 5 yrs vs 5–9 yrs vs 10 or more yrs); - Open-label, randomized, 3-intervention, multi-center trial. | Total: 1,384 | G3: 15 mg transdermal NPfor 16 hr a day, putting on a new patch each morning, plus nicotine nasal spray that delivered 0.5 mg of nicotine per spray, recommended dose of one puff per nostril as needed to a maximum of five doses per hr or 40 doses per day; initiated within 7 days of randomization and continued for 6 wks | Dependent variables: | Differences in CO confirmed 7-day point-prevalence smoking abstinence rates at 6 mos were NS | Adequate randomization:
Medications provided by NcNeil Consumer Products | Inclusion criteria: | Definition of smoking: | C1: NR | Smoking status: wk 6 biochemically confirmed 7-day point prevalence smoking abstinence rate. | Abstinence rates (6 wks): | Yes
Study setting: | - 18 yrs of age or older; - Smoking at least 15 cigarettes per day for past yr; - Good health verified by medical history; - Female subjects of childbearing potential had to be using contraception,; - Ability to participate in all aspects of study | Cigarettes; - At least 15 per day over past yr NR | Method of assessment: | Baseline data: | G1: 20.7% | Attrition rate:
| Exclusion criteria: | | Subjects returned to clinic at 3 wks, 6 wks, and 6 mos postintervention; self-reported smoking rates, expired air CO levels, and reports of adverse events collected Questionnaire about smoking history, Fagerstrom, Health Status Questionnaire | No reported differences among txt groups, but no data given | G2: 13.6% | 6 wks: 47%
Community-based | Exclusion criteria included; - Recent (< 3 mos) history of myocardial infarctionangina pectoris, serious cardiac arrhythmia, or other medical conditions that the health care provider deemed incompatible w/ study participation; - Presence of current (within 30 days) psychiatric disorders (major depression, bipolar disorder, schizophrenia); current use of major psychiatric drugs(antipsychotics, lithium); - Chronic nasal disorders such as nasal polyps, chronic nasal congestion, allergies, or sinusitis that would preclude use of a nasal spray; - Pregnancy or current breast feeding; - Current use of tobacco products other than cigarettes; - Current use of nicotine replacement therapy; - Use of an investigational drug within 30 days of start of study; - Concomitant use of clonidine, buspirone, doxepin, bupropion, or fluoxetine; - History of skin allergies or evidence of chronic dermatosis; - Participation within last 12 mos in a formal smoking cessation program | | | Overall, mean age = 42.0 (+/-10.8); 58% female; mean 26.2 (+/-9.8) cigarettes per day; mean 23.2 (+/-10.7) yrs of smoking | G3: 27.1% | 6 mos: 70%
Practice/provider settings | | | | | P < 0.001
| | | | | NNS associated w/ more adverse events than NP (P < 0.001): burning in nose or throat (63% vs 12%), watery eyes (48% vs 14%), sneezing (49% vs 21%)
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Twelve months after pretest (posttest 2), in-school intervention successful in preventing vocational school students from continuing to smoke, compared w/ students in control condition OR = 0.49; 95% CI 0.29–0.84 | Quality rating:
Dalsgareth et al., 2004 | To evaluate treatment with buproprion hydrochloride sustained release (Zyban) compared with placebo as an aid to smoking cessation in healthcare workers | - Employees were informed of study via E-mail, notification accompanying paychecks, posters and personal contact; - Eligible participants screened; - Participants underwent detailed baseline interview to obtain health-disease profile and info on smoking behavior in general and at work; - Subjects were given info on physiological and harmful effects of smoking as well as on the assumed mechanism of action and likely side-effects of buproprion; - All subjects received behavioral counseling aimed at establishing rational smoking cessation process; - Each participant agreed on a target quit date of 8–13 days after baseline; - Participants then randomly assigned either to receive buproprion 150 mg or placebo | - Telephone counseling; - Clinic visits; - Buprprion 150 mg over 7-week period | - Intent -to-treat analysis, in which all randomized patients who took ≥1 dose of study medication were counted; - Mantel-Haenszel chi-square test at two-sided 5% level of significance used analysis of smoking abstinence endpoints; - Analysis of covariance was used for analysis of change in weight from baseline and nicotine dependence; treatment, center and baseline values were covariates; - Participants with missing cigarette counts after 7-week treatment phase assumed to be treatment failures | Eighteen months after pretest (posttest 3), tailored out-of-school intervention successful in preventing smoking initiation, compared w/ students in control (OR = 0.42; 95% CI, 0.18–0.96) | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | Effect of combined approach not larger than sum of effects of in-school and out-of-school effects. | Comments:
Denmark | Hospital employees from 5 hospitals in eastern part Denmark | G1: 222 | G1: 2 motivating phone calls, 5 clinic visits, and sustained-release bupropion hydrochloride | - Self-report - completion of daily diary cards; - Expired-air carbon monoxide measurements (<10 ppm CO was the cutoff) | | - Refusal rate NR; - Randomization description unclear regarding number of schools in txt groups; - Out-of-school intervention poorly implemented (65% of personalized letters read by participants)
Funding agency: | Study type: | C1: 114 | C1: 2 motivating phone calls, 5 clinic visits, and placebo | Dependent variables: | | Adequate randomization:
GlaxoSmithKline, Denmark | RCT - double-blinded | Definition of smoking: | Method of assessment: | - Smoking status; - Tobacco craving; - Weight gain | | Yes
Study setting: | Inclusion criteria: | Cigarettes; - User: smoked ≥10 cigarettes daily; - Continuous smoking abstinence: not even a puff | Clinic visits at weeks 3,7,12,23 and 26 (post-baseline) | | | Attrition rate:
Hospital | - Age ≥18 yrs old; - Average use of ≥10 cigarettes per day throughout the last year; - Motivation to quit smoking | | Baseline data: | | | School level; - Posttest 1: 5.6% (2 schools); - Posttest 2: 8.3% (3 schools); - Posttest 3: 18.5% (NR)
| Exclusion criteria: | | No significant differences b/w G1 and C1 | | | Student level:; - Posttest 1: 17.3%; - Posttest 2: 5.4%; - Posttest 3: 24.6%
| - Use of other pharmacological support for smoking cessation; - History of or current major depression reported by participant; - Sever neurological, cardiopulmonary, liver or kidney disease; - Epilepsy, predisposition to or former epidsodes of seizures; - Use of medicine known to lower seizure threshold; - Pregnancy and lack of sufficient contraception were additional exclusion criteria for fertile women.
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Intervention patients more likely to advance in stage than control patients | Quality rating:
Davies et al., 2005 | To evaluate the impact of a stage-matched smoking cessation intervention in a sample of hospitalized, low-income, African American smokers admitted to an indigent care hospital | 90 % of patients approached agreed to participate | - Self-help; - individual counseling | - Mann-Whitney U used to examine intervention effects by baseline stage; - Z Test used to compare overall differences between treatment groups (forward movement, success in quitting smoking); - T tests used for 5 measures (Pros, Cons, Confidence, 2 Nicotine Dependent measures); - Intention to treat analysis used only for cessation rates | Dependence score increased as stage of readiness increased | Poor
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | Intervention had a higher proportion of subjects in the preparation and action stages at follow-up, significantly(P < 0.05) for those at contemplation stage at baseline | Comments:
Southeastern US | - Low income hospitalized adult African Americans | 248 | G1: Physician-delivered stage-specific advice to quit smoking; individualized counseling based on the smokers stage of readiness and individual smoking pattern; self-help materials tailored to the African American smokers and their support networks; and a follow-up booster session in the form of a phone call following the patient's discharge from the hospital (at @6 months) | Self report | Greater percentage of intervention than controls progressed at least one stage (40% vs 21.7%, P < 0.01) | - 60% failed to complete 6 month follow-up; - ITT analysis used for cessation rates does not state that all of those with no follow-up data were categorized as smokers
Funding agency: | Study type: | Definition of smoking: | C1: usual care (not defined) | Dependent variables: | ITT analysis for cessation non-significant (G1:7.9% vs C1: 5.8%) | Adequate randomization:
National Cancer Institute | Experimental, pretest-posttest design | NR | Method of assessment: | - Sociodemographic characteristics; - Smoking history; - Present smoking habit; - Stage of change; - Decisional balance; - Self-efficacy to remain abstinent; - Perceived nicotine dependence; - Perceived health status; - Presence of chronic disease | | Not defined, plus there was a second adjustment made by assigning shared rooms to either the intervention or control groups
Study setting: | Inclusion criteria: | | In person and telephone survey at about 6 months | | | Attrition rate:
Hospital | - Adult; - African American; - Admitted to medical and surgery units of the study hospital; - Smoker | | Baseline data: | | | - 152 of 248 were loss to follow-up; - Reasons:; - no telephone,; - telephones disconnected,; - changed residence,; - became homeless,; - went to prison; - died; - Several follow-up interviews took place well after 6 months
| Exclusion criteria: | | Between group differences are not reported
| - Life expectancy less than one year; - Mental conditions (not defined)
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | At 1 year follow-up quit rates for low dependence were | Quality rating:
Garvey et al., 2000 | To investigate the long-term efficacy of 4-mg and 2-mg gum for smokers classified at baseline as low or high in dependence on nicotine | - Recruited smokers from greater Boston area via newspaper ads and press releases; - Subjects needed to obtain a letter from their doctor stating they had no obvious medical conditions that would prevent them from entering the study; those who didn't have primary care physician required to undergo testing at medical lab in Boston; - Subjects chose a quit-day and reported for their baseline visits a median of 3 days before their quit days - at baseline, they completed the Heaviness of Smoking Index and a 2-question subset of the Fagerstrom Test for Nicotine Dependence. Results were used to classify subjects as either low-dependence or high-dependence; - Subjects within each dependence group were assigned to placebo, 2-mg, or 4-mg gum treatment using a randomized, double-blind procedure; - Subjects were instructed on proper use of gum, recommended to use 9–15 pieces of gum a day for 2 months, after which they would wean themselves from the gum - would be weaned off by 5 months post-cessation | - Self help booklet (all groups); - Brief behavioral counseling (all groups); - Nicotine gum - 2mg or 4mg | - Wilcoxon rank sum tests were used to compare percentage baseline cotinine replaced by each dose of nicotine gum; - Logistic regression analysis and pairwise dose comparisons were used to assess differences in abstinence rates among groups at each post-cessation visit. Two dummy variables (each coded 1 or 0) were used to represent the 3 nicotine-gum doses in these analyses; - Chi-square tests for binomial trends were used to examine the significance of dosage effects; - Effects of nicotine gum dose on withdrawal symptoms and urges to smoke were assessed for the 1st 30 days post-cessation using repeated-measures analysis of variance; - For withdrawal indices, changes from baseline on various indices of withdrawal were dependent variables in repeated-measures analysis; while values obtained at 1,7,14,and 30 were used to supplement repeated-measures analysis; - Because of occasional missing data, number of subjects available for some statistical analyses were reduced) | Placebo 11.2% | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | 2 mg gum 19.5% | Comments:
United States | - Smokers from greater Boston area; - ≥20 years old | G1: 87 | G1: Low dependence 2 mg gum | Self-report, saliva cotinine and CO levels | 4 mg gum 18.4% (NS) | - 3 subjects withdrew from study due to adverse effects - dizziness, nausea and vomiting
Funding agency: | Study type: | G2: 88 | G2: Low dependence 4 mg gum | Dependent variables: | High dependence smokers quit rates at 1 year | Adequate randomization:
National Institute on Drug Abuse and the Department of Veteran Affairs | RCT | G3: 115 | G3: High dependence 2 mg gum | Quit rates | 2 mg gum compared to placebo (15.7% vs. 6.1%, P = 0.02) | Yes
Study setting: | Inclusion criteria: | G4: 115 | G4: High dependence 4 mg gum | | 4 mg gum compared to placebo (20.7% vs. 6.1% P = 0.002) | Attrition rate:
Community-based | - Aged ≥20 years, smoke ≥5 cigarettes per day; - Adequate health | C1: 88 | C1: Low dependence placebo | | No statistical differences between 2 and 4 mg gum doses. Both 2 and 4 mg gum users significantly (P < 0.008) more likely to abstain than placebo at all post-cessation assessments, except for day 1 | Overall attrition not reported but 3 left due to adverse events
| Exclusion criteria: | C2: 115 | C2: High dependence placebo | | Other variables related to abstinence at 1 year post-cessation were a longer period of abstinence on a prior quit attempt, being married, higher education level, and having a non-smoking spouse or significant other
| - Cardiologist deemed subjects in “inadequate” health based on medical tests, including hematology analyses, liver-function profiles, urinalyses and if over 50 years old, electrocardiograms | Definition of smoking: | Method of assessment:
| | Cigarettes; - Current Smoker - Smoking ≥5 cigaretters per day; - Relapser - if returned to a regular pattern of smoking at any time during the 1-year period of follow up; - Regular pattern of smoking - 7 or more consecutive days or episodes of smoking; - Day of relapse - the day post-cessation that began the regular pattern of smoking | Follow up visits at 1, 7, 14, 30 days and 2, 3, 6, 9, and 12 months post-cessation
| | | Baseline data:
| | | Placebo, 2-mg and 4-mg gum users were comparable on most baseline variables - those in 4-mg group had higher mean CO values (P= 0.01) and heart rates(P = 0.02)
| | | High-dependence smokers were more likely to be older and less-educated, slightly more likely to be males, and they had significantly larger values on other indices of depencence
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Percentage of participants w/ self-reported 7-day point prevalence abstinence at 3-month followup: | Quality rating:
Hahn et al; 2004 | To evaluate impact of a quit and win contest on smoking cessation among low-income tobacco users | Intervention group: sample of volunteer registrants in a quit-and-win contest | - Self-help; - Individual counseling by health professional; - Group counseling; - Telephone counseling; - Computer-based Program; - Social support; - Media campaign | Group comparisons performed using X^2^ of equal proportions for nominal variables Kruskal- Wallis tests for ordinal variables, or two-sample t-tests for continuous variables | G1: 23.3, | Poor
Geographic area: | Population: | C1: participants randomly selected from outside media campaign geographic area using random digit dialing and meeting inclusion criteria | Intervention: | Repeated measures analysis for logistic regression based on GEE approach used to determine predictors of quit status over three postcontest time periods | C1: 3.1 | Comments:
US | - Adults; - Low SES | Sample size: | G1: A community quit date requiring participants to quit using tobacco for 30 days to be eligible for a large cash prize lottery; provider advice on gender-specific cessation information to participants through weekly mailed postcards during 30-day contest period; online computer registration and quit assistance; one-on-one telephone quit assistance through a toll-free number provided by Cancer Information Service's smoking cessation call center; a media campaign that included paid radio and television advertisements, intensive billboard promotions, magazine or newspaper registration, newspaper features, registration brochures, and promotional flyers; and support from community organizations, work sites, physicians, health professionals, and community leaders | Each model included control variables of baseline age, gender, race (Caucasian v. other), education (<HS v. >HS), marital status (married v. unmarried), and stage of change status to adjust for differences in personal characteristics among participants | P = < 0.001 | - High attrition; - Intervention group volunteer sample; - C care NR; - Exposure to intervention low; - Not generalizable
Funding agency: | Study type: | Total: 538 | Community organization support included promoting the contest at work sites and in community newsletters, recruiting participants via flyers at physician offices and health fairs, and coordinating group cessation classes to coincide w/ the contest. | Data verification: | Percentage of participants w/ confirmed 7-day point prevalence abstinence at 3-month followup: | Adequate randomization:
American Legacy Foundation | Two-group, quasi-experimental study | Definition of smoking: | C1: NR | All participants who reported quitting were asked to provide a urine sample to test for cotinine; cotinine level determined by Accutest NicoMeter | G1: 11.3 | NR
Study setting: | Inclusion criteria: | Cigarettes; - Quitter: not used any form of tobacco in last 7 days | Method of assessment: | Dependent variables: | C1: 0.7 | Attrition rate:
Community-based | Intervention group:; - at least 18 yrs old; - volunteered to participate in a quit-and-win contest; - registered for contest by September 10, 2001; - earned <$ 25,000 per yr | Smokless tobacco; - Quitter: not used any form of tobacco in last 7 days | Telephone interviews conducted at baseline, then 3, 6, and 12 months after baseline interview | Tobacco use status | P = < 0.001 | Loss to followup by 12-month followup:
| C1: | | | Baseline data: | Percentage of participants w/ self-reported 7-day point prevalence abstinence at 6-month followup: | G1: 41%
| - regular tobacco user who had smoked cigarettes or used another form of tobacco in last 30 days; - had not been exposed to promotional media campaign; - earned <$ 25,000 per yr | | | Participants more likely to be married in the intervention group than in the control | G1: 21.2 | C1: 44%
| Exclusion criteria: | | | More than half of intervention group had at least some college education, while only 1/4 of C had any postsecondary education; intervention group significantly younger than control (Median age: G1: 35.9, C1: 42.3, t = 5.3, 535 df, P = < 0.0001); those lost to followup at 1 yr were significantly younger than those who remained in study (loss to followup: mean age = 37.5, remained in study: mean age = 41.2, t = 3.0, P = 0.003) | C1: 5.9
| NR | | | | P = < 0.001
| | | | | Percentage of participants w/ confirmed 7-day point prevalence abstinence at 6-month followup:
| | | | | G1: 9.3
| | | | | C1: 0.7
| | | | | P = < 0.001
| | | | | Percentage of participants w/ self-reported 7-day point prevalence abstinence at 12-month followup:
| | | | | G1: 23.3
| | | | | C1: 8.7
| | | | | P = < 0.001
| | | | | Percentage of participants w/ confirmed 7-day point prevalence abstinence at 12-month followup:
| | | | | G1: 8.1
| | | | | C1: 0.7
| | | | | P = < 0.001
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | A duration by dose by time of assessment effect was significant (X^2^ = 11.90, df=3, P = 0.008) | Quality rating:
Hall et al., 2004 | To determine the effects of brief versus extended treatment with nortriptyline and group counseling | - Subjects were recruited through advertising, PSAs, and flyers; - Interested persons completed a telephone screening and orientation meeting; - After informed consent was obtained, potential subjects were invited to a baseline physical assessment; - For those who did not have any exclusion criteria, 160 subjects smoking ≥ 10 cigarettes per day were stratified by:; - baseline number of cigarettes; - history of nicotine replacement therapy; - history of major depressive disorder; - Subjects were then randomized to four treatment cells | - Transdermal nicotine patch; - Group counseling; - Bupropion | - Powered at 80% with alpha = .05; - Logistic regression was used to test the effect of drug/placebo dose and treatment duration on repeat 7-day abstinence; - Generalized estimating equation was used to test hypotheses about point prevalence abstinence at weeks 24,36,52; - Compared baseline variables among the four groups using ANOVA for continuous and chi-square for categorical to examine if randomization had been compromised; - To identify potential covariates, used point-biserial correlations; - Differences in weeks of medication / placebo dispensed were determined by a two-way ANOVA with individual comparisons with the Tukey test; - Differences in withdrawal symptoms were determined using repeated measures ANOVA; - Chi-square tests or Fisher's exact tests were used to determine differences in side effects; - All tests for all analyses were two-tailed | Brief Nortriptyline vs brief placebo (OR = 0.69, 96%CI; 0.49–0.92, P = 0.02) | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | Brief Nortriptyline vs extended placebo (OR = 0.47, 95%CI; 0.30–0.75, P = 0.001) | Comments:
United States | General public | 160 subjects | G1: Brief Nortriptyline: Nortriptyline for 12 weeks; 5 counseling sessions and NRT patch at week 5 | - Expired carbon monoxide and urinary cotinine were used at 24, 36, and 52 week follow-ups; - Expired carbon monoxide only was used at 12 week follow-up | Extended Nortriptyline did not differ significantly from extended placebo | NR
Funding agency: | Study type: | Definition of smoking: | C1: Brief placebo: Placebo for 12 weeks; 5 counseling sessions and NRT at week 5 | Dependent variables: | | Adequate randomization:
NIDA | RCT | Subject must meet all three criteria to be considered abstinent: | G2: Extended Nortriptyline: G1 + extended pharmacotherapy and counseling (1/month) for 52 weeks | - Abstinence; - Nortriptyline adherence; - Withdrawal symptoms; - Side effects | | Unknown - did not state how they randomized participants
Study setting: | Inclusion criteria: | - self-report of not having had a cigarette in past seven days, not even a puff; - carbon monoxide levels ≤ 10 ppm; - cotinine levels of ≤ 50 ng/ml | C2: Extended placebo: G2 but used placebo instead of Nortriptyline | | | Attrition rate:
Population-based | Smoked >=10 cigarettes per day | | Method of assessment: | | | - 13% for brief nortriptyline; - 7% for brief placebo; - 10% for extended nortriptyline; - 27% for extended placebo
| Exclusion criteria: | | - In-person self-report; - Carbon monoxide; - Urinary cotinine
| - Cardiovascular disease; - History of seizure; - Severe allergies; - Life-threatening disease; - Bipolar disorder; - Current major depressive disorder; - Use of l-dopa; - Migraine headaches; - Current use of any psychiatric medication including bupropion; - Suicidal or psychotic symptoms; - Current use of NRT; - Previous treatment for cigarettes smoking with nortriptyline; - Treatment for drugs or alcohol within 6 months; - Psychiatric hospitalization within 1 year; - Pregnancy or lactation | | Baseline data:
| | | No significant differences among the intervention conditions
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | At week 1, abstinence rates were higher for G1 compared with C1 (54% vs 33%, P < 0.001) | Quality rating:
Hand et al., 2002 | To investigate the effectiveness of combined NRT (Patch and inhaler) for smoking cessation in patients hospitalized for smoking related disease. | - Recruitment began on October 1, 1998 and all patients recruited during this month and in any even month over the next 13 months were given NRT; - Those patients recruited in the following month and in any odd month over the next 12 months were given advice and support; - One extra month of patients were randomized to the NRT group resulting in unequal groups | Pharmacotherapy | Chi square test of significants | At 6 months this significant difference disappeared between the two groups. | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | At year 1, 14% of the total sample were verified as abstinent (G1=15%, C1=14%, NS) | Comments:
UK | Adults | G1: 136 (NRT and advise and support) | G1: Received NRT (combination of nicotine patch and inhalator) for 3 weeks; dosage determined by number of cigarettes smoked; plus G2 | Carbon monoxide verified | 30% of G1 used the full supply of NRT and 43.9% of these patients successfully quit at year 1 | NA
Funding agency: | Study type: | C1: 109 (advice and support) | C1: Four weekly sessions and patient encouraged to set quit date (45 to 60 minutes); followed by 3 weekly 15–30 minute sessions | Dependent variables: | | Adequate randomization:
Author's endowment fund | RCT | Definition of smoking: | Method of assessment: | - Smoking status; - Compliance with NRT treatment | | No
Study setting: | Inclusion criteria: | Abstinence; - Carbon monoxide levels less than 10ppm | Carbon monoxide validated Self-report at 1 week, 3, 6 and 12 months | | | Attrition rate:
Hospital-based | - Hospitalized inpatients or outpatients with smoking related disease referred to counselor by hospital doctor; - Age 18 or older | | Baseline data: | | | 0%
| Exclusion criteria: | | No baseline differences
| - Patients with alcoholism, drug dependeny, active psychiatric illness, preterminal or terminal patients, pregnant women, and patients who suffered a myocardial infarction during previous month
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Additional support (i.e., being referred to the quitline by a health professional) was associated with abstience and persisted with the exclusion of patients with severe smoking related symptoms | Quality rating:
Helgason et al., 2004 | To assess variables related to 12-months abstience using proactive compared to reactive telephone quitline smoking interventions | Immediately after the first call all patients expressing an interest in beign registered as clients received a registration from by mail confirming their idenity | Telephone quitline | Logistic regression was used to calculate Odds Ratios | Overall abstience was not significantly higher in the proactive compared with the reactive group (33% vs 28%, NS) | Poor
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | When men and women are assessed separately, women were signifcantly more likely to be abstinent in the procative compared with the reactive group (34% vs 27%, P.03) | Comments:
Sweden | Adults | G1: 694 (reactive quitline) | G1: Tailored materials to the patients motivation to quit (stage of change) is offered free of charge; treatment protocal is described as a combination of motivational interviewing, cognitive behavioral therapy, and pharmacological counseling | Self-report | | NA
Funding agency: | Study type: | G2: 900 (proactive quitline) | G2: same as G1 with 4 to 5 proactive counseling calls | Dependent variables: | | Adequate randomization:
NR | Cohort study | Definition of smoking: | Method of assessment: | - Smoking status; - Stage of change; - NRT use; - Exposure to second hand smoke; - Treatment compliance; - Periods of depressive moods; - Use of additional support | | NA
Study setting: | Inclusion criteria: | Abstience; - Not a single puff of smoke during the last week | Self-report at 12 to 13 months after first contact | | | Attrition rate:
Population-based | Contacted toll-free Swedish quitline from April to October 1999 | | Baseline data: | | | 30%
| Exclusion criteria: | | NR
| NR
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | | Quality rating:
Hennrikus et al., 2005 | Evaluation of effectiveness of three smoking cessation interventions for a hospital-based population | Research assistant obtained list of all general admissions from previous day at four hospitals and screened patients meeting age and admission dz requirements for smoking status and other eligibility requirements | - Self-help; - Individual counseling by health professional; - Telephone counseling; - Referral to community resources, clinician reminder | Using SAS statistical package, multivariate logistic regression conducted to examine the outcome variable "abstinence from tobacco use; " Mantel-Haenszel test for homogeneity of effects performed for each outcome to determine whether results from 4 hospitals could be pooled; X^2^ analyses of relationships b/w txt condition and outcomes also performed | Percentage of those self-reporting abstinence at 7-day followup: | Fair
Geographic area: | Population: | Research assistants approached patients for informed consent and asked consenting patients to complete a baseline interview; participants then randomized by research assistant by looking up next available group assignment on a list on which 3 conditions were randomly ordered within blocks of 30 assignments | Intervention: | Data verification: | C1: 26.0% | Comments:
US | Adults | Sample size: | G1: Participants given 2 smoking cessation manuals designed for hospital in-patients, a directory of smoking cessation community resources, a label in medical record to cue doctors and nurses to provide brief (60 second) smoking cessation advice and document that advice, and a letter after discharge reiterating that their health care providers would like for them to quit and to encourage them to read manuals provided | Salivary cotinine levels assessed for those who reported abstinence at 12-mo followup | G1: 24.0% | NR
Funding agency: | Study type: | G1: 703 | G2: Participants given 2 smoking cessation manuals designed for hospital in-patients, a directory of smoking cessation community resources, a label in medical record to cue doctors and nurses to provide brief (60 second) smoking cessation advice and document that advice, a letter after discharge reiterating that their health care providers would like for them to quit and to encourage them to read manuals provided, a more extended bedside counseling session in the hospital, and three to six telephone calls from a research nurse during 6 mos after discharge | Dependent variables: | G2: 25.2% | Adequate randomization:
NIH | RCT w/ systematic randomization | G2: 696 | C1: Participants received 2 smoking cessation manuals tailored for hospital in-patients and a directory of smoking cessation community resources | Abstinence; use of NRT | P = > 0.05 | Yes
Study setting: | Inclusion criteria: | C1: 696 | Method of assessment: | Baseline data: | Percentage of those self-reporting abstinence at 12-mo followup: | Attrition rate:
Hospital | - Patient smoked a cigarette in wk before admission and considered themselves a regular smoker for at least 1 mo during yr before admission; - Between 18 and 75 yrs old; - Length of hospital stay of 24 hrs or greater; - Ability to understand consent process; - Availability for telephone contact | Definition of smoking: | Followup interviews 7–18 days and 12 mos post discharge; for those who reported abstinence at 12 mo followup, salivary cotinine levels assessed | Groups similar at baseline | C1: 15.0% | - 7-day followup: 13.5%; - 12-mo followup: 24.1%
| Exclusion criteria: | Cigarettes; - Regular smoker: smoked more than 100 cigarettes in lifetime; - Current smoker: uses cigarettes now | | | G1: 15.2%
| - Pregnancy; - Chemical dependency or psychiatric disturbance as primary reason for admission; - Severe physical or mental distress | | | | G2: 19.8%
| | | | | P = < 0.05
| | | | | Percentage of those abstinent verified by salivary cotinine at 12-mo followup:
| | | | | C1: 8.8%
| | | | | G1: 10.0%
| | | | | G2: 9.9%
| | | | | P > 0.05
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | At 1 wk postcessation: higher levels of depression predicted failure to achieve abstinence (ITT analysis); higher levels of nicotine dependence and depression associated w/ decreasing likelihood of abstinence (analysis of txt-compliant patients) and likelihood of abstinence for participants on fluoxetine tended to be higher than for those on placebo (P = 0.06); At 1 month postcessation: higher levels of weight concern predicted lower abstinence (X^2^ 4.8, P = 0.78); patients on fluoxetine had positive association b/w degree of depression and likelihood of abstinence (highest quartile HRSD = 3, OR = 2, 95% CI, 0.85–4.70); At 3 months postcessation: patients treated w/ fluoxetine had positive association b/w HRSD scores and abstinence likelihood (highest quartile HRSD = 3, OR = 1.44, 95% CI, 0.53–3.91) | Quality rating:
Hitsman et al., 1999 | To identify individual differences that predict cessation when fluoxetine is combined w/ CBT | Specific randomization scheme NR. | - Individual counseling by health professional; - Pharmaceuticals | Constructed predictive models using logistic regression w/ hierarchical approach to variable selection. | Smoking characteristics predicting txt compliance were nicotine intake at baseline, saliva cotinine (X^2^ = 11.4, P < 0.001), and expired CO (X^2^ = 5.3, P < 0.05) | Fair
Geographic area: | Population: | Sample size: | Intervention: | Models evaluated w/ parallel analyses using stepwise selection procedure | | Comments:
US | - Adults | Total: 253 | G1: Nine, 1-hr individual CBT sessions + fluoxetine 30 mg for a total of 10 wks | Data verification: | | - Authors didn't report numbers of participants per arm of study, baseline demographic characteristics of those groups, nor 6 month followup results; - Inclusion/ exclusion criteria are described in companion article, Borrelli, et al. 1997
Funding agency: | Study type: | Definition of smoking: | - Participants required to set a quit date within 2 wks after drug txt began; - Participants quit smoking at 3rd CBT session; - Medication stopped at 9th CBT session, at which time 6-month followup period began; - CBT not explained; - Patients w/ fluoxetine level less than or equal to 150 ng/ml considered compliant | Expired CO and saliva continine | | Adequate randomization:
VA Merit Review award by NIDA, and Eli Lilly and Company | RCT w/ simple randomization | Cigarettes; - Reported smoking; - Expired CO greater than 8 ppm; - Saliva continine value greater than 10 ng/ml | G2: Same as G1:, except fluoxetine dose of 60 mg and fluoxetine blood level less than or equal to 300ng/ml considered compliant | Dependent variables: | | NR
Study setting: | Inclusion criteria: | | C1: Same as G1, except given placebo | Depression, nicotine dependence, weight concerns, self-efficacy about quitting smoking | | Attrition rate:
Population-based | Participants are:; - 18 to 65 yrs of age; - have smoked daily for at least one yr; - exhibit a baseline expired CO level of greater than 8 ppm; - agree to declare a quit date within 2 wks after second study visit (Source: Borrelli, et al. 1997) | | Method of assessment: | Baseline data: | | NR
| Exclusion criteria: | | Self report of smoking, expired CO, and saliva continine | No significant difference b/w txt groups in baseline characteristics: age, gender, education, smoking history, baseline level of nicotine dependence, depression, weight concern, and self-efficacy
| - Clinically significant depression HDRS score greater than 14; - Pregnancy; - Hypertension; - Use of psychotropic medication or current psychiatric illness; - Alcohol or drug abuse in past yr; - Current use of nicotine replacement; - Unstable medical condition or major health event in past 6 months; - Use of ST, pipes or cigars; - Recent experience of a major life event (e.g., divorce or major job change); - Suicidal ideation; - History of bipolar disorder (Source: Borrelli, et al. 1997) | | Also used depresion scale, nicotine dependence, weight restraint scale, and self-efficacy questionnaire
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Rates of continued abstinence in bupropion and placebo groups, respectively = 44.3% vs17.4% at 3 months (RR = 2.54; 95% CI 1.30–5.00); = 21.6% vs10.9% at 12 months (RR = 1.99; 95% CI 0.79–5.00). | Quality rating:
Holt et al., 2005 | To determine whether bupropion is effective in txt of smoking cessation in indigenous Maori population of New Zealand | - Self-recruitment from mall advertisements; - Recruited from Maori health networks; - Randomized (by computer generated code) | - Individual counseling by health professional; - Individual counseling by non health professional; - Telephone counseling; - Pharmaceuticals | Primary: normal approximation to binomial distribution | Bupropion group more likely to have insomnia (26% vs9% w/ RR = 3.0 and 95% CI 1.1–8.2) | Fair
Geographic area: | Population: | Sample size: | Intervention: | Secondary: GEE | | Comments:
New Zealand | - Adolescents; - Young Adults; - Adults | G1: 88 | G1: Bupropion 150 mg once daily for 3 days, then 150 mg twice daily for 7 wks; smoking cessation counseling | Exploratory: general additive model | | - No ITT analysis; - No attrition reported; - Fell just short of sample size needed according to power analysis; - No analysis for confounders.
Funding agency: | Study type: | C1: 46 | Clinic visits (to assess smoking status, exhaled CO, and adverse events) at 3 wk, 7 wk, | Data verification: | | Adequate randomization:
GlaxoSmithKline | - RCT w/ systematic randomization; - Placebo controlled, double blind, parallel group study | Definition of smoking: | 3 mo, 6 mo, 9 mo, and 12 mo after target quit date | Exhaled CO | | Yes
Study setting: | Inclusion criteria: | Cigarettes; - Smoke ≥ 10 per day on average over last yr | C1: Same as G1 except given identical placebo pills | Dependent variables: | | Attrition rate:
Community-based | - Self-indentified Maori; - Age 16 to 70; - Smoked at least 10 cigarettes per day over last yr; - Desire to quit; - Nonpregnant women w/ reliable contraception | | Method of assessment: | Continued abstinence from smoking at 3 and 12 months (or other time points, secondarily) | | NR
Population-based | Exclusion criteria: | | - Self-report; - Fagerstrom score; - exhaled CO
| History of:; - epilepsy; - febrile convulsion; - CNS tumor; - head injury; - cerebrovascular dz; - anorexia; - bulima; - CD; - other severe illnesses; - pregnant or lactating; - drug/alcohol abuse; - unwilling to quit marijuana | | Baseline data:
| | | Mean age (SD): 41.79 (9.2) txt vs 38.0 (11.1) placebo
| | | Mean Fagerstrom index (SD): 5.8 (2.2) txt vs 5.3 (2.0) placebo
| | | Mean initial weight (SD): 85.4kg (18.9) txt vs 80.2 (16.8) placebo; 69.3% female in txt vs 76.1% in placebo
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Of smokers preICU admission, those returning to smoking at 8-wk followup: | Quality rating:
Jones et al., 2001 | Determine whether ICU patients' smoking cessation after critical illness is aided by provision of a rehabilitation program | Recovering ICU patients recruited to study 2 wks after ICU discharge, randomized to receive either usual care followup of unit visits and ICU clinic appointments or routine followup plus an ICU rehabilitation manual | - Self-help; - Social support | NR | G1: 2 | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | C1: 5 | Comments:
United Kingdom | - Adults | G1: 31 (20 smokers) | G1: Verbal encouragement to remain non-smoking at ICU discharge, at 8-wk clinic vist, and six month clinic visit; patients' immediate family instructed not to smoke in same room as patient; 2 wks postdischarge introduction to 6-wk self help ICU rehabilitation manual read by patient and relative that emphasized importance of remaining non-smoking and provided practical tips | Smoking status verified by information from a close family member | RR = 0.24 (CI 0.03–1.84) | Very small study; due to type of article, details about randomization and sampling NR
Funding agency: | Study type: | C1: 30 (16 smokers) | C1: Verbal encouragement to remain non-smoking at ICU discharge, at 8-wk clinic vist, and six-mo clinic visit; patients' immediate family instructed not to smoke in same room as patient | Dependent variables: | Of smokers preICU admission, those returning to smoking at 6-mo followup: | Adequate randomization:
NR | RCT w/ simple randomization | Definition of smoking: | Method of assessment: | - Smoking status; - Levels of anxiety; - Depression; - PTSD-related symptoms | G1: 3 | NR
Study setting: | Inclusion criteria: | Cigarettes | Followup in clinic at 8 wks and 6 mos postdischarge | | C1: 10 | Attrition rate:
Hospital | - Minimum 48 hr ICU admission; - Had been ventilated | NR | Baseline data: | | RR = 0.11 (CI 0.02–.64) | O% attrition
| Exclusion criteria: | | No significant differences in baseline data among C1 and G1 | | No differences in anxiety, depression or PTSD-related symptoms at 6 mos b/w patients who continued to smoke and those who had quit (Mann Whitney U, HAD anxiety P = 0.51, HAD Depression P = 0.74, Impact of Events Scale P = 0.50)
| NR
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | | Quality rating:
Jorenby et al; 1999 | To determine whether buproprion plus NPis more effective for smoking cessation than either cessation aid alone or a placebo | - Subjects recruited at four study sites by advertisements in the media; - First subject enrolled in August 1995, and followup completed in March 1997; subjects randomly assigned to one of four treatments w/ use of an unequal-cell design; - Randomization not balanced within sites | Pharmaceuticals | X^2^ and ANOVA used to test for baseline differences in demographic and smoking-history variables | Proportion of participants abstinent at 6 mo followup: | Fair
Geographic area: | Population: | Sample size: | Intervention: | All statistical tests two-sided and had an alpha level of 0.05 | G1: 38.8% OR = 2.7 (95% CI, 1.7–4.4) P = < 0.001 | Comments:
US | - Adults | G1: 245 | G1: sustained-release bupropion (subjects received 150 mg of bupropion in morning and a placebo tablet in evening on days 1, 2, and 3 of txt; and one bupropion tablet in morning and one in evening on days 4 to 63) plus NP(one patch per day; patches from wks 2 to 7 each contained 21 mg of nicotine, those used during wk 8 each contained 14 mg, and those used during wk 9 each contained 7 mg) | Logistic-regression analysis used to determine pairwise differences among groups in abstinence rates | G2: 34.8% OR = 2.3 (95% CI, 1.4–3.7) P = < 0.001 | NR
Funding agency: | Study type: | G2: 244 | G2: sustained-release bupropion (subjects received 150 mg of bupropion in morning and a placebo tablet in evening on days 1, 2, and 3 of txt; and one bupropion tablet in morning and one in evening on days 4 to 63) plus placebo patch | Kaplan-Meier method used to analyze differences in rates of continuous abstinence; homogeneity among treatments and pairwise differences tested w/ log-rank test | G3: 21.3% OR = 1.2 (95% CI, 0.7–1.9) P = 0.53 | Adequate randomization:
Glaxo Wellcome | - RCT w/ systematic randomization; - Double-blind, placebo-controlled, randomized control trial | G3: 244 | G3: NP(one patch per day; patches from wks 2 to 7 each contained 21 mg of nicotine, those used during wk 8 each contained 14 mg, and those used during wk 9 each contained 7 mg) plus placebo pills 2x per day | Data verification: | C1: 18.8% | Yes
Study setting: | Inclusion criteria: | C1: 160 | C1: placebo pills 2x per day plus placebo patch one time per day | Expired air CO levels assessed to validate self-reported smoking status | Proportion of participants abstinent at 12 mo followup: | Attrition rate:
Community-based | - At least 18 yrs of age; - To smoke at least 15 cigarettes per day; - To weigh at least 45.4 kg (100 lb); - To be motivated to quit smoking; - To speak English; - Only one smoker per household allowed to enroll in study | Definition of smoking: | Method of assessment: | Dependent variables: | G1: 35.5% OR = 3.0 (95% CI, 1.8–4.9) P = < 0.001 | 6 month followup: 30.8%
| Exclusion criteria: | Cigarettes; - Abstinent: no smoking since last clinic visit and expired air CO 10 ppm or less; - Continuously abstinent: no smoking since quit date at expired air CO 10 ppm or less at every clinic visit over 12 mos | Followup at 10 wks, 3 mos, 6 mos, and 12 mos after start of study; assessment consisted of self-reported smoking status, vital signs, measurement of expired air CO, and the Beck Depression Inventory | - Primary: smoking status; - Secondary: withdrawl symptoms, body weight, and Beck Depression Inventory scores | G2: 30.3% OR = 2.3 (95% CI, 1.4–3.9) P = < 0.001 | 12 month followup: 34.6%
| Subjects excluded for following reasons: | | | Baseline data: | G3: 16.4% OR = 1.1 (95% CI, 0.6–1.8) P = 0.84, | Adverse events: 8.8%
| - Serious or unstable cardiac, renal, hypertensive, pulmonary, endocrine, or neurologic disorders, as assessed by study-site physician; - Ulcers; - Seizure or dermatologic disorders; - A current dz of major depressive episode or a history of panic disorder, psychosis, bipolar disorder, or eating disorders; - Use of a nrt within six mos before study enrollment; - Pregnancy or lactation; - Abuse of alcohol or a non-nicotine-containing drug within preceding yr; - Use of a psychoactive drug within wk before enrollment; - Use of an investigational drug within mo before enrollment; - Prior use of bupropion; - Current use of other smoking-cessation treatments; - Regular use of any noncigarette tobacco product | | | No significant differences b/w groups | C1: 15.6%
| | | | | All four groups had significant increases in withdrawal symptoms during first wk of txt (P < 0.001) but changes smaller in three active-txt groups than in placebo group during first six days after quitting date and during following wks
| | | | | No txt effect on Beck Depression Inventory scores
| | | | | Subjects in combined-therapy group had gained significantly less weight than those in placebo group (P < 0.05) or bupriopion group
| | | | | (P < 0.05) at wk 7 but no significant differences b/w groups in mean weight changes after wk 7
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Abstinence Rates (NS) | Quality rating:
Killen et al., 2000 | To examine efficacy of smoking cessation treatment that combined nicotine replacement therapy via transdermal system with antidepressant paraxetine | - Recruitment from local newspapers, then telephone interview screen, then initial office visit screen; - Double blind allocation | - Self-help; - Individual counseling | - Intention to Treat analysis; - Logistic regression; - 75% poser to detect at least a 20% increase in abstinence | At 4 weeks | Good
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | G1: 48% | Comments:
US, San Jose, CA | Adults | Total: 224 | G1: NRT transdermal system patch for 8 weeks plus 20 mg paroxetine for 9 weeks | - Self report; - Saliva cotinine concentrations; - Blood level to determine paroxetine compliance level | G2: 57% | NR
Funding agency: | Study type: | About 75 in each group | G2: NRT transdermal system patch for 8 weeks plus 40 mg paroxetine for 9 weeks | Dependent variables: | C1: 45% | Adequate randomization:
University of California Tobacco-Related Disease Research Program; SmithKline Beechum | RCT, double-blind | Definition of smoking: | C1: NRT transdermal system patch for 8 weeks plus placebo for 9 weeks | - Craving; - Adverse events; - Smoking status; - Compliance; - BMI; - Heart rate; - Blood Pressure; - Expired air CO level; - Depressive symptoms | At 10 weeks | Yes
Study setting: | Inclusion criteria: | - Greater than or equal to 10 cigarettes per day; - Abstinence: nonsmoking not even a puff for 7 consecutive days and saliva cotinine level below 20ng/ml an a CO level below 9ppm; - Smokers - reported abstinence but failed to provide a saliva sample | Method of assessment: | | G1: 33% | Attrition rate:
Population-based | - Adults over age 18 | | - In person interview and biomarkers at initial clinic visit; - Telephone interview at 1, 4, 10 and 26 weeks; - Via an interactive voice response system at 24 hours, weeks 2 and 6 | | G2: 39% | Not clear
| Exclusion criteria: | | Baseline data: | | C1: 36%
| - Pregnant, or lactating; - History of severe liver or kidney disease, epilepsy, bipolar disorder, schizophrenia,; - Receiving active treatment for or reported current depression or substance abuse; - Taking antidepressants, psychotropics, or other drugs that could interact with paraxetine resulting in potentially adverse consequences; - Unable to obtain permission from personal physician to participate in the study - for patients with history of heart disease, diabetes, thyroid disease, recent chest pain, very high blood pressure, skin conditions or peptic ulcer | | - Demographics; - Medical status questions; - Smoking history; - Screen for current major depression; - Modified agerstrom Tolerance Questionnaire; - Self-reported depression symptoms; - Clinical diagnosis of depression; - BMI; - Blood pressure and heart rate | | At 26 weeks
| | | | | G1: 21%
| | | | | G2: 27%
| | | | | C1: 25%
| | | | | Chemical Confirmation
| | | | | At 4 weeks: 95%
| | | | | At 10 weeks 98%
| | | | | At 26 weeks 86%
| | | | | Subanalysis of Compliant Persons
| | | | | At 4 weeks
| | | | | G1: 64%
| | | | | G2: 74%
| | | | | C1: 46%
| | | | | P < 0.001
| | | | | At 10 weeks
| | | | | G1: 43%
| | | | | G2: 51%
| | | | | C1: 35%
| | | | | At 26 weeks
| | | | | G1: 33%
| | | | | G2: 38%
| | | | | C1: 24%
| | | | | Those who reported greater use of nicotine patches and those with higher blood levels of paroxetine in Week 4 were more likely to be abstinent
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Abstinence at 3 month followup: | Quality rating:
Lancaster et al., 1999 | To determine whether receiving brief advice from a GP plus extended counseling and followup from a trained nurse resulted in patients' cessation more than brief advice from a GP alone | - Opportunistic recruitment of patients attending the practice w/ unrelated complaints; - Letters to patients identified as smokers by practice records; - 497 patients from 6 practices systematically randomized to receive brief advice from a GP or brief advice from a GP plus extended counseling and followup from a trained practical nurse | - Self-help; - Individual counseling by health professional; - Pharmaceuticals | - Chi sq used to test for differences b/w proportions and 95% CI calculated; - ITT analysis | G1: 9.2% | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | C1: 8.1%, NS | Comments:
United Kingdom | - Adults | G1: 249 | G1: Brief verbal or written advice to quit from the patients' general practitioners, plus: extended counseling and followup from a trained practing nurse; Health Education Authority leaflet on cessation; fact sheet on NRT; invitation to contact research nurse for more intensive, tailored counseling that included CO breath test and a personalized message about benefits of quitting - minimum one 15 min visit plus 1 followup, max five, 10-min followup visits; NRT if necessary | Salivary cotinine levels obtained to validate self-reported quitters | Abstinence at 12 month followup: | Adequate randomization:
Funding agency: | Study type: | C1: 248 | C1: Brief advice to quit from patients' general practitioners | Dependent variables: | G1: 6.8% | Yes
NR | RCT w/ systematic randomization | Definition of smoking: | Method of assessment: | - Sustained abstinence at 3 and 12 mos; - Biochemically validated; - Forward movement on stage of change | C1: 11.3%, NS | Attrition rate:
Study setting: | Inclusion criteria: | Cigarettes; - Smoker: At least one cigarette smoked per day and/or salivary cotinine levels < 113.5 nmol/l | Surveys administered at 3 and 12 months post quit date; salivary cotinine assessed for self-reported quitters; those who did not provide followup information were assumed to be smokers | Baseline data: | Sustained abstinence (abstinent at both 3- & 12-month followup): | 3 mo followup: 19%
Practice/provider settings | - Adults ages 18 and over who smoked at least one cigarette per day | | | G1 and C1 similar at baseline in terms of demographics and smoking status | G1: 3.6 | 12 mo followup:25%
| Exclusion criteria: | | | | C1: 4.4
| - NR | | | | Difference: -0.8%
| | | | | (CI, -4.3%, 2.6%)
| | | | | Validated (-3.3 vs4.0)
| | | | | Any forward change in stage of change:
| | | | | G1: 20.9%
| | | | | C1: 26.6%
| | | | | Difference: -5.7%
| | | | | (CI, -13.2%, 1.7%)
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Continuous abstinence since 10 days PP: G1+G2 vs C1: 1.20 (95% CI: 0.29–4.88) | Quality rating:
Lawrence et al., 2005 | To evaluate the effect on quitting smoking at 18 months post partum of smoking cessation intervention based on TTM delivered in pregnancy compared to current standard of care | - Recruited 16 of the 19 midwifery services for West Midlands; - 100 general practices randomized into trial arms; - Allocated by computerized minimization algorithm | Self-help | - Cluster randomization; - Random effects liners regression | Point Prevalence for Abstinence: G1+G2 vs C1: 1.15 (95% CI: 0.66–2.03) | Poor
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | Seven of the 54 (13%) who quit at end of pregnancy were still quit 18 months later | Comments:
West Midlands, UK | Women patients at of antenatal clinics in general practices | G1: 305 | G1: TTM-based self help manuals | Self report | No evidence that TTM-based interventions were superior in preventing relapse | NR
Funding agency: | Study type: | G2: 324 | G2: TTM-based self help manuals plus sessions with interactive computer program giving individualized smoking cessation advice | Dependent variables: | 18 of the 54 (33%) of those who had quite 10 days PP were still quite at 18 months, though 11 of these were not continuously | Adequate randomization:
Department of Health and the West Midland Health Authorities | Cluster randomized trial | C1: 289 | C1: Standard care | - Cotinine saliva; - Continuous and point prevalence abstinence since pregnancy | | NR
Study setting: | Inclusion criteria: | 393 (42%) eligible smokers were followed up on | Method of assessment: | | | Attrition rate:
Practice/provider settings | - At least 16 years of age; - Still smoking at 12 weeks gestation | Definition of smoking: | Medical chart abstraction and follow-up telephone interview | | | NR
| Exclusion criteria: | - Urine cotinine of 1.5 ug/ml; - Abstinence: declared nonsmoking and no cigarette consumption in last 24 hours | Baseline data:
| NR | | - Smoking habits; - Urine cotinine levels; - Fagerstrom Test for Nicotine dependence; - Stage of change; - Demographics; - Parity; - Proportion having a partner; - Proportion whose partner smoked; - Educational achievement; - Household net income
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | No statistically significant difference found between treatment groups at 6 months (G1: 12.2%, G2: 15%, NS) | Quality rating:
Lerman, et al., 2004 | To evaluate the comparative efficacy of transdermal nicotine and nicotine nasal spray and identify predictors of treatment outcome | - Participants were recruited through:; - local media ads for free smoking cessation treatment; - physician referral; - Eligible participants randomly assigned to receive transdermal nicotine or nicotine nasal spray | - Nicotine nasal spray; - Transdermal nicotine therapy; - Standardized behavioral group counseling | - Calculated sample size of 140 per group to detect a between-group difference in quit rates of 8% or greater with 80% power (alpha = 0.05); - Chi square and Wilcoxon rank-sum tests were used to examine differences in pre-treatment variables; - Chi square and Wilcoxon rank-sum tests were used to compare treatment groups on abstinence outcomes; - Logistic regression analysis was used to examine the independent effects of treatment group assignment, pretreatment variables, and their interactions on prolonged abstinence and verified point prevalence abstinence; - Wilcoxon rank-sum tests were used to examine differences between treatment group in use and percentage of cotinine replacement | Abstinence rates similar to those achieved in other studies | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | Smokers who were highly dependent, obese, or members of minority groups achieved higher rates of abstinence with nasal spray | Comments:
United States | Adults ≥18 years old enrolled at Georgetown University and the University of Pennsylvania | 299 adults | G1: 8 weeks of nicotine nasal spray and 7 sessions of behavioral group counseling | - Self-report for prolonged abstinence; - Self-report for point prevalence plus carbon monoxide reading < 10 ppm | | Authors stated that stratification was done by study site but no mention of what was stratified, or how or why
Funding agency: | Study type: | Definition of smoking: | G2: 8 weeks of transdermal nicotine therapy (i.e., patch) and 7 sessions of behavioral group counseling | Dependent variables: | | Adequate randomization:
National Cancer Institute; National Institute on Drug Abuse, and Public Health Services Research grant | RCT | - Prolonged abstinence defined as not having smoked for 7 consecutive days at any time during the follow-up period; - Point prevalence defined as 7 days of continuous abstinence immediately before the follow-up point | Method of assessment: | - Smoking status | | Yes
Study setting: | Inclusion criteria: | | 8 weeks and six month telephone interviews plus biochemical verification for point prevalence | | | Attrition rate:
Population-based | - 18 years of age or older; - Had smoked 10 or more cigarettes per day for the previous 12 months | | Baseline data: | | | 18% lost-to-follow-up
| Exclusion criteria: | | Participants at the University of Pennsylvania site were significantly more likely to be non-white, obese, and have lower levels of education
| - Pregnancy or lactation; - Uncontrolled hypertension; - Unstable angina; - Heart attack or stroke within the previous 6 months; - Current treatment or recent diagnosis of cancer, drug or alcohol dependence; - Current diagnosis or history of a psychotic disorder; - Current use of bupropion or nicotine-containing products other than cigarettes
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Telephone counseling improves cessation rates when used in conjunction with the patch | Quality rating:
MacLeod et al., 2003 | To investigate the effectiveness of telephone counseling as an adjunct to nicotine replacement therapy (NRT) by transdermal patch in smoking cessation | - Recruited smokers from New South Wales via newspaper ads; - Consent forms, questionnaires on health, smoking history and attitudes to quitting were mailed to people who responded to the ads.; - Responses were screened by a pharmacist in accordance with the approved product information for transdermal nicotine patches and eligibility criteria for the study; - Those deemed eligible were randomly allocated to either NRT alone or NRT plus telephone counseling; - Participants were contacted by telephone data collectors to verify their understanding of the study (baseline) | - NRT - patch; - Telephone counseling | - Intent-to-treat approach used, where missing values on smoking status imputed as smokers with 0 days abstinence in that period, unless continuous abstinence between calls was subsequently reported; - Statistical significance between groups was tested by X2 tests and logistical regression (categorical variables) or t tests (continuous variables); - Logistic regression analysis was conducted with both treatment group and duration of patch use included as predictors of 90-day abstinence | 28-day continuous abstinence rates at 6-months: G1 30.6%, C1 22.4%, P =.01 | Good
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | 90-day continuous abstinence rates G1 26.7%, C1 18.6%, | Comments:
Australia | - Smokers from New South Wales; - ≥18 years old | G1: 412 | G1: Nicotine Patch and 5 telephone counseling calls, scheduled at 1,2,3,6 and 10 weeks after baseline | - Self-report, bogus pipeline technique used, with possibility of carbon monoxide breath testing mentioned in the consent form and at the 3- and 6-month monitoring calls | P = 0.004 | No biochemical verification of abstinence - relied solely on self-report
Funding agency: | Study type: | C1: 442 | C1: Nicotine Patch only | Dependent variables: | Logistic regression analysis revealed the duration of patch use and telephone counseling made independent contributions to prediction of 90-day abstinence | Adequate randomization:
GlaxoSmithKline | RCT | Definition of smoking: | Method of assessment: | - 28-day continuous abstinence at 3 and 6 months; - 90-day continuous abstinence at 6 months | Odds of successful quitting increased with each extra week of patch use when treatment group held constant (OR=1.24, P < 0.05) | Yes
Study setting: | Inclusion criteria: | Cigarettes | Brief (5 minute) follow-up telephone questionnaires were administered at 1, 2, 3, and 6 months post-baseline | | When controlling for weeks of patch use, the odds of success were higher for those in the counseling group (OR=1.46, P < 0.05) | Attrition rate:
Population-based | - Aged ≥18 years; - English-speaking; - Smoking ≥10 cigarettes per day for the previous year; - Ready to begin a quit attempt within 1 week | - Current Smoker - Smoking ≥10 cigaretters per day for the previous year; - 28-day continuous abstinence (used at 3 and 6 month follow up calls) - complete abstinence, “not even a puff” for at least the previous 28 days; - 90-day continuous abstinence - the reported date of the last cigarette smoked was at least 90 days before 6 month follow-up call | Baseline data: | | | 16%
| Exclusion criteria: | | No significant differences b/w the 2 groups
| - History of cardiovascular disease, diabetes or skin sensitivity; - Currently breastfeeding, pregnant or intending to become pregnant; - Using contraindicated medications
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | No statistically significant difference between groups at any follow up point | Quality rating:
McBride et al., 2004 | - To evaluate whether relative to usual care and a previously evaluated woman-only intevention, if training in optimal support behaviors and giving support to partners increased abstinence rates among pregnany women during and after pregnancy; - 2nd aims - decrease postpartum relapse and increase rates of smoking cessation among partners | - Introductory letters describing the study were sent on behalf of WAMC to all women identified from automated appointment logs with a scheduled 1st prenatal visit.; - Women who did not call study's toll-free number w/in 10 days to decline contact were called to complete screening survey; - Eligible women who agreed to participate were stratified by smoking status (smoker or recent quitter), their partner's smoking status (smoker or nonsmoker) and partner's level of willingness (not at all vs somewhat or very); - Once stratified, participants were then randomly assigned to one of 3 conditions: usual care (UC), woman only (WO) or partner assisted (PA); - Women and partners completed telephone surveys at baseline (about 11 weeks of pregnancy) | - Provider advice; - Self-help quit guides; - Telephone counseling; - Pregnancy relapse kit; - Telephone counseling and support guide geared towards partners | - Logistic regression was used to compare the 2 experimental conditions to the control condition on each outcome measure, controlling for baseline smoking-specific support variables and predictors known to be associated with smoking cessation trials; - Intent-to-treat approach used, where missing values on smoking status imputed as “smoker”; - Comparison on the experimental conditions to the control condition on dichotomous secondary outcomes, such as postpartum relapse and partners' prevalent abstinence, were made with logistic regression; - Proportional hazards model was used to compare conditions on time to relapse, where time to relapse defined as the number of days b/w woman's delivery date and the date she resumed smoking; - Differences by condition for changes in women's and partner's smoking-specific support and general support across time were tested with mixed linear-model repeated measures analysis | No statistically significant difference between groups in the proportion relapsed at any postpartum follow-up | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | In late pregnancy (28 weeks), more partners abstinent in G2 group (15%) than C1 group (5%) P = 0.02 | Comments:
United States | - Pregnant woman who received prenatal care at the Womack Army Medical Centers; - Their live-in partners | G1: (WO): 192 | G1: Usual care plus late pregnancy relapse kit, and 6 counseling calls | Self-report, salivary cotinine | Women in all groups consistently reported a decline in positive partner support from baseline to 12-month postpartum (F=81.43, df=1322, P < 0.001) | By only including women who agreed to involve their partners, couples who were inclined to support each other and attentuated treatment effects may have been over-represented
Funding agency: | Study type: | G2: (PA): 193 | G2: G1 plus the partners received telephone counseling and support guide (partners who smoked received cessation aids and counseling) | Dependent variables: | | Adequate randomization:
National Cancer Institute | RCT | C1: (UC): 198 | C1: Usual Care: provider advice to quit and self-help guide | - Abstinence at 28 weeks, 2, 6 and 12 months postpartum; - Sustained abstinence | | Yes
Study setting: | Inclusion criteria: | Definition of smoking: | Method of assessment: | | | Attrition rate:
Military Medical Center | - Eligible women were ≤20 weeks pregnant; - Aged ≥18 years; - Current smokers or recent quitters; - Living with an intimate partner; - Willing to have the partner contacted for participation in the study | Cigarettes; - Current Smoker - NR; - Recent quitter - smokers in the 30 days prior to pregnancy but not smoking at intake; - Prevalent abstinence - no smoking in prior 7 days; - Sustained abstinence - no smoking across all 4 follow-up times | - Telephone surveys of the women and partners at 28 weeks pregnant, postpartum and 2, 6, and 12 months; - Self reported smoking status assessed at each follow up with the question “have you smoked any cigarettes in the past 7 days?”; - Saliva samples collected by mail at 28 weeks pregnancy and 12 months postpartum from women and partners who reported not smoking in the previous 7 days | | | 19%
| Exclusion criteria: | | Baseline data:
| - >20 weeks pregnant; - Partner not available, or refused partner contact | | No significant differences b/w any of the groups
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Point Prevalence of Abstinence: no significant differences by condition at any assessment point | Quality rating:
Mermelstein et al., 2003 | To compare the relative efficacy of two types of proactive telephone calls following a group cessation program. | - Participants recruited primarily through paid advertisements, media coverage of the program, flyers and referrals; - 905 smokers attended the first group meeting; - 771 smokers completed the group program; - 756 smokers were assessed at least once over the follow-up period | - Group meetings; - Telephone counseling | NR | Post-hoc analysis by condition by gender at all assessment points showed that men receiving the enhanced condition were more likely to abstain while women were more likely to abstain when participating in the basic condition. | Poor
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | | Comments:
US | Participants completing a group smoking cessation program | G1: (basic): 375 | G1: Enhanced: Basic program (see C1 below) plus telephone counseling call content varied by participants' smoking status (i.e., still smoking, abstinent, slipped or relapsed); if still smoking or relapsed also received a videotape; plus abstinent counseling on keeping motivation and self-efficacy high using a variety of techniques | Expired air carbon monoxide and saliva cotinine used to verify abstinence at each major assessment point for participants reporting abstinence | | - No true control group (i.e., those in group program with no telephone follow-up). So no true comparison of whether calls had an effect.; - Random assignment method NR; - Population not described; - No inclusion/exclusion criteria specified
Funding agency: | Study type: | G2: (enhanced): 381 | C1: BasiC1: 7 week group treatment program of telephone counseling giving only words of encouragement without specific guidance | Dependent variables: | | Adequate randomization:
National Heart, Lung and Blood Institute and National Cancer Institute | RCT | Definition of smoking: | Method of assessment: | - Abstinence: no smoking at all in the past 7 days; - Relapse: smoking one one or more days of the past 7 after achieving an initial 7-day period of abstinence at the end of the group program | | NR
Study setting: | Inclusion criteria: | Tobacco dependence as measured by the Fagerstrom Tolerance Questionnaire | 3-,6-,9-,12- and 15-month follow-ups via telephone | | | Attrition rate:
NR | NR | | Baseline data: | | | 6-month: 1%
| Exclusion criteria: | | No significant differences between conditions on any variables or on percentage with a history of depression | | | 15-month: 4%
| NR
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Quitting at 1 yr G1 vs C1: | Quality rating:
Murray et al., 2001 | To evaluate hypothesis that Black smokers will respond differently than Whites to a smoking cessation intervention program where no adjustments are made in recognition of cultural differences | NR | - Group counseling; - Pharmaceuticals | Covariate data used to explore differences using regression t-tests etc. | Blacks: AOR: 1.48 | Poor
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | Whites: AOR: 5.99 | Comments:
US | - Adults; - African Americans | G1: 3,923 | G1: SI (12-wk group program using a quit day in second wk, followed by 4 consecutive days of group meetings) w/ bronchodilator therapy | - Salivary cotinine annually; - Expired CO throughout intervention program and subsequently at 4-mo intervals | P = 0.002 | Large differences in baseline comparisons b/w white and black negate any differences that occur in outcomes, small sample size
Funding agency: | Study type: | C1: 1,964 | G2: SI w/ placebo inhalers | Dependent variables: | Quitting at 5 yrs: | Adequate randomization:
Division of Lung Disease of the National Heart, Lung, and Blood Institute | RCT w/ simple randomization | Definition of smoking: | C1: Usual care- annual physician visits | Smoking cessation | G1 vs C1 | No
Study setting: | Inclusion criteria: | Cigarettes | Method of assessment: | Baseline data: | Blacks: AOR: 1.87 | Study not designed for this comparison
Practice/provider settings | - Age 35–60 yrs; - Mild COPD; - Current smoker | Defined as smoking at any clinic visit | - Interviews at baseline and annually for 5 yrs; - Annual saliva collection | Baseline data comparisons b/w 2 groups showed significant differences | Whites: AOR: 3.34 | Attrition rate:
| Exclusion criteria: | | | Black population had more women (46% vs37%) P = 0.01, less education, less income, less likely to be married (48% vs70%), smoked less (23.5 vs32.9 per day) | P = 0.06 | NR
| - Serious health conditions likely to to affect lung function or ability to stay in trial for 5 yrs; - Use of regular medications that might alter lung function | | | | Significant txt effect for Blacks over 5 yrs of study (OR = 1.95, P = 0.04)
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | At 12-month followup, 7-day point prevalence for non-smoking: | Quality rating:
Peterson, 2004 | To evaluate whether a nurse-managed smoking cessation and relapse prevention program reduced smoking rates at 12 mos in women admitted to hospital w/ CD | NR | - Self-help; - Individual counseling by health professional; - Telephone counseling | NR | G1: 48% | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | C1: 42% | Comments:
US | - Adults,; - Women (only) | G1: 142 | G1: Brief physician counseling and usual care plus nurse managed, cognitive behavioural, relapse prevention intervention given before discharge, <5 structured telephone contacts 2–90 days after discharge, and relapse management counseling as needed | Self-reported smoking status (abstinence in past 7 days) verified by cotinine levels and family/friends | RBI: 14% (95% CI, -14 to 51), | NR
Funding agency: | Study type: | C1: 135 | C1: Brief physician counseling, a self help pamphlet, and a list of community resources | Dependent variables: | P = NS | Adequate randomization:
National Heart, Lung, and Blood Institute | RCT w/ systematic randomization | Definition of smoking: | Method of assessment: | Smoking status | | NR
Study setting: | Inclusion criteria: | Cigarettes; - Abstinent: no smoking in past 7 days | NR | Baseline data: | | Attrition rate:
Hospital | - Female; - At least 18 yrs of age; - Admitted to hospital w/ CVD or peripheral vascular disease; - Had smoked cigarettes in month before admission; - Willing to make a serious attempt to quit smoking after discharge | | | NR | | 11%
| Exclusion criteria:
| - Medical instability; - Alcohol or substance abuse; - Dementia; - Schizophrenia
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Quit rate at 12 months: | Quality rating:
Quist-Paulsen and Gallefoss, 2003 | To determine whether a nurse led smoking cessation intervention affects smoking cessation rates in patients admitted for coronary heart disease | - Invited to participate in study all patients admitted to Vest-Agder Hospital for myocardial infarction, unstable angina, or care after coronary bypass surgery performed at other hospitals; - 1016 patients assessed for eligibility; - Nurses recruited patients 2–4 days after admission; - Participants answered baseline questionnaire and were randomly allocated to usual care (control group) or intervention; - Nurses given serially numbered sealed envelopes from secretary otherwise uninvolved in study; - Randomization was in blocks of varying sizes; - 250 patients randomized; 10 were later withdrawn | - Group sessions with cardiac nurses, including seeing a video and getting info booklet; - Telephone counseling; - Self-help | - Chi-square test used to assess effect of intervention; - NNT calculated with confidence intervals; - Simple and multiple logistic regression models used to test relation between baseline characteristics and outcome measures; - SPSS used for all analyses | G1: 57% | Good
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | C1: 37% (absolute risk reduction 20%, 95% CI 6.4–33.0; P = 0.004) | Comments:
Norway | Adults under 76 yrs of age | G1: 118 | G1: Cardiac nurse consulted patients 1–2 times during hospital stay. Intervention based on booklet focusing on fear arousal and prevention of relapse. Booklet emphasized health benefits of quitting smoking after coronary event, including illustrations showing mortality differences for those who continued smoking after coronary condition vs. those who quit, information on how to prevent relapse, how to stop smoking, how to use nicotine replacement.; also explained how to identify & cope with high risk situations for relapse. Nurses contacted participants by telephone 2 days, 1 week, 3 weeks, 3 months & 5 months after discharge. At 6 weeks aoo participants in G1 had consultation at outpatient clinic with nurse. | Self-report and urine analysis | NNT to get one additional person who would quit was 5 | - Well-reported—interventions and methods fully described; - Objective outcome measure (urine test); - Loss-to-follow up treated as relapsed smokers yielding valid ITT analysis
Funding agency: | Study type: | C1: 122 | C1: Patients were offered group sessions twice/week with nurses where importance of smoking cessation was mentioned; a video was shown and booklet distributed giving general information on coronary heart disease and advice on quitting smoking. No further specific instructions on how to quit were given | Dependent variables: | Assuming dropouts relapsed at 12 months, smoking cessation rates were: | Adequate randomization:
Vest-Agder Council for Public Health and the charity Sykehuset i vaare hender | RCT | Definition of smoking: | Method of assessment: | - Number of days spent in ICU; - Myocardial infarction as reason for admission; - No previous coronary heart disease; - Employment | - G1: 50%; - C1: 37% (absolute risk reduction 13%, 95% CI 0%–26%) | Yes
Study setting: | Inclusion criteria: | - Daily smoker until start of present coronary symptoms | Self report and biochemical verification of smoking cessation rates at 12 months | | Smokers who stated they were still smoking were classified as smokers | Attrition rate:
Cardiac ward of a general hospital | - Patients under the age of 76 admitted for myocardial infarction, unstable angina, or cardiac bypass surgery who had been daily smokers until the start of their present coronary symptoms. Patients had to be sufficiently recovered to reliably receive the intervention and had to live in Vest-Agder or Aust-Agder county. | | Baseline data: | | Those who claimed they had quit and had a nicotine metabolite concentration in urine < 2.0 mmol/mol creatinine were classified as non-smokers | - 10 post-randomization exclusions; - LTF at 12 months(not including post-randomization exclusions): 9% (G1: 15.3%, C1: 3.1%)
| Exclusion criteria: | | - Fewer employed in C1 than in G1; - More with post primary education in C2 than in G1 | | G1: average of 1.6 (SD 0.7) consultations as inpatients and 1.6 (SD 1.5) as outpatients; also received a mean of 8.5 (SD 3.2) telephone calls
| - Patients with serious illness associated with short life expectancies, serious psychiatric problems, alcoholism, and dementia | | | | Mean total time devoted to each patient was 147 minutes (SD 50)
| | | | | Use of nicotine replacements:
| | | | | G1: 36%
| | | | | C1: 28% (without a statistically significant difference)
| | | | | 9% of patients who smoked while in hospital or at 6 wks were abstinent at 12 months
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Treatment group participants (73.0%) were more likely to fast than were controls (53.0%): | Quality rating:
Ratner et al., 2004 | Test an intervention to help smokers abstain (fast) from smoking before surgery, maintain abstinence postoperatively, and achieve long-term cessation | Elective-surgical patients in | - Counseling; - Nicotine replacement therapy | - Univariate descriptive statistics; - Hypothesis testing using contingency tables and chi-square; - Treatment effect- multi-step logistic regression | χ^2^(1,N=228)=8.89, P=.003, and more likely to be abstinent 6 months after surgery (31.2% vs. 20.2%). | Fair
Geographic area: | Population: | - Cardiovascular; - Opthalmology; - Orthopedics; - Plastics; - Urology | Intervention: | Data verification: | There was no significant difference in the abstinence rates at 12 months after surgery,χ^2^(1, N=169) | Adequate randomization:
Western Canada | Patients admitted for presurgical assessment from Nov. 1999 to Oct 2001 | Sample size: | - 2 face to face counseling sessions; - 9 telephone counseling sessions | - Cotinine assay; - CO measure | < 0.001, P =1.00. | Yes
Funding agency: | Study type: | 237 | Method of assessment: | Dependent variables: | | Attrition rate:
National Cancer Institute of Canada | Randomized pretest-posttest control group experiment | Definition of smoking: | - CO measure; - Cotinine assay; - Self-report | - # days until follow-up; - Age; - Education; - Self-efficacy; - POMS; - Fagerstrom test; - Other household smokers; - Smoking stage of change | | 28.70%
Study setting: | Inclusion criteria: | - Smoked in 7 days before surgery | Baseline data:
Teaching hospital | - Self-identified smokers within previous 7 days; - Remain in hospital for at least 24 hours following surgery; - Speak and write English; - Able to be contacted by phone; - Willing and able to participate | | Similar in both groups
| Exclusion criteria:
| NR
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | At 3 months stepped-care treatment increased smoking cessation rates from 42% to 53% during a 3-month follow-up period (P = 0.05) | Quality rating:
Reid et al., 2003 | To determine whether stepped-care treatment helped smokers hospitalized with CAD to quit smoking over 3-month and 1-year follow-up periods. | - 8330 patients admitted for coronary angiography, PTCA, MI, or CABG were screened; - 1379 (16.6%) were identified as cigarette smokers; - 419 individuals who met all eligibility criteria; - 254 (60.6%) agreed to participate | - Self-help; - Stepped-care treatment | - Baseline subject characteristics - t tests for continuous variables and chi-square tests for categorical variables.; - Primary analysis- a Fisher's exact test was used to compare 3-month and 1-year rates A secondary analysis univariate and multivariate logistic regression procedures | 1-year follow-up minimal intervention group of 36% versus 39% for the stepped-care group (P = 0.36) | Good
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | | Comments:
Ottawa, Canada | - Patients hospitalized with CAD; - Age of 18 years or more; - Motivated to quit smoking | G1: 126 | G1: called by a nurse-counselor 4 weeks after discharge and questioned. If not smoking, provided positive reinforcement and reminded about relapse prevention information in the booklet. If smoking, nurse counseling was begun, 3–20 minute face to face sessions over 8 weeks and nicotine patch therapy was made available | Self-reported with a random sample of 25 tested for CO levels | | - Well-thought out design; - Well reported
Funding agency: | Study type: | C1: 128 | C1: no additional counseling after hospital discharge; free to seek assistance from community or primary care physician | Dependent variables: | | Adequate randomization:
NR | RCT | Definition of smoking: | Method of assessment: | - Demographic factors; - reason for admission; - smoking history; - nicotine dependence; - self-efficacy; - motivational readiness variables | | Yes
Study setting: | Inclusion criteria: | - 5 or more cigarettes a day; - Did not include users of pipes, cigars or smokeless tobacco exclusively | Surveyed by mail 3 months and 1 year after hospital discharge. If the questionnaire was not returned promptly, the participants were called, and the questionnaire was completed by telephone | | | Attrition rate:
Tertiary care cardiac facility | - At least 18 years or age; - Hospitalized with coronary artery disease | | Baseline data: | | | C1: 19.5%
| Exclusion criteria: | | - Groups balanced for age, gender, education level, reason for admission, cigarettes per day, Fagerstrom score, years of smoking, quit attempts, motivational readiness to quit smoking, self-efficacy, and preference for cessation assistance | | | G1: 9.5%
| - Unresolved unstable angina; - Life-threatening arrhythmias; - Vasospastic diseases (buerger's disease, prinzmental's variant angina); - Pregnant or lactating women; - Those who lived more than 1 hour of travel time away
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Verified quit rate: | Quality rating:
Rowe et al., 1999 | To evaluate effectiveness of offering an individualized approach to smoking cessation to qualified nurses and student nurses in Northern Ireland | - Nurses and student nurses from a college of nursing and a large hospital trust who self-identified as smokers and wanting to quit were invited to participate in study; - Participants could choose to be in intervention group or control | - Self-help; - Individual counseling by Health professional; - Social support | Frequencies | G1: 22.7% vs 8.6% (C1) | Poor
Geographic area: | Population: | Sample size: | Intervention: | Fisher's Exact Test | P < 0.05 | Comments:
United Kingdom | - Adults | G1: 22 (nurses) | G1: (Qualified nurses): received individual counseling to: (1) assess health beliefs and motivation to quit smoking; (2) plan and implement strategy for quitting (set quit date, discuss coping strategies, identify social support, keep smoking success and failure diary) and make subjects aware follow up would occur at 6 wks, 6 months, 1 yr postintervention. | Qualitative data | G2: 25% vs 6% in C2 | Participants self-selected to intervention and comparison group status; at 1 yr followup, participants self-selected whether to answer a questionnaire for smokers or for non-smokers; motivation and determination to quit smoking higher among intervention groups vscomparison groups, factors not controlled for in analyses; not given all data regarding intervention vscomparison groups (sometimes %s given, but not per group status)
Funding agency: | Study type: | G2: 32 (Student nurses) | G2: (Student nurses): Same intervention as G1 | Data verification: | P < 0.05 | Adequate randomization:
NR | Cohort study | C1: 23 (nurses); 33 (student nurses) | C1: (Qualified nurses) and C2 (Student nurses) received no smoking cessation counseling or assistance, but were followed up at 6 months and 1 yr postenrollment | Self report of smoking status | | Not a RCT, but problematic group membership because participants self-selected into intervention or comparison group per their desire to receive smoking cessation assistance (intervention groups) or to try to stop smoking on their own (comparison group)
Study setting: | Inclusion criteria: | Definition of smoking: | Method of assessment: | For those reporting no smoking, verified through CO in expressed alveolar air (2–10 ppm = non-smoker; 11–60 ppm = smoker) and through salivary cotinine concentrations (20 ng/ml = non-smoker) | | Attrition rate:
Worksite | - Qualified nurse (“nurse”) or student nurse; - Smoked at east one cigarette daily; - Expressed desire to quit smoking; - Agreed to participate in study as an intervention or control participant | Cigarettes; - Unclear, but to enroll, had to report smoking at least one cigarette daily (also see Dependent Variables section) | Self-report on questionnaires and biochemical verification of non-smoking status | Dependent variables: | | At 1 yr, 5% overall (no further attrition detail provided and unable to determine from tables presented)
| Exclusion criteria: | | Followup conducted at 6 wks postintervention for intervention groups, at 6 months and 1 yr for both intervention and Cs | - Verified quit rate; - Perceptions of smoking and health; - Perceptions of their health promotion role
| Did not meet all inclusion criteria | | Definition of smoking: | Baseline data:
| | | Cigarettes | Nurses: G1 and C1 similar (age 23–56 yrs; 45% of G1 and 49% of C1 had spouses, partners, or parents who smoked; 95.5% female)
| | | - Unclear, but to enroll, had to report smoking at least one cigarette daily (also see Dependent Variables section) | G1 and C1 similar in smoking history (89% began smoking before nursing, 64% smoked 20 cigarettes daily; 82% had been smoking more than 10 yrs)
| | | | 68% G1 vs100% C1 tried to quit smoking previously (no test)
| | | | Student nurses: 62% b/w 17–21, range 17–36; 60% had family members who smoked; 91% female; 91% single (no further detail by group)
| | | | 97% of G2 and 94% C2 began smoking before entering nursing; range of smoking = 1–10 yrs, 68% smoked b/w 1–6 yrs
| | | | 88% G2 and 73% C2 smoked 10–20 cigarettes daily
| | | | About 75% of each group had tried to stop smoking at least once before
| | | | 100% of G2 and C2 accepted smoking did or might influence their or their family's/friends' health
| | | | 78% of G2 and 45% C2 experiencing some ill health effect of smoking
| | | | # Perception of role as health promoter:
| | | | G1: 100%
| | | | C1: 96%
| | | | G2: 94%
| | | | C2: 82% (no test)
| | | | All Groups: Motivation to quit smoking (“want to very much” or“would like to”):
| | | | G1: 100% vs
| | | | C1: 65%, P < 0.01
| | | | G2: 61% vs C2: 61%
| | | | (P < 0.01)
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | No significant differences observed in smoking status at end of trial (assuming that end of trial was at 12-months post quit date although time frame is not stated in the article text or table for these assessments): | Quality rating:
Saules, et al., 2004 | To test effect of fluoxetine on smoking cessation in the context of a program that includes group cognitive-behavioral therapy (6 weeks) and transdermal nicotine patch (10 weeks) | - Participants recruited by flyers and notics distributed throughout the university and through paid advertisements in local newspapers and radio stations.; - Telephone screening of all respondents.; - Candidated attended a screening visit at which expired CO reading were required to be greater ahn or equal to 15 ppm. | - Pharmaceuticals: fluoxetine and transdermal NRT; - Cognitive-behavioral counseling (CBT) | Chi-square analysis | C1: 35.4% | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | G1: 43.1% | Comments:
US | Adults | G1: 51 | G1: Fluoxetine (20mg) 4 weeks before quit date, changed to 40 mg fluoxetine after one week, CBT starting 2 weeks before quit date and 15 mg NRT patch on morning after quit date visit | Expired CO of less than 10 ppm obtained for self-reported quitters | G2: 43.1% | Random assignment method NR
Funding agency: | Study type: | G2: 51 | G2: Fluoxetine (20mg) 4 weeks before quit date and for 15 weeks total, CBT starting 2 weeks before quit date and 15 mg NRT patch on morning after quit date visit | Dependent variables: | Change in weight was significant for treatment group (P = 0.010), smoking cessation (P = 0.037) and their interaction (P = 0.012). Withdrawal symptom scores were significantly lower in both fluoxetine groups as compared to the placebo group | Adequate randomization:
National Institute on Drug Abuse and State of Michigan | Randomized, double-blind, placebo-controlled trial | C1: Placebo | C1: Placebo and CBT starting 2 weeks before quit date and 15 mg NRT patch on morning after quit date visit | Documented nonsmoking: self-reported abstinence combined with CO less than 10 ppm | (P = 0.038) | NR
Study setting: | Inclusion criteria: | Note: planned sample size was 168 with 56 participants per arm | Method of assessment: | | | Attrition rate:
Population-based | - Adults 21–65; - Smoking > 15 cigarettes/day; - Producing CO. 15ppm | Definition of smoking: | NR | | | 40%
| Exclusion criteria: | Self-reported smoking of any cigarettes at all (or even part of one cigarette), CO greater than or equal to 10 ppm | Baseline data: | | | Drop-out was related to smoking status, as 90% of the people who did not complete the study had documented smoking at their last assessment whereas only 32% of those who completed the study had documented smoking at the last assessment (X^2^(1)=9.94, P = 0.002)
| - Candidates in acute psychiatric crisis; - Met criteria for apsychieatric disorder within the past six months; - Were currently taking psychiatric medications; - Clinically significant medical conditions; - Pregnant; - Inability to comprehend and respond to measures | | No significant differences across groups except for significant differences in baseline depression with elevated levels among those randomized to placebo.
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | No statistically significant differences in smoking cessation rates at end of medication 3, 6, and 12 months | Quality rating:
Simon et al., 2004 | Whether the addition of bupropion to transdermal NRT and cognitive-behavioral counseling would increase quit rates compared with standard therapy using NRT and cognitive-behavioral counseling only | Participants were recruited from the three following sources: | - Bupropion; - Transdermal nicotine replacement therapy; - Cognitive-behavioral counseling | - 2-sample t tests and Wilcoxon rank sum tests for continuous variables; - Chi square tests for categorical variables; - Calculated relative risk and 95% CIs; - For multi-variate analysis, used backward stepwise procedure to examine relationship between demographic and historical variables and smoking cessation; - Variables were retained in the model if they remained associated with quitting at P ≤ 0.20; - All regression models were adjusted for treatment assignment; - Hosmer-Lemeshow goodness-of-fit test was used to assess adequacy of the models; - 2-tailed P values < 0.05 were considered significant | The addition of 7-week treatment with Bupropion did not significantly increase quit rates over NRT and counseling | Fair
Geographic area: | Population: | - Lists of known smokers from previous smoking cessation clinical trials at the San Francisco VA Medical Center; - Hospital-based advertising at major teaching hospitals; - Local Bay Area advertising and PSAs | Intervention: | Data verification: | | Comments:
United States | Adults | Eligible smokers were assessed for their readiness to quit smoking | G1: 7 week course of Bupropion, 2 months transdermal nicotine replacement therapy, 1 visit with counselor (30–60 minute session), and 5 telephone follow-up calls | Self-report plus cotinine saliva for those who self-reported quitting at the 12 month followup | | No power analysis
Funding agency: | Study type: | Subjects in the contemplation or preparation stages of quitting were randomized to either treatment or control arm | C1: Same as G1 except participants received placebo instead of Bupropion | Dependent variables: | | Adequate randomization:
California Tobacco-Related Disease Research Program | RCT | Sample size: | Method of assessment: | Quit rates | | Yes
Study setting: | Inclusion criteria: | 244 adults | Follow-up at 7 weeks (end-of treatment), 3 months, 6 months, and 12 months by telephone | | | Attrition rate:
Hospital | - Smoked 20 or more cigarettes during the week prior to enrollment; - Have a telephone and no plans to leave the catchment area during the study period; - In the contemplation or preparation stages of quitting according to the Prochaska and DiClemente Stages of Change model; - ≥ 20 years of age | Definition of smoking: | Baseline data: | | | - 1% lost to followup; - 2% died
| Exclusion criteria: | Non-smoker; - Self-report of no smoking for the past seven days during each follow-up counseling call; - Follow-up self report of no-smoking in the past six months and twelve months; - Among those who reported no smoking at 12 months, follow-up saliva cotinine level had to be less than 15 ng/ml | No statistically significant differences in any of the baseline demographic of medical characteristics between the samples in the 2 study arms
| - Contraindications to bupropion or NRT; - Serious psychiatric illness including major depression; - History of alcohol abuse within the past three months or consuming more than 3 alcoholic beverages per day | Continous non-smoker; - Self-reported quitting at each follow-up assessment, and biochemical or proxy verification of no smoking at 12 months | Males: 86%
| | Smoker; - Self-reported no smoking but using NRT and salivary cotinine levels >= 15 ng/ml; - Stopped smoking cigarettes but using other tobacco products
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Swan 2003a | Quality rating:
Swan^a^, et al., 2003 and Swan^b^ et al., 2003 | Swan:^a^ To identify individual characteristics predictive of more clinically relevant smoking end-points beyond end of treatment in smokers prescribed bupropion SR and counseling. | - Participants who called the study center were screened over the telephone.; - Eligible volunteers were sent a pretreatment questionnaire and consent form.; - Participants were randomly assigned to 4 treatment arms by a computer-generated number.; - The computer code calculated probabilities of group assignment that were dynamically modified based on the number of members in each group so that final group sizes were equal.; - No restrictions such as stratification or blocking were used in the process. | - Pharmacologic treatment; - Tailored mail program (ZAP); - Proactive telephone counseling program (Free and Clear Program) | - Intent-to-treat analysis; - Logistic regression for assessing pretreatment characteristics for their relationship to point-prevalent smoking at 12 months | At 12-month follow-up, type of behavioral treatment had a strong association with point-prevalent smoking (e.g., participation in the less-intensive TM program being associated with a greater likelihood of smoking) whereas dose and the dose x treatment interaction had little or no association with outcome OR=1.21 (95% CI, 1.08–1.35). | Fair
Geographic area: | Swan:^b^ To determine the differential effectiveness of 2 doses of bupropion in combination with behavioral interventions of minimal to moderate intensity. | Sample size: | Intervention: | Data verification: | Swan 2003b | Comments:
US, Seattle | Population: | G1: 382 | G1: 150 mg bupropion SR and proactive telephone counseling (Free and Clear Program) | Self-report | - At 3 months:; 300mg G3: 35% vs 150 mg; G1: 24.4% (P=0.001); 300mg G3: 35% vs 150mg; G2: 24.2% (P =0.001); 300mg; G3: 35% vs 300mg G4= 26.7% (P =0.01); - At 12 months:; 300mg G3: 33.2% vs 150mg G2: 23.6% (P =0.004); 300mg G3: 33.2% vs 300mg G4: 25.7% (P =0.02); 150 mg G1: 31.4% vs 150mg G2: 23.6% vs (P =0.02) | - Lack of blinding; - No biochemical confirmation of self-reported smoking status; - No objective measurement of adherence to the therapeutic regime
Funding agency: | - 18 years of age or older | G2: 381 | G2: 150 mg bupropion SR and tailored mail ( Zyban Advantage Plan - ZAP) | Dependent variables: | | Adequate randomization:
National Cancer Institute | Study type: | G3: 383 | G3: 300 mg bupropion SR and proactive telephone counseling (Free and Clear Program) | - Smoking: any smoking within the 7 days prior to follow-up | | NR
Bupropion SR provided by Group Health Cooperative Pharmacy | - Data from a large, randomized effectiveness trial; - Two dosage levels of bupropion SR (Zyban, 150 and 300 mg) were crossed with two behavioral treatment programs of lower or higher intensity to create a four-cell design. | G4: 378 | G4: 300 mg bupropion SR and (ZAP) | | | Attrition rate:
Study setting: | Inclusion criteria: | Definition of smoking: | Method of assessment: | | | - 3-month follow-up: 20.8%; - 12-month follow-up: 14.9%
Non-profit consumer-governed health care system serving 600,000 residents of western Washington (GHC) | - Individuals at least 18 years of age; - Smoking an average of 10 or more cigarettes per day in the 12 months prior to enrollment; - Motivated to stop smoking; - Otherwise in good general health and had proper GHC coverage | - Any smoking within the past 7 days (7 day point prevalence) | 3- and 12-month follow-up
| Exclusion criteria: | | Baseline data:
| - Predisposition to seizure; - Current use of medications contraindicated for use with bupropoion SR or know to lower seizure threshold; - History of or current diagnosis of anorexia nervosa or bulimia or presence of any severe chronic medical condition; - Use of any investigational drug within 1 month of treatment with buropion SR; - Participation in GHC's Free and Clear smoking cessation program in the previous 12 months; - Current depression; - Recent high frequency or binge drinking; - Abuse of other substances including recreational/street drugs; - Current pregnancy or plans to become pregnant; - Current nursing of a child | | - Reported by gender not treatment condition.; - Men had significantly more years of formal schooling, smoked more cigarettes per day, had higher number of previous attempts to quit.; - Women significantly more likely to report perceived stress, social support depression, ever having depression in lifetime or percentage of family ever depressed.
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Outcome Measures: | Quality rating:
Wakefield et al., 2004 | To determine whether a motivational interviewing intervention increased successful smoking cessation attempts of patients with cancer attending a South Australian public hospital, as compared with usual care | - Patients were screened by doctors after scheduled appointments in the radiation therapy, medical oncology, and hematology departments at Royal Adelaide Hospital over 20 month period; - After several months, accrual of participants too slow, so patients living remotely were approached to increase numbers; - Once patients consented to participate, they completed a baseline questionnaire; - 6-month follow up interviews were done and those who said had stopped smoking were asked to provide either a urine sample for cotinine analysis or a CO reading using a breath monitor | - Visit with smoking cessation counselor; - Booklets; - NRT; - Family advice to quit; - In-person or telephone follow-up conversation | - Data were analyzed using SPSS; - Fisher's exact tests and chi-square tests were used to establish whether groups differed significantly across categorical variables, and t-tests were used for continuous variables; - An intention to treat analysis was used, as well as an analysis excluding those lost to follow-up evaluation; - Phi coefficients were calculated to determine the degree of association between the intervention and control groups across variables; - Binary logistic regression was used to examine predictors of smoking cessation | - At 6-month follow up, no difference in biochemically confirmed 3-month prevalence quit rates between the intervention (5%) and control (6%) groups; - Sensitivity analysis using more lenient criteria indicated quit rates of 29% for intervention group and 18% for control group (P = 0.32); - Predictors of smoking cessation at 6 months for all patients included a smoking-related cancer site, more cessation attempts in the year before the enrollment study, and no radiation therapy | Poor
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | | Comments:
South Australia | - Cancer patients at South Australian public hospital | G1: 74 | G1: Specific advice and booklets about benefits of quitting for patients with cancer, telephone and in-person counseling using the framework of motivational counseling, supplemented with NRT if patient smoked ≥15 cigarettes per day | Self-report, urine cotinine and CO levels | | Study lacked power, had a high attrition rate and there were significant differences in groups at baseline
Funding agency: | Study type: | C1: 63 | C1: brief advice to quit, widely-available quit-smoking brochures, and info about well-promoted state-based telephone quit-line service | Dependent variables: | | Adequate randomization:
National Health and Medical Research Council | RCT | Definition of smoking: | Method of assessment: | - Quit rates - 3 month period prevalence, 7-day period prevalence | | No
Study setting: | Inclusion criteria: | Tobacco; - Current Smoker - Smoke tobacco at least weekly | In-person follow up visit or telephone assessment at 6 months post-baseline | | | Attrition rate:
Hospital-based | - Participant must have a cancer diagnosis; - Smoke tobacco more than weekly; - Speak English; - Be cognitively able to consent; - Have a prognosis exceeding 6 months; - Live close enough to maximize biochemical confirmation at follow-up assessment* (changed to include patients living remotely to increase participation numbers) | | Baseline data: | | | 36%
| Exclusion criteria: | | Patients in intervention group were more likely than control patients to have ever tried to quit (P = 0.04) and to have made more quit attempts in the past year (P = 0.02)
| See above | | Control patients were more likely to live remotely (P = 0.04)
Holt et al., 2005 | To determine whether bupropion is effective in txt of smoking cessation in indigenous Maori population of New Zealand | - Self-recruitment from mall advertisements; - Recruited from Maori health networks; - Randomized (by computer generated code) | - Individual counseling by health professional; - Individual counseling by non health professional; - Telephone counseling; - Pharmaceuticals | Primary: normal approximation to binomial distribution | Bupropion group more likely to have insomnia (26% vs9% w/ RR = 3.0 and 95% CI 1.1–8.2) | Fair
Geographic area: | Population: | Sample size: | Intervention: | Secondary: GEE | | Comments:
New Zealand | - Adolescents; - Young Adults; - Adults | G1: 88 | G1: Bupropion 150 mg once daily for 3 days, then 150 mg twice daily for 7 wks; smoking cessation counseling | Exploratory: general additive model | | - No ITT analysis; - No attrition reported; - Fell just short of sample size needed according to power analysis; - No analysis for confounders.
Funding agency: | Study type: | C1: 46 | Clinic visits (to assess smoking status, exhaled CO, and adverse events) at 3 wk, 7 wk, | Data verification: | | Adequate randomization:
GlaxoSmithKline | - RCT w/ systematic randomization; - Placebo controlled, double blind, parallel group study | Definition of smoking: | 3 mo, 6 mo, 9 mo, and 12 mo after target quit date | Exhaled CO | | Yes
Study setting: | Inclusion criteria: | Cigarettes | C1: Same as G1 except given identical placebo pills | Dependent variables: | | Attrition rate:
Community-based | - Self-indentified Maori; - Age 16 to 70; - Smoked at least 10 cigarettes per day over last yr; - Desire to quit; - Nonpregnant women w/ reliable contraception | - Smoke ≥ 10 per day on average over last yr | Method of assessment: | Continued abstinence from smoking at 3 and 12 months (or other time points, secondarily) | | NR
Population-based | Exclusion criteria: | | - Self-report; - Fagerstrom score; - exhaled CO
| History of:; - epilepsy; - febrile convulsion; - CNS tumor; - head injury; - cerebrovascular dz; - anorexia; - bulima; - CD; - other severe illnesses; - pregnant or lactating; - drug/alcohol abuse; - unwilling to quit marijuana | | Baseline data:
| | | Mean age (SD): 41.79 (9.2) txt vs 38.0 (11.1) placebo
| | | Mean Fagerstrom index (SD): 5.8 (2.2) txt vs 5.3 (2.0) placebo
| | | Mean initial weight (SD): 85.4kg (18.9) txt vs 80.2 (16.8) placebo; 69.3% female in txt vs 76.1% in placebo
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Of smokers preICU admission, those returning to smoking at 8-wk followup: | Quality rating:
Jones et al., 2001 | Determine whether ICU patients' smoking cessation after critical illness is aided by provision of a rehabilitation program | Recovering ICU patients recruited to study 2 wks after ICU discharge, randomized to receive either usual care followup of unit visits and ICU clinic appointments or routine followup plus an ICU rehabilitation manual | - Self-help; - Social support | NR | G1: 2 | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | C1: 5 | Comments:
United Kingdom | - Adults | G1: 31 (20 smokers) | G1: Verbal encouragement to remain non-smoking at ICU discharge, at 8-wk clinic vist, and six month clinic visit; patients' immediate family instructed not to smoke in same room as patient; 2 wks postdischarge introduction to 6-wk self help ICU rehabilitation manual read by patient and relative that emphasized importance of remaining non-smoking and provided practical tips | Smoking status verified by information from a close family member | RR = 0.24 (CI 0.03–1.84) | Very small study; due to type of article, details about randomization and sampling NR
Funding agency: | Study type: | C1: 30 (16 smokers) | C1: Verbal encouragement to remain non-smoking at ICU discharge, at 8-wk clinic vist, and six-mo clinic visit; patients' immediate family instructed not to smoke in same room as patient | Dependent variables: | Of smokers preICU admission, those returning to smoking at 6-mo followup: | Adequate randomization:
NR | RCT w/ simple randomization | Definition of smoking: | Method of assessment: | - Smoking status; - Levels of anxiety; - Depression; - PTSD-related symptoms | G1: 3 | NR
Study setting: | Inclusion criteria: | Cigarettes | Followup in clinic at 8 wks and 6 mos postdischarge | | C1: 10 | Attrition rate:
Hospital | - Minimum 48 hr ICU admission; - Had been ventilated | NR | Baseline data: | | RR = 0.11 (CI 0.02–.64) | O% attrition
| Exclusion criteria: | | No significant differences in baseline data among C1 and G1 | | No differences in anxiety, depression or PTSD-related symptoms at 6 mos b/w patients who continued to smoke and those who had quit (Mann Whitney U, HAD anxiety P = 0.51, HAD Depression P = 0.74, Impact of Events Scale P = 0.50)
| NR
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | | Quality rating:
Jorenby et al; 1999 | To determine whether buproprion plus NPis more effective for smoking cessation than either cessation aid alone or a placebo | - Subjects recruited at four study sites by advertisements in the media; - First subject enrolled in August 1995, and followup completed in March 1997; subjects randomly assigned to one of four treatments w/ use of an unequal-cell design; - Randomization not balanced within sites | Pharmaceuticals | X^2^ and ANOVA used to test for baseline differences in demographic and smoking-history variables | Proportion of participants abstinent at 6 mo followup: | Fair
Geographic area: | Population: | Sample size: | Intervention: | All statistical tests two-sided and had an alpha level of 0.05 | G1: 38.8% OR = 2.7 (95% CI, 1.7–4.4) P = < 0.001 | Comments:
US | - Adults | G1: 245 | G1: sustained-release bupropion (subjects received 150 mg of bupropion in morning and a placebo tablet in evening on days 1, 2, and 3 of txt; and one bupropion tablet in morning and one in evening on days 4 to 63) plus NP(one patch per day; patches from wks 2 to 7 each contained 21 mg of nicotine, those used during wk 8 each contained 14 mg, and those used during wk 9 each contained 7 mg) | Logistic-regression analysis used to determine pairwise differences among groups in abstinence rates | G2: 34.8% OR = 2.3 (95% CI, 1.4–3.7) P = < 0.001 | NR
Funding agency: | Study type: | G2: 244 | G2: sustained-release bupropion (subjects received 150 mg of bupropion in morning and a placebo tablet in evening on days 1, 2, and 3 of txt; and one bupropion tablet in morning and one in evening on days 4 to 63) plus placebo patch | Kaplan-Meier method used to analyze differences in rates of continuous abstinence; homogeneity among treatments and pairwise differences tested w/ log-rank test | G3: 21.3% OR = 1.2 (95% CI, 0.7–1.9) P = 0.53 | Adequate randomization:
Glaxo Wellcome | - RCT w/ systematic randomization; - Double-blind, placebo-controlled, randomized control trial | G3: 244 | G3: NP(one patch per day; patches from wks 2 to 7 each contained 21 mg of nicotine, those used during wk 8 each contained 14 mg, and those used during wk 9 each contained 7 mg) plus placebo pills 2x per day | Data verification: | C1: 18.8% | Yes
Study setting: | Inclusion criteria: | C1: 160 | C1: placebo pills 2x per day plus placebo patch one time per day | Expired air CO levels assessed to validate self-reported smoking status | Proportion of participants abstinent at 12 mo followup: | Attrition rate:
Community-based | - At least 18 yrs of age; - To smoke at least 15 cigarettes per day; - To weigh at least 45.4 kg (100 lb); - To be motivated to quit smoking; - To speak English; - Only one smoker per household allowed to enroll in study | Definition of smoking: | Method of assessment: | Dependent variables: | G1: 35.5% OR = 3.0 (95% CI, 1.8–4.9) P = < 0.001 | 6 month followup: 30.8%
| Exclusion criteria: | Cigarettes | Followup at 10 wks, 3 mos, 6 mos, and 12 mos after start of study; assessment consisted of self-reported smoking status, vital signs, measurement of expired air CO, and the Beck Depression Inventory | - Primary: smoking status; - Secondary: withdrawl symptoms, body weight, and Beck Depression Inventory scores | G2: 30.3% OR = 2.3 (95% CI, 1.4–3.9) P = < 0.001 | 12 month followup: 34.6%
| Subjects excluded for following reasons: | - Abstinent: no smoking since last clinic visit and expired air CO 10 ppm or less; - Continuously abstinent: no smoking since quit date at expired air CO 10 ppm or less at every clinic visit over 12 mos | | Baseline data: | G3: 16.4% OR = 1.1 (95% CI, 0.6–1.8) P = 0.84, | Adverse events: 8.8%
| - Serious or unstable cardiac, renal, hypertensive, pulmonary, endocrine, or neurologic disorders, as assessed by study-site physician; - Ulcers; - Seizure or dermatologic disorders; - A current dz of major depressive episode or a history of panic disorder, psychosis, bipolar disorder, or eating disorders; - Use of a nrt within six mos before study enrollment; - Pregnancy or lactation; - Abuse of alcohol or a non-nicotine-containing drug within preceding yr; - Use of a psychoactive drug within wk before enrollment; - Use of an investigational drug within mo before enrollment; - Prior use of bupropion; - Current use of other smoking-cessation treatments; - Regular use of any noncigarette tobacco product | | | No significant differences b/w groups | C1: 15.6%
| | | | | All four groups had significant increases in withdrawal symptoms during first wk of txt (P < 0.001) but changes smaller in three active-txt groups than in placebo group during first six days after quitting date and during following wks
| | | | | No txt effect on Beck Depression Inventory scores
| | | | | Subjects in combined-therapy group had gained significantly less weight than those in placebo group (P < 0.05) or bupriopion group
| | | | | (P < 0.05) at wk 7 but no significant differences b/w groups in mean weight changes after wk 7
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Abstinence Rates (NS) | Quality rating:
Killen et al., 2000 | To examine efficacy of smoking cessation treatment that combined nicotine replacement therapy via transdermal system with antidepressant paraxetine | - Recruitment from local newspapers, then telephone interview screen, then initial office visit screen; - Double blind allocation | - Self-help; - Individual counseling | - Intention to Treat analysis; - Logistic regression; - 75% poser to detect at least a 20% increase in abstinence | At 4 weeks | Good
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | G1: 48% | Comments:
US, San Jose, CA | Adults | Total: 224 | G1: NRT transdermal system patch for 8 weeks plus 20 mg paroxetine for 9 weeks | - Self report; - Saliva cotinine concentrations; - Blood level to determine paroxetine compliance level | G2: 57% | NR
Funding agency: | Study type: | About 75 in each group | G2: NRT transdermal system patch for 8 weeks plus 40 mg paroxetine for 9 weeks | Dependent variables: | C1: 45% | Adequate randomization:
University of California Tobacco-Related Disease Research Program; SmithKline Beechum | RCT, double-blind | Definition of smoking: | C1: NRT transdermal system patch for 8 weeks plus placebo for 9 weeks | - Craving; - Adverse events; - Smoking status; - Compliance; - BMI; - Heart rate; - Blood Pressure; - Expired air CO level; - Depressive symptoms | At 10 weeks | Yes
Study setting: | Inclusion criteria: | - Greater than or equal to 10 cigarettes per day; - Abstinence: nonsmoking not even a puff for 7 consecutive days and saliva cotinine level below 20ng/ml an a CO level below 9ppm; - Smokers - reported abstinence but failed to provide a saliva sample | Method of assessment: | | G1: 33% | Attrition rate:
Population-based | - Adults over age 18 | | - In person interview and biomarkers at initial clinic visit; - Telephone interview at 1, 4, 10 and 26 weeks; - Via an interactive voice response system at 24 hours, weeks 2 and 6 | | G2: 39% | Not clear
| Exclusion criteria: | | Baseline data: | | C1: 36%
| - Pregnant, or lactating; - History of severe liver or kidney disease, epilepsy, bipolar disorder, schizophrenia,; - Receiving active treatment for or reported current depression or substance abuse; - Taking antidepressants, psychotropics, or other drugs that could interact with paraxetine resulting in potentially adverse consequences; - Unable to obtain permission from personal physician to participate in the study - for patients with history of heart disease, diabetes, thyroid disease, recent chest pain, very high blood pressure, skin conditions or peptic ulcer | | - Demographics; - Medical status questions; - Smoking history; - Screen for current major depression; - Modified agerstrom Tolerance Questionnaire; - Self-reported depression symptoms; - Clinical diagnosis of depression; - BMI; - Blood pressure and heart rate | | At 26 weeks
| | | | | G1: 21%
| | | | | G2: 27%
| | | | | C1: 25%
| | | | | Chemical Confirmation
| | | | | At 4 weeks: 95%
| | | | | At 10 weeks 98%
| | | | | At 26 weeks 86%
| | | | | Subanalysis of Compliant Persons
| | | | | At 4 weeks
| | | | | G1: 64%
| | | | | G2: 74%
| | | | | C1: 46%
| | | | | P < 0.001
| | | | | At 10 weeks
| | | | | G1: 43%
| | | | | G2: 51%
| | | | | C1: 35%
| | | | | At 26 weeks
| | | | | G1: 33%
| | | | | G2: 38%
| | | | | C1: 24%
| | | | | Those who reported greater use of nicotine patches and those with higher blood levels of paroxetine in Week 4 were more likely to be abstinent
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Abstinence at 3 month followup: | Quality rating:
Lancaster et al., 1999 | To determine whether receiving brief advice from a GP plus extended counseling and followup from a trained nurse resulted in patients' cessation more than brief advice from a GP alone | - Opportunistic recruitment of patients attending the practice w/ unrelated complaints; - Letters to patients identified as smokers by practice records; - 497 patients from 6 practices systematically randomized to receive brief advice from a GP or brief advice from a GP plus extended counseling and followup from a trained practical nurse | - Self-help; - Individual counseling by health professional; - Pharmaceuticals | - Chi sq used to test for differences b/w proportions and 95% CI calculated; - ITT analysis | G1: 9.2% | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | C1: 8.1%, NS | Comments:
United Kingdom | - Adults | G1: 249 | G1: Brief verbal or written advice to quit from the patients' general practitioners, plus: extended counseling and followup from a trained practing nurse; Health Education Authority leaflet on cessation; fact sheet on NRT; invitation to contact research nurse for more intensive, tailored counseling that included CO breath test and a personalized message about benefits of quitting - minimum one 15 min visit plus 1 followup, max five, 10-min followup visits; NRT if necessary | Salivary cotinine levels obtained to validate self-reported quitters | Abstinence at 12 month followup: | Adequate randomization:
Funding agency: | Study type: | C1: 248 | C1: Brief advice to quit from patients' general practitioners | Dependent variables: | G1: 6.8% | Yes
NR | RCT w/ systematic randomization | Definition of smoking: | Method of assessment: | - Sustained abstinence at 3 and 12 mos; - Biochemically validated; - Forward movement on stage of change | C1: 11.3%, NS | Attrition rate:
Study setting: | Inclusion criteria: | Cigarettes | Surveys administered at 3 and 12 months post quit date; salivary cotinine assessed for self-reported quitters; those who did not provide followup information were assumed to be smokers | Baseline data: | Sustained abstinence (abstinent at both 3- & 12-month followup): | 3 mo followup: 19%
Practice/provider settings | - Adults ages 18 and over who smoked at least one cigarette per day | - Smoker: At least one cigarette smoked per day and/or salivary cotinine levels < 113.5 nmol/l | | G1 and C1 similar at baseline in terms of demographics and smoking status | G1: 3.6 | 12 mo followup:25%
| Exclusion criteria: | | | | C1: 4.4
| - NR | | | | Difference: -0.8%
| | | | | (CI, -4.3%, 2.6%)
| | | | | Validated (-3.3 vs4.0)
| | | | | Any forward change in stage of change:
| | | | | G1: 20.9%
| | | | | C1: 26.6%
| | | | | Difference: -5.7%
| | | | | (CI, -13.2%, 1.7%)
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Continuous abstinence since 10 days PP: G1+G2 vs C1: 1.20 (95% CI: 0.29–4.88) | Quality rating:
Lawrence et al., 2005 | To evaluate the effect on quitting smoking at 18 months post partum of smoking cessation intervention based on TTM delivered in pregnancy compared to current standard of care | - Recruited 16 of the 19 midwifery services for West Midlands; - 100 general practices randomized into trial arms; - Allocated by computerized minimization algorithm | Self-help | - Cluster randomization; - Random effects liners regression | Point Prevalence for Abstinence: G1+G2 vs C1: 1.15 (95% CI: 0.66–2.03) | Poor
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | Seven of the 54 (13%) who quit at end of pregnancy were still quit 18 months later | Comments:
West Midlands, UK | Women patients at of antenatal clinics in general practices | G1: 305 | G1: TTM-based self help manuals | Self report | No evidence that TTM-based interventions were superior in preventing relapse | NR
Funding agency: | Study type: | G2: 324 | G2: TTM-based self help manuals plus sessions with interactive computer program giving individualized smoking cessation advice | Dependent variables: | 18 of the 54 (33%) of those who had quite 10 days PP were still quite at 18 months, though 11 of these were not continuously | Adequate randomization:
Department of Health and the West Midland Health Authorities | Cluster randomized trial | C1: 289 | C1: Standard care | - Cotinine saliva; - Continuous and point prevalence abstinence since pregnancy | | NR
Study setting: | Inclusion criteria: | 393 (42%) eligible smokers were followed up on | Method of assessment: | | | Attrition rate:
Practice/provider settings | - At least 16 years of age; - Still smoking at 12 weeks gestation | Definition of smoking: | Medical chart abstraction and follow-up telephone interview | | | NR
| Exclusion criteria: | - Urine cotinine of 1.5 ug/ml; - Abstinence: declared nonsmoking and no cigarette consumption in last 24 hours | Baseline data:
| NR | | - Smoking habits; - Urine cotinine levels; - Fagerstrom Test for Nicotine dependence; - Stage of change; - Demographics; - Parity; - Proportion having a partner; - Proportion whose partner smoked; - Educational achievement; - Household net income
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | No statistically significant difference found between treatment groups at 6 months (G1: 12.2%, G2: 15%, NS) | Quality rating:
Lerman, et al., 2004 | To evaluate the comparative efficacy of transdermal nicotine and nicotine nasal spray and identify predictors of treatment outcome | - Participants were recruited through:; - local media ads for free smoking cessation treatment; - physician referral; - Eligible participants randomly assigned to receive transdermal nicotine or nicotine nasal spray | - Nicotine nasal spray; - Transdermal nicotine therapy; - Standardized behavioral group counseling | - Calculated sample size of 140 per group to detect a between-group difference in quit rates of 8% or greater with 80% power (alpha = 0.05); - Chi square and Wilcoxon rank-sum tests were used to examine differences in pre-treatment variables; - Chi square and Wilcoxon rank-sum tests were used to compare treatment groups on abstinence outcomes; - Logistic regression analysis was used to examine the independent effects of treatment group assignment, pretreatment variables, and their interactions on prolonged abstinence and verified point prevalence abstinence; - Wilcoxon rank-sum tests were used to examine differences between treatment group in use and percentage of cotinine replacement | Abstinence rates similar to those achieved in other studies | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | Smokers who were highly dependent, obese, or members of minority groups achieved higher rates of abstinence with nasal spray | Comments:
United States | Adults ≥18 years old enrolled at Georgetown University and the University of Pennsylvania | 299 adults | G1: 8 weeks of nicotine nasal spray and 7 sessions of behavioral group counseling | - Self-report for prolonged abstinence; - Self-report for point prevalence plus carbon monoxide reading < 10 ppm | | Authors stated that stratification was done by study site but no mention of what was stratified, or how or why
Funding agency: | Study type: | Definition of smoking: | G2: 8 weeks of transdermal nicotine therapy (i.e., patch) and 7 sessions of behavioral group counseling | Dependent variables: | | Adequate randomization:
National Cancer Institute; National Institute on Drug Abuse, and Public Health Services Research grant | RCT | - Prolonged abstinence defined as not having smoked for 7 consecutive days at any time during the follow-up period; - Point prevalence defined as 7 days of continuous abstinence immediately before the follow-up point | Method of assessment: | - Smoking status | | Yes
Study setting: | Inclusion criteria: | | 8 weeks and six month telephone interviews plus biochemical verification for point prevalence | | | Attrition rate:
Population-based | - 18 years of age or older; - Had smoked 10 or more cigarettes per day for the previous 12 months | | Baseline data: | | | 18% lost-to-follow-up
| Exclusion criteria: | | Participants at the University of Pennsylvania site were significantly more likely to be non-white, obese, and have lower levels of education
| - Pregnancy or lactation; - Uncontrolled hypertension; - Unstable angina; - Heart attack or stroke within the previous 6 months; - Current treatment or recent diagnosis of cancer, drug or alcohol dependence; - Current diagnosis or history of a psychotic disorder; - Current use of bupropion or nicotine-containing products other than cigarettes
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Telephone counseling improves cessation rates when used in conjunction with the patch | Quality rating:
MacLeod et al., 2003 | To investigate the effectiveness of telephone counseling as an adjunct to nicotine replacement therapy (NRT) by transdermal patch in smoking cessation | - Recruited smokers from New South Wales via newspaper ads; - Consent forms, questionnaires on health, smoking history and attitudes to quitting were mailed to people who responded to the ads.; - Responses were screened by a pharmacist in accordance with the approved product information for transdermal nicotine patches and eligibility criteria for the study; - Those deemed eligible were randomly allocated to either NRT alone or NRT plus telephone counseling; - Participants were contacted by telephone data collectors to verify their understanding of the study (baseline) | - NRT - patch; - Telephone counseling | - Intent-to-treat approach used, where missing values on smoking status imputed as smokers with 0 days abstinence in that period, unless continuous abstinence between calls was subsequently reported; - Statistical significance between groups was tested by X2 tests and logistical regression (categorical variables) or t tests (continuous variables); - Logistic regression analysis was conducted with both treatment group and duration of patch use included as predictors of 90-day abstinence | 28-day continuous abstinence rates at 6-months: G1 30.6%, C1 22.4%, P =.01 | Good
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | 90-day continuous abstinence rates G1 26.7%, C1 18.6%, | Comments:
Australia | - Smokers from New South Wales; - ≥18 years old | G1: 412 | G1: Nicotine Patch and 5 telephone counseling calls, scheduled at 1,2,3,6 and 10 weeks after baseline | - Self-report, bogus pipeline technique used, with possibility of carbon monoxide breath testing mentioned in the consent form and at the 3- and 6-month monitoring calls | P = 0.004 | No biochemical verification of abstinence - relied solely on self-report
Funding agency: | Study type: | C1: 442 | C1: Nicotine Patch only | Dependent variables: | Logistic regression analysis revealed the duration of patch use and telephone counseling made independent contributions to prediction of 90-day abstinence | Adequate randomization:
GlaxoSmithKline | RCT | Definition of smoking: | Method of assessment: | - 28-day continuous abstinence at 3 and 6 months; - 90-day continuous abstinence at 6 months | Odds of successful quitting increased with each extra week of patch use when treatment group held constant (OR=1.24, P < 0.05) | Yes
Study setting: | Inclusion criteria: | Cigarettes | Brief (5 minute) follow-up telephone questionnaires were administered at 1, 2, 3, and 6 months post-baseline | | When controlling for weeks of patch use, the odds of success were higher for those in the counseling group (OR=1.46, P < 0.05) | Attrition rate:
Population-based | - Aged ≥18 years; - English-speaking; - Smoking ≥10 cigarettes per day for the previous year; - Ready to begin a quit attempt within 1 week | - Current Smoker - Smoking ≥10 cigaretters per day for the previous year; - 28-day continuous abstinence (used at 3 and 6 month follow up calls) - complete abstinence, “not even a puff” for at least the previous 28 days; - 90-day continuous abstinence - the reported date of the last cigarette smoked was at least 90 days before 6 month follow-up call | Baseline data: | | | 16%
| Exclusion criteria: | | No significant differences b/w the 2 groups
| - History of cardiovascular disease, diabetes or skin sensitivity; - Currently breastfeeding, pregnant or intending to become pregnant; - Using contraindicated medications
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | No statistically significant difference between groups at any follow up point | Quality rating:
McBride et al., 2004 | - To evaluate whether relative to usual care and a previously evaluated woman-only intevention, if training in optimal support behaviors and giving support to partners increased abstinence rates among pregnany women during and after pregnancy; - 2nd aims - decrease postpartum relapse and increase rates of smoking cessation among partners | - Introductory letters describing the study were sent on behalf of WAMC to all women identified from automated appointment logs with a scheduled 1st prenatal visit.; - Women who did not call study's toll-free number w/in 10 days to decline contact were called to complete screening survey; - Eligible women who agreed to participate were stratified by smoking status (smoker or recent quitter), their partner's smoking status (smoker or nonsmoker) and partner's level of willingness (not at all vs somewhat or very); - Once stratified, participants were then randomly assigned to one of 3 conditions: usual care (UC), woman only (WO) or partner assisted (PA); - Women and partners completed telephone surveys at baseline (about 11 weeks of pregnancy) | - Provider advice; - Self-help quit guides; - Telephone counseling; - Pregnancy relapse kit; - Telephone counseling and support guide geared towards partners | - Logistic regression was used to compare the 2 experimental conditions to the control condition on each outcome measure, controlling for baseline smoking-specific support variables and predictors known to be associated with smoking cessation trials; - Intent-to-treat approach used, where missing values on smoking status imputed as “smoker”; - Comparison on the experimental conditions to the control condition on dichotomous secondary outcomes, such as postpartum relapse and partners' prevalent abstinence, were made with logistic regression; - Proportional hazards model was used to compare conditions on time to relapse, where time to relapse defined as the number of days b/w woman's delivery date and the date she resumed smoking; - Differences by condition for changes in women's and partner's smoking-specific support and general support across time were tested with mixed linear-model repeated measures analysis | No statistically significant difference between groups in the proportion relapsed at any postpartum follow-up | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | In late pregnancy (28 weeks), more partners abstinent in G2 group (15%) than C1 group (5%) P = 0.02 | Comments:
United States | - Pregnant woman who received prenatal care at the Womack Army Medical Centers; - Their live-in partners | G1: (WO): 192 | G1: Usual care plus late pregnancy relapse kit, and 6 counseling calls | Self-report, salivary cotinine | Women in all groups consistently reported a decline in positive partner support from baseline to 12-month postpartum (F=81.43, df=1322, P < 0.001) | By only including women who agreed to involve their partners, couples who were inclined to support each other and attentuated treatment effects may have been over-represented
Funding agency: | Study type: | G2: (PA): 193 | G2: G1 plus the partners received telephone counseling and support guide (partners who smoked received cessation aids and counseling) | Dependent variables: | | Adequate randomization:
National Cancer Institute | RCT | C1: (UC): 198 | C1: Usual Care: provider advice to quit and self-help guide | - Abstinence at 28 weeks, 2, 6 and 12 months postpartum; - Sustained abstinence | | Yes
Study setting: | Inclusion criteria: | Definition of smoking: | Method of assessment: | | | Attrition rate:
Military Medical Center | - Eligible women were ≤20 weeks pregnant; - Aged ≥18 years; - Current smokers or recent quitters; - Living with an intimate partner; - Willing to have the partner contacted for participation in the study | Cigarettes | - Telephone surveys of the women and partners at 28 weeks pregnant, postpartum and 2, 6, and 12 months; - Self reported smoking status assessed at each follow up with the question “have you smoked any cigarettes in the past 7 days?”; - Saliva samples collected by mail at 28 weeks pregnancy and 12 months postpartum from women and partners who reported not smoking in the previous 7 days | | | 19%
| Exclusion criteria: | - Current Smoker - NR; - Recent quitter - smokers in the 30 days prior to pregnancy but not smoking at intake; - Prevalent abstinence - no smoking in prior 7 days; - Sustained abstinence - no smoking across all 4 follow-up times | Baseline data:
| - >20 weeks pregnant; - Partner not available, or refused partner contact | | No significant differences b/w any of the groups
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Point Prevalence of Abstinence: no significant differences by condition at any assessment point | Quality rating:
Mermelstein et al., 2003 | To compare the relative efficacy of two types of proactive telephone calls following a group cessation program. | - Participants recruited primarily through paid advertisements, media coverage of the program, flyers and referrals; - 905 smokers attended the first group meeting; - 771 smokers completed the group program; - 756 smokers were assessed at least once over the follow-up period | - Group meetings; - Telephone counseling | NR | Post-hoc analysis by condition by gender at all assessment points showed that men receiving the enhanced condition were more likely to abstain while women were more likely to abstain when participating in the basic condition. | Poor
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | | Comments:
US | Participants completing a group smoking cessation program | G1: (basic): 375 | G1: Enhanced: Basic program (see C1 below) plus telephone counseling call content varied by participants' smoking status (i.e., still smoking, abstinent, slipped or relapsed); if still smoking or relapsed also received a videotape; plus abstinent counseling on keeping motivation and self-efficacy high using a variety of techniques | Expired air carbon monoxide and saliva cotinine used to verify abstinence at each major assessment point for participants reporting abstinence | | - No true control group (i.e., those in group program with no telephone follow-up). So no true comparison of whether calls had an effect.; - Random assignment method NR; - Population not described; - No inclusion/exclusion criteria specified
Funding agency: | Study type: | G2: (enhanced): 381 | C1: BasiC1: 7 week group treatment program of telephone counseling giving only words of encouragement without specific guidance | Dependent variables: | | Adequate randomization:
National Heart, Lung and Blood Institute and National Cancer Institute | RCT | Definition of smoking: | Method of assessment: | - Abstinence: no smoking at all in the past 7 days; - Relapse: smoking one one or more days of the past 7 after achieving an initial 7-day period of abstinence at the end of the group program | | NR
Study setting: | Inclusion criteria: | Tobacco dependence as measured by the Fagerstrom Tolerance Questionnaire | 3-,6-,9-,12- and 15-month follow-ups via telephone | | | Attrition rate:
NR | NR | | Baseline data: | | | 6-month: 1%
| Exclusion criteria: | | No significant differences between conditions on any variables or on percentage with a history of depression | | | 15-month: 4%
| NR
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Quitting at 1 yr G1 vs C1: | Quality rating:
Murray et al., 2001 | To evaluate hypothesis that Black smokers will respond differently than Whites to a smoking cessation intervention program where no adjustments are made in recognition of cultural differences | NR | - Group counseling; - Pharmaceuticals | Covariate data used to explore differences using regression t-tests etc. | Blacks: AOR: 1.48 | Poor
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | Whites: AOR: 5.99 | Comments:
US | - Adults; - African Americans | G1: 3,923 | G1: SI (12-wk group program using a quit day in second wk, followed by 4 consecutive days of group meetings) w/ bronchodilator therapy | - Salivary cotinine annually; - Expired CO throughout intervention program and subsequently at 4-mo intervals | P = 0.002 | Large differences in baseline comparisons b/w white and black negate any differences that occur in outcomes, small sample size
Funding agency: | Study type: | C1: 1,964 | G2: SI w/ placebo inhalers | Dependent variables: | Quitting at 5 yrs: | Adequate randomization:
Division of Lung Disease of the National Heart, Lung, and Blood Institute | RCT w/ simple randomization | Definition of smoking: | C1: Usual care- annual physician visits | Smoking cessation | G1 vs C1 | No
Study setting: | Inclusion criteria: | Cigarettes | Method of assessment: | Baseline data: | Blacks: AOR: 1.87 | Study not designed for this comparison
Practice/provider settings | - Age 35–60 yrs; - Mild COPD; - Current smoker | Defined as smoking at any clinic visit | - Interviews at baseline and annually for 5 yrs; - Annual saliva collection | Baseline data comparisons b/w 2 groups showed significant differences | Whites: AOR: 3.34 | Attrition rate:
| Exclusion criteria: | | | Black population had more women (46% vs37%) P = 0.01, less education, less income, less likely to be married (48% vs70%), smoked less (23.5 vs32.9 per day) | P = 0.06 | NR
| - Serious health conditions likely to to affect lung function or ability to stay in trial for 5 yrs; - Use of regular medications that might alter lung function | | | | Significant txt effect for Blacks over 5 yrs of study (OR = 1.95, P = 0.04)
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | At 12-month followup, 7-day point prevalence for non-smoking: | Quality rating:
Peterson, 2004 | To evaluate whether a nurse-managed smoking cessation and relapse prevention program reduced smoking rates at 12 mos in women admitted to hospital w/ CD | NR | - Self-help; - Individual counseling by health professional; - Telephone counseling | NR | G1: 48% | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | C1: 42% | Comments:
US | - Adults,; - Women (only) | G1: 142 | G1: Brief physician counseling and usual care plus nurse managed, cognitive behavioural, relapse prevention intervention given before discharge, <5 structured telephone contacts 2–90 days after discharge, and relapse management counseling as needed | Self-reported smoking status (abstinence in past 7 days) verified by cotinine levels and family/friends | RBI: 14% (95% CI, -14 to 51), | NR
Funding agency: | Study type: | C1: 135 | C1: Brief physician counseling, a self help pamphlet, and a list of community resources | Dependent variables: | P = NS | Adequate randomization:
National Heart, Lung, and Blood Institute | RCT w/ systematic randomization | Definition of smoking: | Method of assessment: | Smoking status | | NR
Study setting: | Inclusion criteria: | Cigarettes | NR | Baseline data: | | Attrition rate:
Hospital | - Female; - At least 18 yrs of age; - Admitted to hospital w/ CVD or peripheral vascular disease; - Had smoked cigarettes in month before admission; - Willing to make a serious attempt to quit smoking after discharge | - Abstinent: no smoking in past 7 days | | NR | | 11%
| Exclusion criteria:
| - Medical instability; - Alcohol or substance abuse; - Dementia; - Schizophrenia
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Quit rate at 12 months: | Quality rating:
Quist-Paulsen and Gallefoss, 2003 | To determine whether a nurse led smoking cessation intervention affects smoking cessation rates in patients admitted for coronary heart disease | - Invited to participate in study all patients admitted to Vest-Agder Hospital for myocardial infarction, unstable angina, or care after coronary bypass surgery performed at other hospitals; - 1016 patients assessed for eligibility; - Nurses recruited patients 2–4 days after admission; - Participants answered baseline questionnaire and were randomly allocated to usual care (control group) or intervention; - Nurses given serially numbered sealed envelopes from secretary otherwise uninvolved in study; - Randomization was in blocks of varying sizes; - 250 patients randomized; 10 were later withdrawn | - Group sessions with cardiac nurses, including seeing a video and getting info booklet; - Telephone counseling; - Self-help | - Chi-square test used to assess effect of intervention; - NNT calculated with confidence intervals; - Simple and multiple logistic regression models used to test relation between baseline characteristics and outcome measures; - SPSS used for all analyses | G1: 57% | Good
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | C1: 37% (absolute risk reduction 20%, 95% CI 6.4–33.0; P = 0.004) | Comments:
Norway | Adults under 76 yrs of age | G1: 118 | G1: Cardiac nurse consulted patients 1–2 times during hospital stay. Intervention based on booklet focusing on fear arousal and prevention of relapse. Booklet emphasized health benefits of quitting smoking after coronary event, including illustrations showing mortality differences for those who continued smoking after coronary condition vs. those who quit, information on how to prevent relapse, how to stop smoking, how to use nicotine replacement.; also explained how to identify & cope with high risk situations for relapse. Nurses contacted participants by telephone 2 days, 1 week, 3 weeks, 3 months & 5 months after discharge. At 6 weeks aoo participants in G1 had consultation at outpatient clinic with nurse. | Self-report and urine analysis | NNT to get one additional person who would quit was 5 | - Well-reported—interventions and methods fully described; - Objective outcome measure (urine test); - Loss-to-follow up treated as relapsed smokers yielding valid ITT analysis
Funding agency: | Study type: | C1: 122 | C1: Patients were offered group sessions twice/week with nurses where importance of smoking cessation was mentioned; a video was shown and booklet distributed giving general information on coronary heart disease and advice on quitting smoking. No further specific instructions on how to quit were given | Dependent variables: | Assuming dropouts relapsed at 12 months, smoking cessation rates were: | Adequate randomization:
Vest-Agder Council for Public Health and the charity Sykehuset i vaare hender | RCT | Definition of smoking: | Method of assessment: | - Number of days spent in ICU; - Myocardial infarction as reason for admission; - No previous coronary heart disease; - Employment | - G1: 50%; - C1: 37% (absolute risk reduction 13%, 95% CI 0%–26%) | Yes
Study setting: | Inclusion criteria: | - Daily smoker until start of present coronary symptoms | Self report and biochemical verification of smoking cessation rates at 12 months | | Smokers who stated they were still smoking were classified as smokers | Attrition rate:
Cardiac ward of a general hospital | - Patients under the age of 76 admitted for myocardial infarction, unstable angina, or cardiac bypass surgery who had been daily smokers until the start of their present coronary symptoms. Patients had to be sufficiently recovered to reliably receive the intervention and had to live in Vest-Agder or Aust-Agder county. | | Baseline data: | | Those who claimed they had quit and had a nicotine metabolite concentration in urine < 2.0 mmol/mol creatinine were classified as non-smokers | - 10 post-randomization exclusions; - LTF at 12 months(not including post-randomization exclusions): 9% (G1: 15.3%, C1: 3.1%)
| Exclusion criteria: | | - Fewer employed in C1 than in G1; - More with post primary education in C2 than in G1 | | G1: average of 1.6 (SD 0.7) consultations as inpatients and 1.6 (SD 1.5) as outpatients; also received a mean of 8.5 (SD 3.2) telephone calls
| - Patients with serious illness associated with short life expectancies, serious psychiatric problems, alcoholism, and dementia | | | | Mean total time devoted to each patient was 147 minutes (SD 50)
| | | | | Use of nicotine replacements:
| | | | | G1: 36%
| | | | | C1: 28% (without a statistically significant difference)
| | | | | 9% of patients who smoked while in hospital or at 6 wks were abstinent at 12 months
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Treatment group participants (73.0%) were more likely to fast than were controls (53.0%): | Quality rating:
Ratner et al., 2004 | Test an intervention to help smokers abstain (fast) from smoking before surgery, maintain abstinence postoperatively, and achieve long-term cessation | Elective-surgical patients in | - Counseling; - Nicotine replacement therapy | - Univariate descriptive statistics; - Hypothesis testing using contingency tables and chi-square; - Treatment effect- multi-step logistic regression | χ^2^(1,N=228)=8.89, P=.003, and more likely to be abstinent 6 months after surgery (31.2% vs. 20.2%). | Fair
Geographic area: | Population: | - Cardiovascular; - Opthalmology; - Orthopedics; - Plastics; - Urology | Intervention: | Data verification: | There was no significant difference in the abstinence rates at 12 months after surgery,χ^2^(1, N=169) | Adequate randomization:
Western Canada | Patients admitted for presurgical assessment from Nov. 1999 to Oct 2001 | Sample size: | - 2 face to face counseling sessions; - 9 telephone counseling sessions | - Cotinine assay; - CO measure | < 0.001, P =1.00. | Yes
Funding agency: | Study type: | 237 | Method of assessment: | Dependent variables: | | Attrition rate:
National Cancer Institute of Canada | Randomized pretest-posttest control group experiment | Definition of smoking: | - CO measure; - Cotinine assay; - Self-report | - # days until follow-up; - Age; - Education; - Self-efficacy; - POMS; - Fagerstrom test; - Other household smokers; - Smoking stage of change | | 28.70%
Study setting: | Inclusion criteria: | - Smoked in 7 days before surgery | Baseline data:
Teaching hospital | - Self-identified smokers within previous 7 days; - Remain in hospital for at least 24 hours following surgery; - Speak and write English; - Able to be contacted by phone; - Willing and able to participate | | Similar in both groups
| Exclusion criteria:
| NR
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | At 3 months stepped-care treatment increased smoking cessation rates from 42% to 53% during a 3-month follow-up period (P = 0.05) | Quality rating:
Reid et al., 2003 | To determine whether stepped-care treatment helped smokers hospitalized with CAD to quit smoking over 3-month and 1-year follow-up periods. | - 8330 patients admitted for coronary angiography, PTCA, MI, or CABG were screened; - 1379 (16.6%) were identified as cigarette smokers; - 419 individuals who met all eligibility criteria; - 254 (60.6%) agreed to participate | - Self-help; - Stepped-care treatment | - Baseline subject characteristics - t tests for continuous variables and chi-square tests for categorical variables.; - Primary analysis- a Fisher's exact test was used to compare 3-month and 1-year rates A secondary analysis univariate and multivariate logistic regression procedures | 1-year follow-up minimal intervention group of 36% versus 39% for the stepped-care group (P = 0.36) | Good
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | | Comments:
Ottawa, Canada | - Patients hospitalized with CAD; - Age of 18 years or more; - Motivated to quit smoking | G1: 126 | G1: called by a nurse-counselor 4 weeks after discharge and questioned. If not smoking, provided positive reinforcement and reminded about relapse prevention information in the booklet. If smoking, nurse counseling was begun, 3–20 minute face to face sessions over 8 weeks and nicotine patch therapy was made available | Self-reported with a random sample of 25 tested for CO levels | | - Well-thought out design; - Well reported
Funding agency: | Study type: | C1: 128 | C1: no additional counseling after hospital discharge; free to seek assistance from community or primary care physician | Dependent variables: | | Adequate randomization:
NR | RCT | Definition of smoking: | Method of assessment: | - Demographic factors; - reason for admission; - smoking history; - nicotine dependence; - self-efficacy; - motivational readiness variables | | Yes
Study setting: | Inclusion criteria: | - 5 or more cigarettes a day; - Did not include users of pipes, cigars or smokeless tobacco exclusively | Surveyed by mail 3 months and 1 year after hospital discharge. If the questionnaire was not returned promptly, the participants were called, and the questionnaire was completed by telephone | | | Attrition rate:
Tertiary care cardiac facility | - At least 18 years or age; - Hospitalized with coronary artery disease | | Baseline data: | | | C1: 19.5%
| Exclusion criteria: | | - Groups balanced for age, gender, education level, reason for admission, cigarettes per day, Fagerstrom score, years of smoking, quit attempts, motivational readiness to quit smoking, self-efficacy, and preference for cessation assistance | | | G1: 9.5%
| - Unresolved unstable angina; - Life-threatening arrhythmias; - Vasospastic diseases (buerger's disease, prinzmental's variant angina); - Pregnant or lactating women; - Those who lived more than 1 hour of travel time away
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Verified quit rate: | Quality rating:
Rowe et al., 1999 | To evaluate effectiveness of offering an individualized approach to smoking cessation to qualified nurses and student nurses in Northern Ireland | - Nurses and student nurses from a college of nursing and a large hospital trust who self-identified as smokers and wanting to quit were invited to participate in study; - Participants could choose to be in intervention group or control | - Self-help; - Individual counseling by Health professional; - Social support | Frequencies | G1: 22.7% vs 8.6% (C1) | Poor
Geographic area: | Population: | Sample size: | Intervention: | Fisher's Exact Test | P < 0.05 | Comments:
United Kingdom | - Adults | G1: 22 (nurses) | G1: (Qualified nurses): received individual counseling to: (1) assess health beliefs and motivation to quit smoking; (2) plan and implement strategy for quitting (set quit date, discuss coping strategies, identify social support, keep smoking success and failure diary) and make subjects aware follow up would occur at 6 wks, 6 months, 1 yr postintervention. | Qualitative data | G2: 25% vs 6% in C2 | Participants self-selected to intervention and comparison group status; at 1 yr followup, participants self-selected whether to answer a questionnaire for smokers or for non-smokers; motivation and determination to quit smoking higher among intervention groups vscomparison groups, factors not controlled for in analyses; not given all data regarding intervention vscomparison groups (sometimes %s given, but not per group status)
Funding agency: | Study type: | G2: 32 (Student nurses) | G2: (Student nurses): Same intervention as G1 | Data verification: | P < 0.05 | Adequate randomization:
NR | Cohort study | C1: 23 (nurses); 33 (student nurses) | C1: (Qualified nurses) and C2 (Student nurses) received no smoking cessation counseling or assistance, but were followed up at 6 months and 1 yr postenrollment | Self report of smoking status | | Not a RCT, but problematic group membership because participants self-selected into intervention or comparison group per their desire to receive smoking cessation assistance (intervention groups) or to try to stop smoking on their own (comparison group)
Study setting: | Inclusion criteria: | Definition of smoking: | Method of assessment: | For those reporting no smoking, verified through CO in expressed alveolar air (2–10 ppm = non-smoker; 11–60 ppm = smoker) and through salivary cotinine concentrations (20 ng/ml = non-smoker) | | Attrition rate:
Worksite | - Qualified nurse (“nurse”) or student nurse; - Smoked at east one cigarette daily; - Expressed desire to quit smoking; - Agreed to participate in study as an intervention or control participant | Cigarettes | Self-report on questionnaires and biochemical verification of non-smoking status | Dependent variables: | | At 1 yr, 5% overall (no further attrition detail provided and unable to determine from tables presented)
| Exclusion criteria: | - Unclear, but to enroll, had to report smoking at least one cigarette daily (also see Dependent Variables section) | Followup conducted at 6 wks postintervention for intervention groups, at 6 months and 1 yr for both intervention and Cs | - Verified quit rate; - Perceptions of smoking and health; - Perceptions of their health promotion role
| Did not meet all inclusion criteria | | Definition of smoking: | Baseline data:
| | | Cigarettes | Nurses: G1 and C1 similar (age 23–56 yrs; 45% of G1 and 49% of C1 had spouses, partners, or parents who smoked; 95.5% female)
| | | - Unclear, but to enroll, had to report smoking at least one cigarette daily (also see Dependent Variables section) | G1 and C1 similar in smoking history (89% began smoking before nursing, 64% smoked 20 cigarettes daily; 82% had been smoking more than 10 yrs)
| | | | 68% G1 vs100% C1 tried to quit smoking previously (no test)
| | | | Student nurses: 62% b/w 17–21, range 17–36; 60% had family members who smoked; 91% female; 91% single (no further detail by group)
| | | | 97% of G2 and 94% C2 began smoking before entering nursing; range of smoking = 1–10 yrs, 68% smoked b/w 1–6 yrs
| | | | 88% G2 and 73% C2 smoked 10–20 cigarettes daily
| | | | About 75% of each group had tried to stop smoking at least once before
| | | | 100% of G2 and C2 accepted smoking did or might influence their or their family's/friends' health
| | | | 78% of G2 and 45% C2 experiencing some ill health effect of smoking
| | | | # Perception of role as health promoter:
| | | | G1: 100%
| | | | C1: 96%
| | | | G2: 94%
| | | | C2: 82% (no test)
| | | | All Groups: Motivation to quit smoking (“want to very much” or“would like to”):
| | | | G1: 100% vs
| | | | C1: 65%, P < 0.01
| | | | G2: 61% vs C2: 61%
| | | | (P < 0.01)
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | No significant differences observed in smoking status at end of trial (assuming that end of trial was at 12-months post quit date although time frame is not stated in the article text or table for these assessments): | Quality rating:
Saules, et al., 2004 | To test effect of fluoxetine on smoking cessation in the context of a program that includes group cognitive-behavioral therapy (6 weeks) and transdermal nicotine patch (10 weeks) | - Participants recruited by flyers and notics distributed throughout the university and through paid advertisements in local newspapers and radio stations.; - Telephone screening of all respondents.; - Candidated attended a screening visit at which expired CO reading were required to be greater ahn or equal to 15 ppm. | - Pharmaceuticals: fluoxetine and transdermal NRT; - Cognitive-behavioral counseling (CBT) | Chi-square analysis | C1: 35.4% | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | G1: 43.1% | Comments:
US | Adults | G1: 51 | G1: Fluoxetine (20mg) 4 weeks before quit date, changed to 40 mg fluoxetine after one week, CBT starting 2 weeks before quit date and 15 mg NRT patch on morning after quit date visit | Expired CO of less than 10 ppm obtained for self-reported quitters | G2: 43.1% | Random assignment method NR
Funding agency: | Study type: | G2: 51 | G2: Fluoxetine (20mg) 4 weeks before quit date and for 15 weeks total, CBT starting 2 weeks before quit date and 15 mg NRT patch on morning after quit date visit | Dependent variables: | Change in weight was significant for treatment group (P = 0.010), smoking cessation (P = 0.037) and their interaction (P = 0.012). Withdrawal symptom scores were significantly lower in both fluoxetine groups as compared to the placebo group | Adequate randomization:
National Institute on Drug Abuse and State of Michigan | Randomized, double-blind, placebo-controlled trial | C1: Placebo | C1: Placebo and CBT starting 2 weeks before quit date and 15 mg NRT patch on morning after quit date visit | Documented nonsmoking: self-reported abstinence combined with CO less than 10 ppm | (P = 0.038) | NR
Study setting: | Inclusion criteria: | Note: planned sample size was 168 with 56 participants per arm | Method of assessment: | | | Attrition rate:
Population-based | - Adults 21–65; - Smoking > 15 cigarettes/day; - Producing CO. 15ppm | Definition of smoking: | NR | | | 40%
| Exclusion criteria: | Self-reported smoking of any cigarettes at all (or even part of one cigarette), CO greater than or equal to 10 ppm | Baseline data: | | | Drop-out was related to smoking status, as 90% of the people who did not complete the study had documented smoking at their last assessment whereas only 32% of those who completed the study had documented smoking at the last assessment (X^2^(1)=9.94, P = 0.002)
| - Candidates in acute psychiatric crisis; - Met criteria for apsychieatric disorder within the past six months; - Were currently taking psychiatric medications; - Clinically significant medical conditions; - Pregnant; - Inability to comprehend and respond to measures | | No significant differences across groups except for significant differences in baseline depression with elevated levels among those randomized to placebo.
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | No statistically significant differences in smoking cessation rates at end of medication 3, 6, and 12 months | Quality rating:
Simon et al., 2004 | Whether the addition of bupropion to transdermal NRT and cognitive-behavioral counseling would increase quit rates compared with standard therapy using NRT and cognitive-behavioral counseling only | Participants were recruited from the three following sources: | - Bupropion; - Transdermal nicotine replacement therapy; - Cognitive-behavioral counseling | - 2-sample t tests and Wilcoxon rank sum tests for continuous variables; - Chi square tests for categorical variables; - Calculated relative risk and 95% CIs; - For multi-variate analysis, used backward stepwise procedure to examine relationship between demographic and historical variables and smoking cessation; - Variables were retained in the model if they remained associated with quitting at P ≤ 0.20; - All regression models were adjusted for treatment assignment; - Hosmer-Lemeshow goodness-of-fit test was used to assess adequacy of the models; - 2-tailed P values < 0.05 were considered significant | The addition of 7-week treatment with Bupropion did not significantly increase quit rates over NRT and counseling | Fair
Geographic area: | Population: | - Lists of known smokers from previous smoking cessation clinical trials at the San Francisco VA Medical Center; - Hospital-based advertising at major teaching hospitals; - Local Bay Area advertising and PSAs | Intervention: | Data verification: | | Comments:
United States | Adults | Eligible smokers were assessed for their readiness to quit smoking | G1: 7 week course of Bupropion, 2 months transdermal nicotine replacement therapy, 1 visit with counselor (30–60 minute session), and 5 telephone follow-up calls | Self-report plus cotinine saliva for those who self-reported quitting at the 12 month followup | | No power analysis
Funding agency: | Study type: | Subjects in the contemplation or preparation stages of quitting were randomized to either treatment or control arm | C1: Same as G1 except participants received placebo instead of Bupropion | Dependent variables: | | Adequate randomization:
California Tobacco-Related Disease Research Program | RCT | Sample size: | Method of assessment: | Quit rates | | Yes
Study setting: | Inclusion criteria: | 244 adults | Follow-up at 7 weeks (end-of treatment), 3 months, 6 months, and 12 months by telephone | | | Attrition rate:
Hospital | - Smoked 20 or more cigarettes during the week prior to enrollment; - Have a telephone and no plans to leave the catchment area during the study period; - In the contemplation or preparation stages of quitting according to the Prochaska and DiClemente Stages of Change model; - ≥ 20 years of age | Definition of smoking: | Baseline data: | | | - 1% lost to followup; - 2% died
| Exclusion criteria: | Non-smoker | No statistically significant differences in any of the baseline demographic of medical characteristics between the samples in the 2 study arms
| - Contraindications to bupropion or NRT; - Serious psychiatric illness including major depression; - History of alcohol abuse within the past three months or consuming more than 3 alcoholic beverages per day | - Self-report of no smoking for the past seven days during each follow-up counseling call; - Follow-up self report of no-smoking in the past six months and twelve months; - Among those who reported no smoking at 12 months, follow-up saliva cotinine level had to be less than 15 ng/ml | Males: 86%
| | Continous non-smoker
| | - Self-reported quitting at each follow-up assessment, and biochemical or proxy verification of no smoking at 12 months
| | Smoker
| | - Self-reported no smoking but using NRT and salivary cotinine levels >= 15 ng/ml; - Stopped smoking cigarettes but using other tobacco products
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Swan 2003a | Quality rating:
Swan^a^, et al., 2003 and Swan^b^ et al., 2003 | Swan:^a^ To identify individual characteristics predictive of more clinically relevant smoking end-points beyond end of treatment in smokers prescribed bupropion SR and counseling. | - Participants who called the study center were screened over the telephone.; - Eligible volunteers were sent a pretreatment questionnaire and consent form.; - Participants were randomly assigned to 4 treatment arms by a computer-generated number.; - The computer code calculated probabilities of group assignment that were dynamically modified based on the number of members in each group so that final group sizes were equal.; - No restrictions such as stratification or blocking were used in the process. | - Pharmacologic treatment; - Tailored mail program (ZAP); - Proactive telephone counseling program (Free and Clear Program) | - Intent-to-treat analysis; - Logistic regression for assessing pretreatment characteristics for their relationship to point-prevalent smoking at 12 months | At 12-month follow-up, type of behavioral treatment had a strong association with point-prevalent smoking (e.g., participation in the less-intensive TM program being associated with a greater likelihood of smoking) whereas dose and the dose x treatment interaction had little or no association with outcome OR=1.21 (95% CI, 1.08–1.35). | Fair
Geographic area: | Swan:^b^ To determine the differential effectiveness of 2 doses of bupropion in combination with behavioral interventions of minimal to moderate intensity. | Sample size: | Intervention: | Data verification: | Swan 2003b | Comments:
US, Seattle | Population: | G1: 382 | G1: 150 mg bupropion SR and proactive telephone counseling (Free and Clear Program) | Self-report | - At 3 months:; 300mg G3: 35% vs 150 mg; G1: 24.4% (P=0.001); 300mg G3: 35% vs 150mg; G2: 24.2% (P =0.001); 300mg; G3: 35% vs 300mg G4= 26.7% (P =0.01); - At 12 months:; 300mg G3: 33.2% vs 150mg G2: 23.6% (P =0.004); 300mg G3: 33.2% vs 300mg G4: 25.7% (P =0.02); 150 mg G1: 31.4% vs 150mg G2: 23.6% vs (P =0.02) | - Lack of blinding; - No biochemical confirmation of self-reported smoking status; - No objective measurement of adherence to the therapeutic regime
Funding agency: | - 18 years of age or older | G2: 381 | G2: 150 mg bupropion SR and tailored mail ( Zyban Advantage Plan - ZAP) | Dependent variables: | | Adequate randomization:
National Cancer Institute | Study type: | G3: 383 | G3: 300 mg bupropion SR and proactive telephone counseling (Free and Clear Program) | - Smoking: any smoking within the 7 days prior to follow-up | | NR
Bupropion SR provided by Group Health Cooperative Pharmacy | - Data from a large, randomized effectiveness trial; - Two dosage levels of bupropion SR (Zyban, 150 and 300 mg) were crossed with two behavioral treatment programs of lower or higher intensity to create a four-cell design. | G4: 378 | G4: 300 mg bupropion SR and (ZAP) | | | Attrition rate:
Study setting: | Inclusion criteria: | Definition of smoking: | Method of assessment: | | | - 3-month follow-up: 20.8%; - 12-month follow-up: 14.9%
Non-profit consumer-governed health care system serving 600,000 residents of western Washington (GHC) | - Individuals at least 18 years of age; - Smoking an average of 10 or more cigarettes per day in the 12 months prior to enrollment; - Motivated to stop smoking; - Otherwise in good general health and had proper GHC coverage | - Any smoking within the past 7 days (7 day point prevalence) | 3- and 12-month follow-up
| Exclusion criteria: | | Baseline data:
| - Predisposition to seizure; - Current use of medications contraindicated for use with bupropoion SR or know to lower seizure threshold; - History of or current diagnosis of anorexia nervosa or bulimia or presence of any severe chronic medical condition; - Use of any investigational drug within 1 month of treatment with buropion SR; - Participation in GHC's Free and Clear smoking cessation program in the previous 12 months; - Current depression; - Recent high frequency or binge drinking; - Abuse of other substances including recreational/street drugs; - Current pregnancy or plans to become pregnant; - Current nursing of a child | | - Reported by gender not treatment condition.; - Men had significantly more years of formal schooling, smoked more cigarettes per day, had higher number of previous attempts to quit.; - Women significantly more likely to report perceived stress, social support depression, ever having depression in lifetime or percentage of family ever depressed.
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Outcome Measures: | Quality rating:
Wakefield et al., 2004 | To determine whether a motivational interviewing intervention increased successful smoking cessation attempts of patients with cancer attending a South Australian public hospital, as compared with usual care | - Patients were screened by doctors after scheduled appointments in the radiation therapy, medical oncology, and hematology departments at Royal Adelaide Hospital over 20 month period; - After several months, accrual of participants too slow, so patients living remotely were approached to increase numbers; - Once patients consented to participate, they completed a baseline questionnaire; - 6-month follow up interviews were done and those who said had stopped smoking were asked to provide either a urine sample for cotinine analysis or a CO reading using a breath monitor | - Visit with smoking cessation counselor; - Booklets; - NRT; - Family advice to quit; - In-person or telephone follow-up conversation | - Data were analyzed using SPSS; - Fisher's exact tests and chi-square tests were used to establish whether groups differed significantly across categorical variables, and t-tests were used for continuous variables; - An intention to treat analysis was used, as well as an analysis excluding those lost to follow-up evaluation; - Phi coefficients were calculated to determine the degree of association between the intervention and control groups across variables; - Binary logistic regression was used to examine predictors of smoking cessation | - At 6-month follow up, no difference in biochemically confirmed 3-month prevalence quit rates between the intervention (5%) and control (6%) groups; - Sensitivity analysis using more lenient criteria indicated quit rates of 29% for intervention group and 18% for control group (P = 0.32); - Predictors of smoking cessation at 6 months for all patients included a smoking-related cancer site, more cessation attempts in the year before the enrollment study, and no radiation therapy | Poor
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | | Comments:
South Australia | - Cancer patients at South Australian public hospital | G1: 74 | G1: Specific advice and booklets about benefits of quitting for patients with cancer, telephone and in-person counseling using the framework of motivational counseling, supplemented with NRT if patient smoked ≥15 cigarettes per day | Self-report, urine cotinine and CO levels | | Study lacked power, had a high attrition rate and there were significant differences in groups at baseline
Funding agency: | Study type: | C1: 63 | C1: brief advice to quit, widely-available quit-smoking brochures, and info about well-promoted state-based telephone quit-line service | Dependent variables: | | Adequate randomization:
National Health and Medical Research Council | RCT | Definition of smoking: | Method of assessment: | - Quit rates - 3 month period prevalence, 7-day period prevalence | | No
Study setting: | Inclusion criteria: | Tobacco | In-person follow up visit or telephone assessment at 6 months post-baseline | | | Attrition rate:
Hospital-based | - Participant must have a cancer diagnosis; - Smoke tobacco more than weekly; - Speak English; - Be cognitively able to consent; - Have a prognosis exceeding 6 months; - Live close enough to maximize biochemical confirmation at follow-up assessment* (changed to include patients living remotely to increase participation numbers) | - Current Smoker - Smoke tobacco at least weekly | Baseline data: | | | 36%
| Exclusion criteria: | | Patients in intervention group were more likely than control patients to have ever tried to quit (P = 0.04) and to have made more quit attempts in the past year (P = 0.02)
| See above | | Control patients were more likely to live remotely (P = 0.04)

Evidence Table 6. Community strategies to increase the implementation of proven population-level tobacco use cessation strategies

Study Characteristics | Study Design | Sample Design and Definitions | Intervention Details | Statistical Analysis and Baseline Data | Outcome Measures | Quality Comments
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Quit attempts w/ 95% CI | Quality rating:
Borland et al., 2003 | To assess effectiveness computer-generated tailored advice for callers to telephone helpline; to assess if it enhanced series of callback telephone counseling sessions in aiding smoking cessation. | Recruited eligible callers of Victorian Quitline telephone counseling and advice service | - Self-help; - Telephone counseling; - Computer-based program | Data analyzed using SPSS | G1: 56% (51.3–60.7) | Good
Geographic area: | Population: | Sample size: | Intervention: | ITT analysis | G2: 62.8% (58.2–67.4) | Comments:
Australia | - Adolescents; - Young adults; - Adults | G1: 523 | G1: Offered a ‘Quit Pack’ and a series of 3 computer-generated tailored letters | Data verification: | C1: 57.4% (52.5–61.5) | Groups similar at baseline in spite of suboptimal randomziation scheme
Funding agency: | Study type: | G2: 528 | G2: Offered a ‘Quit Pack’ and a series of 3 computer-generated tailored letters and callback counseling service | NR | Smoking point prevalence at 12-mo followup: | Adequate randomization:
NHMRC grant, supplemented by The Cancer Council Victoria; callbacks funded by Quit Victoria | RCT w/ simple randomization Randomization done by shuffling questionnaires | C1: 527 | G3: NR | Dependent variables: | G1: 22.6% (18.5–26.7) | Yes
Study setting: | Inclusion criteria: | Definition of smoking: | C1: Offered a ‘Quit Pack’, printed self-help materials consisting of: a 30 pg booklet based on stage of disease, leaflets promoting smoking cessation courses and card w/ strategies to reduce cravings | - Self-reported smoking status at 3-, 6-,and 12-month followups, both point prevalence and 9 months' sustained absitinece; - Duration of cessation; - Use of nicotine replacement; - Extent of participation in callback | G2: 25.6% (21.3–29.9) | Attrition rate:
Population-based | - English-speaking; - No obvious psychiatric or neurological problems; - Called quitline b/w October 1996 and August 1997 | NR | Method of assessment: | Baseline data: | C1: 22.1% (18.1–26.1) | Overall: 23.4%
| Exclusion criteria: | | Baseline interview; mailed survey at 3, 6, and 12 months post baseline | Smoked average of 22.8 cigarettes/day: | Chi sq 1.5,P 0.46 | G1: 23.1%
| - Small # of callers who sought callback service proactively after self-help materials offered | | | Prepartion stage: 45% | | G2: 25.9%
| | | | Contemplation stage: 54% | | C1: 21.1%
| | | | Groups similar at baseline by gender, age, education, level of addiction, stage of readiness, quit attempts in past yr
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Self-reported non-smoking status at 3-month followup: | Quality rating:
Maguire et al., 2001 | To evaluate whether a structured community pharmacy-based smoking cessation program would result in a higher smoking cessation rate compared to ad hoc advice from pharmacists | - 100 pharmacists working in community pharmacies in N. Ireland and 24 in London participated in study; - Each asked to enroll 12 smokers | - Self-help; - Individual counseling by health professional; - Media campaign; - Pharmaceuticals | NR | G1: 27.5% | Fair
Geographic area: | Population: | Pharmacists promoted study to:; - People who used pharmacy for non-medical reasons, using window displays, posters in-pharmacy and leaflets at cash registers; - People reporting and asking for advice on minor ailments, e.g. chest cold, asking them about smoking and telling them about program; - People being dispensed medicines, asking them about smoking and telling them about program | Intervention: | Data verification: | C1: 11% | Comments:
United Kingdom | - Adults | Sample size: | G1: Initial interview lasting b/w 10 and 30 minutes; smoking cessation contract; indication for NRT assessed and offered if appropriate; leaflet; weekly followup for 4 wks, then monthly followup for 3 months | Urinary cotinine assessed to validate self-reported non-smoking at 12 months | Self-reported non-smoking status at 6-month followup: | NR
Funding agency: | Study type: | G1: 265 smokers | C1: Normal pharmaceutical service (including provision of NRT as appropriate) provided by pharmacist | Dependent variables: | G1: 18.5% | Adequate randomization:
Medical Research Council and the Northern Ireland DHSS | - RCT w/ systematic randomization; - Comparing a structured intervention w/ usual care | C1: 219 smokers | Method of assessment: | Smoking status | C1: 8.2% | Yes
Study setting: | Inclusion criteria: | Definition of smoking: | - Telephone interviews at 3, 6, and 12 mos; - Urinary cotinine assessed to validate self-reported non-smoking at 12 mos; - Qualitative assessments also conducted using semi-structured telephone interviews and focus groups | Baseline data: | Self-reported non-smoking status validated by urinary cotinine (50 ng/ml) at 12-month followup: | Attrition rate:
Community-based | - More than 18 yrs of age; - Not pregnant; - Expressing a wish to stop smoking | NR | | Numbers given but no tests for significance | G1: 14.3% | G1: 10.2%
| Exclusion criteria: | | | | C1: 2.7% | C1: 14.2%
| NR | | | | X^2^ = 16.2
| | | | | P = <.001
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Outcome measures: | Quality rating:
Ronda et al., 2004 | To assess whether Hartslag community smoking cessation intervention resulted in increased smoking cessation in Maastricht region as compared to control region | A cohort research population of 1,200 smokers (age 18 and over) recruited in each region by taking a stratified random sample of 6,500 inhabitants in each region from computerized telephone registers, based on number of inhabitants i n each municipality included in region | - Self-help; - Telephone counseling; - Media campaign | - Multiple logistic regression analysis conducted to identify potential dropout bias (w/ attendance v. dropout as the dependent variable and baseline values for gender, age, education, and condition as independent variables); - Multiple logistic regression analysis used to identify potential baseline differences b/w G1 region and control region; - Independent variables in this analysis were baseline values for gender, age and education; - Only respondents who completed all surveys included; - Analyses performed using SPSS 10.0 | No significant differences found b/w G1 and control regions regarding smoking status and determinants of smoking behavior | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | | Comments:
Western Europe | - Adults | G1: 4,242 (35.4% of whom were smokers) | G1: Regional mass media-led smoking cessation campaign Proficiat (Congratulations) implemented in January and February 2000 and 2001, consisting of radio commercials, advertisements and messages in papers, billboards along roads, and posters and postcards in waiting rooms and public buildings; local activities organised by working groups consisting of representatives of local organizations, such as a non-smoking campaign for parents of children in playgroups | NR | | NR
Funding agency: | Study type: | C1: 4,697 (34% of whom were smokers) | C1: National mass media-led smoking cessation campaign Dat kan ik ook (I can do that too) implemented around the turn of the century, consisting of various television programmes, an info line, non-smoking courses, mailings to variousorganizations, billboards in bus shelters, brochures, posters | Dependent variables: | | Adequate randomization:
Netherlands Heart Foundation | - Cohort Study; - A pretest-posttest C design w/ two posttests | Definition of smoking: | Method of assessment: | Primary: smoking status | | NR
Study setting: | Inclusion criteria: | Cigarettes | Short structured telephone interviews | Secondary: intention to quit, cessation self-efficacy, perceived social support for cessation | | Attrition rate:
Community-based | - Over 18 yrs old; - Living in intervention or control regions | - Smoker: smoked at all in last 7 days | | Baseline data: | | 37.9%, net attrition after excluding unreachable respondents from T0 to T2 18.7%
| Exclusion criteria: | | | Respondents from G1 region significantly older, more often female, and more highly educated than respondents from control region
| - NR

Evidence Table 7. Health care systems strategies to increase implementation of population-level tobacco use cessation

Study Characteristics | Study Design | Sample Design and Definitions | Intervention Details | Statistical Analysis and Baseline Data | Outcome Measures | Quality Comments
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | At one-yr followup, 1-wk point prevalence of abstinence: | Quality rating:
Cornuz et al., 2002 | To assess efficacy of an educational program based on behavioral theory, active learning methods and practice w/ standardized patients for internal medicine residents in helping patients abstain from smoking and changing counseling practices | - 35 residents at 2 general medicine clinics randomly assigned by computer and stratified by clinic to either intervention group trained in smoking cessation or C trained in dyslipidemia; - Patients screened for eligibility by research assistants; - Eligibile patients asked for written informed consent to participate in a study about preventive care | - Self-help; - Individual counseling by health professional | To compare baseline data, X^2^ and Fisher exact tests used for categorical data and t-test and Wilcoxon rank-sum test used for continuous data; to measure outcomes, logistic regression performed w/ a generalized estimating equation to stratify by clinic and adjust for clustering by resident; all statistical analysis performed using STATA | G1: 13% (95% CI, 7% to 21%) | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | C1: 5% (95% CI, 1% to 9%) | Comments:
Western Europe | - Young adults; - Adults | G1: 17 residents, 115 patients | G1: Intervention training program for residents based on active learning of counseling skills and interventions that matched patients' readiness to quit; after training, residents supposed to reach the following objectives: Systematically identify all smoking patients, clearly advise smokers to quit, assess each smoker's readiness to quit, use applied counseling strategies and offer a brochure that matched patient's stage of readiness, propose an individual smoking cessation program, follow smokers in short and long term, and facilitate implementation of smoking cessation in routine practice; received control training 4 months later, after 3 month patient recruitment period had ended | Self-reported abstinence validated at one clinic by measurement of exhaled CO by a research assistant blinded to group allocation | P = 0.005 | No comments
Funding agency: | Study type: | C1: 18 residents, 136 patients | C1: Traditional diadactic training program on management of dyslipidemia; received intervention training 4 months later, after 3 month patient recruitment period had ended | Dependent variables: | OR = 2.8 (95% CI, 1.4 to 5.5) | Adequate randomization:
Swiss Federal Office for Public Health, Swiss Medical Association, Swiss Foundation for Health Promotion | RCT w/ cluster randomization | Definition of smoking: | Method of assessment: | Primary: Smoking status | Residents who recieved study training provided better counseling (mean score 4 vs2.7, P = 0.002) | Yes
Study setting: | Inclusion criteria: | Cigarettes | Baseline information collected by research assistant immediately after a patient's medical visit; 1-yr followup survey administered by mail; self-reported abstinence validated at one clinic by measurement of exhaled CO by a research assistant blinded to group allocation | Secondary: Counseling score, willingness to quit, daily cigarette consumption | Smokers willingness to quit higher in IG (94% vs80%, P = 0.007) | Attrition rate:
Practice/provider settings | - 16 to 75 yrs old; - Understood French; - Consulted an outpatient clinic for a followup or an emergency visit; - Had smoked 1 or more cigarettes daily during previous wk | - 1-wk point prevalence of abstinence: no smoking in last wk | | Baseline data: | No significant trend toward lower daily cigarette consumption in G1. | Loss to followup at 1 yr:
| Exclusion criteria: | | | - Both groups of residents similar at baseline; - Both groups of patients similar at baseline | | G1: 33%
| - NR | | | | | C1: 26.5%
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Percentage of patients who quit smoking at 6-month followup: | Quality rating:
Goldstein et al., 2003 | To determine effect of a community-based academic detailing intervention on quit rates of a population-based sample of smokers | - A list of all licensed physicians obtained from Rhode Island Department of Health, Folio's Medical Directory of Rhode Island, 1990, and local health care institutions; - Physicians received mailed invitations followed by postcards, and then phone calls from physician recruiters; - Principal Investigator contacted nonresponders to complete recruitment process; - All physicians providing direct care to adults in Newport, Washington, and Kent counties targeted for participation in intervention and delayed intervention (control) arms of PCS trial | - Self-help; - Individual counseling by health professional; - Multi-component office-based intervention; - Academic detailing | - Descriptive statistics (mean, median, proportions) used to characterize study sample at baseline and to examine demographic differences b/w study groups which might confound study outcomes at 24 months; - Multivariate logistic regressions done to examine differences in smoking status at 24 mos | G1: 8.4 | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | G2: 7.6 | Comments:
US | - Adults | G1: 376 patients | G1: Physicians provided 4 A's to patients | NR | G3: 8.9 | Adequate randomization:
Funding agency: | Study type: | G2: 385 patients | G2: Smokers provided w/ computer-generated, stage-tailored information about quitting smoking at home | Dependent variables: | C1: 7.1 | NR
NCI | - Cross-sectional; - Community-based, quasi-experimental study | G3: 332 patients | G3: Physician delivered 4 A's to patients, and patients received computer-generated, stage-tailored smoking cessation information at home | Self-reported smoking status | P = NR | Attrition rate:
Study setting: | Inclusion criteria: | C1: 1253 patients | C1: No intervention | Baseline data: | Percentage of patients who quit smoking at 12-month followup: | At 24 mos, of 2346 participants, 35% attrition in controlled/delayed G1, 35% attrition in physician only IG, 35% attrition in physician and home G1
Community-based | - Physicians eligible if they practiced a primary care specialty (i.e., family medicine, internal medicine, obstetrics /gynecology), provided primary care for at least 25% of their patients, completed postgraduate training, and planned to practice in the state for the 3 study yrs; - Patients recruited through random digit dialing; - Patients must be 18 to 75 yrs old; - Live in a household w/ a phone; - Current smokers | Definition of smoking: | Method of assessment: | - Those residing in physician intervention areas (G1 & G3) less likely to be less than HS educated and more likely to be college educated than C; - C more likely to be in preparation state of change for cessation than intervention groups; - Those visiting physicians more likely to be older female, higher education, report poorer health | G1: 17.0
Practice/provider settings | Exclusion criteria: | Cigarettes | Telephone survey at 6, 12, 18, and 24 mos | | G2: 16.5
| - Full-time hospital-based physicians excluded; - Only one smoking patient per household included | - Smoker: currently smokes cigarettes | | | G3: 16.9
| | | | | C1: 16.1
| | | | | P = NR
| | | | | Percentage of patients who quit smoking at 18-month followup:
| | | | | G1: 25.2
| | | | | G2: 24.8
| | | | | G3: 19.2
| | | | | C1: 20.0
| | | | | P = NR
| | | | | Percentage of patients who quit smoking at 24-month followup:
| | | | | G1: 33.3
| | | | | G2: 26.3
| | | | | G3: 25.7
| | | | | C1: 22.6
| | | | | P = 0.006
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | G1: 11.4% quit smoking | Quality rating:
Joseph, Arikian, et al., 2004 | To test the effect of modest intensity, practical systems change that might increase delivery of smoking cessation treatment within Veterans Affairs. | - Telephone surveys were conducted among 3 cohorts of patients; - A cross-sectional survey was conducted at baseline among a sample randomly selected from patients who had seen their primary care provider within 6 months (preintervention); - A second cross-sectional survey sample was obtained 1 year after the intervention using the same sampling technique (post intervention); - Preintervention smokers at baseline were surveyed 1 year after intervention; - Medical records reviewed 6 months before intervention and 6 months following intervention for all subjects who provided consent and smoked and a random sample of equal size of subjects that did not smoke. | - Multicomponent intervention | - A McNemar odds on change was calculated to assess difference in change between the intervention groups; - The significance of the resulting odds was computed by the Pearson chi square; - For continuous variables measured at facility level a Wilcoxon rank sum test was used. | C1 13.2% quit smoking, NS | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | No effects of the intervention on change scores between groups for reporting that their provider asked about smoking, or being counseled to quit at 1 year post intervention | Comments:
US | - Adults (N = 5,678); - 20 Veteran Affairs Medical Centers (results from this analysis were not used because sample size too small) | Total: 5,678 Adults | G1: Received documentation of tobacco use status in medical records; delivery of intervention to all smokers; liberal use of smoking cessation medication; organizational support; site visits; 2 day training meeting; an interventionist at coordinating site. | Self-report (no biochemical verification) and medical record review | Intervention had no effect on smokers' report of being counseled to quit | - Organizational level analysis was not used (N = 20)
Funding agency: | Study type: | Preintervention | C1: NR | Dependent variables: | Smokers only group, 30% of smokers in G1 were counseled before the intervention and 44% counseled after the intervention; C1 smokers counseled 39.1% before intervention and 42.2% post intervention. Amomg smokers who had a change in counseling before and after the intervention, the subjects in the intervention group had 2 times the odds of being counseled relative to controls (OR=2.24, 95% CI, 1.17 to 4.28, P=.014). | Adequate randomization:
Veterans Administration Health Services Research and Development Service (CPG 97–039) | - Cross-sectional design (individual analysis); - RCT w/ simple randomization (organizational analysis) | G1: 2,112 | Method of assessment: | - Smoking status; - General health; - Nicotine dependence; - Services provided at last visit to primary care provider; - Mood; - Alcohol use; - Demographics | Medical records: Post intervention had a significant effect on smoking status documentation where intervention records were more likely to document smokers (67% vs 60%,P=.0007) | Yes for VA hospitals only not individual subjects
Study setting: | Inclusion criteria: | C1: 2,142 | Medical record review and telephone survey | | Smokers were more likely to be documented as smokers than non smokers were to be documented as nonsmokers | Attrition rate:
Provider-based | - Existence of referral-based smoking cessation program that treated a minimum of 50 patients/year, information resource management capacity for data collection, institutional review board, and evidence of commitment to participation in the project | Post intervention | Baseline data: | | | - Pre-intervention = 21%; - Smokers followup = 13%; - Post- intervention = 16%
| Exclusion criteria: | G1: 641 | No differences at baseline between intervention and control group sites.
| - Facilities serving predominatly psychiatric patients, or displayed communication problems. | C1:783
| | Definition of smoking:
| | Cigarettes
| | - Current smokers
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Ask about smoking: | Quality rating:
Katz et al., 2004 | To compare MAs' and LPNs' performance of recommended smoking cessation activities w/ that of RNs | NR | - Self-help; - Individual counseling by health professional; - Individual counseling by non health professional; - Telephone counseling | Two-level hierarchical logistic regression | Control RN/LPN/MA: 67%/35%/41% vstest site RN/LPN/MA: 92%/86%/78%. | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | Assess willingness to quit: control RN/LPN/MA = 15%/8%/7% vstest site RN/LPN/MA = 85%/75%/60%. | Comments:
US | - Adults | G1: 724 patients | G1: In original RCT: study personnel worked w/ intake clinicians to implement guideline intervention (tutorial w/ feedback, real-time reminder, self-help material, onsite pharmacotherapy, and proactive telephone counseling) | NR | Advise to quit: control RN/LPN/MA = 16%/7%/9% vstest site RN/LPN/MA = 41%/46%/28%. | Secondary analysis, so study not designed to answer this question
Funding agency: | Study type: | By intake clinician: | - Survey administered to intake clinicians immediately preceeding intervention; - After clinic visit, study personnel interviewed consecutive adults who had routine, non-emergency appointment and who smoked ≥ 1 cigarette per day; - Patients asked whether they received cessation counseling from intake clinician | Dependent variables: | Assist in quitting: control RN/LPN/MA = 17%/8%/9% vstest site RN/LPN/MA = 73%/69%/51%. | Missing important info that's reported in original study
National Cancer Institute and University of Wisconsin Comprehensive Cancer Center. | - Secondary analysis of data from a RCT of guideline implementation; - Intake clinicians (RNs, LPNs, MAs) paired w/ primary care physician (PCP); - Clinic randomized to receive help implementing AHRQ cessation guidelines vs control; - Patients interviewed after clinic visit | RN: 100 | C1: Intake clinicians completed survey just prior to tutorial session at end of intervention period, but had no help w/ guideline implementation | Proportion of patients receiving guideline-recommended counseling at time of scheduled clinic visit | (Also reported as difference in proportion (& 95% CI) b/w RNs and other intake clinicians). | Adequate randomization:
Study setting: | Inclusion criteria: | LPN: 154 | Method of assessment: | Baseline data: | | NR
Community-based | - NR | MA: 470 | Exit interview of patients | Patients seen by MA vsRN at control site = 57% vs43% male (P = 0.01), and 49% vs71% w/ regular clinician (P = 0.02) | | Attrition rate:
Practice/provider settings | Exclusion criteria: | C1: 497 patients | | Patients seen by MA vsRN at test site = 57% vs75% w/ regular clinician (P = 0.001) | | NR
| - NR | By intake clinician:
| | RN: 153
| | LPN: 256
| | MA: 88
| | Definition of smoking:
| | Cigarettes
| | - At least one per day on average
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | During the intervention period, more patients at test sites were asked about their smoking status (OR = 3.1; 95%,CI; 1.2 to 8.2; P = 0.02) or about their willingness to quit smoking (OR = 6.4, 95%, CI; 3.7 to 10.8; P < 0.001), were given literature about quitting (OR = 21, 95%, CI; 8.8to 49; P < 0.001), were assisted with setting quit date (OR = 33, 95%, CI;11 to 100; P < 0.001) or were engaged in a discussion about pharmacotherapy (OR = 3.9, 95%, CI; 2.5 to6.3; P < 0.001). | Quality rating:
Katz et al., 2004 | To test the effectiveness of a multi-modality intervention to implement the AHRQ Smoking Cessation Clinical Practice Guideline in primary care settings | - 12 eligible clinics were invited to participate; 9 clinics agreed to participate; 1 clinic participated only in the pilot phase; - Matched clinic sites (8) by primary care discipline and health plan affiliation (if any); - For each pair of clinics, project statistician used a random number generator to randomly assign each clinic to receive either the intervention (test site, n=4) or usual care (control site, n=4) | - Multicomponent office based intervention | Hierarchical logistic regression models used to estimate the odds rations for treatment assignment after adjustment for patient characteristics | Among participants treated during the intervention period, those at test sites were more likely than those at control sites to report being abstinent at the 2- month (16.4% vs. 5.8%, adjusted OR = 3.3, 95% CI, 1.9 –5.6, P < 0.001) and 6-months (15.4% vs 9.8%; adjusted OR = 1.7, (95% CI = 1.2–2.6), P = 0.009) follow-up assessments and to report continuous abstinence (10.9% vs 3.8%, adjusted OR = 3.4 (95% CI, 1.8–6.3),P < 0.001) | Good
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | With biochemically confirmed abstinence at 6 months, showed no difference between G1 and C1 | Comments:
US | Adults | G1: 4 clinics, 1141 patients | G1: Tutorial for intake clinicians, group and individual performance feedback for intake clinicians, use of a modified vital signs stamp, an offer of free nicotine replacement therapy and proactive telephone counseling. | Self-report and confirmatory salivary cotinine for self-reported quitters | Very low response rate for planned collection of confirmatory salivary cotinine tests of self-report cessation | Failed to reach original enrollment target resulting in slightly lower power than originally planned to detect differences in cessation outcomes.
Funding agency: | Study type: | C1: 4 clinics, 1022 patients | C1: Staff received only general information on the AHRQ Guideline | Dependent variables: | | Adequate randomization:
National Cancer Institute; University of Wisconsin; GlaxoSmithKline donated transdermal nicotine patches for use in trial | RCT | Definition of smoking: | Method of assessment: | - Performance of recommended smoking cessation activities by clinic staff; - Abstinence at 2 and 6 months after the initial clinic visit (7-day point prevalence); - Continuous abstinence at 2 and 6 months (self-reported abstinence at both 2 and 6 month assessments) | | Yes
Study setting: | Inclusion criteria: | 7-day point prevalence | Self-reported by telephone interview at 2- and 6-month follow-up | | | Attrition rate:
Provider-based | Adults smoking at least one cigarette per day and having an appointment with a primary care clinician for routine, non-emergency care and willing to complete a brief exit interview immediately after the clinic appointment | | Baseline data: | | | G1: 11%
| Exclusion criteria: | | No statistically significant differences in smoking cessation rates between participants at test and control sites during the baseline period, except in educational level | | | C1: 10%
| NR | | During the intervention period, patients at test sites were older, had more years of education and smoked more cigarettes per day than patients at control sites
| | | No significant differences between characteristics of intake clinicians at test sites and those at control sites with one exception, intake clinicians at control sites had more years of work experience than those at test sites
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | 30-day abstinence rates at end of pregnancy among women who did not spontaneously quit upon learning of their pregnancy: | Quality rating:
Pbert et al., 2004 | To evaluate effect of a provider counseling and office systems intervention in obstetric, pediatric, and Special Supplemental Nutrition Program for WIC clinics on smoking and relapse rates in pregnant and postpartum wome | - Five community health centers randomized to special intervention or usual care; - Research assistants screened women in WIC offices | Individual Counseling by non Health Professional | - A mixed-effects linear modeling used to test hypotheses about txt conditions controlling for clustering of respondents within each community health center; - Linear logistic regression analyses computed using GLIMMIX macro, which uses iteratively reweighted likelihoods to fit a logistic regression; - PROC MIXED procedure in SAS used for analysis of number of cigarettes per day over time; - ReportedP values are for two-sided alternative hypotheses | G1: 26% | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | C1: 12% | Comments:
US | - Adults; - Women (only); - Pregnant women | G1: 272 | G1: Clients visited community health centers and WIC offices that received: provider training to deliver a SIbased on national clinical practice guidelines tailored to woman's stage of change and delivered through three channels (obstetric, pediatric, and WIC providers); an office practice management system to routinely screen for smoking status, prompt/remind providers to intervene, document the encounter, distribute materials, and arrange followup; and establishment of program boards to coordinate transfer of documentation among clinics, including periodic meetings w/ representatives from all clinics | Salivary cotinine levels ≤ 20 ng/ml assessed to confirm 7 day abstinence | OR = 2.57 | NR
Funding agency: | Study type: | C1: 278 | C1: Usual care | Dependent variables: | P = 0.05 | Adequate randomization:
NHLBI | RCT w/ cluster randomization | Definition of smoking: | Method of assessment: | Smoking status | 30-day abstinence rates at 1-month postpartum among women who did not spontaneously quit upon learning of their pregnancy: | Yes
Study setting: | Inclusion criteria: | Cigarettes | Data collected from participants at five time points during regular WIC appointments or by telephone: baseline interview upon enrollment, 9-month interview before delivery, 1-month postpartum interview within 30 days after delivery, 3-month postpartum interview, and 6-month postpartum interview | Baseline data: | G1: 26% | Attrition rate:
Practice/provider settings | - Women receiving prenatal care and WIC services and planning to receive pediatric care at one of community health centers; - Speaking English or Spanish; - Having at least 2 months before their due date; - Being a current smoker or spontaneous quitter (quit smoking after learning of pregnancy); - Planning to remain in area for at least 6 months following delivery | - Abstinence: not smoking within last 7 days; - Spontaneous quitter: quit smoking since learning of pregnancy and not smoking for at least 7 days prior to baseline | | Groups similar at baseline | C1: 11% | 20%
| Exclusion criteria: | | | | OR = 3.01
| - NR | | | | P = 0.04
| | | | | All other effects not statistically significant
| | | | | No effect remained at 3 and 6 mo followup
| | | | | Intent to treat at 30 day followup:
| | | | | Non-spontaneous quitters: 2.02 P = 0.09
| | | | | Spontaneous quitters 0.95
| | | | | P = 0.95
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | 1-month followup smoking abstinence rates greater among those in intervention compared to controls (OR = 2.56; CI, 1.8, 3.8) | Quality rating:
Pieterse, 2001 | To test effectiveness of a minimal contact smoking cessation program implemented by Dutch general practitioners. | Smoking patients 18 to 70 recruited from participating Dutch general practitioners' clinics | - Self-help; - Individual counseling by health professional; - Individual counseling by non health professional; - Telephone counseling; - Pharmaceuticals | Logistic regression, backward stepwise procedures, univariate ANOVA, X^2^ tests | Similarly, 12-month follow up smoking abstinence rates were 13.4% (G1) vs 7.3% (C1), w/ an OR = 1.51 (CI, 1.1, 2.1), P < 0.05 | Fair
Geographic area: | Population: | Only info regarding randomization process: | Intervention: | Data verification: | Consecutive abstinence greater among intervention group (8.2%) than among C (3.1%); OR = 3.04 (CI, 1.7, 5.6), P < 0.001 | Comments:
Western Europe | - Young adults; - Adults | - Occurred within clinics and used a prestructured allocation list | G1: Brief (10-minute) counseling sessions w/ physician; self-help manual; followup sessions. | Self-report. | | Not clear about randomization procedures because only vague information provided
Funding agency: | Study type: | Sample size: | C1: Usual txt - no counseling or advice on smoking except when initiated by patient or when indicated by the contact reason, in which case counseling limited to a straightforward stop-smoking advice and possibly a referral to local municipal health organization | No biochemical verification | | Important potential influence identified by authors -- implementation of national mass-media stop-smoking campaign, which started shortly before second followup
Dutch Cancer Society | - RCT w/ simple randomization; - Randomization occurring within practice sites according to a “prestructured allocation list” | G1: 269 | Method of assessment: | Dependent variables: | | Adequate randomization:
Study setting: | Inclusion criteria: | C1: 261 | Self-report by questionnaire | - Self-reported abstinence from smoking; - Point prevalence of smoking; - Consecutive abstinence from smoking (abstinent at both 6- and 12-month followups) | | Yes
Practice/provider settings | - 18 to 70; - Self-reported smoker | Definition of smoking: | | Baseline data: | | Attrition rate:
| Exclusion criteria: | Cigarettes | | Significant difference in G1 vsC1 in baseline measures of: | | 1 month:
| - Controls exposed to txt; - Controls w/ severe tobacco-related health problems (thus given intervention) | - Non-smokers at followup defined as consistently providing non-smoker responses to two questions 1) contact name for someone to verify smoking status and 2) self-reported smoking status | | Percent smoking ≤ 10 cigarettes per day (G1: 13.3, C1: 20.4; F = 4.3, P = 0.04) | | Overall: 26%
| | | | Motivation to quit score (G1: 14.8, C1: 13.8, F = 6.7, P = 0.01) | | G1: 33%
| | | | Otherwise, population considered representative of average Dutch visitor of a general practice | | C1: 19%
| | | | | | 6 month:
| | | | | | Overall: 26% (no info on each group).
| | | | | | 12 month:
| | | | | | Overall: 19% (no info on each group).
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Proportion of all participants asked by any clinic staff person about smoking before and after implementation of vital sign stamp revealed an overall increase of 9.6% in control group and 30.9% in intervention clinics | Quality rating:
Piper et al., 2003 | To test effectiveness of expanded vital sign stamp to identify smokers and reduce smoking rates | - Convenience sample; - Adults exiting health clinics (n = 5) were approached; - Any adult smoker willing to participate was enrolled | Expanded vital sign stamps | Chi square (response rates not reported) | Mean increase in asking behavior of physicians at vital sign clinics was statistically greater than that of physicians at control clinics t = -3.61; P = 0.002) | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | No statistically significant differences in abstinence rates (complete abstinence during past 7 days) between G1 and C1 after 1 year (P = 0.27). | Comments:
US | Adult smokers attending health care clinics | G1: 5582 | G1: smoking status was added to the vital sign stamp | NR | | Response rates to follow up questionnaire at 1 year not reported
Funding agency: | Study type: | C1: 3857 | C1: usual vital sign stamp without smoking status | Dependent variables: | | Adequate randomization:
National Cancer Institute | Cluster RCT (clinics unit of randomization) | Definition of smoking: | Method of assessment: | - Smoking cessation; - Identification of smokers; - Rates of smoking counseling by physicians | | NR
Study setting: | Inclusion criteria: | NR | Follow up questionnaire after 1 year (method NR) | | | Attrition rate:
Provider-based | - Any adult smoker (older than 18 years); - Attended only one health care clinic | | Baseline data: | | | NR
| Exclusion criteria: | | Similar at baseline
| None reported
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Outcome measures: | Quality rating:
Russos et al., 1999 | To examine rate and determinants (especially as related to social learning factors) of tobacco prevention and cessation counseling by orthodontists participating in a controlled trial to decrease incidence of tobacco use among adolescents. | Orthodontists recruited from 154 participating orthodontic offices within various southern Calif counties | - Self-help; - Individual counseling by non health professional; - Telephone counseling; - Video; - Media campaign | - Nonparametric statistics (Kendall, Mann-Whitney) used in bivariate analyses; - Multivariate analysis | In a typical wk more clinicians in experimental vsC provided prevention counseling to patients (Mean: 25.4% v 3%, Mann-Whitney U = 696.5, z = -7.0, P < 0.01) and at least some cessation counseling (91% vs 72%, chi sq = 8.4, P < 0.01) | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | G1 asked higher % (4.8) of their patients whether they use tobacco than C1 (2.9), (U = 1349.0, z = -3.3, P < 0.01) | Comments:
US | - Adults | G1: 63 | G1: Anti-tobacco materials (e.g., posters), 1.5 hr training session on tobacco prevention, written anti-tobacco prescriptions, reimbursement for anti-tobacco prescription given to patients, quarterly visits and calls; office staff asked to make office tobacco-free (remove ashtrays, distribute anti-tobacco materials and prescriptions to all youth, to remind patients not to begin tobacco use) | Telephone survey of orthodontists | G1 more likely to report mostly positive reactions from tobacco users for cessation counseling (chi sq = 7.8, P < 0.05) | Good, documentation of reasons for attrition and distribution of non-responders by group; things to consider when trying to improve providers' provision of tobacco use prevention and cessation advice Similar findings from comparison of results to other studies
Funding agency: | Study type: | C1: 63 | C1: No training, materials, or visits, nor asked to change their offices or practices | Dependent variables: | C1 more likely than G1 to say they don't provide counseling because it's not their job or not expected of them (chi sq = 3.7, P = 0.05) | Adequate randomization:
Cigarette and Tobacco Surtax Fund of the State of Calif through the Tobacco-Related Disease Research Program of the University of Calif | - Cross-sectional; - Current study based on cross-sectional interview design survey of orthodontists randomized to intervention to enhance skills in delivering smoking prevention and cessation counseling to adolescent patients or to C (thus, interventions described relate to the RCT, not the cross-sectional survey) | Definition of smoking: | Method of assessment: | - Provision of prevention and cessation counseling to patients; - Counseling content; - Counseling determinants | G1 more likely to say lack of time is significant barrier to giving prevention counseling (chi sq = 4.2, P < 0.05) | Yes
Study setting: | Inclusion criteria: | NR | Mailed survey requesting self-report from orthodontists | Baseline data: | Demographic, office, and clinic practice variables not associated w/ prevention or cessation counseling (P > 0.05) | Attrition rate:
Practice/provider settings | - Orthodontist from an office in one of the selected Calif counties; - Practiced at least 2 days a wk; - Had at least 75 adolescent patients; - Planned to remain in practice at least 2 yrs (for survey: participated in original study) | | | No significant differences (P > 0.05) found b/w G1 and C1 in terms of demographics, clinical practices, office characteristics, history of tobacco use, nor training for tobacco counseling Mean age about 51, mean yrs in practice about 24 yrs, about 230 adolescent patients, mean gross annual income 445,000 | Higher rates of prevention and cessation counseling associated (P < 0.05) w/: asking patients whether they used tobacco; belief that counseling is important; belief that clinicians should receive counseling training; intent to attend training; and to disagree that counseling is not part of their jobs | Survey:
| Exclusion criteria: | | | | | G1 and C1: 18% each
| - Not meeting inclusion criteria
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Doctors who were smokers less likely than non-smoking GPs to participate in the smoking cessation trial, despite having originally consented to do so (45% vs 54.1%, chi sq: 5.147, P < 0.05) | Quality rating:
Slama et al., 1999 | To examine participation and effectiveness of GPs in offering a minimal smoking cessation intervention according to attitudinal and behavior variables | - 2,860 GPs from France interviewed about their attitudes and behaviors; - From this group, 170 of 371 randomly selected smoking GPs and 202 of 375 randomly selected non-smoking GPs participated in survey | Extra-curricular activities | Chi sq tests | None of the GPs' smoking related attitudes and reported behaviors significantly related to their participation in the study nor to their patients' rates of smoking cessation at 1 mo, 12 mos, or both | Fair
Geographic area: | Population: | Sample size: | Intervention: | Frequencies | Conclusion: When minimal advice has an effect, it is due more to systematic nature of the provision of intervention than to the attitudes or reported practices of practioner giving advice | Comments:
Western Europe | - Adults | Smokers: 170 smokers | G1: NA | Proportions | | Interesting practical applications to understanding factors that might influence physicians' willingness to participate in interventions to address smoking cessation w/ patients; Limited discussion of intervention, though refers to previous article description
Funding agency: | Study type: | Non-smokers: 202 | G2: NA | Data verification: | | Adequate randomization:
French Ministry of Health; European Union “Europe Against Cancer Programme”; French Committee for Health Education | Cross-sectional survey w/ GPs who participated in a previous smoking cessation intervention | C1: NA | G3: NA | Self report | | NR
Study setting: | Inclusion criteria: | Definition of smoking: | C1: NA | Dependent variables: | | Attrition rate:
Practice/provider settings | - Participated in previous smoking cessation intervention study | Cigarettes | Method of assessment: | - Rate of participation in cessation trial by GP's smoking status; - Effect of GPs' smoking-related attitudes and reported practices | | Smoking GPs (%):; 1 wk: 11.8; 2 wks: 8.2; 3 wks: 12.9; 4 wks: 32
| Exclusion criteria: | - Abstinent: not smoking cigarettes | For GPs' attitudes and reported practices: self report obtained by telephone survey | Baseline data: | | Non-smoking GPs (%):; 1 wk: 9.9; 2 wks: 10.3; 3 wks: 15.3; 4 wks: 35.5
| - NR | | GPs' participation in intervention measured by patient information GP returned per protocol at 1 and 12 mo followups. Patient smoking status: self report at 1 and 12 mo followups | 50% of eligible GPs participated (45% smoked; 54.1% did not; X^2^ = 5.147, P < 0.05) Significant differences b/w participating and non-participating GPs in beliefs about usefulness of screening for cervical (96.2% vs 91.6%, X^2^ = 6.460, P < 0.011) and breast cancer (98.1% v 94.8%, X^2^ = 5.918, P < 0.015)
| | | | Other differences NS
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Including only those who were reached at 12 mos, 49% reported being smoke free for previous 7 days | Quality rating:
Smith et al., 2002 | To assess effectiveness of a nurse case-managed smoking cessation program for general hospitalized patients, was continued for 3 yrs after completion of RCT | Patients admitted to Stanford (Calif.) Hospital who smoked any amount the month before admission were offered a smoking cessation program during hospitalization | - Self-help; - Individual counseling by health professional; - Telephone counseling; - Video; - Pharmaceuticals | - ANOVAX; - X^2^; - Frequencies; - Intent-to-treat analysis | Including 211 who were not reached at 12 mos (intent to treat) and counting them as smokers, self-reported smoking cessation rate is 35%. | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | | Comments:
US | - Adults | 12 month sample = 720 | G1: Used multiple-reinforcement approach (multiple providers, components, and contacts) | - Self-report by telephone No biochemical assessment | | Though no comparison group in this study, it provides very good and detailed data regarding continuation of a smoking cessation program implemented previously as part of a RCT; only 52% of eligible patients participated, but this is considered fairly high acceptance rate for the population; only 52% of eligible patients participated, but this is considered fairly high acceptance rate for the population; it also presents data both w/ and without intent-to-treat approach; partial reasons for high attrition rate at 12 mos include nurse not having time to devote to trying to make follow up calls and only 3 attempts made to reach participants by phone. Study also addresses practical hospital-related issues to be considered when implementing an inpatient smoking cessation program
Funding agency: | Study type: | Definition of smoking: | During hospitalization: Physician advice on smoking cessation; bedside education and counseling w/ specially trained nurse; take-home materials (video, workbook, relaxation audiotape), NRT if requested or indicated, 4 nurse-initiated postdischarge phone counseling calls (2,7,21, and 90 days postdischarge) | Dependent variables: | | Adequate randomization:
NCI, Canadian Cancer Society | - Time series; - Single group effectiveness study using a program put into standard hospital practice.; - No comparison group for this study; instead, follows participants over time and assesses smoking status at various points postintervention | Cigarettes | C1: No control or comparison group | 12 mo quit rate (7 day point prevalence at 12 mos) | | No
Study setting: | Inclusion criteria: | - 7 day point-prevalence as defined by NHLBI (not even a puff for a minimum of 7 consecutive days prior to assessment | Method of assessment: | Baseline data: | | Attrition rate:
Hospital | - Patients who smoked in month before hospital admission; - Wanted to quit smoking; - Agreed to participate in intervention | | In-person survey for demographic information, and baseline smoking history and alcohol consumption | Mean age: 52 | | Excluding 42 who died before assessment, 29% attrition rate (not reached or dropped out
| Exclusion criteria: | | Postdischarge data collected by telephone and involved self-report | Males: 58%
| - Did not speak English; - Impaired level of consciousness; - Terminal; - Primary reason for hospitalization was substance abuse; - Hospital stay less than 36 hrs | | | Race/ethnicity:
| | | | - Caucasian: 79%; - African American: 5%; - Asian: 9%; - HispaniC1: 1%; - Other race: 6%
| | | | Hospitalization reasons:
| | | | - Cardiovascular: 41%; - Cancer: 12%; - Pulmonary: 6%; - Gynecological: 4%; - Internal medicine: 19%; - OrthopediC1: 10%; - Other: 9%
| | | | Significant (P < 0.001) differences in age, sex, ethnicity, primary reason for hospitalization b/w total smokers identified, ineligibles, participants, wanted to quit on own, and did not want to quit groups
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Non-smokers at baseline and each followup: | Quality rating:
Soulier-Parmeggiani et al., 1999 | To evaluate effectiveness of a smoking cessation program for outpatients | NR | - Individual counseling by health professional; - Group counseling; - Telephone counseling; - Social support; - Video; - Pharmaceuticals | Proportions of smokers calculated at baseline and followup intervals | Baseline: 0% | Poor
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | End of intervention: 54% | Comments:
Western Europe | - Adults | G1: 299 | G1: One-hr group consultations once per wk for 4 wks; followup individual consultations by telephone at 1, 3, 6, and 12 mos after intervention; prescription of NRT; individual strategy for cessation discussed w/ a provider; family support recommended; video of benefits of cessation; dietitian-led session on preventing weight gain and individual diet recommendations; relapse prevention counseling | Patients' CO levels measured at each session and followup | 3-mo followup: 39.4% | Sampling not explained, no C, limited generalizability
Funding agency: | Study type: | Definition of smoking: | C1: NR | Dependent variables: | 6-mo followup: 25.8% | Adequate randomization:
NR | - Before and after study; - Patients participated in 1-hr consultation groups once a wk for 4 wks; patients interviewed at baseline and 3, 6, and 12 months after intervention | NR | Method of assessment: | Smoking status | 12-mo followup: 20.9% | NR
Study setting: | Inclusion criteria: | | - Questionnaires filled out by patients at baseline and 3, 6, and 12 mos postintervention; - Patients' CO levels measured at each session and followup | Baseline data: | | Attrition rate:
Hospital | - NR | | | Collected data on smoking history, addiction level as measured by FTQ, and motivation and confidence to quit smoking | | 10.4%
Practice/provider settings | Exclusion criteria:
| - NR
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | NR | Quality rating:
Stevens et al., 2000 | To evaluate implementation and effectiveness of hospital-based smoking cessation counseling delivered by respiratory therapists chosen from among hospital staff | - Smokers b/w 18 to 70 yrs old identified by questionnaire upon hospital admission; - Eligible smokers assigned to txt or usual care by a random digit in their HMO member number | - Self-help; - Individual counseling by health professional; - Telephone counseling; - Video | X^2^ tests and one logistic regression | | Poor
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | | Comments:
US | - Adults | G1: 541 | G1: If assigned to intervention but did not agree to participate, received smoking cessation brochure only If agreed to participate, watched 12 minute video for hospitalized smokers; offered one 20-minute counseling session w/ RT; choice of written materials (e.g., NCI's | Relied on self-report of smoking status | | NR
Funding agency: | Study type: | C1: 632 | C1: no information | Dependent variables: | | Adequate randomization:
NCI | RCT w/ simple randomization | Definition of smoking: | Method of assessment: | 6 month abstinence from smoking | | Yes
Study setting: | Inclusion criteria: | Cigarettes | Mailed questionnaire and follow up by phone for non-responders | Baseline data: | | Attrition rate:
Hospital | - Between 18 to 70 yrs old; - Being admitted to one of two participating Kaiser Permanente hospitals in Portland, OR; - Reporting regular smoking anytime in 3 months preceding hospitalization | - Abstinence from smoking considered as ≥ 6 months; - Second analysis included pipes or cigars | | - 57% women, mean age 47 yrs; - Mean smoking rate before hospitalization: 19 cigarettes per day; - Similar baseline characteristics among intervention and Cs | | NR
| Exclusion criteria: | | | No statistically significant differences b/w groups at baseline in terms of demographics or smoking, but race/ethnicity NR)
| - Obstetric patients; - < 18 or >70 yrs old; - Hospitalized for psychiatric or drug or alcohol abuse diagnoses; - Patients w/ hospital stays less than 36 hrs; - Hospice patients
Autor: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Improvements b/w baseline and posttest in patient recall of FP advice about nicotine replacement patches and gum were significantly greater in intervention than C (P = 0.0056 and P = 0.0002, respectively) | Quality rating:
Young et al., 2002 | To evaluate a multifaceted, practice-based intervention involving audit, feedback, and academic detailing to improve family physicians' smoking cessation advice | - All FPs in defined geographical area in 1999 were invited to participate; - Following baseline data collection, practices stratified according to number of participating FPs at practice (1, 2–4, 5+) to ensure approximately equal numbers of FPs in each study group; - Within each stratum, practices then randomly allocated to intervention or C using random numbers generated by SAS | - Self-help; - Individual counseling by health professional; - Video; - Pharmaceuticals | Frequencies, proportions, univariate analysis, bivariate analysis, X^2^, Wilcoxon's rank sum tests, Fisher's exact test, McNemar's test for paired proportions, Wilcoxon's sign rank tests for paired ordinal data, logistic regression using GEE | Substantial increases in patient recall of assessment of smoking status and FP use of quit dates, behavioral advice, written materials in intervention group, but changes not significantly greater than those in C | Fair
Geographic area: | Population: | FP patients 18 to 70 recruited consecutively and invited to participate in a study about health care in a general practice. | Intervention: | Data verification: | Medical chart review indicated FP notation of smoking cessation advice remained suboptimal after intervention | Comments:
Australia | - Adults | Sample size: | G1: FP received three academic detail visits which combined audit and feedback; resources for FPs (skills training video and workbook package, clinical practice guidelines, prompt sheet to assist w/ smokers' excuses and self-exceptions); resources for practices (patient-mediated prompts, reminders for medical records) and resources for patients (patient brochures and free starter packs of nicotine replacement gum) | Self-report of FP practices and patient recall of them, supplemented w/ patient medical chart review for verification | 100% of FPs found following intervention components | - Low consent rate among FPs (35%), limiting generalizability of findings; - Some significant differences b/w patients in G1 vs C1; - Though many comparisons of improvements in FPs' smoking cessation advice (G1 v C1) were NS, could be due to both groups being trained to be more mindful of addressing patients' health risks, thus reducing apparent effect of intervention; - High rate of attrition in both groups and at both time points
Funding agency: | Study type: | G1: 30 (FPs) in 20 practices | - Sessions 1 and 2 conducted by a medical peer; - Session 3 conducted by a non-medical public health academic | Dependent variables: | | Adequate randomization:
CSAHS Tobacco Education Team. (NSW Quit Campaign supplied free“Quit Kits,” Pharmacia Upjohn donated NRT starter packs; NSW Cancer Council supplied videos and workbooks at cost.) | - RCT w/ cluster randomization; - Each family practice, representing a cluster, randomly allocated to receive either intervention in smoking cessation advice (G1) or an intervention of identical format and intensity but about cervical screening (C1); - This constituted a 2 x 2 balanced incomplete block design, used to equalize nonspecific effects of research participation b/w groups and thereby minimize Hawthorne effect; - Data from FPs' patients used to assess effectiveness of intervention by comparing baseline and posttest questionnaires | C1: 30 (FPs) in 19 practices | C1: Received similar intervention in terms of intensity and format, but w/ regard to cervical screening | - Patient recall of smoking cessation-related interactions w/ FP during clinic visit; - Recall of: question from FP about smoking status; - Smokers' recall of specific smoking cessation advice; - Discussion of health risks of smoking; - Discussion of passive smoking; - Providing practical advice; - Setting a quit date; - Providing written materials; - Recommending nicotine replacement patches; - Arranging follow up appointment; referring to a smoking clinic | | Yes
Study setting: | Inclusion criteria: | Definition of smoking: | Method of assessment: | Medical record audit of patient smoking status and cessation advice in chart for index consultation (for smokers only). | | Attrition rate:
Practice/provider settings | - Family physicians from practices located within a defined geographical area in 1999; - Patients: Aged 18 to 70; - Attending FPs during specified data collection periods; - Spoke and read English; - Could read questionnaire | Cigarettes | - Baseline: Demographic questionnaires completed by participating FPs; - Patients at participating practices also completed baseline and posttest questionnaires; - Medical record audit | - Also assessed FPs thoughts about usefulness of intervention components | | Baseline follow up:
| Exclusion criteria: | - NA | | Baseline data: | | G1: 34%
| FPs: | Smokless tobacco | | FPs: | | C1: 27%
| - Ineligible if they worked < 2 days per wk; - Planning to leave practice within 6 months; - On extended or maternity leave; - Did not employ a receptionist; - Already participating in a clinical audit; - More than 50% of their patients spoke a language other than English at home | - NA | | Representative of reference FP population except for participating FPs more likely to be full-time vs part-time | | Posttest follow up:
| Patients: | | | Personal and professional characteristics of FPs allocated to each group were comparable | | G1: 37%
| - Did not read or speak English; - Were unable to read or understand questionnaire; - Were too sick or distressed to participate; - Had participated previously | | | G1 vs C1: | | C1:31%
| | | | Mean age 46.4 v. 49.8;
| | | | Female (%): 43 v. 33; Mean yrs in practice: 18 vs 19
| | | | Patients:
| | | | 77% consented to participate
| | | | 70% response rate
| | | | Less likely to respond: Smokers vs non-smokers (57% v 73%, chi sq = 35.3, P < 0.001)
| | | | Males (65% v 73%, chi- sq = 11.8, P < 0.001)
| | | | Those from intervention practices (66% v 73% chi sq = 11.2, P < 0.001)

Evidence Table 8. Effect of smokeless tobacco product marketing and use on population harm from tobacco use

Study Characteristics | Study Design | Sample Design and Definitions | Intervention Details | Statistical Analysis and Baseline Data | Outcome Measures | Quality Comments
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Ever experimented w/ ST: | Quality rating:
Choi et al., 1995 | To assess trends in ST use and to identify risk factors that distinguish youths who use or who are at risk of using ST | Stratified random sample of adults and all 12 to 17 yr old adolescents | NA | Multivariate logistic regression | 1990: 15.2% (95% CI, 13.7–16.7) | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | 1992: 12.3% (95% CI, 9.8–14.8) | Comments:
US | - Adolescent males, ages 12 to 17; - Young adult males, ages 18 to 24 | 1990: 3,912 | NA | NR | 1993: 13.8% (95% CI, 12.3–15.3) | Cross sectional study design; only reported analysis on 1993 data and youth subjects; no clear explanation of final sample size
Funding agency: | Study design: | 1992: 883 | Method of assessment: | Dependent variables: | Current use of ST (%) 1993: | Adequate randomization:
UCSF, Institute for Health and Aging | - Cross-sectional; - Telephone survey using random digit dialing | 1993: 2,814 | Telephone survey | - Current use and susceptibility to use ST; - Current cigarette use; - Exposure to other ST users; - Exposure to other ST users; - Exposure to ST advertisements; - Rebelliousness; - Participation in team sports; - Depression; - Peer Use of drugs or alcohol; - Peer norms | - 12 to 13 yrs:; OR = 0.3 (95% CI, 0.1 –0.05); - 14 to 15 yrs:; OR = 2.6 (95% CI, 1.0–4.2); - 16 to 17 yrs:; OR = 6.6 (95% CI, 4.1–9.1) | Yes
Study setting: | Inclusion criteria: | Definition of smoking: | | Baseline data: | Susceptibility to use ST (%) in 1993: | Attrition rate:
Population-based in Calif | Residing in Calif | Cigarettes | | NA | - 12 to 13 yrs:; OR = 16.8 (95% CI, 13.7–19.9); - 4 to 15 yrs:; OR = 17.3 (95% CI, 14.8–19.8); - 16–17 yrs:; OR = 18.8 (95% CI, 14.6–23.0) | NR
| Exclusion criteria: | - Current users: respondents who smoked a cigarette within last 30 days | | | Exposure to SLT advertising (%) in 1993:
| NR | Smokeless tobacco | | | - 12 to 13 yrs:; OR = 21.0 (95% CI, 17.4–24.6); - 14 to 15 yrs:; OR = 34.3 (95% CI, 30.3–38.3); - 16 to 17 yrs:; OR = 43.8 (95% CI, 38.3–48.8)
| | - Current users: reported use of smokeless tobacco within last 30 days | | | Recall of ST advertisements in 1993:
| | | | | AOR 7.5 (95% CI, 3.1–18.1), (P < 0.001)
| | | | | Susceptibility to use of ST in 1993:
| | | | | OR = 1.6 (95% CI, 1.2–2.0), (P<.001)
| | | | | Cigarette smokers risk of being ST users in 1993:
| | | | | OR = 3.3 (95% CI, 1.9 –5.7), (P<.001)
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | At 4 yr followup: | Quality rating:
Tomar; 2003 | To assess 4-yr initiation rates of ST use and cigarette smoking in relation to each other and examine switching b/w products | 1989 TAPS-I and its 1993 followup TAPS-II: TAPS-I sampling frame consisted of all teenagers aged 12–18 yrs on November 1, 1989, who resided in households interviewed for the NHIS during last two quarters of 1988 and first two quarters of 1989 | NA | - Estimates of prevalence and initiation rates included 95% CI; - Multiple logistic regression modeling used to adjust for age and race/ethnicity; - OR estimate interpreted as significantly different from reference group, at 95% level of confidence, if its 95% CI, excluded 1.0; - All analyses of TAPS data conducted using sampling weights developed by National Center for Health Statistics | - current smokers: 21.2%; - regular users of ST at sometime: 11.9%; - current regular users: 5.7% | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | After adjusting for age and race, males who had been regular users of ST were more than 3 times as likely as never users of ST to become smokers, | Comments:
US | - Adolescents, ages 11 to 19; - Young adults; - Men | Total: 3,996 | NA | NR | OR = 3.45 (95% CI, = 1.84 –6.47) | - Self report without any biochemical verification; participants lost at followup may have been more difficult to capture because they were more likely to progress to current smoking or regular use of ST; - Definition of ST use relied on respondents' self characterization of regular use
Funding agency: | Study design: | Definition of smoking: | Method of assessment: | Dependent variables: | Current smokers not different from never smokers in rate of initiating current regular ST use | Adequate randomization:
NR | - Cross-sectional; - Nationally-representative, cross-sectional telephone and mail survey | Cigarettes | - Computer-assisted telephone interviews; - Traditional telephone interviews; - Mailed surveys (TAPS-I 1989 data and TAPS-II 1993 data) | - ST use; - Cigarette use | OR = 1.45 (95% CI, = .5–4.22) | NR
Study setting: | Inclusion criteria: | - Current smoker: reported smoking at least 100 cigarettes in their lifetime and smoked at least 1 cigarette in 30 days preceding interview; - Former smoker: smoked at least 100 cigarettes in their lifetime, but smoked no cigarettes in last 30 days preceding interview; - Never smokers: had not smoked 100 cigarettes in their lifetime | | Baseline data: | NS | Attrition rate:
Population-based | - 11 to 19 yrs of age at baseline; - Reside in households interviewed for National Health Interview Survey; - Male | Smokeless tobacco groups: | | Prevalence of tobacco use at baseline (males only): | Among males who were regular ST users but were not smokers at baseline: | NR
| Exclusion criteria: | - never user of ST; - used ST, but never regularly; - used ST regularly but not currently; - current, regular user of ST | | - current smoker: 9%; - former smoker: 1.6%; - regular ST user at sometime: 6.1%; - current regular ST user: 2.7% | - continued to exclusively use ST at followup: 44.8%; - had switched to smoking at followup: 25.5%; - continued to use ST while also smoking at followup: 14.3%; - no longer using tobacco: 15.2%
| NR | | | | Of smokers at baseline who were not ST users:
| | | | | - switched to ST exclusively: 8%; - continued to smoke but also use ST: 3.6%; - quit using tobacco: 16.9%

Evidence Table 9. Tobacco cessation interventions for persons w/ co-occurring morbidities and risk behaviors

Study Characteristics | Study design | Sample Design and Definition | Intervention Details | Statistical Analysis and Baseline Data | Outcome Measures | Quality Comments
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | No statistical difference between groups were found for 7 day point prevalence abstinence rates at 1, 6 and 12 months for C1 = 30.1%, 24.7%, 24.7%, respectively; G1 = 39.5%, 24.4%, 32.5%. | Quality rating:
Brown et al., 2001 | To assess the efficacy of a standard, cognitive-behavioral smoking cessation treatment vs standard treatment combined with CBT for depression in smokers with a positive history of MDD | - Potential participants screened by telephone prior to an intake interview to confirm eligibility; - Eligible participants required to provide a $75 deposit, refunded incrementally on completion of follow-up procedures; - 358 invited to study center for diagnostic interview to confirm eligibility; 100 did not show up; - 258 participants completed informed consent and participated in the interview; 5 withdrew prior to being assigned to a treatment condition; 74 did not meet inclusion-exclusion criteria | - Group counseling; - Tailored cognitive behavioral therapy | - Chi-square analyses; - Repeated measures analyses for categorical outcomes using generalized estimating equation | In the final step of the GEE analysis a significant interaction was found between treatment and heavy smoking (P = 0.02), and between treatment and recurrent depression (P = 0.02) | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | | Adequate randomization:
US | Smokers with a positive history of MDD | G1: 86 | G1: Eight 2-hr sessions over 6 weeks standard comprehensive CBT for smoking cessation, plus cognitive behavioral coping for depression | - Self report; - CO and saliva cotinine | | NR
Funding agency: | Study type: | C1: 93 | C1: Eight 2-hr sessions over 6 weeks; comprehensive, standard CBT for smoking cessation | Dependent variables: | | Attrition rate:
National Institute on Drug Abuse; American Cancer Society | RCT | Definition of smoking: | Method of assessment: | - Demographic characteristics (age, gender, marital status, and years of education); - Nicotine dependence severity (FTND score, number of years smoking, average daily smoking rate, and saliva cotinine); - Depression severity and chronicity | | - 5% at 1 month; - 8.9% at 6 months; - 7.8% at 1 year
Study setting: | Inclusion criteria: | - Smoked at least 10 cigarettes a day for at least 1 year | Assessment battery administered at pretreatment; questionnaires administered at each session during treatment; follow-up phone interviews occurred at 1, 6, and 12 months posttreatment, and self-reported abstinence was verified biochemically
Population-based | - Ages of 18 and 70 years; - Smoked for at least 1 year; - Currently smoking at least 10 cigarettes per day; - Had a history of MDD according to the DSM-III | | Baseline data:
| Exclusion criteria: | | Groups were similar
| - DSM-III-R diagnosis of current MDD, dysthymia, or other Axis I disorder; - DSM-III-R diagnosis of psychoactive substance abuse or dependence within the past 6 months (other than nicotine); - Current use of psychotropic medication; - Current weekly psychotherapy; - Use of other tobacco products; - Intent to use pharmacological aid to cessation
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Mean of anxiety disorders: | Quality rating:
Brown et al., 2003 | To test hypothesis that among adolescent smokers hospitalized for psychiatric and/or substance use disorders, MIwould lead to more and longer quit attempts, reduced smoking, and more abstinence from smoking over 12 mo followup | Consecutive sample of eligible 13 to 17 yr olds hospitalized for psychiatric and/or substance use disorder but not psychotic | - Self-help; - Individual counseling by health professional; - Telephone counseling; - Pharmaceuticals | Hierarchical Linear Modeling | G1: 1.1 | Fair
Geographic area: | Population: | Sample size: | Intervention: | GEE | G2: 1.3 | Comments:
US | - Adolescents; - Aged 13 to 17 from Providence, RI | G1: 116 | G1: two in-person 45-minute MI sessions during hospitalization or on outpatient basis; self-help pamphlet and manual; offer of up to two 8-wk courses of free transdermal NPtherapy if eligible; up to 6 postdischarge phone counseling sessions; up to 4 brief parent intervention phone counseling sessions. | Linear and Logistic Regression | P = NS | - High refusal rate; - Due to slow participant flow, recruitment ended before all cohorts completed, resulting in imbalance of participants across conditions; - Inconsistent txt implementation
Funding agency: | Study type: | G2: 75 | G2: 5–10 minute in-person advice to quit smoking; self-help pamphlet; offered one course of transdermal NPtxt if eligible | Data verification: | Odds for quit attempts | Adequate randomization:
None listed | RCT w/ systematic cohort randomization | Definition of smoking: | C1: NA | Self-report plus biochemical verification (saliva cotinine) for those claiming tobacco use abstinence | AOR 1.99 (95% CI, 1.08, 3.71) | Yes
Study setting: | Inclusion criteria: | Cigarettes | Method of assessment: | Dependent variables: | Longest quit attempt, days: | Attrition rate:
Psychiatric hospital | - Hospitalized for psychiatric and/or substance use disorder; - Age 13 to 17; - Smoked at least 1 cigarette/wk for 4 wks prior to hospitalization; - Access to phone | - Number of cigarettes smoked per day | Pre and postintervention assessment of various outcomes at 1, 3, 6, 9, and 12 mo follow ups | - Point prevalence abstinence; - Quit attempts; - Changes in smoking rate; - Longest quit attempt | G1: 48.2 | 20 (9%)
| Exclusion criteria: | | Smoking: | Baseline data: | G2: 60.9
| - DSM-IV criteria for psychotic disorder; - Recent violent behavior; - Recent participation in another study; - Uncertain guardianship status; - Language incompatibility; - Sibling in study; - Significant cognitive impairment; - Residing too far away to complete followups; - Patient or parent refusal | | - Self-report and biochemical verification for those claiming abstinence | - Female: 62.3; - Mean age: 15.4 | P > 0.05
| | | Nicotine Dependence: | Race/ethnicity | NS
| | | - Fagerstrom tolerance questionnaire; - Psychopathology dz: C-DISC; - Intent to change: Self-report to single item; - Self-efficacy: SCQ | - White: 94.8; - HispaniC1: 1.6; - African American: 0; - Other Race: 3.6 | Point prevalence abstinence at 1, 6 and 12 mos:
| | | | Other | P > 0.30, NS
| | | | - Mean age at first cigarette: 10.85; - Smoked on avg: 91.19% of previous 3 mos; - Mean: 14.48 cigarettes on smoking days; - Daily smokers: 63.9; - Mean Fagerstrom tolerance score: 4.9; - Met DSM-IV criteria for nicotine dependence: 68.6; - Mean length inpatient stay: 9.11 days; - Used NRT during hospital stay: 26% | Smoking rate: (b = 0.05, SE = 0.16, P = 0.74, NS)
| | | | | Higher discharge scores on situational confidence questionnaire associated w/ significantly less smoking during followup (b = -0.02, SE = 0.007, P = 0.007)
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | At 1 wk postcessation: higher levels of depression predicted failure to achieve abstinence (Itt analysis); higher levels of nicotine dependence and depression associated w/ decreasing likelihood of abstinence (analysis of txt-compliant patients) and likelihood of abstinence for participants on fluoxetine tended to be higher than for those on placebo (P = 0.06); At 1 month postcessation: higher levels of weight concern predicted lower abstinence (X^2^ 4.8, P = 0.78); patients on fluoxetine had positive association b/w degree of depression and likelihood of abstinence (highest quartile HRSD = 3, OR = 2, 95% CI, 0.85–4.70); At 3 months postcessation: patients treated w/ fluoxetine had positive association b/w HRSD scores and abstinence likelihood (highest quartile HRSD = 3, OR = 1.44, 95% CI, 0.53–3.91) | Quality rating:
Hitsman et al., 1999 | To identify individual differences that predict cessation when fluoxetine is combined w/ CBT | Specific randomization scheme NR. | - Individual counseling by health professional; - Pharmaceuticals | Constructed predictive models using logistic regression w/ hierarchical approach to variable selection. | Smoking characteristics predicting txt compliance were nicotine intake at baseline, saliva cotinine (X^2^ = 11.4, P < 0.001), and expired CO ( X^2^ = 5.3, P < 0.05) | Fair
Geographic area: | Population: | Sample size: | Intervention: | Models evaluated w/ parallel analyses using stepwise selection procedure | | Comments:
US | - Adults | Total: 253 | G1: Nine, 1-hr individual CBT sessions + fluoxetine 30 mg for a total of 10 wks | Data verification: | | - Authors didn't report numbers of participants per arm of study, baseline demographic characteristics of those groups, nor 6 month followup results; - Inclusion/exclusion criteria are described in companion article, Borrelli, et al. 1997
Funding agency: | Study type: | Definition of smoking: | - Participants required to set a quit date within 2 wks after drug txt began; - Participants quit smoking at 3rd CBT session; - Medication stopped at 9th CBT session, at which time 6-month followup period began; - CBT not explained; - Patients w/ fluoxetine level less than or equal to 150 ng/ml considered compliant | Expired CO and saliva continine | | Adequate randomization:
VA Merit Review award by NIDA, and Eli Lilly and Company | RCT w/ simple randomization | Cigarettes | G2: Same as G1:, except fluoxetine dose of 60 mg and fluoxetine blood level less than or equal to 300ng/ml considered compliant | Dependent variables: | | NR
Study setting: | Inclusion criteria: | - Reported smoking; - Expired CO greater than 8 ppm; - Saliva continine value greater than 10 ng/ml | C1: Same as G1, except given placebo | Depression, nicotine dependence, weight concerns, self-efficacy about quitting smoking | | Attrition rate:
Population-based | Participants are: | | Method of assessment: | Baseline data: | | NR
| - 18 to 65 yrs of age; - have smoked daily for at least one yr; - exhibit a baseline expired CO level of greater than 8 ppm'; - agree to declare a quit date within 2 wks after second study visit (Source: Borrelli, et al. 1997) | | Self report of smoking, expired CO, and saliva continine | No significant difference b/w txt groups in baseline characteristics: age, gender, education, smoking history, baseline level of nicotine dependence, depression, weight concern, and self-efficacy
| Exclusion criteria: | | Also used depresion scale, nicotine dependence, weight restraint scale, and self-efficacy questionnaire
| - Clinically significant depression HDRS score greater than 14; - Pregnancy; - Hypertension; - Use of psychotropic medication or current psychiatric illness; - Alcohol or drug abuse in past yr; - Current use of nicotine replacement; - Unstable medical condition or major health event in past 6 months; - Use of ST, pipes or cigars; - Recent experience of a major life event (e.g., divorce or major job change); - Suicidal ideation; - History of bipolar disorder (Source: Borrelli, et al. 1997)
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Proportion of patients that want to quit smoking while in hospital at three-wk followup: | Quality rating:
Joseph, 1993 | To evaluate effect of smoke-free policies in in-patient alcohol txt wards and effect of these policies on long-term txt outcomes | - Enrolled consecutive patients; - Admitted to an inpatient substance abuse txt program prior to implementation of a smoke-free policy and those patients admitted after smoke-free policy was implemented | - Group counseling; - Classroom instruction | NR | G1: 24% | Fair
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | G2: = 61% | Comments:
US | - Adults | G1: 407 | G1: Patients not given specific information about smoking or cessation; smoking on the ward only permitted in 2 designated rooms and not allowed during group sessions | NR | P = < 0.001 | - Statistical methods NR; - No biochemical verification; - High attrition
Funding agency: | Study type: | G2: 299 | G2: Patients required upon admission to acknowledge the smoke-free policy and sign a contract agreeing to abstain from nicotine during their stay; smoking cessation program designed for substance abusers delivered (didactic lectures on pharmacology of nicotine, films, and discussion group); Clonidine patches available but not studied in a systematic fashion | Dependent variables: | Proportion of patients that has abstained from smoking for > 1 wk: | Adequate randomization:
NR | Prospective cohort study | Definition of smoking: | Method of assessment: | Tobacco-use status; motivation to quit; use of substances other than nicotine | G1: 9% | NR
Study setting: | Inclusion criteria: | NR | A one-pg, standardized, self-administered questionnaires given upon admission to hospital and third wk of hospitalization to assess smoking status and motivation to quit | Baseline data: | G2: 41% | Attrition rate:
Hospital | NR | | Structured telephone interviews at 1 yr posthospitalization (pre policy group interviewed at 16.2 mos and post policy group at 10.7 mos) conducted to assess use of substances other than nicotine | Demographic data from both groups similar at baseline | P = < 0.001 | Attrition at 1-yr followup:
| Exclusion criteria: | | Improvement in chemical dependency defined as less or no use of substance abuse they were treated for at hospital | | Proportion of patients that cut down smoking while in hospital: | G1: 61.7%
| Excluded patients admitted b/w May and July, 1988, because they would have overlapped w/ the implementation of smoke-free policy | | | | G1: 46% | G2: 45.5%
| | | | | G2: 93%
| | | | | P = < 0.001
| | | | | Quit smoking as reported at 1 yr followup interview:
| | | | | G1: 3%
| | | | | G2: 8%
| | | | | P < 0.05 quit smoking
| | | | | No significant difference found in 1-yr followup for non-nicotine substance use b/w groups
Author: | Research objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Smoking Cessation Outcomes | Quality rating:
Joseph, Willenbring et al., 2004 | To compare the effects of smoking treatment and intensive treatment for alcohol dependence, delivered concurrently, with treatment delayed by 6 months on smoking outcomes and alcohol use | - Treatment assignment accomplished by stratifying by substance use disorder treatment site and blocking within site in groups of 10. Computer generated random sequence was concealed from study personnel; - Initial screening included questions about interest in participating in a research study, stage of change and potential concerns about participating. (Screen A); - Patients passing Screen A invited to do Screen B, a computerized self-administered Quick Diagnostic Interview Schedule to confirm that they met criteria for alcohol dependence.; - 1,943 adults assessed for eligibility; - 499 adults agreed to participate | Behavioral counseling and pharmacological treatment | - Simple likelihood ratio chi-square tests compared rates of tobacco and alcohol abstinence; - Logistic regression analyses modeled the odds of smoking abstinence and prolonged alcohol abstinence as a function of intervention group and baseline measures that might affect smoking and alcohol treatment outcomes | Intention-to-treat Analysis | Good
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | 7 day point prevalent smoking abstinence rates at 3 months were 15.5% in the concurrent treatment group and 4.4% in the delayed group (P < 0.0001); at 6 months, 10.5% vs. 5.2% ( P = 0.02) (note that at 3 and 6 months the delayed treatment group had not received intervention). At 9,12 and 18 months there were no significant differences between treatment groups. | Comments:
US | Adult men and women ages 21–75 | G1: 251 | G1 (concurrent treatment): Individual counseling (1-hour face-to-face session) and up to 3 follow-up sessions conducted in person or by telephone | Self-report abstinence | Alcohol Abstinence Outcomes | - Very low participation rate in expired carbon monoxide testing, 34% at 12 months and 25% at 18 months; - 6.6% failed to support self-reported abstinence rates
Funding agency: | Study type: | G2: 248 | Participants in the action stage of change received a free prescription for NRT, unless they declined or had a medical contraindication | Smoking validated by expired carbon monoxide; alcohol by breath alcohol concentration. | At 6- 12- and 18-month visits, point prevalent alcohol abstinence was lower in the concurrent treatment group than in the delayed treatment group (P = 0.004, P = 0.11, and P = .001, respectively) | Adequate randomization:
National Institute on Alcohol Abuse and Alcoholism; Health Services Research and Development Center for Chronic Disease Outcomes Research, Veterans Affairs | RCT Stratified random sampling | Definition of smoking: | Medication algorithm recommended nicotine patches (21 mg for 6 weeks, 14 mg for 2 weeks and 7 mg for 2 weeks). A combination of patches and nicotine gum was offered to participants who smoked more than 20 cigarettes per day. | Dependent variables: | | Yes
Study setting: | Inclusion criteria: | Any smoking within past 7 days | Method of assessment: | - Smoking: 7 day point prevalence; - Smoking abstinence at 3, 6 and 12 months; - Prolonged (6-mo.) smoking abstinence at 18 months; - Number of quit and relapse episodes; - Participation in treatment; - Alcohol: 6-months duration of alcohol; - 1-months duration of alcohol abstinence and number of drinking days in the past 6 months; - Relapse to alcohol | | Attrition rate:
Residential treatment program | - Met criteria for alcohol dependence or abuse according to the Diagnostic and Statistical Manual of Mental Disorders, 4th ed. and who smoked more than 5 cigarettes per day for more than 1 year; - Completed first week of alcoholism treatment | | - Data collected at treatment site, research study office or by telephone at 6, 12 and 18 months after study enrollment; - Brief smoking outcome data were also collected at 3 and 9 months | | | 18% at 6 months
| Exclusion criteria: | | Baseline data: | | | 20% at 18 months
| - No interest in stopping smoking; - Diagnosis of dementia or schizophrenia; - Inability to comply with the protocol due to severe psychiatric symptoms or cognitive deficits; - Refusal to provide the name of a contact or source of collateral information; - Unwillingness to attend visits as planned in the protocol | | No baseline group differences
Author: | Study objective: | Sampling plan: | Intervention methods: | Statistical analysis: | Outcome measures: | Quality rating:
Murray et al., 1995 | Explore relationship b/w alcohol consumption and smoking cessation | NR | - Group counseling; - Pharmaceuticals | Polychotomous ordinal logistic regression | No significant relationship b/w amount of alcohol consumed at baseline and smoking status after 1 yr for G1. | Poor
Geographic area: | Population: | Sample size: | Intervention: | Data verification: | In G2, women baseline drinkers more likely not to be smoking after 1 yr: | Comments:
US | - Adults; - Describe: aged 35 to 60 | G1: 2,649 | G1: Bronchodilator inhaler or placebo inhaler and multi-component counseling and nicotine gum; counseling intervention included a multi-component approach w/ standard cognitive-behavioral strategies such as stimulus control, avoidance, role playing, assertiveness training, reinforcement, and relaxation techniques | Self-report on CO in expired air | G1:14% | - Changed exclusion criteria after recruiting 1/3 of participants; - Post randomization of subjects (excluded recovering alcoholics); - No systematic control of NRT use; - No information on attrition; - Within txt group analysis
Canada | Study type: | C1: 1,327 | - Following counseling program, regular maintenance program scheduled on at least a monthly basis; - Maintenance programs included weight management and exercise; - In addition an extended group intervention program offered to participants who relapsed and want to try and quit again; NRT available free of charge to study participants but not tracked systematically in relationship to quit rates | Dependent variables: | G2: 6.3% | Adequate randomization:
Funding agency: | RCT w/ simple randomization | Definition of smoking: | C1: Usual care | - Current alcohol use; - History of alcoholism; - History and current use of tobacco; - Family smoking; - Attitudes towards smoking and stopping smoking; - Physical dependence on nicotine (Fagerstrom) | P = NR | Yes
Division of Lung Diseases of the NHLBI | Multi-center clinical trial | Cigarettes | Method of assessment: | Baseline data: | Currently drinking at end of intervention: | Attrition rate:
Study setting: | Inclusion criteria: | Defined as smoking at any clinic visit | - Baseline interviews using self-reported alcohol and tobacco use; - Intervention group (only), contacted monthly for 1st yr then w/ clinic visits every 4 mos w/ alcohol used assessed at 12 mos | Similar w/ an exception, less female alcoholics in C than in txt group (2.8% vs5.8%) | G1: | NR
Practice/provider settings | - Smokers; - Age 35 to 60 w/ evidence of early stage COPD | | | | Smokers: 5.24 drinks/wk
| Exclusion criteria: | | | | Nonsmokers: 4.46 drinks/wk (t = 1.94, 1,440df, P = 0.05)
| - Serious health condition that is likely to affect lung function; - Use of regular medications that might interfere w/ study results; - Consumption of more than 25 alcohol drinks per wk or 8 drinks in one occasion once a mo or any consumption of alcohol in past yr for recovering alcoholics | | | | Within smoking cessation intervention (G1), those who drank eight or more drinks per occasion (binge drinkers) more likely to be current smokers (i.e., lower cessation rate) after 1 yr (men binge = 44.8%, no binge = 51%, P < 0.05) and (women binge = 27.3%, no binge = 41.8%, P < 0.01)
| | | | | Within intervention group, binge drinkers smoked more cigarettes per day than those without a history of binge drinking (Men binge = 12.5, no binge = 10.3, P < 0.05) and (women binge = 14.3, no binge = 10.7, P < 0.01)
| | | | | When volume of drinking and drinking of eight or more drinks per occasion were compared in polychotomous ordinal logistic regressions, only binge drinking for men predicted failure at smoking cessation (Chi sq = 4.11, 1 d.f. P < 0.05, OR = 0.76)

Evidence Table 10. Systematic and meta-analysis reviews

Study Demographics | Study Characteristics | Aim of Review | Quality Rating
| | Main Results
Author, yr | Inclusion criteria | Aim of review | Quality rating
Ebbert et al., 2004 | Randomized trials of behavioral or pharmacologicial interventions to help users of ST to quit, w/ a followup of at least 6 months | To assess effects of behavioral and pharmacotherapeutic interventions to treat ST use | Good
Geographic area | Population | Main results | Adverse events
United Kingdom | Users of any tobacco product that is placed in mouth and not burned, including moist snuff, chewing tobacco and betel quid | No evidence of ST abstinence for trials using bupropion, NRT, or nicotine gum | Yes
Funding source | Characteristics of studies (Interventions) | Three trials showed significant effects using behavioral interventions | All reported adverse events associated w/ NRT such as skin reactions, nausea, headache and gastro-intestinal distress
No source of support supplied | Interventions studies could be pharmacologicial (NRT or bupropion) or behavioral, either directed at individual ST users or a groups of users | A subgroup of behavioral studies that randomized individuals showed a pooled significant effect (OR 1.43, 95% CI, 1.06 to 1.93); OR higher in trials that included an oral exam and feedback (OR 2.41, 95% CI, 1.79 to 3.24)
Time period covered | Method of review
Databases searched systematically through March 2004 | - One author examined all titles generated from search and obtained abstracts; - Abstracts considerd by two authors for full text review; - Differences of opinion resolved by consensus
| Study design
| Cochrane Systematic Review and meta analysis.
| Studies included in meta-analysis
| - Eight behavioral trials; - Separate meta analyses performed on 4 studies that randomized individuals and on 4 studies that gave oral exams and feedback to ST users
Author, year | Inclusion criteria | Main results | Quality rating
El-Guebaly et al., 2002 | Studies that presented data on samples of people with diagnoses of specific mental illness or addictive disorders, with not restrictions as to methodology. Broader studies reporting symptomatic sub groups in their analysis were excluded | Twenty-four studies, 8 included schizophrenia, 8 included depression, and 8 included persons with addictive disorders | Fair
Geographic area | Population | Interventins used a combination of medication, educational and cognitive-behavioral approaches | Comments
Canada | People with diagnoses of specific mental illness or addictive disorders | Post-treatment quit rates for Schizphrenia ranged from 35% to 56%, and a 6 months quit rate of 12% | NR
Funding source | Characteristics of studies (interventions) | Postreatment quit rates for depression ranged from 31% to 72%, and 12 months quit rates 11.8% to 46% | Adverse events
NR | Smoking cessation interventions targeted at people with diagnoses of specific mental illness or addictive disorders | Postreatment quit rates for addictive disorders ranged from 7% to 60%, and 12 months quit rates 13% to 27% | NA
Time period covered | Method of review | Aim of review
Reveiwed the following databases between 1991 through 2001: Medline, CINAHL, PsycINFO, Best evidence, Healthstar, Cochrane Database of Systematic Reviews, Legal Trac, Bioethicsline, Philosopher's Index, and Dissertation abstracts | NR | To assess the impact of smoking cessation approaches on individuals with mental illness or addictive disorders
| Study design
| Qualitative narrative synthesis
| What studies are included in meta-analysis
| NA
Author, yr | Inclusion criteria | Aim of review | Quality rating
Lancaster et al., 2005 | Randomized trials of smoking cessation w/ followup of at least six months, where at least one arm tested a self-help intervention | To detemine effectiveness of different forms of self-help materials, compared w/ no txt and w/ other minimal contact strategies; effectiveness of adjuncts to self-help, such as computer generated feedback, telephone hotlines, and pharmacotherapies | Good
Geographic area | Self help defined as a structured program of smokers trying to quit without intensive contact w/ a therapist | Main results | Adverse events
United Kingdom | Population | Self-help vs no intervention: OR favored self-help intevention, although C1 narrowly excluded 1 (N = 13,773; OR 1.24, 95% CI, 1.07–1.45) | No
Funding source | Any smoker except pregnant smokers and adolescent smokers. | - Two trials excluded due to significant heterogeneity; - Where controls received an alterative form of written materials -- no evidence of an effect (N = 4,807; OR .87, 95% CI, .68 to 1.12);; - Failed to find evidence of an increased quit rate by adding self-help to advice or NRT; - Based on 3 studies self-help tailored materials were better than no intervention (N = 7,790 OR 1.38, 95% CI, 1.15–1.66)
Internal: Department of Primary Health Care, University of Oxford UK | Characteristics of studies (Interventions)
External: NHS Research and Development Programme UK | - Self-help interventions used by individual to assist a quit attempt not aided by health professionals, counsellors and group support; - Included written materials, audio, videotape or computer programs
Time period covered | Method of review
Databases searched systematically through April 2005 | - Two authors extracted data; - Trials categorized according to amount of face to face contact provided to both txt and comparison intervention, and according to whether txt group received any written materials
| Study design
| Cochrane Systematic Review and meta analysis performed where appropriate
| Studies included in meta-analysis
| NR
Author, yr | Inclusion criteria | Aim of review | Quality rating
Lancaster et al., 2005 | Randomized and quasi-randomized trials w/ a least one txt are consisting of face to face individual counseling from a health care worker not involved in routine clinical care and outcome of smoking cessation at least 6 months after intervention | To determine effects of individual counseling | Good
Geographic area | Population | Main results | Adverse events
United Kingdom | Any smoker except children, adolescents, and pregnant women. | - Studies comparing counseling w/ minimal contact controls reported counseling significantly increases likelihood of cessation compared to less intense support (OR 1.56 95% CI, 1.32–1.84); - No evidence of benefit from more intensive compared to brief counseling (OR .98, 95% CI, .61–1.56);; - Cessation rates higher in trials that used NRT, and patients w/ coronary artery disease; - No significant differences occured b/w the comparison of counseling approaches | No
Funding source | Characteristics of studies (Interventions)
Internal: Oxford University of Primary Health Care UK; External: NHS Research and Development Programme UK | - Face to face encounter b/w a smoking patient and a counsellor trained in assisting smoking cessation; - Excludes studies of counseling delivered by doctors or nurses involved in regular clinical care; - Also excluded multiple risk factor interventions
Time period covered | Method of review
Databases systematically searched though Dec 2004 | - Two authors extracted data; - Studies summarized; - Results reported as odds ratios; - Meta analysis used when appropriate
| Study design
| Cochrane Systematic Review w/ meta analysis of pooled studies
| Studies included in meta-analysis
| NR
Author, yr | Inclusion criteria | Aim of review | Quality rating
Lancaster et al., 2004 | - Randomized trials of smoking cessation advice from a medical practitioner in which abstinence was assessed at least 6 months following advice.; - For inclusion in meta analysis: 1) had to have at least 2 txt groups, and 2) allocation to groups must use formal randomization | To assess effectiveness of advice from physicians in promoting smoking cessation; to compare minimal interventions by physicians w/ more intensive interventions; to assess effectiveness of various aids to advice in prom | Good
Geographic area | Population | Main results | Adverse events
United Kingdom | - Participants were smokers recruited in any setting; - Pregnant smokers excluded | Small satistically significant increase in odds of quiting (OR 1.74, 95% CI,1.48 to 2.05); Intense advice vs no advice and minimal advice showed a small but significant advantage to more intense advice | NA
Funding source | Characteristics of studies (Interventions) | A subset of 10 trials of smoker NOT selected as having smoking related disease showed a marginal significant impact for more intensive interventions (OR 1.24, 95% CI, 1.02 to 1.50);
NHS Research and Development Programme UK | Studies included physician advice to stop smoking vs no advice or comparing different levels of physician advice to stop smoking | Studies that included followup visits had a higher success rate vs no advice than those studies that didn't have followup visits (OR 2.55, 95% CI, 2.04 to 3.19)
Time period covered | Method of review | Lack of evidence as to effectiveness of aids used in addition to providing advice and motivational counseling vs brief advice did not increase cessation rates
Reviewed the following databases b/w 1972 and 2003. | - Data extracted from published reports by 2 people independently; - Disagreeements resolved by referral to a third party; - Quality assessment performed on all studies
Tobacco Addiction Group Register, Medline, Embase, Psyclit and the Cochrane Central Register of Controlled Trials, handsearching of specialist journals, and conference proceedings | Study design
| Cochrane systematic reivew and meta analysis
| Studies included in meta-analysis
| Seventeen trials of brief advice vs no advice were pooled
Author, yr | Inclusion criteria | Aim of review | Quality rating
Lancaster et al., 2000 | - Randomized trials in which the intervention was training of health care professionals in smoking cessation; - Only used trials w/ outcomes from patient smoking rates at least 6 months after intervention | To assess effectiveness of training health care professionals to deliver smoking cessation interventions to their patients, and to assess additional effects of prompts and reminders to the health professional to intervene | Good
Geographic area | Population | Main results | Adverse events
United Kingdom | Health care practitioner or health care practice | - 10 studies met criteria; - Trained professionals about 1.5 to 2.5 times more likely to counsel patients about smoking; - One study found a significant effect of training on sustained abstinence at one yr (8.8% trained group vs 6.1% and 4.4% in comparison groups P < 0.001); - Prompts increase frequency of health professions performing intervention but only 1 out of 3 studies reported significant abstinence rates | No
Funding source | Characteristics of studies (Interventions)
Internal: Department of Primary Health Care, University of Oxford UK; | - Health care professionals trained in methods to promote smoking cessation among their patients; - Allocated health care professionals into at least 2 groups by a formal method of randomization; - Studies that compared trained professionals to C and studies that examined effectiveness of adding prompts and reminders to training
External: NHS Anglia and Oxford Region Research and Development Programme UK; NHS Research and Dvelopment National Cancer Programme UK | Method of review
Time period covered | - Two reviewers independently extracted data from published articles. Disagreement resolved by referral to another person
Database searched systematically through May 2000 | Study design
| Cochrane Systematic Review using a narrative approach to synthesising data
| Studies included in meta-analysis
| NR
Author, yr | Inclusion criteria | Aim of review | Quality rating
Lumley et al., 2004 | Randomized and quasi-randomized trials of smoking cessation programs implemented during pregnancy in settings such as hopitals, and community clinics | To assess effects of smoking cessation programs implemented during pregnancy on health of fetus, infant, mother, and family | Good
Geographic area | Population | Main results | Adverse events
United Kingdom | Healthy pregnant women, women seeking a pre pregnancy consultation, and health professionals. | - 48 trials revealed a significant reduction in smoking in late pregnancy for aintervention groups (RR.09, 95% CI, .93–.95) this is an absolute difference of 6 out of 100 women continuing smoking; - With biochemically validated studies, absolute difference was same (RR.94, 95% CI, .92–.95); - Smoking cessation interventions signifcantly reduced low birth weight, preterm birth, and increase birth weight by 33 g (RR .81, 95% CI, .70–.94), (RR .84, 95% CI, .72–.98), and (95% CI, 11g - 55g); - Intervention strategy (reward + social support) showed significantly greater smoking reduction (RR .77, 95% CI, .72–.82); - Stages of change and relapse showed no significant reduction in smoking | No
Funding source | Characteristics of studies (Interventions)
NHS Central R & D Programme, Dept. of Health 1995-1996 UK; Victorian Health Promotion Foundation Australia; Dept. of Health, funding for EPI Center, London University UK; Public Health Branch Victoria Dept. of Human Services Australia; La Trobe University | Interventions include programs providing information on risks of smoking to fetus and infant, benefits of quitting, recommendations to quit, setting quit date, feedback about fetus and harmful levels of cotinine or CO, teaching cognitive behavior strategies, advice tailored to stages of change model, rewards/incentives, social support or peer support, and NRT
Time period covered | Method of review
Databases searched systematically though July 2003 | - Two reviewers independently extracted data from published reports; - Quality review of methodology assessed; - Heterogeneity tested In all pooled analyses
| Study design
| Cochrane Systematic Review and meta analysis
| Studies included in meta-analysis
| NR
Author, year | Inclusion criteria: | Aim of review | Quality rating
Melvin et al., 2003 | Randomized, comparison-controlled intervention trials for pregnant smokers at the individual level | To review the recommendations made in 2000 regarding treatment for pregnant and parenting | Good
Geographic area | Population | Main results | Adverse events
United States | Pregnant smokers | The 5 A's approach is still the best treatment for light and moderate smokers | NR
Funding source | Characteristics of studies (interventions) | Clinicians offering care to postpartum women and parents should asses smoking status and second hand smoke exposure
The Robert Wood Johnson Foundation | - Brief counseling approach for pregnant smokers; - Improving disclosure of smoking status; - Spontaneous quitting and eminence of cessation; - Postpartum relapse prevention; - Adjuncts to brief counseling; - Exposure to second hand smoke around time of pregnancy; - Disclosure of second hand smoke around time of pregnancy; - Increasing compliance with best practice | For parents willing to quit, the use of pharmacotherapy should be used to help
Time period covered | Method of review | To assess compliance of practice guidelines with best practice guide evaluation of effectiveness, assessment of financial incentives, and identification of methods is needed
Databases systematically search from January 1994 through March 31 2002. | Pre-screened published articles for relevance, two reviewers assessed studies independently for inclusion, data extracted by 1 reviewer and checked by a second, and used narrative synthese | Additional research is recommended on ways to improve disclosure, safety and efficacy of pharmacotherapy, use of biomarker feedback or incentives, partner involvement, and interventions to reduce second hand smoke
| Study design
| Systematic review of literature
| What studies are included in meta-analysis
| NA
Author, yr | Inclusion criteria | Aim of review | Quality rating
Moher et al., 2005 | Interventions categorized into two groups: 1)Interventions aimed at individual to promote smoking cessation in the workplace setting (included randomized control trials) 2) Interventions aimed at workplace as a whole (included controlled trials w/ baseline and post interventionoutcomes and interrrupted times series studies) | To assess extent to which different kinds of workplace smoking programs help smokers to reduce or stop cigarette consumption. | Good
Geographic area | Population | Main results | Adverse events
United Kingdom | Adults, over 18 yrs of age, in employment, who smoked. | - Group and individual counseling (particularly by a physician), and NRT significantly increased cessation rates vs no txt or minimal intervention controls; - Self-help interventions less effective; - Tobacco bans aimed at workplace as a whole decreased cigarette consumption at work but no evidence that total consumption decreased; - Quit rates not increased by adding social or environmental support to workplace programs Competitions and incentives increased attempts to quit but less evidence for actual quitting | No
Funding source | Characteristics of studies (Interventions)
Internal: Department of Primary Health Care, Oxford University, External: NHS Research and Development Program UK | - Smoking cessation programs aimed at individual in workplace including individual and group counseling, self help materials, advice from physicians and NRT; - Interventions aimed at workforce population to assess a comprehensive approach to workers health, including smoking cessation
Time period covered | Method of review
Databases searched systematically through October 2004. | - Prescreened published articles for relevance; - Two reviewers assessed studies independently for inclusion; - Data extracted by 1 reviewer and checked by a second; - Because of considerable heterogeneity studies were combined using qualitative narrative synthesis
| Study design
| Cochrane Systematic Review
| Studies included in meta-analysis
| NR
Author, yr | Inclusion criteria | Aim of review | Quality rating
Prochaska et al., 2004 | Randomized controlled designs of evaluations of a smoking cessation intervention where study participants were in addiction txt or recovery | To examine outcomes of smoking cessastion interventions evaluated w/ individual in current addictions txt or recovery | Good
Geographic area | Studies used quantitative assessment | Main results | Adverse events
US | Population | - Abstinence rates for addictions txt were 12% vs 3% in intervention and Cs; - Abstinence rates for recovery were 38% vs 22% in intervention and Cs; - Summary RR for addiction txt 2.03 (95% CI, 1.21–3.39; heterogeneity, P = 0.519) indicated a significant increase in likelihood of abstinence in intervention group; - Summary RR for recovery 1.77 (95%CI, 1.37–2.30; heterogeneity, P = 0.878) indicated a significant increase in likelihood of abstinence in intervention group; - ANOVA comparing addiction and recovery intervention effects were NS; - Long term follow up no significant differences in smoking outcomes by condition; - Significant increase of drug and alcohol abstinence occurred in intervention groups RR = 1.25 (95% CI, 1.07–1.46, heterogeneity, P = 0.496); - NRT studies revealed stronger effects and more recently published | No
Funding source | Adults aged 18 yrs and older.
Calif Tobacco-Related Disease Research Program, and National Institute on Drug Abuse | Characteristics of studies (Interventions)
Time period covered | - Psychosocial smoking cessation interventions provided in all but 1 study and included the following: brief advice, educational information, skill based, behavioral, cognitive behavioral, motivational, or staged based interventions; - Eleven studies provided NRT, one evaluated bupropion, and another fluoxetine
January 1966 through September 2003 | Method of review
| - Two reviewers independently conducted article abstraction; - One reviewer blinded to study author, institution, artile title, journal, and yr of publication; - Qualilty assessment used a 3 pt scale; - Discrepancies settled though discussion or consulting a third reviewer
| Study design
| - Abstinence ratios used to measure effect for smoking and substance use; - Meta Analysis performed using 2X2 tables for txt and Cs; - To reduce bias .5 was added to every cell in the table containing a zero; - Abstinence rates expressed as relative risk w/ 95% CI; RR > 1.0 indicated favoring of intervention for increased abstinence
| Studies included in meta-analysis
| - 19 studies; - 12 conducted w/ 1,410 participants in addiction txt and 7 studies w/ 638 participants in recovery
Author, year | Inclusion criteria: | Aim of review | Quality rating
Rigotti et al., 2002 | - Randomized and quasi-randomized trials of behavioral, pharmacological or multicomponent interventions to help patients to stop smoking conducted with hospitalized patients; - Trials of secondary prevention or cardiac rehabilitation that did not recruit on the basis of smoking history and trials in patients hospitalized for psychiatric disorders or substance abuse (including inpatient tobacco addiction programs) were excluded. | To determine the effectiveness of interventions for smoking cessation in hospitalized patients. | Good
Geographic area | Population | Main results | Adverse events
United Kingdom | Patients who were hospitalized, or about to be hospitalized and who were currently smoking or had recently quit. | Intensive intervention (inpatient contact plus follow-up for at least 1 month) was associated with a significantly higher quit rate compared to control (Peto Odds Ratio = 1.82 (95% CI, 1.49–2.22, six trials). Inteventions with less than a month of follow-up did not show evidence of significant benefit (Peto Odds Ratio 1.99, (95%CI, 0.91–1.31, seven trials). There was no evidence to judge the effect of very brief (<20 minutes) interventions delivered only during rhe hospital stay. Longer inteventions delivered only during the hospital stay were not significantly associated with a higher quit rate (Peto Odds Ratio 1.07 (95% CI, 0.79–1.44, three trials). Although the interventions increased quit rates irrespective of whether nicotine replacement therapy (NRT) was used, the results for NRT were compatible with other data indicating that it increases quit rates. There was no strong evidence that clincial diagnosis affected the likelihood of quitting. | No
Funding source | Characteristics of studies (interventions)
NHS Research and Development Programme UK and Department of Primary Health Care, Oxford University,UK | Any intervention to increase motivation to quit, to assist a quit attempt or to help recent quitters avoid relapse.
Time period covered | Interventions during the hospital stay were categorized according to whether they included follow-up after discharge and by level of intensity leading to four categories of intervention intensity:
Databases systematically searched through March 2002 | - Single contact in hospital lasting ≤ 15 minutes, no follow-up support; - One of more contacts in hospital lasting in total > 15 minutes, no follow-up support; - Any hospital contact plus follow-up ≤ 1 month; - Any hospital contact plus follow-up ≥ 1 month
| Method of review
| Pre-screened published articles for relevance, three reviewers assessed studies independently for inclusion, data extracted by 1 reviewer and checked by a second, and used statistical methods for pooling described by Peto's group (Yusuf 1985)
| Study design
| Cochrane Systematic Review
| What studies are included in meta-analysis
| 17 trials conducted in the US, the UK, Canada and Spain between 1990 and 2002
Author, yr | Inclusion criteria | Aim of review | Quality rating
Secker-Walker et al., 2002 | Controlled trials of community interventions for reducing smoking prevalence in adult smokers where primary outcome measure was smoking behavior | To assess effectiveness of community interventions for reducing prevalence of smoking | Good
Geographic area | Population | Main results | Adverse events
United Kingdom | Adults, 18 yrs and older | - Changes in smoking prevalence measured using cross sectional data in 27 studies; - Net decline ranged from -1.0% to 3.0%/yr; for women -.2% to 3.5%/yr; for men -.4% to 1.6%/yr; - Two rigorous studies found significant results:1) change in smoking prevalence among light/moderate smokers, 2) greater quit rates among men but community level changes not found; - Projects that address smoking alone scarcely more effective than general health prevention projects; - Longer project, projects using formative research, and projects w/ higher levels of participation and awareness were more effective | No
Funding source | Characteristics of studies (Interventions)
No source of support supplied | Coordinated, multidimensional programs aimed at changing adult smoking behavior involving several segments of the community and conducted in a defined geographical area such as a town, city, county, or administrative district
Time period covered | Method of review
Databases searched systematically through August, 2001 | - Prescreened published articles for relevance; - Two reviewers assessed studies independently for inclusion; - Data extracted by 1 reviewer and checked by a second; - Studies combined using qualitative narrative synthesis
| Study design
| Cochrane Systematic Review
| Studies included in meta-analysis
| NR
Author, yr | Inclusion criteria | Aim of review | Quality rating
Sinclair et al., 2005 | Randomized trials which compared interventions by community pharmacy personnel to promote smoking cessation amongst their clients who were smokers compared to usual pharmacy support or any less intensive program | To assess effectiveness of interventions by community pharmacy personnel to assist clients to stop smoking | Good
Geographic area | Population | Main results | Adverse events
United Kingdom | Community pharmacy clients who are smokers and wish to stop. | - Two trials met the criteria w/ a total of 976 smokers; - Both studies involved training using stages of change model, and compared a support program of counseling and record keeping w/ a C who recieved normal services; - Significant result for study 1 showed cotinine-validated continuous abstinence at 12 months of 14.3% in intervention group and 2.7% in C; - Study 2 did not show a statistically significant effect at any followup, but there was a consistent trend toward benefits fro intervention; - Using a random effects model to pool results showed no evidence of significant benefits | NA
Funding source | Characteristics of studies (Interventions)
University of Aberdeen UK | Any intervention by community pharmacy personnel to promote smoking cessation amongst their clients
Time period covered | Pharmaceutical trials which compared only NRT w/ a control in the community pharmacy setting did not fall within scope of this review
Databases systematically searched through March 2003. | Method of review
| - Studies generated by search strategy reviewed by two authors, according to inclusion criteria; - Data extracted by one author and checked by a second
| Study design
| Cochrane Systematic Review
| Studies included in meta-analysis
| NR
Author, yr | Inclusion criteria | Aim of review | Quality rating
Sowden et al., 2003 | Randomized and non RCTs that assessed effectiveness of multi-component community (geographical or school district) interventions to prevent uptake of smoking in young people | To determine effectiveness of community interventions in preventing initation of smoking in young people. | Good
Geographic area | Population | Main results | Adverse events
United Kingdom | Young people aged less than 25 yrs | - Community interventions vs no intervention controls reported lower smoking prevalence;; - Community interventions vs school-based only intervention found a significant smoking prevalence in one study; - Community interventions vs community w/ school-based component found no differences in smoking cessation rates; - Community intervention w/ media component vs media alone found significantly lower rate of increased smoking in community and media intervention | No
Funding source | Characteristics of studies (Interventions)
NHS Center for Reviews and Dissemination, UK | Interventions targeted at entire or parts of entire communities or lage ares w/ intention of influencing smoking behaviors of young people
Time period covered | Method of review
Databases searched systematically through September 2002 | - Prescreened published articles for relevance; - Two reviewers assessed studies independently for inclusion; - Data extracted by 1 reviewer and checked by a second,; - Studies combined using qulitative narrative synthesis
| Study design
| Cochrane Systematic Review
| Studies included in meta-analysis
| NR
Author, yr | Inclusion criteria | Aim of review | Quality rating
Sowden et al., 1998 | Studies that evaluated effectiveness of mass media campaigns influencing smoking behaviors in young people using the following designs: 1) RCT w/ unit of analysis as school, community or geographic area, 2) controlled trial w/o randomization, 3) time series | To determine effectiveness of mass media campaigns in preventing uptake of smoking in young people. | Good
Geographic area | Population | Main results | Adverse events
United Kingdom | Young people aged less than 25 yrs. | - Two of these six control trial design interventions found to be associated w/ reductions in smoking behavior; - A media campaign aimed at girls found 4% lower smoking rates for girls in the media county (8.6% vs 12.4%, P < 0.01); OR of being a smoker in intervention county compared w/ being a smoker in control was .74 (95% CI, .64 to .86) after adjusting for baseline and gender; - A media campaign combined w/ a school-based program vs school based program alone found a lower risk for weekly smoking at 2 yr in communities w/ combined intervention (OR .62, 95% CI, .49 to .78); - Both studies had effective campaigns w/ solid theoretical basis, used formative research in designing messages, and message broadcasts were intense over a extensive period of time; - Problems w/ other studies: allocation of communities, areas and schools, unit of analysis, differences in baseline measure, and high attrition | NA
Funding source | Characteristics of studies (Interventions)
Internal: NHS Centre for Reviews and Dissemination UK; External: NHS Research and Development National Cancer Programme, England UK | - Mass media interventions using communication channels such as TV, radio, newspapers, bill boards, posters, leaflets or booklets intended to prevent uptake of smoking in young people; - Also mass media campaigns combined w/ school-based programs designed to influence smoking behaviors were included
Time period covered | Method of review
Databases searched systematically through June 1998 | - Stage 1: Reports of evaluations prescreened for relevance by at least one reviewer; - Stage 2: Relevant studies assessed independently by 2 reviewers; - Stage 3: Data extracted from included studies by one reviewer and checked by a second reviewer; - Stage 4: Studies combined using qualitative narrative synthesis
| Study design
| - Cochrane Systematic Review; - Studies combined using qualitative narrative synthesis
| Studies included in meta-analysis
| NR
Author, yr | Inclusion criteria | Aim of review | Quality rating
Stead et al., 2005 | Randomized trials w/ a minimum of two group meetings and followup at least 6 months | To determine effects of smoking cessation programs delivered in a group format compared to self-help materials, no intervention, individual counseling, advice from Physician, and NRT | Good
Geographic area | Population | Main results | Adverse events
United Kingdom | Smokers of either gender irrespective of initial level of nicotine dependency, except for pregnant smokers. | - Group therapy significantly increased cessation vs self-help using same or different content (N = 4395, OR 2.04, 95% CI, 1.60–2.60); - Higher quit rates comparing group to no intervention N = 815, OR 2.17, 95% CI, 1.37–3.45); No significant difference comparing group w/ individual therapy and only limited evidence that group produces extra benefits when combined w/ physician advice and NRT | No
Funding source | Characteristics of studies (Interventions)
Internal: Department of Primary Helath Care, Oxford University UK, External: NHS Research and Development National Cancer Programme UK | Studies where smokers met for scheduled meetings and received some form of behavioral therapy delivered over at least 2 sessions
Time period covered | Method of review
Database searched sytematically through February 2005 | - Studies idenified and reviewed independently by 2 authors and disagreements referred to a third party; - If 2 group methods were compared w/ another method the groups were combined and compared w/ the non group method
| Study design
| Cochrane Systematic Review and meta analysis performed if appropriate
| Studies included in meta-analysis
| NR
Author, yr | Inclusion criteria | Aim of review | Quality rating
Stead, 2003 | Randomized or quasi-RCTs in which proactive or reactive telephone counseling to assist smoking cessation was offered to smokers or recent quitters | To evaluate effect of proactive and reactive telephone support to help smokers quit | Good
Geographic area | Population | Main results | Adverse events
United Kingdom | Smokers or recent quitters | - Procative phone counseling + minimal intervention vs minimal intervention only: indicted a significant benefit from addition of phone counseling when minimal intervention used standard self-help material (OR 1.56, 95% CI, 1.38–1.77); - Proactive phone counseling increasec quit rates from 4.1% to 7.5% when compared to self-help or reactive counseling; Adding telephone counseling to face to face interventions failed to significantly increase OR (OR 1.08, 95% CI, .87–1.33); - Adding proactive counseling to NRT did not signficantly increasequit rates; proactive counseling compared to group counseling showed no differences; - Access to a hotline or reactive phone counseling showed a significant benefit in one out of 3 trials | No
Funding source | Characteristics of studies (Interventions)
NHS Research and Development Programme UK | - Proactive or reactive telephone counseling to assist smoking cessation to any population; - Also studies that combined telephone counseling w/ self-help materials
Time period covered | Method of review
Databases searched systematically through September 2002 | Relevant studies identified by one person and checked for inclusion or exclusion by a second person
| Data extracted by one author and checked by a second
| Study design
| Cochrane Systematic Review and if no signficant heterogeneity studies pooled for a meta analysis
| Studies included in meta-analysis
| NR
Author, yr | Inclusion criteria | Aim of review | Quality rating
Thomas et al., 2002 | Studies where individual students, classes, schools, or school districts were randomised to intervention or Cs and followed for at least 6 months | To review all RCTs of behavioural interventions in schools to prevent children and adolescents starting smoking | Good
Geographic area | Population | Main results | Adverse events
United Kingdom | Children (aged 5 to 12) or adolescents (aged 13 to 18) in school settings | - Information curriculum interventions less effective or showed no difference compared to other models of delivery; - SLT (most widely used theory) had 8 studies w/ positive effects and 7 w/o positive effects and HSPP study had no effect; - SLT lacks evidences about effectiveness; - Limited evidence that combining social influence models w/ other components improves effectiveness | No
Funding source | Characteristics of studies (Interventions)
No source of support supplied | Classroom programs or curricula, including those associated w/ family or community interventions, intended to deter use of tobacco
Time period covered | Method of review
Databases systematically searched through January 2002 | - Prescreened published articles for relevance; - Two reviewers assessed studies independently for inclusion; - Data extracted by 1 reviewer and checked by a second; - Because of considerable heterogeneity the studies were combined using qualitative narrative synthesis
| Study design
| Cochrane Systematic Reveiw
| Studies included in meta-analysis
| NR

## References for Evidence Tables

Ausems M, Mesters I, van Breukelen G, De Vries H. Effects of in-school and tailored out-of-school smoking prevention among Dutch vocational school students. Health Educ Res. 2004;19(1):51-63. [pmid: 15020545].
Aveyard P, Griffin C, Lawrenc T, Cheng KK. A controlled trial of an expert system and self-help manual intervention based on the stages of change versus standard self-help materials in smoking cessation. Addiction. 2003;98(3):345-54. [pmid: 12603234].
Aveyard P, Sherrat E, Almond J, et al. The change-in-stage and updated smoking status results from a cluster-randomized trial of smoking prevention and cessation using the transtheoretical model among British adolescents. Prev Med. 2001;33(4):313-24. [pmid: 11570836].
Bauman KE, Ennet ST, Foshee VA, Pemberton M, King TS, Koch GG. Influence of a family-directed program on adolescent cigarette and alcohol cessation. Prev Sci. 2000;1(4):227-37. [pmid: 11523750].
Bier ID, Wilso J, Studt P, Shakleton M. Auricular acupuncture, education, and smoking cessation: a randomized, sham-controlled trial. Am J Public Health. 2002;92(10):1642-7. [pmid: 12356614]. [pmcid: 1447300].
Bohadana A, Nilsso F, Rasmussen T, Martinet Y. Nicotine inhaler and nicotine patch as a combination therapy for smoking cessation: a randomized, double-blind, placebo-controlled trial. Arch Intern Med. 2000;160(20):3128-34. [pmid: 11074742].
Borland R, Balmfor J, Segan C, Livingston P, Owen N. The effectiveness of personalized smoking cessation strategies for callers to a Quitline service. Addiction. 2003;98(6):837-46. [pmid: 12780372].
Brown KS, Camero R, Madill C, et al. Outcome evaluation of a high school smoking reduction intervention based on extracurricular activities. Prev Med. 2002;35(5):506-10. [pmid: 12431899].
Brown RA, Kahle CW, Niaura R, et al. Cognitive-behavioral treatment for depression in smoking cessation. J Consult Clin Psychol. 2001;69(3):471-80. [pmid: 11495176]. [pmcid: 1832078].
Brown RA, Ramse SE, Strong DR, et al. Effects of motivational interviewing on smoking cessation in adolescents with psychiatric disorders. Tob Control. 2003;12 Suppl 4:IV3-10. [pmid: 14645934].
Cang N, De Irala J, Vara E, Duaso MJ, Ferrer A, Martinez-Gonzalez MA. Intervention study for smoking cessation in diabetic patients: a randomized controlled trial in both clinical and primary care settings. Diabetes Care. 2000;23(10):1455-60. [pmid: 11023136].
Carpenter MJ, Hughe JR, Solomon LJ, Callas PW. Both smoking reduction with nicotine replacement therapy and motivational advice increase future cessation among smokers unmotivated to quit. J Consult Clin Psychol. 2004;72(3):371-81. [pmid: 15279521].
Chalmers K, Bramada IJ, Cantin B, et al. A smoking reduction and cessation program with registered nurses: findings and implications for community health nursing. J Community Health Nurs. 2001;18(2):115-34. [pmid: 11407180].
Choi WS, Farka AJ, Rosbrook B. Does advertising promote smokeless tobacco use among adolescent boys? Evidence from California. Tob Control. 1995;4(Supplement 1):S57-S63.
Clark MM, Cox LS, Jett JR, et al. Effectiveness of smoking cessation self-help materials in a lung cancer screening population. Lung Cancer. 2004;44(1):13-21. [pmid: 15013579].
Cornuz J, Humair JP, Seematter L, et al. Efficacy of resident training in smoking cessation: a randomized, controlled trial of a program based on application of behavioral theory and practice with standardized patients. Ann Intern Med. 2002;136(6):429-37. [pmid: 11900495].
Covey LS, Glassma AH, Stetner F, Becker J. Effect of history of alcoholism or major depression on smoking cessation. Am J Psychiatry. 1993;150(10):1546-7. [pmid: 8379564].
Croghan GA, Sloan JA, Croghan IT, et al. Comparison of nicotine patch alone versus nicotine nasal spray alone versus a combination for treating smokers: A minimal intervention, randomized multicenter trial in a nonspecialized setting. Nicotine and Tobacco Research. 2003;5(2):181-7. [pmid: 12745490].
Crone MR, Reijneveld SA, Willemsen MC, van Leerdam FJ, Spruijt RD, Sing RA. Prevention of smoking in adolescents with lower education: a school based intervention study. J Epidemiol Community Health. 2003;57(9):675-80. [pmid: 12933772]. [pmcid: 1732562].
Dalsgareth OJ, Hansen NC, Soes-Petersen U, et al. A multicenter, randomized, double-blind, placebo-controlled, 6-month trial of bupropion hydrochloride sustained-release tablets as an aid to smoking cessation in hospital employees. Nicotine Tob Res. 2004;6(1):55-61. [pmid: 14982688].
Davies SL, Kohler CL, Fish L, Taylor BE, Foster GE, Annang L. Evaluation of an intervention for hospitalized African American smokers. Am J Health Behav. 2005;29(3):228-39. [pmid: 15899686].
Ebbert JO, Rowland LC, Montori V et al. Interventions for smokeless tobacco use cessation. Cochrane Database Syst Rev 2004; (3):CD004306
el-Guebaly N, Cathcart J, Currie S, Brown D, Gloster S. Smoking cessation approaches for persons with mental illness or addictive disorders. Psychiatr Serv. 2002;53(9):1166-70. [pmid: 12221317].
Ellickson PL, McCaffrey DF, Ghosh-Dastidar B, Longshore DL. New inroads in preventing adolescent drug use: results from a large-scale trial of project ALERT in middle schools. Am J Public Health. 2003;93(11):1830-6. [pmid: 14600049]. [pmcid: 1448059].
Ennett ST, Bauman KE, Pemberton M, et al. Mediation in a family-directed program for prevention of adolescent tobacco and alcohol use. Prev Med. 2001;33(4):333-46. [pmid: 11570838].
Etter JF, Perneger TV. Post-intervention effect of a computer tailored smoking cessation programme. J Epidemiol Community Health. 2004;58(10):849-51. [pmid: 15365111]. [pmcid: 1763345].
Garvey AJ, Kinnunen T, Nordstrom BL, et al. Effects of nicotine gum dose by level of nicotine dependence. Nicotine Tob Res. 2000;2(1):53-63. [pmid: 11072441].
Goldstein MG, Niaura R, Willey C, et al. An academic detailing intervention to disseminate physician-delivered smoking cessation counseling: smoking cessation outcomes of the Physicians Counseling Smokers Project. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2003;36(2):185-96.
Hahn EJ, Rayens MK, Chirila C, Riker CA, Paul TP, Warnick TA. Effectiveness of a quit and win contest with a low-income population. Prev Med. 2004;39(3):543-50. [pmid: 15313094].
Hall SM, Humfleet GL, Reus VI, Munoz RF, Cullen J. Extended nortriptyline and psychological treatment for cigarette smoking. Am J Psychiatry. 2004;161(11):2100-7. [pmid: 15514412].
Hand S, Edwards S, Campbell IA, Cannings R. Controlled trial of three weeks nicotine replacement treatment in hospital patients also given advice and support. Thorax. 2002;57(8):715-8. [pmid: 12149533]. [pmcid: 1746389].
Helgason AR, Tomson T, Lund KE, Galanti R, Ahnve S, Gilljam H. Factors related to abstinence in a telephone helpline for smoking cessation. Eur J Public Health. 2004;14(3):306-10. [pmid: 15369039].
Hennrikus DJ, Lando HA, McCarty MC, et al. The TEAM project: the effectiveness of smoking cessation intervention with hospital patients. Prev Med. 2005;40(3):249-58. [pmid: 15533536].
Hitsman B, Pingitore R, Spring B, et al. Antidepressant pharmacotherapy helps some cigarette smokers more than others. J Consult Clin Psychol. 1999;67(4):547-54. [pmid: 10450625].
Holt S, Timu-Parata C, Ryder-Lewis S, Weatherall M, Beasley R. Efficacy of bupropion in the indigenous Maori population in New Zealand. Thorax. 2005;60(2):120-3. [pmid: 15681499]. [pmcid: 1747282].
Jones C, Griffiths RD, Skirrow P, Humphris G. Smoking cessation through comprehensive critical care. Intensive Care Med. 2001;27(9):1547-9. [pmid: 11685350].
Jorenby DE, Leischow SJ, Nides MA, et al. A controlled trial of sustained-release bupropion, a nicotine patch, or both for smoking cessation. N Engl J Med. 1999;340(9):685-91. [pmid: 10053177].
Josendal O, Aaro LE, Torsheim T, Rasbash J. Evaluation of the school-based smoking-prevention program “BE smokeFREE”. Scand J Psychol. 2005;46(2):189-99. [pmid: 15762946].
Joseph AM. Nicotine treatment at the Drug Dependency Program of the Minneapolis VA Medical Center. A researcher's perspective. J Subst Abuse Treat. 1993;10(2):147-52.
Joseph AM, Arikian NJ, An LC, Nugent SM, Sloan RJ, Pieper CF. Results of a randomized controlled trial of intervention to implement smoking guidelines in Veterans Affairs medical centers: increased use of medications without cessation benefit. Med Care. 2004;42(11):1100-10. [pmid: 15586837].
Joseph AM, Willenbring ML, Nugent SM, Nelson DB. A randomized trial of concurrent versus delayed smoking intervention for patients in alcohol dependence treatment. J Stud Alcohol. 2004;65(6):681-91. [pmid: 15700504].
Katz DA, Brown RB, Muehlenbruch DR, Fiore MC, Baker TB. Implementing guidelines for smoking cessation: comparing the efforts of nurses and medical assistants. Am J Prev Med. 2004;27(5):411-6. [pmid: 15556742].
Katz DA, Muehlenbruch DR, Brown RL, Fiore MC, Baker TB. Effectiveness of implementing the agency for healthcare research and quality smoking cessation clinical practice guideline: a randomized, controlled trial. J Natl Cancer Inst. 2004;96(8):594-603. [pmid: 15100337].
Killen JD, Fortmann SP, Schatzberg AF, et al. Nicotine patch and paroxetine for smoking cessation. J Consult Clin Psychol. 2000;68(5):883-9. [pmid: 11068974].
Lancaster T, Dobbie W, Vos K, Yudkin P, Murphy M, Fowler G. Randomized trial of nurse-assisted strategies for smoking cessation in primary care. Br J Gen Pract. 1999;49(440):191-4. [pmid: 10343421]. [pmcid: 1313370].
Lancaster T, Silagy C, Fowler G. Training health professionals in smoking cessation. Cochrane Database Syst Rev 2000 (3) CD000214
Lancaster T, Stead L. Self-help interventions for smoking cessation. Cochrane Database Syst Rev 2005; (3): CD001118
Lancaster T, Stead LF. Individual behavioural counselling for smoking cessation. Cochrane Database Syst Rev 2005; (2):CD001292
Lancaster, T. and Stead, L. Physician advice for smoking cessation. Cochrane Database Syst Rev. 2004; (4):CD000165
Lawrence T, Aveyard P, Cheng KK, Griffin C, Johnson C, Croghan E. Does stage-based smoking cessation advice in pregnancy result in long-term quitters? 18-month postpartum follow-up of a randomized controlled trial. Addiction. 2005;100(1):107-16. [pmid: 15598198].
Lerman C, Kaufmann V, Rukstalis M, et al. Individualizing nicotine replacement therapy for the treatment of tobacco dependence: a randomized trial. Ann Intern Med. 2004;140(6):426-33. [pmid: 15023708].
Lipkus IM, McBride CM, Pollak KI, Schwartz-Bloom RD, Tilson E, Bloom PN. A randomized trial comparing the effects of self-help materials and proactive telephone counseling on teen smoking cessation. Health Psychol. 2004;23(4):397-406. [pmid: 15264976].
Lumley J, Oliver SS, Chamberlain C, Oakley L. Interventions for promoting smoking cessation during pregnancy. Cochrane Database Syst Rev 2004; (4):CD001055
Macleod ZR, Charles MA, Arnaldi VC, Adams IM. Telephone counselling as an adjunct to nicotine patches in smoking cessation: a randomised controlled trial. Med J Aust. 2003;179(7):349-52. [pmid: 14503897].
Maguire TA, McElnay JC, Drummond A. A randomized controlled trial of a smoking cessation intervention based in community pharmacies. Addiction. 2001;96(2):325-31. [pmid: 11182878].
McBride CM, Baucom DH, Peterson BL, et al. Prenatal and postpartum smoking abstinence a partner-assisted approach. Am J Prev Med. 2004;27(3):232-8. [pmid: 15450636].
McBride CM, Bepler G, Lipkus IM, et al. Incorporating genetic susceptibility feedback into a smoking cessation program for African-American smokers with low income. Cancer Epidemiol Biomarkers Prev. 2002;11(6):521-8. [pmid: 12050092].
Melvin CL, Gaffney C. Treating nicotine use and dependence of pregnant and parenting smokers: An update. Nicotine & Tobacco Research. 2004;6(S2):S107-S124. [pmid: 15203815].
Mermelstein R, Hedeker D, Wong SC. Extended telephone counseling for smoking cessation: does content matter?. J Consult Clin Psychol. 2003;71(3):565-74. [pmid: 12795579].
Moher M, Hey K, Lancaster T. Workplace interventions for smoking cessation. Cochrane Database Syst Rev 2005; (2):CD003440
Murray RP, Connett JE, Buist AS, Gerald LB, Eichenhorn MS. Experience of Black participants in the Lung Health Study smoking cessation intervention program. Nicotine Tob Res. 2001;3(4):375-82. [pmid: 11694205].
Murray RP, Connett JE, Rand CS, Pan W, Anthonisen NR. Persistence of the effect of the Lung Health Study (LHS) smoking intervention over eleven years. Prev Med. 2002;35(4):314-9. [pmid: 12453707].
Murray RP, Istvan JA, Voelker HT, Rigdon MA, Wallace MD. Level of involvement with alcohol and success at smoking cessation in the lung health study. J Stud Alcohol. 1995;56(1):74-82. [pmid: 7752637].
Pbert L, Ockene JK, Zapka J, et al. A Community Health Center Smoking-Cessation Intervention for Pregnant and Postpartum Women. Am J Prev Med. 2004;26(5):377-85. [pmid: 15165653].
Perry CL, Komro KA, Veblen-Mortenson S, et al. A randomized controlled trial of the middle and junior high school D.A.R.E. and D.A.R.E. Plus programs. Arch Pediatr Adolesc Med. 2003;157(2):178-84. [pmid: 12580689].
Peterson W. A nurse managed smoking cessation and relapse prevention programme did not reduce smoking rates at 12 months beyond rates achieved by usual care in women with cardiovascular disease. Evidence Based Nursing. 2004;7(3):83. [pmid: 15252911].
Pieterse ME, Seydel ER, DeVries H, Mudde AN, Kok GJ. Effectiveness of a minimal contact smoking cessation program for Dutch general practitioners: a randomized controlled trial. Prev Med. 2001;32(2):182-90. [pmid: 11162345].
Piper ME, Fiore MC, Smith SS, et al. Use of the vital sign stamp as a systematic screening tool to promote smoking cessation. Mayo Clin Proc. 2003;78(6):716-22. [pmid: 12934781].
Prochaska JJ, Delucchi K, Hall SM. A Meta-Analysis of Smoking Cessation Interventions With Individuals in Substance Abuse Treatment or Recovery. J Consult Clin Psychol. 2004;72(6):1144-56. [pmid: 15612860].
Quist-Paulsen P, Gallefoss F. Randomised controlled trial of smoking cessation intervention after admission for coronary heart disease. BMJ. 2003;327(7426):1254-7. [pmid: 14644967]. [pmcid: 286243].
Rabius V, McAlister AL, Geiger A, Huang P, Todd R. Telephone counseling increases cessation rates among young adult smokers. Health Psychol. 2004;23(5):539-41. [pmid: 15367074].
Ratner PA, Johnson JL, Richardson CG, et al. Efficacy of a smoking-cessation intervention for elective-surgical patients. Res Nurs Health. 2004;27(3):148-61. [pmid: 15141368].
Reid R, Pipe A, Higginson L, et al. Stepped care approach to smoking cessation in patients hospitalized for coronary artery disease. J Cardiopulm Rehabil. 2003;23(3):176-82. [pmid: 12782900].
Rigotti NA, Munafo MR, Murphy MFG, Stead LF. Interventions for smoking cessation in hospitalised patients. The Cochrane Database Syst Rev 2002; (4.Art. No.: CD001837. DOI: 10.1002/14651858.CD001837)
Ronda G, Van Assema P, Candel M, et al. The Dutch Heart Health Community Intervention 'Hartslag Limburg': effects on smoking behaviour. Eur J Public Health. 2004;14(2):191-3. [pmid: 15230508].
Rowe K, Clark JM. Evaluating the effectiveness of a smoking cessation intervention designed for nurses. Int J Nurs Stud. 1999;36(4):301-11. [pmid: 10404298].
Russos S, Keating K, Hovell MF, et al. Counseling youth in tobacco-use prevention: determinants of clinician compliance. Prev Med. 1999;29(1):13-21. [pmid: 10419794].
Saules KK, Schuh LM, Arfken CL, Reed K, Kilbey MM, Schuster CR. Double-blind placebo-controlled trial of fluoxetine in smoking cessation treatment including nicotine patch and cognitive-behavioral group therapy. Am J Addict. 2004;13(5):438-46. [pmid: 15764422].
Schofield MJ, Lynagh M, Mishra G. Evaluation of a Health Promoting Schools program to reduce smoking in Australian secondary schools. Health Educ Res. 2003;18(6):678-92. [pmid: 14654501].
Secker-Walker RH, Gnich W, Platt S, Lancaster T. Community interventions for reducing smoking among adults. The Cochrane Database of Systematic Reviews 2002; (2)
Share M, Quinn M, Ryan C. Evaluation of a 5-year school-based county-wide smoking education programme. Ir Med J 2004; 97(9):264, 266–7
Simon JA, Duncan C, Carmody TP, Hudes ES. Bupropion for smoking cessation: a randomized trial. Arch Intern Med. 2004;164(16):1797-803. [pmid: 15364675].
Simons-Morton B, Chen R, Abroms L, Haynie DL. Latent growth curve analyses of peer and parent influences on smoking progression among early adolescents. Health Psychol. 2004;23(6):612-21. [pmid: 15546229].
Sinclair HK, Bond CM, Stead LF. Community pharmacy personnel interventions for smoking cessation. The Cochrane Library. 2005;1:1.
Slama K, Karsenty S, Hirsch A. French general practitioners' attitudes and reported practices in relation to their participation and effectiveness in a minimal smoking cessation programme for patients. Addiction. 1999;94(1):125-32. [pmid: 10665104].
Smith PM, Cameron R, McDonald PW, Kawash B, Madill C, Brown KS. Telephone counseling for population-based smoking cessation. Am J Health Behav. 2004;28(3):231-41. [pmid: 15152882].
Smith PM, Reilly KR, Houston Miller N, DeBusk RF, Taylor CB. Application of a nurse-managed inpatient smoking cessation program. Nicotine Tob Res. 2002;4(2):211-22. [pmid: 12096707].
Soulier-Parmeggiani L, Griscom S, Bongard O, Avvanzino R, Bounameaux H. One-year results of a smoking-cessation programme. Schweiz Med Wochenschr. 1999;129(10):395-8. [pmid: 10212973].
Sowden A, Arblaster L, Stead L. Community interventions for preventing smoking in young people. The Cochrane Database of Systematic Reviews 2003; (1)
Sowden AJ, Arblaster L. Mass media interventions for preventing smoking in young people. The Cochrane Library 2005; 1:1
Stead LF, Lancaster T. Group behaviour therapy programmes for smoking cessation. Cochrane Database Syst Rev 2005; (2):CD001007
Stead LF, Lancaster T, Perera R. Telephone counselling for smoking cessation. Cochrane Database Syst Rev 2003; (1):CD002850
Stevens VJ, Glasgow RE, Hollis JF, Mount K. Implementation and effectiveness of a brief smoking-cessation intervention for hospital patients. Med C. 2000;38(5):451-9.
Swan GE, Jack LM, Curry S, et al. Bupropion SR and counseling for smoking cessation in actual practice: predictors of outcome. Nicotine Tob Res. 2003;5(6):911-21. [pmid: 14668075].
Swan GE, McAfee T, Curry SJ, et al. Effectiveness of bupropion sustained release for smoking cessation in a health care setting: a randomized trial. Arch Intern Med. 2003;163(19):2337-44. [pmid: 14581254].
Thomas R. School-based programmes for preventing smoking. Cochrane Database Syst Rev 2002; (4):CD001293
Thomson CC, Gokhale M, Biener L, Siegel MB, Rigotti NA. Statewide evaluation of youth access ordinances in practice: effects of the implementation of community-level regulations in Massachusetts. J Public Health Manag Pract. 2004;10(6):481-9. [pmid: 15643369].
Tomar SL. Is use of smokeless tobacco a risk factor for cigarette smoking? The U.S. experience. Nicotine Tob Res. 2003;5(4):561-9. [pmid: 12959794].
Tyc VL, Rai SN, Lensing S, Klosky JL, Stewart DB, Gattuso J. Intervention to reduce intentions to use tobacco among pediatric cancer survivors. J Clin Oncol. 2003;21(7):1366-72. [pmid: 12663728].
Unger JB, Chou CP, Palmer PH, et al. Project FLAVOR: 1-Year Outcomes of a Multicultural, School-Based Smoking Prevention Curriculum for Adolescents. Am J Public Health. 2004;94(2):263-5. [pmid: 14759940]. [pmcid: 1448241].
Winkleby MA, Feighery E, Dunn M, Kole S, Ahn D, Killen JD. Effects of an advocacy intervention to reduce smoking among teenagers. Arch Pediatr Adolesc Med. 2004;158(3):269-75. [pmid: 14993087].
Young JM, D'Este C, Ward JE. Improving family physicians' use of evidence-based smoking cessation strategies: a cluster randomization trial. Prev Med. 2002;35(6):572-83. [pmid: 12460525].