# Appendix B Sample Review Forms/Quality Rating Forms

To view the Sample Review Forms/Quality Rating Forms, please select the link below. This link will take you to a PDF version of the forms.

Sample Review Forms/Quality Rating Forms