# Appendix A. Search Strategy

#1 | Search “Tobacco Use Cessation”[MeSH] OR “Smoking Cessation”[MeSH] OR “Smoking/prevention and control”[MeSH] | 17017
#2 | Search “Smoking”[MeSH] AND “Primary Prevention”[MeSH] | 479
#3 | Search #1 OR #2 | 17275
#4 | Search #1 OR #2 Limits: Adolescent: 13–18 years, Adult: 19–44 years, Middle Aged: 45–64 years, English, Humans | 7383
#5 | Search (“Community Networks”[MeSH] OR “Community Health Services”[MeSH] OR “Community Health Planning”[MeSH] OR “Community Health Aides”[MeSH] OR “Community Health Nursing”[MeSH] OR “Community Health Centers”[MeSH] OR “Community Mental Health Services”[MeSH] OR “Community Medicine”[MeSH] OR “Community Mental Health Centers”[MeSH]) | 345024
#9 | Search (“Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials”[MeSH]) OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] | 310410
#10 | Search #4 AND #5 AND #9 | 402
#11 | Search (“Consumer Satisfaction”[MeSH] OR “Consumer Participation”[MeSH]) OR “Health Services Needs and Demand”[MeSH] | 84543
#12 | Search #4 AND #11 | 129
#13 | Search “Health Plan Implementation”[MeSH] OR “Diffusion of Innovation”[MeSH] OR “Patient Education”[MeSH] | 52494
#14 | Search #4 AND #13 | 334
#15 | Search “Tobacco, Smokeless”[MeSH]OR “spit tobacco” OR “chewing tobacco” OR “dip tobacco” OR “oral tobacco” | 1893
#16 | Search #4 AND #15 | 160
#17 | Search (“Marketing”[MeSH] OR “Social Marketing”[MeSH]) OR “Choice Behavior”[MeSH] OR “Advertising”[MeSH] | 39557
#18 | Search #4 AND #17 | 402
#19 | Search “Comorbidity”[MeSH] OR (“Risk-Taking”[MeSH] OR “Risk Factors”[MeSH]) OR (“Depressive Disorder”[MeSH] OR “Depression”[MeSH]) OR “Bipolar Disorder”[MeSH] OR “Attention Deficit Disorder with Hyperactivity”[MeSH] OR “Stress Disorders, Post-Traumatic”[MeSH] OR “Diabetes Mellitus”[MeSH] OR “Hypertension”[MeSH] OR “Heart Diseases”[MeSH] OR “Asthma”[MeSH] OR “Obesity”[MeSH] | 1406831
#20 | Search #4 AND #19 | 1742
#21 | Search #20 AND #9 | 250

Cochrane and the CCTR

(smoking or tobacco) AND (tobacco or quit) AND community

Reviews = 3

Trials = 89

Psychological Abstracts

(smoking or tobacco) AND (cessation or quit) AND community = 79

Sociological Abstracts

(( smoking or tobacco )and( cessation or quit )) and (( community )and( intervention or Program or plan )) = 48

Cumulative Index for Nursing and Allied Health

(smoking AND (cessation OR quit) ) AND community AND trial = 36

1237 unduplicated records