# Appendixes

Appendix A. Search Strategy

Appendix B Sample Review Forms/Quality Rating Forms

Appendix C Evidence Tables

Appendix D List of Excluded Studies

Appendix E. Acknowledgments