# References and Included Studies

1 Radimer K, Bindewald B, Hughes J, et al. Dietary supplement use by US adults: data from the National Health and Nutrition Examination Survey, 1999-2000. Am J Epidemiol 2004;160(4):339–49.
2 2005. Nutrition Business Journal Supplement Business Report 2005. Available at: http://store.yahoo.com/nbj/nbsupbusrep2.html. Accessed 2005.
3 Strong K, Mathers C, Leeder S, et al. Preventing chronic diseases: how many lives can we save?. Lancet. 2005;366(9496):1578-82. [pmid: 16257345].
4 Yach D, Hawkes C, Gould CL, et al. The global burden of chronic diseases: overcoming impediments to prevention and control. JAMA. 2004;291(21):2616-22. [pmid: 15173153].
5 Must A, Spadano J, Coakley EH, et al. The disease burden associated with overweight and obesity. JAMA. 1999;282(16):1523-9. [pmid: 10546691].
6 Korner J, Eberle MA. An update on the science and therapy of obesity and its relationship to osteoarthritis. Curr Rheumatol Rep. 2001;3(2):101-6. [pmid: 11286664].
7 Flegal KM, Carroll MD, Ogden CL, et al. Prevalence and trends in obesity among US adults, 1999-2000. JAMA 2002;288(14):1723–7.
8 Thylefors B, Negrel AD, Pararajasegaram R, et al. Global data on blindness. Bull World Health Organ. 1995;73(1):115-21. [pmid: 7704921].
9 Williams RA, Brody BL, Thomas RG, et al. The psychosocial impact of macular degeneration. Arch Ophthalmol. 1998;116(4):514-20. [pmid: 9565052].
10 Jorm AF, Jolley D. The incidence of dementia: a meta-analysis. Neurology. 1998;51(3):728-33. [pmid: 9748017].
11 Lobo A, Launer LJ, Fratiglioni L, et al. Prevalence of dementia and major subtypes in Europe: a collaborative study of population-based cohorts. Neurologic Diseases in the Elderly Research Group. Neurology. 2000;54(11 Suppl 5):S4-9. [pmid: 10854354].
12 Steinberg D, Parthasarathy S, Carew TE, et al. Beyond cholesterol. Modifications of low-density lipoprotein that increase its atherogenicity. N Engl J Med. 1989;320(14):915-24. [pmid: 2648148].
13 Breimer LH. Molecular mechanisms of oxygen radical carcinogenesis and mutagenesis: the role of DNA base damage. Mol Carcinog. 1990;3(4):188-97. [pmid: 2206282].
14 Ames BN, Shigenaga MK. Oxidants are a major contributor to aging. Ann NY Acad Sci 1992;(66):385–96.
15 Spector A. Oxidative stress-induced cataract: mechanism of action. FASEB J. 1995;9(12):1173-82. [pmid: 7672510].
16 Snodderly DM. Evidence for protection against age-related macular degeneration by carotenoids and antioxidant vitamins. Am J Clin Nutr. 1995;62(6 Suppl):1448S-61S. [pmid: 7495246].
17 Hensley K, Hall N, Subramaniam R, et al. Brain regional correspondence between Alzheimer's disease histopathology and biomarkers of protein oxidation. J Neurochem. 1995;65(5):2146-56. [pmid: 7595501].
18 Mecocci P, MacGarvey U, Beal MF. Oxidative damage to mitochondrial DNA is increased in Alzheimer's disease. Ann Neurol. 1994;36(5):747-51. [pmid: 7979220].
19 Marcus DL, Thomas C, Rodriguez C, et al. Increased peroxidation and reduced antioxidant enzyme activity in Alzheimer's disease. Exp Neurol. 1998;150(1):40-4. [pmid: 9514828].
20 Esterbauer H, Schaur RJ, Zollner H. Chemistry and biochemistry of 4-hydroxynonenal, malonaldehyde and related aldehydes. Free Radic Biol Med. 1991;11(1):81-128. [pmid: 1937131].
21 Loft S, Poulsen HE. Cancer risk and oxidative DNA damage in man. J Mol Med. 1996;74(6):297-312. [pmid: 8862511].
22 Holbrook NJ, Ikeyama S. Age-related decline in cellular response to oxidative stress: links to growth factor signaling pathways with common defects. Biochem Pharmacol. 2002;64(56):999-1005. [pmid: 12213598].
23 Willerson JT, Ridker PM. Inflammation as a cardiovascular risk factor. Circulation. 2004;109(21 Suppl 1):II2-10. [pmid: 14707015].
24 Marx J. Cancer research. Inflammation and cancer: the link grows stronger. Science. 2004;306(5698):966-8. [pmid: 15528423].
25 Granger DN, Vowinkel T, Petnehazy T. Modulation of the inflammatory response in cardiovascular disease. Hypertension. 2004;43(5):924-31. [pmid: 15007038].
26 Das PM, Singal R. DNA methylation and cancer. J Clin Oncol. 2004;22(22):4632-42. [pmid: 15542813].
27 Davis CD, Uthus EO. DNA methylation, cancer susceptibility, and nutrient interactions. Exp Biol Med (Maywood). 2004;229(10):988-95. [pmid: 15522834].
28 Kuo HK, Sorond FA, Chen JH, et al. The role of homocysteine in multisystem age-related problems: a systematic review. J Gerontol A Biol Sci Med Sci. 2005;60(9):1190-201. [pmid: 16183962].
29 Halliwell B, Gutteridge JM. Oxygen toxicity, oxygen radicals, transition metals and disease. Biochem J. 1984;219(1):1-14. [pmid: 6326753]. [pmcid: 1153442].
30 Duthie SJ, Narayanan S, Brand GM, et al. Impact of folate deficiency on DNA stability. J Nutr. 2002;132(8 Suppl):2444S-9S. [pmid: 12163709].
31 Selhub J, Bagley LC, Miller J, et al. B vitamins, homocysteine, and neurocognitive function in the elderly. Am J Clin Nutr. 2000;71(2):614S-20S. [pmid: 10681269].
32 Lowering blood homocysteine with folic acidbased supplements: meta-analysis of randomised trials. Indian Heart J 2000;52(7 Suppl):S59–64.
33 Singh U, Jialal I. Anti-inflammatory effects of alpha-tocopherol. Ann NY Acad Sci 2004;1031195–203.
34 Tosetti F, Ferrari N, De Flora S, et al. Angioprevention': angiogenesis is a common and key target for cancer chemopreventive agents. FASEB J. 2002;16(1):2-14. [pmid: 11772931].
35 Ashino H, Shimamura M, Nakajima H, et al. Novel function of ascorbic acid as an angiostatic factor. Angiogenesis. 2003;6(4):259-69. [pmid: 15166494].
36 Kelloff GJ, Boone CW, Steele VE, et al. Mechanistic considerations in chemopreventive drug development. J Cell Biochem Suppl 1994;201–24.
37 Reifen R. Vitamin A as an anti-inflammatory agent. Proc Nutr Soc. 2002;61(3):397-400. [pmid: 12230799].
38 Bogden JD. Influence of zinc on immunity in the elderly. J Nutr Health Aging. 2004;8(1):48-54. [pmid: 14730367].
39 Villamor E, Fawzi WW. Effects of Vitamin A supplementation on immune responses and correlation with clinical outcomes. Clin Microbiol Rev. 2005;18(3):446-64. [pmid: 16020684]. [pmcid: 1195969].
40 Huang H-Y, Berndt S, Helzlsouer KJ. Vitamin E as a Cancer Chemopreventive Agent. In: Kelloff GJ, Hawk ET, and Sigman CC, editors. Cancer Chemoprevention. Vol 1: Promising Cancer Chemopreventive Agents. New Jersey: Humana Press ; 2004. p. 451–484.
41 McAlindon T, Felson DT. Nutrition: risk factors for osteoarthritis. Ann Rheum Dis. 1997;56(7):397-400. [pmid: 9485998]. [pmcid: 1752412].
42 McAlindon T, Felson DT. Nutrition: risk factors for osteoarthritis. Ann Rheum Dis. 1997;56(7):397-400. [pmid: 9485998]. [pmcid: 1752412].
43 Griffith LE, Guyatt GH, Cook RJ, et al. The influence of dietary and nondietary calcium supplementation on blood pressure: an updated metaanalysis of randomized controlled trials. Am J Hypertens. 1999;12(1 Pt 1):84-92. [pmid: 10075392].
44 Jee SH, Miller ER 3rd,, Guallar E, et al. The effect of magnesium supplementation on blood pressure: a meta-analysis of randomized clinical trials. Am J Hypertens. 2002;15(8):691-6. [pmid: 12160191].
45 Baron JA. Calcium. In: Kelloff GJ, Hawk ET, and Sigman CC, editors. Cancer Chemoprevention. Vol 1: Promising Cancer Chemopreventive Agents. New Jersey: Humana Press; p. 547–558.
46 Guyton KZ, Thomas W., Posner GH. Chemopreventive Efficacy of Natural Vitamin D and Synthetic Analogs. In: Kelloff GJ, Hawk ET, and Sigman CC, editors. Cancer Chemoprevention. Vol 1: Promising Cancer Chemopreventive Agents. New Jersey: Humana Press; 2004. p. 259–274.
47 Shea B, Wells G, Cranney A, et al. Calcium supplementation on bone loss in postmenopausal women. Cochrane Database Syst Rev 2004;(1):CD004526.
48 Weingarten MA, Zalmanovici A, and Yaphe J. Dietary calcium supplementation for preventing colorectal cancer and adenomatous polyps. Cochrane Database Syst Rev 2004;(1):CD003548.
49 Papadimitropoulos E, Wells G, Shea B, et al. Meta-analyses of therapies for postmenopausal osteoporosis. VIII: Meta-analysis of the efficacy of vitamin D treatment in preventing osteoporosis in postmenopausal women. Endocr Rev. 2002;23(4):560-9. [pmid: 12202471].
50 Shea B, Wells G, Cranney A, et al. Meta-analyses of therapies for postmenopausal osteoporosis. VII. Meta-analysis of calcium supplementation for the prevention of postmenopausal osteoporosis. Endocr Rev. 2002;23(4):552-9. [pmid: 12202470].
51 Gillespie WJ, Avenell A, Henry DA, et al. Vitamin D and vitamin D analogues for preventing fractures associated with involutional and post-menopausal osteoporosis. Cochrane Database Syst Rev 2001;(1):CD000227.
52 Mackerras D, Lumley T. First- and second-year effects in trials of calcium supplementation on the loss of bone density in postmenopausal women. Bone. 1997;21(6):527-33. [pmid: 9430243].
53 US Surgeon General. 2005. 2004 US Surgeon General's Report on Bone Health and Osteoporosis. Available at: http://www.surgeongeneral.gov/library/bonehealth. Accessed 2005.
54 Moore CE, Murphy MM, Holick MF. Vitamin D intakes by children and adults in the United States differ among ethnic groups. J Nutr. 2005;135(10):2478-85. [pmid: 16177216].
55 Hajjar IM, Grim CE, Kotchen TA. Dietary calcium lowers the age-related rise in blood pressure in the United States: the NHANES III survey. J Clin Hypertens (Greenwich). 2003;5(2):122-6. [pmid: 12671324].
56 Clark LC. The epidemiology of selenium and cancer. Fed Proc. 1985;44(9):2584-9. [pmid: 3996614].
57 Huang HY, Appel LJ. Supplementation of diets with alpha-tocopherol reduces serum concentrations of gamma- and delta-tocopherol in humans. J Nutr. 2003;133(10):3137-40. [pmid: 14519797].
58 Koehler KM, Pareo-Tubbeh SL, Romero LJ, et al. Folate nutrition and older adults: challenges and opportunities. J Am Diet Assoc. 1997;97(2):167-73. [pmid: 9020245].
59 Christian P, West KP Jr. Interactions between zinc and vitamin A: an update. Am J Clin Nutr. 1998;68(2 Suppl):435S-41S. [pmid: 9701158].
60 Institute of Medicine. 2005. Dietary reference intakes tables: vitamins table. Available at: Washington DC: Institute of Medicine. Accessed 2005.
61 Anonymous. 2005. Title 21--Food and Drug Administration, Department of Health and Human Services. Part 184--Direct food substances affirmed as generally recognized as safe. Available at: http://www.access.gpo.gov/nara/cfr/waisidx_98/21cfr184_98.html. Accessed 2005.
62 Anonymous. 2005. Title 21¯Food and Drug Administration, Department of Health and Human Services. Part 182¯Substances generally recognized as safe. Available at: http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfcfr/CFRSearch.cfm?CFRPart=182. Accessed 2005.
63 Atkins D, Best D, Briss PA, et al. Grading quality of evidence and strength of recommendations. BMJ. 2004;328(7454):1490. [pmid: 15205295]. [pmcid: 428525].
64 Blot WJ, Li JY, Taylor PR, et al. Nutrition intervention trials in Linxian, China: supplementation with specific vitamin/mineral combinations, cancer incidence, and disease-specific mortality in the general population. J Natl Cancer Inst. 1993;85(18):1483-92. [pmid: 8360931].
65 Sperduto RD, Hu TS, Milton RC, et al. The Linxian cataract studies. Two nutrition intervention trials. Arch Ophthalmol. 1993;111(9):1246-53. [pmid: 8363468].
66 Mark SD, Wang W, Fraumeni JF Jr, et al. Do nutritional supplements lower the risk of stroke or hypertension?. Epidemiology. 1998;9(1):9-15. [pmid: 9430262].
67 Blot WJ, Li JY, Taylor PR, et al. The Linxian trials: mortality rates by vitamin-mineral intervention group. Am J Clin Nutr. 1995;62(6 Suppl):1424S-6S. [pmid: 7495242].
68 Wang GQ, Dawsey SM, Li JY, et al. Effects of vitamin/mineral supplementation on the prevalence of histological dysplasia and early cancer of the esophagus and stomach: results from the General Population Trial in Linxian, China. Cancer Epidemiol Biomarkers Prev. 1994;3(2):161-6. [pmid: 8049638].
69 Hercberg S, Galan P, Preziosi P, et al. The SU.VI.MAX Study: a randomized, placebo-controlled trial of the health effects of antioxidant vitamins and minerals. Arch Intern Med. 2004;164(21):2335-42. [pmid: 15557412].
70 Meyer F, Galan P, Douville P, et al. Antioxidant vitamin and mineral supplementation and prostate cancer prevention in the SU.VI.MAX trial. Int J Cancer. 2005;116(2):182-6. [pmid: 15800922].
71 AMD Group. Multicenter ophthalmic and nutritional age-related macular degeneration study--part 1: design, subjects and procedures. Age-related Macular Degeneration Study Group. J Am Optom Assoc. 1996;67(1):12-29. [pmid: 8825016].
72 Chylack LT Jr, Brown NP, Bron A, et al. The Roche European American Cataract Trial (REACT): a randomized clinical trial to investigate the efficacy of an oral antioxidant micronutrient mixture to slow progression of age-related cataract. Ophthalmic Epidemiol. 2002;9(1):49-80. [pmid: 11815895].
73 Age-Related Eye Disease Study Research Group. A randomized, placebo-controlled, clinical trial of high-dose supplementation with vitamins C and E and beta carotene for age-related cataract and vision loss: AREDS report no. 9. Arch Ophthalmol. 2001;119(10):1439-52. [pmid: 11594943]. [pmcid: 1472812].
74 Richer S. Multicenter ophthalmic and nutritional age-related macular degeneration study--part 2: antioxidant intervention and conclusions. J Am Optom Assoc. 1996;67(1):30-49. [pmid: 8825017].
75 Age-Related Eye Disease Study Research Group. A randomized, placebo-controlled, clinical trial of high-dose supplementation with vitamins C and E, beta carotene, and zinc for age-related macular degeneration and vision loss: AREDS report no. 8. Arch Ophthalmol. 2001;119(10):1417-36. [pmid: 11594942]. [pmcid: 1462955].
76 Shi FL, Hart RG, Sherman DG, et al. Stroke in the People's Republic of China. Stroke. 1989;20(11):1581-5. [pmid: 2683247].
77 Sibulesky L, Hayes KC, Pronczuk A, et al. Safety of <7500 RE (<25000 IU) vitamin A daily in adults with retinitis pigmentosa. Am J Clin Nutr. 1999;69(4):656-63. [pmid: 10197566].
78 Xuan XZ, Schatzkin A, Mao BL, et al. Feasibility of conducting a lung-cancer chemoprevention trial among tin miners in Yunnan, P. R. China. Cancer Causes Control. 1991;2(3):175-82. [pmid: 1873448].
79 Ohtake T, Kobayashi S, Negishi K, et al. Supplement nephropathy due to long-term, high-dose ingestion of ascorbic acid, calcium lactate, vitamin D and laxatives. Clin Nephrol. 2005;64(3):236-40. [pmid: 16175950].
80 Grouhi M, Sussman G. Pseudoallergic toxic reaction. Ann Allergy Asthma Immunol. 2000;85(4):269-71. [pmid: 11061468].
81 Gulati R, Bhargava P, Mathur NK. Fixed drug eruption due to multi-vitamin multi-mineral preparation as part of familial polysensitivity. J Assoc Physicians India. 1999;47(2):253. [pmid: 10999109].
82 Heinonen OP, Huttunen JK, Albanes D, et al. The Alpha-Tocopherol, Beta-Carotene Lung Cancer Prevention Study: Design, methods, participant characteristics, and compliance. Ann Epidemiol. 1994;4(1):1-10. [pmid: 8205268].
83 Omenn GS. A double-blind randomized trial with beta-carotene and retinol in persons at high risk of lung cancer due to occupational asbestos exposures and/or cigarette smoking. Public Health Rev. 1988;16(12):99-125. [pmid: 3073436].
84 Green A, Williams G, Neale R, et al. Daily sunscreen application and betacarotene supplementation in prevention of basal-cell and squamous-cell carcinomas of the skin: a randomised controlled trial. Lancet. 1999;354(9180):723-9. [pmid: 10475183].
85 Greenberg ER, Baron JA, Karagas MR, et al. Mortality associated with low plasma concentration of beta carotene and the effect of oral supplementation. JAMA. 1996;275(9):699-703. [pmid: 8594267].
86 Frieling UM, Schaumberg DA, Kupper TS, et al. A randomized, 12-year primary-prevention trial of beta carotene supplementation for nonmelanoma skin cancer in the physician's health study. Arch Dermatol. 2000;136(2):179-84. [pmid: 10677093].
87 Lee IM, Cook NR, Gaziano JM, et al. Vitamin E in the primary prevention of cardiovascular disease and cancer: the Women's Health Study: a randomized controlled trial. JAMA. 2005;294(1):56-65. [pmid: 15998891].
88 The ATBC Cancer Prevention Study Group. The alpha-tocopherol, beta-carotene lung cancer prevention study: design, methods participant characteristics, and compliance. Ann Epidemiol. 1994;4(1):1-10. [pmid: 8205268].
89 Virtamo J, Pietinen P, Huttunen JK, et al. Incidence of cancer and mortality following alpha-tocopherol and beta-carotene supplementation: a postintervention follow-up. JAMA. 2003;290(4):476-85. [pmid: 12876090].
90 Varis K, Taylor PR, Sipponen P, et al. Gastric cancer and premalignant lesions in atrophic gastritis: a controlled trial on the effect of supplementation with alpha-tocopherol and beta-carotene. The Helsinki Gastritis Study Group. Scand J Gastroenterol. 1998;33(3):294-300. [pmid: 9548624].
91 Omenn GS, Goodman GE, Thornquist MD, et al. The Carotene and Retinol Efficacy Trial (CARET) to prevent lung cancer in high-risk populations: pilot study with asbestos-exposed workers. Cancer Epidemiol Biomarkers Prev. 1993;2(4):381-7. [pmid: 8348062].
92 Goodman GE, Omenn GS, Thornquist MD, et al. The Carotene and Retinol Efficacy Trial (CARET) to prevent lung cancer in high-risk populations: pilot study with cigarette smokers. Cancer Epidemiol Biomarkers Prev. 1993;2(4):389-96. [pmid: 8348063].
93 Omenn GS, Goodman GE, Thornquist MD, et al. Effects of a combination of beta carotene and vitamin A on lung cancer and cardiovascular disease. New Engl J Med. 1996;334(18):1150-5. [pmid: 8602180].
94 Goodman GE, Thornquist MD, Balmes J, et al. The Beta-Carotene and Retinol Efficacy Trial: Incidence of lung cancer and cardiovascular disease mortality during 6-year follow-up after stopping (beta)-carotene and retinol supplements. J. Natl. Cancer Inst. 2004;96(23):1743-50.
95 Hennekens CH, Buring JE, Manson JE, et al. Lack of effect of long-term supplementation with beta carotene on the incidence of malignant neoplasms and cardiovascular disease. N Engl J Med. 1996;334(18):1145-9. [pmid: 8602179].
96 Lee IM, Cook NR, Manson JE, et al. Beta-carotene supplementation and incidence of cancer and cardiovascular disease: the Women's Health Study. J Natl Cancer Inst. 1999;91(24):2102-6. [pmid: 10601381].
97 The Alpha-Tocopherol BCCPSG. The effect of vitamin E and beta carotene on the incidence of lung cancer and other cancers in male smokers. N Engl J Med 1994;330(15):1029–35.
98 Albanes D, Heinonen OP, Taylor PR, et al. Alpha-Tocopherol and beta-carotene supplements and lung cancer incidence in the alpha-tocopherol, beta-carotene cancer prevention study: effects of base-line characteristics and study compliance. J Natl Cancer Inst. 1996;88(21):1560-70. [pmid: 8901854].
99 Rautalahti MT, Virtamo JR, Taylor PR, et al. The effects of supplementation with alpha-tocopherol and beta-carotene on the incidence and mortality of carcinoma of the pancreas in a randomized, controlled trial. Cancer. 1999;86(1):37-42. [pmid: 10391561].
100 Malila N, Virtamo J, Virtanen M, et al. The effect of (alpha)-tocopherol and (beta)-carotene supplementation on colorectal adenomas in middle-aged male smokers. Cancer Epidemiol. Biomarkers Prev. 1999;8(6):489-93.
101 Heinonen OP, Albanes D, Virtamo J, et al. Prostate cancer and supplementation with alpha-tocopherol and beta-carotene: incidence and mortality in a controlled trial. J Natl Cancer Inst. 1998;90 (6):440-6. [pmid: 9521168].
102 Albanes D, Malila N, Taylor PR, et al. Effects of supplemental alpha-tocopherol and beta-carotene on colorectal cancer: results from a controlled trial (Finland). Cancer Causes Control. 2000;11(3):197-205. [pmid: 10782653].
103 Virtamo J, Pietinen P, Huttunen JK, et al. Incidence of cancer and mortality following alpha-tocopherol and beta-carotene supplementation: a postintervention follow-up. JAMA. 2003;290(4):476-85. [pmid: 12876090].
104 Cook NR, Le IM, Manson JE, et al. Effects of beta-carotene supplementation on cancer incidence by baseline characteristics in the Physicians' Health Study (United States). Cancer Causes Control. 2000;11(7):617-26. [pmid: 10977106].
105 Omenn GS, Goodman GE, Thornquist MD, et al. Risk factors for lung cancer and for intervention effects in CARET, the Beta-Carotene and Retinol Efficacy Trial. J Natl Cancer Inst. 1996;88(21):1550-9. [pmid: 8901853].
106 Rapola JM, Virtamo J, Haukka JK, et al. Effect of vitamin E and beta carotene on the incidence of angina pectoris. A randomized, double-blind, controlled trial. JAMA. 1996;275(9):693-8. [pmid: 8594266].
107 Leppala JM, Virtamo J, Fogelholm R, et al. Controlled trial of alpha-tocopherol and beta-carotene supplements on stroke incidence and mortality in male smokers. Arterioscler Thromb Vasc Biol. 2000;20(1):230-5. [pmid: 10634823].
108 Liu S, Ajani U, Chae C, et al. Long-term beta-carotene supplementation and risk of type 2 diabetes mellitus: a randomized controlled trial. JAMA. 1999;282(11):1073-5. [pmid: 10493207].
109 Teikari JM, Virtamo J, Rautalahti M, et al. Long-term supplementation with alpha-tocopherol and beta-carotene and age-related cataract. Acta Ophthalmol Scand. 1997;75(6):634-40. [pmid: 9527321].
110 Teikari JM, Laatikainen L, Virtamo J, et al. Six-year supplementation with alpha-tocopherol and beta-carotene and age-related maculopathy. Acta Ophthalmol Scand. 1998;76(2):224-9. [pmid: 9591958].
111 Taylor PR, Li B, Dawsey SM, et al. Prevention of esophageal cancer: the nutrition intervention trials in Linxian, China. Linxian Nutrition Intervention Trials Study Group. Cancer Res. 1994;54(7 Suppl):2029s-31s. [pmid: 8137333].
112 de Gaetano G. Low-dose aspirin and vitamin E in people at cardiovascular risk: a randomised trial in general practice. Collaborative Group of the Primary Prevention Project. Lancet. 2001;357(9250):89-95. [pmid: 11197445].
113 McNeil JJ, Robman L, Tikellis G, et al. Vitamin E supplementation and cataract: randomized controlled trial. Ophthalmology. 2004;111(1):75-84. [pmid: 14711717].
114 Shekelle PG, Morton SC, Jungvig LK, et al. Effect of supplemental vitamin E for the prevention and treatment of cardiovascular disease. J Gen Intern Med. 2004;19(4):380-9. [pmid: 15061748]. [pmcid: 1492195].
115 Shekelle P, Morton S, and Hardy ML. Effect of supplemental antioxidants vitamin C, vitamin E, and coenzyme Q10 for the prevention and treatment of cardiovascular disease. Evid Rep Technol Assess (Summ) 2003;( 83):1–3.
116 Leppala JM, Virtamo J, Fogelholm R, et al. Controlled trial of alpha-tocopherol and beta-carotene supplements on stroke incidence and mortality in male smokers. Arterioscler Thromb Vasc Biol. 2000;20(1):230-5. [pmid: 10634823].
117 de Gaetano G. Low-dose aspirin and vitamin E in people at cardiovascular risk: a randomised trial in general practice. Collaborative Group of the Primary Prevention Project. Lancet. 2001;357(9250):89-95. [pmid: 11197445].
118 Salonen JT, Nyyssonen K, Salonen R, et al. Antioxidant Supplementation in Atherosclerosis Prevention (ASAP) study: a randomized trial of the effect of vitamins E and C on 3-year progression of carotid atherosclerosis. J Intern Med. 2000;248(5):377-86. [pmid: 11123502].
119 Mark SD, Wang W, Fraumeni JF Jr, et al. Do nutritional supplements lower the risk of stroke or hypertension?. Epidemiology. 1998;9(1):9-15. [pmid: 9430262].
120 Sneath P, Chanarin I, Hodkinson HM, et al. Folate status in a geriatric population and its relation to dementia. Age Ageing. 1973;2(3):177-82. [pmid: 4777516].
121 Renvall MJ, Spindler AA, Ramsdell JW, et al. Nutritional status of free-living Alzheimer's patients. Am J Med Sci. 1989;298(1):20-7. [pmid: 2750771].
122 Clarke R, Smith AD, Jobst KA, et al. Folate, vitamin B12, and serum total homocysteine levels in confirmed Alzheimer disease. Arch Neurol. 1998;55(11):1449-55. [pmid: 9823829].
123 Goodwin JS, Goodwin JM, Garry PJ. Association between nutritional status and cognitive functioning in a healthy elderly population. JAMA. 1983;249(21):2917-21. [pmid: 6842805].
124 La Rue A, Koehler KM, Wayne SJ, et al. Nutritional status and cognitive functioning in a normally aging sample: a 6-y reassessment. Am J Clin Nutr. 1997;65(1):20-9. [pmid: 8988908].
125 Hofman A, Ott A, Breteler MM, et al. Atherosclerosis, apolipoprotein E, and prevalence of dementia and Alzheimer's disease in the Rotterdam Study. Lancet. 1997;349(9046):151-4. [pmid: 9111537].
126 McCaddon A, Davies G, Hudson P, et al. Total serum homocysteine in senile dementia of Alzheimer type. Int J Geriatr Psychiatry. 1998;13(4):235-9. [pmid: 9646150].
127 Malouf R, Grimley Evans J. The effect of vitamin B6 on cognition. Cochrane Database Syst Rev 2003;(4):CD004393.
128 Malouf M, Grimley EJ, and Areosa SA. Folic acid with or without vitamin B12 for cognition and dementia. Cochrane Database Syst Rev 2003;(4):CD004514.
129 Ahrens RA. Glutathione peroxidase: a role for selenium (Rotruck 1972). J Nutr. 1997;127(5 Suppl):1052S-3S. [pmid: 9164308].
130 Arthur JR, McKenzie RC, Beckett GJ. Selenium in the immune system. J Nutr. 2003;133(5 Suppl 1):1457S-9S. [pmid: 12730442].
131 Bedwal RS, Nair N, Sharma MP, et al. Selenium--its biological perspectives. Med Hypotheses. 1993;41(2):150-9. [pmid: 8231995].
132 Ganther HE. Selenium metabolism, selenoproteins and mechanisms of cancer prevention: complexities with thioredoxin reductase. Carcinogenesis. 1999;20(9):1657-66. [pmid: 10469608].
133 Clark LC, Combs GF Jr, Turnbull BW, et al. Effects of selenium supplementation for cancer prevention in patients with carcinoma of the skin. A randomized controlled trial. Nutritional Prevention of Cancer Study Group. JAMA. 1996;276(24):1957-63. [pmid: 8971064].
134 Clark LC, Dalkin B, Krongrad A, et al. Decreased incidence of prostate cancer with selenium supplementation: results of a double-blind cancer prevention trial. Br J Urol. 1998;81(5):730-4. [pmid: 9634050].
135 Reid ME, Duffield-Lillico AJ, Garland L, et al. Selenium supplementation and lung cancer incidence: an update of the nutritional prevention of cancer trial. Cancer Epidemiol Biomarkers Prev. 2002;11(11):1285-91. [pmid: 12433704].
136 Duffield-Lillico AJ, Reid ME, Turnbull BW, et al. Baseline characteristics and the effect of selenium supplementation on cancer incidence in a randomized clinical trial: a summary report of the Nutritional Prevention of Cancer Trial. Cancer Epidemiol Biomarkers Prev. 2002;11(7):630-9. [pmid: 12101110].
137 Duffield-Lillico AJ, Dalkin BL, Reid ME, et al. Selenium supplementation, baseline plasma selenium status and incidence of prostate cancer: an analysis of the complete treatment period of the Nutritional Prevention of Cancer Trial. BJU Int. 2003;91(7):608-12. [pmid: 12699469].
138 Stranges S, Marshall JR, Trevisan M, et al. Effects of Selenium Supplementation on Cardiovascular Disease Incidence and Mortality: Secondary Analyses in a Randomized Clinical Trial. Am J Epidemiol 2006;
139 Yu SY, Zhu YJ, Li WG, et al. A preliminary report on the intervention trials of primary liver cancer in high-risk populations with nutritional supplementation of selenium in China. Biol Trace Elem Res. 1991;29(3):289-94. [pmid: 1726411].
140 Loke YK, Price D, Derry S, et al. Case reports of suspected adverse drug reactions--systematic literature survey of follow-up. BMJ. 2006;332(7537):335-9. [pmid: 16421149]. [pmcid: 1363912].
141 Holick MF. High prevalence of vitamin D inadequacy and implications for health. Mayo Clin Proc. 2006;81(3):353-73. [pmid: 16529140].
142 Guyatt GH, Cranney A, Griffith L, et al. Summary of meta-analyses of therapies for postmenopausal osteoporosis and the relationship between bone density and fractures. Endocrinol Metab Clin North Am. 2002;31(3):659-79. , xii. [pmid: 12227126].
143 Avenell A, Gillespie WJ, Gillespie LD, et al. Vitamin D and vitamin D analogues for preventing fractures associated with involutional and post-menopausal osteoporosis. Cochrane Database Syst Rev. 2005;-(3): CD000227.
144 Bischoff-Ferrari HA, Willett WC, Wong JB, et al. Fracture prevention with vitamin D supplementation: a meta-analysis of randomized controlled trials. JAMA. 2005;293(18):2257-64. [pmid: 15886381].
145 Bischoff-Ferrari HA, Dawson-Hughes B, Willett WC, et al. Effect of Vitamin D on falls: a meta-analysis. JAMA. 2004;291(16):1999-2006. [pmid: 15113819].
146 Jackson RD, LaCroix AZ, Gass M, et al. Calcium plus vitamin D supplementation and the risk of fractures. N Engl J Med. 2006;354(7):669-83. [pmid: 16481635].
147 Meier C, Woitge HW, Witte K, et al. Supplementation with oral vitamin D3 and calcium during winter prevents seasonal bone loss: a randomized controlled open-label prospective trial. J Bone Miner Res. 2004;19(8):1221-30. [pmid: 15231008].
148 Hunter D, Major P, Arden N, et al. A randomized controlled trial of vitamin D supplementation on preventing postmenopausal bone loss and modifying bone metabolism using identical twin pairs. J Bone Miner Res. 2000;15(11):2276-83. [pmid: 11092410].
149 Storm D, Eslin R, Porter ES, et al. Calcium supplementation prevents seasonal bone loss and changes in biochemical markers of bone turnover in elderly New England women: a randomized placebo-controlled trial. J Clin Endocrinol Metab. 1998;83(11):3817-25. [pmid: 9814452].
150 Porthouse J, Cockayne S, King C, et al. Randomised controlled trial of calcium and supplementation with cholecalciferol (vitamin D3) for prevention of fractures in primary care. BMJ. 2005;330(7498):1003. [pmid: 15860827]. [pmcid: 557150].
151 Grant AM, Avenell A, Campbell MK, et al. Oral vitamin D3 and calcium for secondary prevention of low-trauma fractures in elderly people (Randomised Evaluation of Calcium Or vitamin D, RECORD): a randomised placebo-controlled trial. Lancet. 2005;365(9471):1621-8. [pmid: 15885294].
152 Wactawski-Wende J, Kotchen JM, Anderson GL, et al. Calcium plus vitamin D supplementation and the risk of colorectal cancer. N Engl J Med. 2006;354(7):684-96. [pmid: 16481636].
153 Omenn GS, Goodman GE, Thornquist M, et al. Long-term vitamin A does not produce clinically significant hypertriglyceridemia: results from CARET, the beta-carotene and retinol efficacy trial. Cancer Epidemiol Biomarkers Prev. 1994;3(8):711-3. [pmid: 7881345].
154 Feskanich D, Singh V, Willett WC, et al. Vitamin A intake and hip fractures among postmenopausal women. J. Am. Med. Assoc. 2002;287(1):47-54.
155 Lim LS, Harnack LJ, Lazovich D, et al. Vitamin A intake and the risk of hip fracture in postmenopausal women: The Iowa Women's Health Study. Osteoporosis Int. 2004;15(7):552-9.
156 Melhus H, Michaelsson K, Kindmark A, et al. Excessive dietary intake of vitamin A is associated with reduced bone mineral density and increased risk for hip fracture. Ann Intern Med. 1998;129(10):770-8. [pmid: 9841582].
157 Wolf RL, Cauley JA, Pettinger M, et al. Lack of a relation between vitamin and mineral antioxidants and bone mineral density: results from the Women's Health Initiative. Am J Clin Nutr. 2005;82 (3):581-8. [pmid: 16155271].
158 Ballew C, Galuska D, Gillespie C. High serum retinyl esters are not associated with reduced bone mineral density in the Third National Health And Nutrition Examination Survey, 1988-1994. J Bone Miner Res. 2001;16(12):2306-12. [pmid: 11760846].
159 Idjradinata P, Watkins WE, Pollitt E. Adverse effect of iron supplementation on weight gain of ironreplete young children. Lancet. 1994;343(8908):1252-4. [pmid: 7910275].
160 Routine Vitamin Supplementation to Prevent Cancer and Cardiovascular Disease: Recommendations and Rationale. Ann Intern Med. 2003;139(1):51–5.
161 Mark SD, Liu SF, Li JY, et al. The effect of vitamin and mineral supplementation on esophageal cytology: results from the Linxian Dysplasia Trial. Int J Cancer. 1994;57(2):162-6. [pmid: 8157352].
162 Li JY, Taylor PR, Li B, et al. Nutrition intervention trials in Linxian, China: multiple vitamin/mineral supplementation, cancer incidence, and disease-specific mortality among adults with esophageal dysplasia. J Natl Cancer Inst. 1993;85(18):1492-8. [pmid: 8360932].
163 Palozza P. Prooxidant actions of carotenoids in biologic systems. Nutr Rev. 1998;56(9):257-65. [pmid: 9763875].
164 Zhang P, Omaye ST. Antioxidant and prooxidant roles for beta-carotene, alpha-tocopherol and ascorbic acid in human lung cells. Toxicol In Vitro. 2001;15(1):13-24. [pmid: 11259865].
165 Arora A, Willhite CA, Liebler DC. Interactions of beta-carotene and cigarette smoke in human bronchial epithelial cells. Carcinogenesis. 2001;22(8):1173-8. [pmid: 11470745].
166 Eidelman RS, Hollar D, Hebert PR, et al. Randomized trials of vitamin E in the treatment and prevention of cardiovascular disease. Arch Intern Med. 2004;164(14):1552-6. [pmid: 15277288].
167 Kelley MJ, McCrory DC. Prevention of lung cancer: summary of published evidence. Chest. 2003;123(1 Suppl):50S-9S. [pmid: 12527564].
168 Miller III ER, Pastor-Barriuso R, Dalal D, et al. Meta-analysis: high-dosage vitamin E supplementation may increase all-cause mortality. Ann Intern Med. 2005;142(1):37–46+I.
169 Morris CD, Carson S. Routine vitamin supplementation to prevent cardiovascular disease: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Inter Med. 2003;139(1):56–70+I76.
170 Hosomi A, Arita M, Sato Y, et al. Affinity for alpha-tocopherol transfer protein as a determinant of the biological activities of vitamin E analogs. FEBS Lett. 1997;409(1):105-8. [pmid: 9199513].
171 Yoshida H, Yusin M, Ren I, et al. Identification, purification, and immunochemical characterization of a tocopherol-binding protein in rat liver cytosol. J Lipid Res. 1992;33(3):343-50. [pmid: 1569384].
172 Swanson JE, Ben RN, Burton GW, et al. Urinary excretion of 2,7, 8-trimethyl-2-(beta-carboxyethyl)-6-hydroxychroman is a major route of elimination of gamma-tocopherol in humans. J Lipid Res. 1999;40(4):665-71. [pmid: 10191290].
173 Jiang Q, Elson-Schwab I, Courtemanche C, et al. gamma-tocopherol and its major metabolite, in contrast to alpha-tocopherol, inhibit cyclooxygenase activity in macrophages and epithelial cells. Proc Natl Acad Sci U S A. 2000;97(21):11494-9. [pmid: 11005841]. [pmcid: 17228].
174 Wechter WJ, Kantoci D, Murray ED Jr, et al. A new endogenous natriuretic factor: LLU-alpha. Proc Natl Acad Sci USA. 1996;93(12):6002-7. [pmid: 8650209]. [pmcid: 39178].
175 Huang HY, Appel LJ. Supplementation of diets with alpha-tocopherol reduces serum concentrations of gamma- and delta-tocopherol in humans. J Nutr. 2003;133(10):3137-40. [pmid: 14519797].
176 Klein EA, Thompson IM, Lippman SM, et al. SELECT: the Selenium and Vitamin E Cancer Prevention Trial: rationale and design. Prostate Cancer Prostatic Dis. 2000;3(3):145-51. [pmid: 12497090].
177 Steinberg D, Parthasarathy S, Carew TE, et al. Beyond cholesterol. Modifications of low-density lipoprotein that increase its atherogenicity. N Engl J Med. 1989;320(14):915-24. [pmid: 2648148].
178 Olson RE. Atherogenesis in children: implications for the prevention of atherosclerosis. Adv Pediatr 2000;4755–78.
179 McGill HC Jr, McMahan CA, Zieske AW, et al. Associations of coronary heart disease risk factors with the intermediate lesion of atherosclerosis in youth. The Pathobiological Determinants of Atherosclerosis in Youth (PDAY) Research Group. Arterioscler Thromb Vasc Biol. 2000;20(8):1998-2004. [pmid: 10938023].
180 Dawsey SM, Wang GQ, Taylor PR, et al. Effects of vitamin/mineral supplementation on the prevalence of histological dysplasia and early cancer of the esophagus and stomach: results from the Dysplasia Trial in Linxian, China. Cancer Epidemiol Biomarkers Prev. 1994;3(2):167-72. [pmid: 8049639].
181 Sacco M, Pellegrini F, Roncaglioni MC, et al. Primary prevention of cardiovascular events with low-dose aspirin and vitamin E in type 2 diabetic patients: results of the Primary Prevention Project (PPP) trial. Diabetes Care. 2003;26(12):3264-72. [pmid: 14633812].
182 Ramirez-Tortosa MC, Urbano G, Lopez-Jurado M, et al. Extra-virgin olive oil increases the resistance of LDL to oxidation more than refined olive oil in free-living men with peripheral vascular disease. J Nutr. 1999;129(12):2177-83. [pmid: 10573546].
183 Goodman GE, Thornquist MD, Balmes J, et al. The Beta-Carotene and Retinol Efficacy Trial: incidence of lung cancer and cardiovascular disease mortality during 6-year follow-up after stopping beta-carotene and retinol supplements. J Natl Cancer Inst. 2004;96(23):1743-50. [pmid: 15572756].
184 Gordis L. Epidemiology. Second ed. Philadelphia, PA: W.B. Saunders Company; 2000.
185 Cartmel B, Moon TE, Levine N. Effects of long-term intake of retinol on selected clinical and laboratory indexes. Am J Clin Nutr. 1999;69(5):937-43. [pmid: 10232634].
186 Ragavan VV, Smith JE, Bilezikian JP. Vitamin A toxicity and hypercalcemia. Am J Med Sci. 1982;283(3):161-4. [pmid: 6211095].
187 Stauber PM, Sherry B, VanderJagt DJ, Bhagavan HN, Garry PJ. A longitudinal study of the relationship between vitamin A supplementation and plasma retinol, retinyl esters, and liver enzyme activities in a healthy elderly population. Am J Clin Nutr. 1991;54(5):878-83. [pmid: 1951160].
188 Micozzi MS, Brown ED, Taylor PR, Wolfe E. Carotenodermia in men with elevated carotenoid intake from foods and (beta)-carotene supplements. Am J Clin Nutr. 1988;48(4):1061-4. [pmid: 3421202].
189 Simons LA, Von Konigsmark M, Balasubramaniam S. What dose of vitamin E is required to reduce susceptibility of LDL to oxidation?. Aust N Z J Med. 1996;26(4):496-503. [pmid: 8873932].
190 Tsai AC, Kelley JJ, Peng B, Cook N. Study on the effect of megavitamin E supplementation in man. Am J Clin Nutr. 1978;31(5):831-7. [pmid: 347918].
191 Coplin M, Schuette S, Leichtmann G, Lashner B. Tolerability of iron: a comparison of bis-glycino iron II and ferrous sulfate. Clin Ther. 1991;13(5):606-12. [pmid: 1799918].
192 MMWR. Toddler deaths resulting from ingestion of iron supplements--Los Angeles, 1992-1993. MMWR Morb Mortal Wkly Rep 1993; 42(6):111–3.
193 Strause L, Saltman P, Smith KT, Bracker M, Andon MB. Spinal bone loss in postmenopausal women supplemented with calcium and trace minerals. J Nutr. 1994;124(7):1060-4. [pmid: 8027856].