# Acknowledgments

The Evidence-based Practice Center thanks Karen Robinson for her assistance in developing the search strategies; Steven Bressler and Archana Ramaswami, for their assistance with literature searching and database management; Gabriel Lai, Karran Phillips, Konstantinos K. Tsilidisand, and Amina Chaudhry for their assistance with article reviewing and data entry; Christine Napolitano for her assistance with budget matters, and Brenda Zacharko for her assistance with final preparations of the report.